# Search Strategy

TRD Search 06.23.09

Search | Most Recent Queries | Result
#1 | Search “Depression”[Mesh] OR “Depressive Disorder”[Mesh] | 110342
#2 | Search #1 Limits: Entrez Date from 1980/01/01, Humans, English, All Adult: 19+ years | 56274
#3 | Search #2 Limits: Editorial, Letter, Case Reports | 7200
#5 | Search “Case Control Studies”[Mesh] | 421177
#6 | Search #2 AND #5 | 3156
#7 | Search #3 OR #6 | 10272
#8 | Search #2 NOT #7 | 46002
| Depression articles limited to English, Human, and Adults, with no editorials, letters, case reports or case-control studies.
#9 | Search “Socioenvironmental Therapy”[Mesh] OR “interpersonal psychotherapy”[tw] OR “ipt”[tw] OR “psychotherapy”[mesh] OR “Cognitive Therapy”[Mesh] OR “cognitive behavioral therapy”[tw] OR “cbt”[tw] | 123383
#10 | Search #8 AND #9 | 2910
#11 | Search “Drug Resistance”[Mesh] OR refractory[tw] OR resistant[tw] | 379438
#12 | Search #10 AND #11 | 48
| 48 Psychotherapy/CBT/Depression articles limited to the “refractory” terms.
#13 | Search “Electroconvulsive Therapy”[Mesh] OR “ect”[tw] OR “electroconvulsive therapy”[tw] | 10514
#14 | Search #8 AND #13 | 1112
#16 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 392864
| These are the terms used for RCTs.
#17 | Search #14 AND #16 | 203
| There are 203 RCTs about Depression and ECT.
#18 | Search “Longitudinal Studies”[Mesh] OR “Comparative Study ”[Publication Type]) OR “Cohort Studies”[Mesh] OR “observational studies”[tw] | 1992678
#19 | Search #14 AND #18 | 361
| There are 361 “observational studies” about Depression and ECT.
#20 | Search #17 OR #19 | 447
| Combining the RCTs and Observational studies for the ECT literature here.
#21 | Search “Transcranial Magnetic Stimulation”[Mesh] OR “(r)tms”[tw] | 2864
#22 | Search #8 AND #21 | 141
| 141 TMS articles.
#23 | Search “Vagus Nerve Stimulation”[Mesh] OR “vagus nerve stimulation”[tw] | 808
#24 | Search #8 AND #23 | 37
| 37 VNS articles.
#25 | Search #12 OR #20 OR #22 OR #24 | 649
| Combining all results for the main search here: Psychotherapy, ECT, TMS, and VNS.
| Final number of records after duplicates removed | 630

A search with analogous terms was performed in the following databases:

Embase = 269 (159 after duplicates removed)

PsycINFO= 422 (296 after duplicates removed)

Cochrane = 6 (no duplicates found)

EndNote file for the main search = 1346 (1074 after duplicates removed)

TRD Update Search 11.18.2010

Search | Most Recent Queries | Result
#1 | Search “Depression”[Mesh] OR “Depressive Disorder”[Mesh] | 120871
#2 | Search ((#1) AND “2009/04/01”[Entrez Date] : “3000”[Entrez Date]) AND “0”[Entrez Date] : “3000”[Entrez Date] | 9152
#3 | Search #2 Limits: Editorial, Letter, Case Reports | 909
#4 | Search “Case Control Studies”[Mesh] | 476252
#5 | Search #2 AND #4 | 558
#6 | Search #3 OR #5 | 1460
#7 | Search #2 NOT #6 | 7692
#8 | Search “Socioenvironmental Therapy”[Mesh] OR “interpersonal psychotherapy”[tw] OR “ipt”[tw] OR “psychotherapy”[mesh] OR “Cognitive Therapy”[Mesh] OR “cognitive behavioral therapy”[tw] OR “cbt”[tw] | 131504
#9 | Search #7 AND #8 | 758
#10 | Search “Drug Resistance”[Mesh] OR refractory[tw] OR resistant[tw] | 414955
#11 | Search #9 AND #10 | 25
#12 | Search “Electroconvulsive Therapy”[Mesh] OR “ect”[tw] OR “electroconvulsive therapy”[tw] | 11003
#13 | Search #2 AND #12 | 149
#14 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 431969
#15 | Search #13 AND #14 | 21
#16 | Search “Longitudinal Studies”[Mesh] OR “Comparative Study ”[Publication Type]) OR “Cohort Studies”[Mesh] OR “observational studies”[tw] | 2109685
#17 | Search #13 AND #16 | 27
#18 | Search #15 OR #17 | 37
#19 | Search “Transcranial Magnetic Stimulation”[Mesh] OR “(r)tms”[tw] | 3733
#20 | Search #2 AND #19 | 78
#21 | Search “Vagus Nerve Stimulation”[Mesh] OR “vagus nerve stimulation”[tw] | 988
#22 | Search #2 AND #21 | 18
#23 | Search #22 OR #20 OR #18 OR #11 | 143
#24 | Search #23 Limits: Humans, English, All Adult: 19+ years Sort by: PublicationDate | 77
#25 | Search #23 | 143

A search with analogous terms was performed in the following databases:

PubMed 76 (77 before duplicates removed)

Embase 80 (187 before duplicates removed)

PsycINFO 170 (211 before duplicates removed)

The Cochrane Library 26 (27 before duplicates removed)

EndNote file for the Update Search = 352 (before being added to main database and duplicates removed)

TRD Pharmacologic Search (Key Question 1b)

Search | Most Recent Queries | Result
#1 | Search “Antidepressive Agents”[MeSH] | 37171
#2 | Search “Fluoxetine”[Mesh] OR “Sertraline”[Mesh] OR “Paroxetine”[Mesh] OR “Citalopram”[Mesh] OR “Fluvoxamine”[Mesh] OR “Bupropion”[Mesh] OR “nefazodone ”[Substance Name] OR “mirtazapine ”[Substance Name] OR “venlafaxine ”[Substance Name] OR “desmethylcitalopram ”[Substance Name] OR Escitalopram[tw] OR “duloxetine ”[Substance Name] OR “Trazodone”[Mesh] OR “O-desmethylvenlafaxine ”[Substance Name] OR “Imipramine”[Mesh] OR “Desipramine”[Mesh] OR “Nortriptyline”[Mesh] OR “Amitriptyline”[Mesh] OR “Phenelzine”[Mesh] OR “Tranylcypromine”[Mesh] OR “Doxepin”[Mesh] OR “Clomipramine”[Mesh] OR “Maprotiline”[Mesh] | 39294
#3 | Search Fluoxetine OR Sertraline OR Paroxetine OR Citalopram OR Fluvoxamine OR Bupropion OR Nefazodone OR Mirtazapine OR Venlafaxine OR Escitalopram OR Duloxetine OR Trazodone OR Desvenlafaxine OR Imipramine OR Desipramine OR Nortriptyline OR Amitriptyline OR Phenelzine OR Tranylcypromine OR Doxepin OR Clomipramine OR Maprotiline | 48657
#4 | Search #1 OR #2 OR #3 | 70932
#5 | Search (“Depression”[MeSH] or “Depressive Disorder”[MeSH]) | 113094
#6 | Search “Drug Resistance”[MeSH] OR refractory[tw] OR resistant[tw] | 387599
#7 | Search #4 AND #5 AND #6 | 1359
#8 | Search (“1980”[Entrez Date] : “3000”[Entrez Date]) AND (#7) Limits: Humans, English | 1075
#9 | Search #8 Limits: Editorial, Letter, Case Reports | 222
#10 | Search #8 Limits: All Infant: birth-23 months, All Child: 0-18 years, Newborn: birth-1 month, Infant: 1-23 months, Preschool Child: 2-5 years, Child: 6-12 years, Adolescent: 13-18 years | 105
#11 | Search #8 NOT( #9 OR #10) Sort by: Title | 758
| Final number of records after duplicates removed (in comparison with the main TRD nonpharmacologic database). | 663

A search with analogous terms was performed in the following databases:

EMBASE (unduplicated) = 78

PsycINFO (unduplicated)= 171

Unduplicated EndNote file for the main search = 912

TRD Pharmacologic Search (KQ1b) 11.19.2010

Search | Most Recent Queries | Result
#1 | Search “Antidepressive Agents”[MeSH] | 39236
#2 | Search “Fluoxetine”[Mesh] OR “Sertraline”[Mesh] OR “Paroxetine”[Mesh] OR “Citalopram”[Mesh] OR “Fluvoxamine”[Mesh] OR “Bupropion”[Mesh] OR “nefazodone ”[Substance Name] OR “mirtazapine ”[Substance Name] OR “venlafaxine ”[Substance Name] OR “desmethylcitalopram ”[Substance Name] OR Escitalopram[tw] OR “duloxetine ”[Substance Name] OR “Trazodone”[Mesh] OR “O-desmethylvenlafaxine ”[Substance Name] OR “Imipramine”[Mesh] OR “Desipramine”[Mesh] OR “Nortriptyline”[Mesh] OR “Amitriptyline”[Mesh] OR “Phenelzine”[Mesh] OR “Tranylcypromine”[Mesh] OR “Doxepin”[Mesh] OR “Clomipramine”[Mesh] OR “Maprotiline”[Mesh] | 40799
#3 | Search Fluoxetine OR Sertraline OR Paroxetine OR Citalopram OR Fluvoxamine OR Bupropion OR Nefazodone OR Mirtazapine OR Venlafaxine OR Escitalopram OR Duloxetine OR Trazodone OR Desvenlafaxine OR Imipramine OR Desipramine OR Nortriptyline OR Amitriptyline OR Phenelzine OR Tranylcypromine OR Doxepin OR Clomipramine OR Maprotiline | 50880
#4 | Search #1 OR #2 OR #3 | 74378
#5 | Search (“Depression”[MeSH] or “Depressive Disorder”[MeSH]) | 120871
#6 | Search “Drug Resistance”[MeSH] OR refractory[tw] OR resistant[tw] | 415078
#7 | Search #4 AND #5 AND #6 | 1465
#8 | Search ((#7) AND “2009/09/01”[Entrez Date] : “3000”[Entrez Date]) AND “0”[Entrez Date] : “3000”[Entrez Date] | 78
#9 | Search #8 Limits: Editorial, Letter, Case Reports | 8
#10 | Search #8 NOT #9 | 70
#11 | Search #10 Limits: All Infant: birth-23 months, All Child: 0-18 years, Newborn: birth-1 month, Infant: 1-23 months, Preschool Child: 2-5 years, Child: 6-12 years, Adolescent: 13-18 years | 7
#12 | Search #10 NOT #11 | 63
#13 | Search (“Amoxapine”[Mesh] OR “Protriptyline”[Mesh]) OR “Selegiline”[Mesh] | 2578
#14 | Search “Amoxapine” OR “Protriptyline” OR “Selegiline” | 3228
#15 | Search #13 OR #14 | 3228
#16 | Search #15 AND #5 AND #6 | 16
#17 | Search #16 Limits: Editorial, Letter, Case Reports | 7
#18 | Search #16 NOT #17 | 9
#19 | Search #18 Limits: All Infant: birth-23 months, All Child: 0-18 years, Newborn: birth-1 month, Infant: 1-23 months, Preschool Child: 2-5 years, Child: 6-12 years, Adolescent: 13-18 years | 0
#20 | Search #12 OR #18 | 72
#21 | Search #20 Limits: Humans, English | 60

A search with analogous terms was performed in the following databases:

PubMed 60 (60 before duplicates removed)

Embase 131 (172 before duplicates removed)

PsycINFO 51 (69 before duplicates removed)

The Cochrane Library 66 (73 before duplicates removed)

EndNote file for the Update Search = 308 (before being added to the main EndNote Database and duplicates removed)