# Appendixes

Appendix A Search Strategy

Appendix B Data Abstraction Forms

Appendix C Excluded Studies

Appendix D Evidence Tables

Appendix E Abbreviations and Full Names of Diagnostic Scales and Other Instruments

Appendix F Characteristics of Studies With Poor Internal Validity

Appendix G Articles by Database Searched

Appendix H Studies Recommended for Inclusion by Peer and Public Reviewers