# Acknowledgments

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina. We express our gratitude to RTI staff Amy Greenblatt, B.A., Andrea Yuen, B.S., and Laura C. Morgan, M.A., Research Analysts, Megan Van Noord, M.S.L.S., our EPC Librarian; and Loraine Monroe, our EPC publications specialist.