# Technical Expert Panel

Charles Atwood, MD

Director, Sleep Disorders Program

VA Pittsburgh Healthcare System

Pittsburgh, PA

Paul Dallas, MD

Carilion Clinic Internal Medicine

Roanoke, VA

Douglas K. Owens, MD, MS

Director, Stanford-UCSF EPC

Center for Primary Care and Outcomes Research

Stanford University

Palo Alto, CA

Allan Pack, MD, PhD

Professor of Medicine

Director Center for Sleep and Respiratory Neurobiology

University of Pennsylvania

Michael J. Sateia, MD

Director, Sleep Medicine

Dartmouth-Hitchcock Psychiatric Associates

Sleep Disorders Center

Lebanon, NH

Walter Shaffer, MD

Medical Director

Division of Medical Assistance Programs

Salem, OR