# Summary and Discussion

The following table summarizes the main findings that address the seven Key Questions in this systematic review. Of note, where interventions are not discussed (either diagnostic tests or treatments), this does not imply that the interventions were excluded from analysis (unless explicitly stated); instead, no studies of these interventions met eligibility criteria Discussion regarding the report and recommendations for future research follow.

Table 4 Summary of findings of studies addressing key questions on obstructive sleep apnea

Key Question | Strength of Evidence | Summary/Conclusions/Comments
Key Question 1: Diagnosis Portable monitors vs. PSG | Low (Type II monitors); Moderate (Types III & IV monitors) | - No recent studies have compared Type II portable monitors to PSG. 7 A prior systematic review concluded that “based on [3 quality B studies], Type II monitors [used at home] may identify AHI suggestive of OSA with high positive likelihood ratios and low negative likelihood ratios,” though “substantial differences in the [measurement of] AHI may be encountered between Type II monitors and facility-based PSG.”; - There were 29 studies that compared Type III portable monitors 8 with PSG. 7 of these are new since a previous report. 18 Type III monitors have been evaluated.; - There were 70 studies that compared Type IV portable monitors 9 to PSG. 24 of these are new since a previous report. 23 Type IV monitors have been evaluated.; - Overall, 15 studies were graded quality A, 45 quality B, and 39 quality C. The studies were applicable to the general population of patients being referred to specialized sleep centers or hospitals for evaluation of suspected sleep apnea. It is unclear if the studies are applicable to patients with comorbidities or who may have central sleep apnea. Most of the studies were conducted either in the sleep laboratory setting or at home.; - Studies measured either concordance (comparisons of estimates of AHI), test sensitivity and specificity (to diagnose OSA as defined by PSG), or both.; - Type III monitors had a wide range of mean biases (difference in AHI estimate from PSG), from −10 to +24 events/hr, with wide limits of agreements within studies.; - Type IV monitors had a wide range of mean biases, from −17 to +12 events/hr, with wide limits of agreements within studies.; - To diagnose OSA defined as a PSG AHI ≥5 events/hr, Type III monitors had sensitivities of 83–97% and specificities of 48–100%. Type III monitors commonly less accurately diagnosed OSA with AHI ≥15 events/hr, with sensitivities 64–100% and specificities 41–100%.; - Evaluation of positive and negative likelihood ratios, and available ROC curves, suggest that Type III monitors are generally accurate in diagnosing OSA (as measured by PSG), with high positive likelihood ratios, low negative likelihood ratios, and high AUC.; - To diagnose OSA, Type IV monitors had a very wide range of sensitivities and specificities.; - Across studies (by indirect comparison), the range of sensitivities and specificities of both Type III and Type IV monitors largely overlapped, thus not demonstrating greater accuracy with either type of monitor.; - Conclusion: The strength of evidence is low that Type II monitors are accurate to diagnose OSA (as defined by PSG), but have a wide and variable bias in estimating the actual AHI.; - Conclusion: The strength of evidence is moderate that Type III and IV monitors are generally accurate to diagnose OSA (as defined by PSG), but have a wide and variable bias in estimating the actual AHI. The evidence is insufficient to adequately compare specific monitors to each other.
Key Question 1: Diagnosis Questionnaires vs. PSG | Low/Insufficient | - There were 6 studies that compared 6 questionnaires with PSG diagnosis of OSA. Overall, these studies are applicable to patients visiting preoperative clinics, sleep laboratories, and primary care centers for evaluation of sleep apnea.; - There were 1 quality A and 3 quality C studies that evaluated the Berlin Questionnaire (based on snoring, tiredness, and blood pressure), with OSA defined as AHI ≥ 5 events/hr; sensitivity ranged from 69–93%, specificity ranged from 56–95%. With an AHI ≥ 15 events/hr definition, sensitivity was somewhat lower and specificity was similar. To predict severe OSA (AHI ≥30 events/hr), sensitivity and specificity were generally lower.; - Each of the following 4 questionnaires was evaluated in a single study (1 quality B, 2 quality C): STOP, STOP-Bang, ASA checklist, Hawaii Sleep Questionnaire), which all had relatively low specificity for OSA (AHI thresholds of 5, 10, or 30 events/hr), ranging from 37–67%. STOP, ESS, and the Hawaii Questionnaire had sensitivities <80%. STOP-Bang had high sensitivity to predict diagnosis of OSA, particularly those with AHI ≥15 or ≥30 events/hr (93 and 100%, respectively). The American Society of Anesthesiologists Checklist had a sensitivity of 87% to predict severe OSA, but lower sensitivity to predict those with lower AHI. In 1 quality A study, ESS had a low sensitivity (49%) and higher specificity (80%) to predict OSA with AHI ≥5.; - Conclusion: The strength of evidence is low that the Berlin Questionnaire is moderately accurate (sensitivity and specificity generally <90%) to screen for OSA. The strength of evidence is insufficient to evaluate other questionnaires, but 1 study found that STOP-Bang may have high enough sensitivity to accurately screen for OSA.
Key Question 1: Diagnosis Clinical Prediction, Rules vs. PSG | Low | - There were 7 studies that compared 10 validated clinical prediction rules with PSG (3 quality A, 3 quality B, 1 quality C). Only 1 model has been externally validated (by independent researchers); thus the applicability of the studies to the general population is unclear. Of the models, 8 include variables obtainable through routine clinical history and examination.; - A single morphometric model and a model that included pulmonary function test data had near perfect discrimination (AUC=0.996) or sensitivity (100%), but neither was independently validated. The other clinical prediction rules had variable accuracy for predicting OSA (AHI ≥5, 10, or 15 events/hr) or severe OSA (AHI ≥30 events/hr).; - Conclusion: The strength of evidence is low that some clinical prediction rules may be useful in the prediction of a diagnosis of OSA.
Key Question 2: Diagnosis Phased testing | Insufficient | - A single quality C study partially addressed the value of phased testing, but had substantial verification bias due to implementation of the phased testing.; - Conclusion: The strength of evidence is insufficient to determine the utility of phased testing.
Key Question 3: Diagnosis Preoperative screening | Insufficient | - There were 2 quality C studies that assessed the effect of preoperative screening for OSA on surgical outcomes, though only 1 of these was designed to address the question.; - The retrospective study that compared mandatory prebariatric-surgery PSG with PSG performed based on clinical parameters (performed during different time periods) did not find significant differences in outcomes. The other study found only that those patients who volunteered for preoperative PSG were more likely to suffer cardiopulmonary perioperative complications than patients who refused PSG.; - Conclusion: The strength of evidence is insufficient to determine the utility of preoperative sleep apnea screening.
Key Question 4: Predictors AHI as a predictor of long-term clinical outcomes | Variable (High for all-cause mortality; Low for diabetes; Insufficient for other long-term clinical outcomes) | - There were 11 studies (of 8 large cohorts) that performed multivariable analyses of AHI as an independent predictor of long-term clinical outcomes.; - There were 4 studies (3 quality A, 1 quality B) that evaluated all-cause mortality. All found that AHI was a statistically significant independent predictor of death during 2–14 years of followup. The association was strongest among people with an AHI >30 events/hr. There was 1 study, however, that found an interaction with sex and age such that AHI was associated with death only in men ≤ 70 years of age. The evidence on mortality is applicable to the general population, with and without OSA, and also more specifically to men with OSA symptoms or evidence of OSA.; - There were 2 quality A studies that evaluated cardiovascular mortality. There was 1 study that found that only AHI >30 events/hr predicted cardiovascular death; the other study found no association.; - A single quality A study evaluated nonfatal cardiovascular disease and similarly found that only AHI >30 events/hr was an independent predictor.; - A single quality B study suggested that the association between AHI and stroke may be confounded by obesity.; - There were 2 studies (1 quality A, 1 quality B) that came to uncertain conclusions regarding the possible association between AHI and incident hypertension.; - There were 2 studies (1 quality A, 1 quality B) that suggested an association between AHI and incident type 2 diabetes, though 1 study found that the association was confounded by obesity.; - A single quality A study found no significant association between AHI and future quality of life (SF-36 after 5 years). This conclusion appears to be applicable for both the general population and specifically for patients diagnosed with sleep disordered breathing.; - Conclusion: The strength of evidence is high that an AHI >30 events/hr is an independent predictor of all-cause mortality; although one study found that this was true only in men under age 70. The strength of evidence is low that a higher AHI is associated with incident diabetes, though possibly confounded with obesity. The strength of evidence is insufficient to determine the association between AHI and other clinical outcomes.
Key Question 5: Treatment OSA treatments CPAP vs. control | Moderate | - There were 43 trials that compared CPAP devices with either no treatment or sham CPAP. All but 2 evaluated fixed CPAP. Of the 43 trials, 4 were rated quality A, 22 quality B, and 17 quality C. Overall, the studies are applicable to a broad range of patients with OSA.; - Only 1 study evaluated a clinical outcome, namely heart failure symptomatology, and found no significant effect after 3 months.; - By meta-analysis, CPAP results in a statistically significant large reduction in AHI (−20 events/hr compared with no treatment and −46 events/hr compared with sham CPAP). All studies found statistically significant effects, though there was statistical heterogeneity across studies that could not be fully explained. There were no clear, consistent relationships across studies between definition of OSA (by minimum threshold AHI) or other clinical features and effect size.; - By meta-analysis, CPAP results in a statistically and clinically significant improvement in sleepiness as measured by ESS (−2.6 compared with no treatment and −2.7 compared with sham CPAP). The studies were statistically significant and most, but not all, found significant improvements in ESS. No factors clearly explained the heterogeneity.; - CPAP also generally resulted in improvements in other sleep study measures, but had inconsistent effects on other sleepiness tests, quality of life tests, neurocognitive tests, and blood pressure.; - All adverse events related to CPAP treatment were potentially transient and could be alleviated with either stopping treatment or with ancillary interventions. Generally about 5–15% of patients in trials had specific adverse events they considered to be a major problem while using CPAP. These included claustrophobia, oral or nasal dryness, epistaxis, irritation, pain, and excess salivation. No adverse event with potentially long-term consequences was reported.; - Conclusion: Despite no evidence or weak evidence on clinical outcomes, given the large magnitude of effect on the important intermediate outcomes AHI, ESS, and other sleep study measures, the strength of evidence is moderate that CPAP is an effective treatment for OSA. However, the strength of evidence is insufficient to determine which patients might benefit most from treatment.
Key Question 5: Treatment OSA treatments Different CPAP devices vs. each other | Variable (Moderate for autoCPAP vs. CPAP; Low for C-Flex™ vs. CPAP; Insufficient for others) | - No study evaluated clinical outcomes.; - There were 21 trials that compared autoCPAP with fixed CPAP. Of these, 1 trial was rated quality A; 10 trials each were rated quality B or C. These studies are applicable mainly to patients with AHI more than 15 events/hr and BMI more than 30 kg/m^2^. By meta-analysis there was statistically significant, but clinically nonsignificant better improvement in ESS (−0.5), minimum oxygen saturation (1%), and compliance (11 minutes) with autoCPAP than fixed CPAP, and no statistically significant differences in AHI or arousal index.; - There were 4 trials comparing C-Flex™ to fixed CPAP. No statistically significant differences were found for compliance, sleep study measures, or other tested outcomes.; - There were 14 trials comparing bilevel or flexible bilevel CPAP with fixed CPAP, humidification with no humidification (with fixed CPAP), or oral with nasal fixed CPAP. The studies had either inconsistent results, were sparse, or had imprecise results.; - Conclusion: Despite no or weak evidence on clinical outcomes, overall, there is moderate strength of evidence that autoCPAP and fixed CPAP result in similar compliance and treatment effects for patients with OSA.; - Conclusion: The strength of evidence is low of no substantial difference in compliance or other outcomes between C-Flex and CPAP.; - Conclusion: The strength of evidence is insufficient regarding comparisons of different CPAP devices (or modifications).
Key Question 5: Treatment OSA treatments MAD vs. control | Moderate | - There were 10 trials comparing various MADs with either no treatment or with sham devices (without mandibular advancement). No studies were rated quality A, 8 quality B, 2 quality C. The studies are generally applicable to patients with AHI ≥15 events/hr, though less so to patients with comorbidities or excessive sleepiness. All studies excluded edentulous patients or those with periodontal diseases.; - No study evaluated clinical outcomes.; - By meta-analysis, MAD results in a statistically significant reduction in AHI (−12 events/hr). All studies found statistically significant improvements in AHI, ranging from −6 to −25 events/hr, without statistical heterogeneity.; - By meta-analysis, MAD results in a statistically and clinically significant improvement in sleepiness as measured by ESS (−1.4). Of 8 studies, 5 found statistically and clinically significant improvements in ESS, ranging from −1 to −4.5, without statistical heterogeneity.; - MAD also generally resulted in improvements in other sleep study measures, but had inconsistent effects on or inadequate evidence for other outcomes of interest.; - There was insufficient evidence to address whether study heterogeneity could be explained by different definitions of OSA or other clinical factors, particularly in light of the clinical heterogeneity across studies due to the difference in MADs.; - In 2 studies about 5% of patients had tooth damage (or loosening). Substantial jaw pain was reported in about 2–4% of patients, but no study reported on the long-term consequences of any adverse events.; - Conclusion: Despite no evidence or weak evidence on clinical outcomes, given the large magnitude of effect on the important intermediate outcomes AHI, ESS, and other sleep study measures, overall, the strength of evidence is moderate that MAD is an effective treatment for OSA in patients without comorbidities (including periodontal disease) or excessive sleepiness. However, the strength of evidence is insufficient to address which patients might benefit most from treatment.
Key Question 5: Treatment OSA treatments Oral devices vs. each other | Insufficient | - There were 5 trials comparing different oral devices; 3 compared different MADs; 2 compared different tongue devices. Of these 5 trials, 4 were rated quality B and 1 quality C. These studies are applicable mostly to patients with AHI of 15 to 30 events/hr and BMI less than 30 kg/m^2^. All studies were restricted to patients with a sufficient number of teeth to anchor the mandibular devices in place.; - No study evaluated clinical outcomes. In general, the studies found no differences among devices in sleep study or other measures. Only 1 study (comparing 2 tongue-retaining devices) evaluated compliance and found no difference.; - Conclusion: The strength of evidence is insufficient regarding comparisons of different oral devices.
Key Question 5: Treatment OSA treatments CPAP vs. MAD | Moderate | - There were 10 trials comparing different MADs with CPAP. A single study of an extraoral device vs. autoCPAP was rated quality C; 9 studies of oral MAD vs. fixed CPAP were rated quality B. The studies are generally applicable to patients with AHI >5–10 events/hr.; - No study evaluated clinical outcomes.; - A single study compared compliance rates, finding that patients used MAD significantly more hours per night and nights per week than CPAP.; - There were 2 studies that found that CPAP was significantly more likely to result in 50% reductions in AHI and achieved AHI <5 events/hr, but 1 study found no difference in achieving <10 events/hr. By meta-analysis, CPAP resulted in significantly greater reductions in AHI (−8 events/hr); 7 of 9 studies found statistically significant differences. By meta-analysis, CPAP results in a statistically significant greater improvement in AHI than MAD (−8 events/hr).; - The studies had inconsistent findings regarding the relative effects of MAD and CPAP on ESS.; - The studies generally found superior effects of CPAP over MAD for other sleep study measures, but no differences in quality of life or neurocognitive function.; - A single study found no differences with either device in achieving an AHI of either <5 or <10 events/hr based on baseline severity of OSA (at an AHI threshold of 30 events/hr).; - Conclusion: Despite no evidence or weak evidence on clinical outcomes, overall the strength of evidence is moderate that the use of CPAP is superior to MAD. However, the strength of evidence is insufficient to address which patients might benefit most from either treatment.
Key Question 5: Treatment OSA treatments Surgery vs. control | Insufficient | - There were 7 studies comparing 7 different surgical interventions to sham surgery, conservative therapy, or no treatment. Of these, 3 studies were rated quality A, 1 quality B, and 3 quality C.; - No study evaluated clinical outcomes.; - Of these 7 studies, 4 found statistically significant improvements in AHI, other sleep study measures, and/or sleepiness measures. The remaining studies found no differences in these outcomes or quality of life or neurocognitive function.; - Adverse events from surgery (also evaluated from large surgical cohort studies) were generally due to perioperative complications, including perioperative death in about 1.5% in two studies of UPPP – though most studies reported no deaths, hemorrhage, nerve palsies, emergency surgical treatments, cardiovascular events, respiratory failure, and rehospitalizations. Long-term adverse events included speech or voice changes, difficulties swallowing, airway stenosis, and others. In smaller studies, when these adverse events were reported they occurred in about 2–15% of patients. However the largest 2 studies (of 3,130 UPPP surgeries and 422 RFA surgeries) reported no long-term complications (not including perioperative death or cardiovascular complications).; - Conclusion: Overall, the strength of evidence is insufficient to evaluate the relative efficacy of surgical interventions for the treatment of OSA.
Key Question 5: Treatment OSA treatments Surgery vs. CPAP | Insufficient | - Of 12 eligible studies comparing surgery with CPAP (1 quality A, 11 quality C), only 2 were RCTs.; - There were 2 retrospective studies that evaluated mortality in UPPP vs. CPAP. Of these, 1 study found higher mortality over 6 years among patients using CPAP (HR = 1.31; 95% CI 1.03, 1.67) and 1 study found no difference in 5-year survival.; - Both trials found no difference in outcomes either between RFA and CPAP after 2 months or between maxillomandibular advancement osteotomy and CPAP at after 12 months. The remaining studies were heterogeneous in their conclusions.; - Conclusion: The strength of evidence is insufficient to determine the relative merits of surgical treatments versus CPAP.
Key Question 5: Treatment OSA treatments Surgery vs. MAD | Insufficient | - A single trial (quality B) compared UPPP and MAD treatment.; - The trial did not evaluate clinical outcomes. The study found that significantly more patients using MAD achieved 50% reductions in AHI at 1 year and significantly lower AHI at 4 years.; - Conclusion: The strength of evidence is insufficient to determine the relative merits of surgical treatments versus MAD.
Key Question 5: Treatment OSA treatments/Other treatments | Variable (Low for weight loss vs. control; Insufficient for others) | - There were 3 trials (1 quality A, 2 quality B) comparing weight loss interventions with control interventions. The studies were heterogeneous in terms of baseline OSA severity, presence of comorbidities, and severity of obesity. The studies are generally applicable to people with BMI >30 kg/m^2^.; - No study evaluated clinical outcomes.; - A single study found increased odds of achieving an AHI <5 events/hr after 1 year of a very low calorie diet compared with no treatment (OR=4.2, 95% CI 1.4, 12). All 3 trials found significant relative reductions in AHI with diet, from −4 to −23 events/hr. Other outcome data are inconsistent or sparse.; - A total of 19 studies evaluated 21 other interventions including atrial overdrive pacing, 8 different drugs, palatal implants, oropharyngeal exercises, a tongue-retaining device, a positional alarm, combination tongue-retaining device and positional alarm, bariatric surgery, nasal dilator strips, acupuncture, and auricular plaster. All of these interventions were evaluated by 1 or 2 studies only. No study evaluated clinical outcomes.; - Conclusion: The strength of evidence is low to show that some intensive weight loss programs are effective treatment for OSA in obese patients.; - Conclusion: The strength of evidence is insufficient to determine the effects of other potential treatments for OSA.
Key Question 6: Predictors Predictors of treatment compliance | Variable (see Conclusions) | - There were 5 large cohort studies that conducted multivariable analyses of potential predictors of compliance with CPAP treatment. Of these, 1 study was rated quality A, 1 quality B, and 3 quality C. In general, the studies are applicable to patients initiating CPAP whose AHI is greater than 30 events/hr.; - Of these 5 cohort studies, 4 studies all found that higher baseline AHI was associated with greater compliance. Also, 2 of 3 studies found that higher baseline ESS was a predictor of greater compliance. And 2 of 3 studies found that age was not a predictor of compliance. Only 1 or 2 studies evaluated other potential predictors, with no consistent findings.; - A single quality C cohort study evaluated potential predictors of compliance with newly initiated MAD. The study did not identify any statistically significant predictors.; - Conclusion: The strength of evidence is moderate that more severe OSA as measured by higher AHI is associated with greater compliance with CPAP use. The strength of evidence is moderate that higher ESS is also associated with improved compliance.; - Conclusion: The strength of evidence is insufficient regarding potential predictors of compliance with MAD.
Key Question 7: Treatment Treatments to improve compliance | Low | - There were 18 trials evaluating interventions to improve CPAP compliance. Of these, 2 were rated quality A, 8 quality B, and 8 quality C. These studies are mostly applicable to patients initiating CPAP with AHI >30 events/hr and BMI greater than 30 kg/m^2^. No study evaluated interventions to improve compliance with other devices.; - There were 9 studies evaluating extra support or education. These studies had inconsistent findings regarding the effect of the interventions on compliance. Only 3 of 7 studies found increased number of hours of CPAP use; only 1 of 3 studies found persistent improved compliance (and that was of compliance with followup visits).; - There were 3 studies evaluating telemonitoring. No study found a statistically significant increase in CPAP usage (hours per night).; - A single study evaluated the effect of cognitive behavioral therapy, and showed that the behavioral intervention significantly increased hours of CPAP use per night compared with usual care (difference = 2.8 hours; 95% CI 1.8, 3.9; P<0.0001).; - There were 2 studies evaluating 2 other interventions: the hypnotic zolpidem and nasal pillows. No intervention was found to be effective to improve compliance.; - There were 3 studies evaluating nursing care models. None improved compliance.; - Conclusion: The strength of evidence is low that some specific adjunct interventions may improve CPAP compliance among overweight patients with more severe OSA who are initiating CPAP treatment. However, studies are heterogeneous and no general type of intervention (e.g., education) was more promising than others.

AHI = apnea-hypopnea index, AUC = area under the ROC curve, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure, ESS = Epworth Sleepiness Scale, HR = hazard ratio, MAD = mandibular advancement device, OSA = obstructive sleep apnea, PSG = polysomnography (sleep-laboratory based), RFA = radiofrequency ablation, ROC = receiver operating characteristics, SF-36 = Short Form Health Survey 36, UPPP = uvulopalatopharyngoplasty.

7 Type II monitors are portable devices that record all the same information as PSG (Type I monitors).

8 Type III monitors are portable devices that contain at least two airflow channels or one airflow and one effort channel.

9 Type IV monitors comprise all other devices that fail to fulfill criteria for Type III monitors. They include monitors that record more than two physiological measures as well as single channel monitors.

## General Discussion

In theory, obstructive sleep apnea (OSA) should be relatively simple to diagnose and treat. Diagnosis involves determining whether the number of apnea and hypopnea events caused by upper airway obstruction during sleep exceed a given threshold, and continuous positive airway pressure (CPAP) is an effective treatment to minimize the apnea-hypopnea index (AHI) and improve symptoms.

### Screening and Diagnostic Tests

Polysomnography (PSG), the standard test to diagnose OSA, requires one or more full night stays in a sleep laboratory. This can prove to be a difficult, inconvenient, and resource-intensive procedure requiring separate facilities and a full-time overnight skilled sleep technician. For many patients PSG may not be representative of a typical night’s sleep given the foreign setting, lack of nighttime routine, attached equipment, and being under observation. This may be particularly true the first night the test is given. Further complicating diagnosis, definitions of OSA vary widely, employing thresholds of AHI ranging from 5 to 15 events/hr. The American Academy of Sleep Medicine uses a threshold of 15 events/hr (with or without OSA symptoms) or 5 events/hr with OSA symptoms (unintentional sleep episodes during wakefulness; daytime sleepiness; unrefreshing sleep; fatigue; insomnia; waking up breath-holding, gasping, or choking; or the bed partner describing loud snoring, breathing interruptions, or both during the patient’s sleep).31,32 Variations in how PSG results are read and interpreted are also inevitable, possibly leading to inconsistent diagnosis of OSA across different sleep laboratories. In fact, as discussed in the Introduction, in-laboratory PSG has never been validated, and its true sensitivity and specificity in diagnosing OSA are not well documented.26 Moreover, the AHI, which is used as the single metric to define OSA for insurance companies and in clinical settings, can vary from night-to-night and does not take into account symptoms, comorbidities, or response to treatment.30

Two approaches have been taken to reduce the resources involved in diagnosing (or ruling out) OSA: tests to screen for the likelihood of OSA and portable monitors instead of sleep-laboratory PSG. Questionnaires and clinical prediction rules have been developed to screen patients with complaints suggestive of OSA to determine whether full testing is warranted. As addressed by Key Question 1, five questionnaires and 10 validated clinical prediction rules have been compared with PSG to test their accuracy to predict diagnosis with OSA (or severity of OSA). However, very few of the screening tests have been evaluated by more than one set of researchers and few have been directly compared with each other. The Berlin questionnaire’s accuracy to screen for OSA (based on snoring, tiredness, and blood pressure), the only questionnaire that has been compared with PSG by two sets of investigators is supported by only a low strength of evidence. All other tests, including the commonly used STOP and STOP-Bang questionnaires, have not been adequately tested. To be of clinical value, such tests would need a very high sensitivity (to avoid failures to diagnose) and a sufficiently high specificity to minimize unnecessary testing of patients without OSA. Furthermore, the most clinically useful tests would be those that can be easily performed based on symptoms and signs easily obtainable during a physical examination. Screening tests that require specialized testing, such as pulmonary function tests, are likely of limited clinical value.

The second approach to reduce the resources involved in diagnosing OSA is the use of portable monitors developed for home or outside the laboratory. However, these monitors suffer similar deficiencies in validation. The addition of more recent studies has not substantially changed the conclusions from our Evidence-based Practice Center’s 2007 Technology Assessment on Home Diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome.26 Numerous monitors have been evaluated across 93 eligible studies. Most of the tested portable monitors fairly accurately predict OSA, with high positive likelihood ratios and low negative likelihood ratios for various AHI cutoffs in laboratory-based PSG; however, it is unclear whether any of the portable monitors are sufficiently accurate to replace laboratory-based PSG. In general, portable monitors use many fewer “channels” (specific physiologic measures) than typical 16-channel PSG. Different portable monitors use different numbers of channels and different specific channels. In general, across studies, monitors with more channels perform better than monitors with fewer channels. However, a lack of direct comparisons between portable monitors in their performance compared with PSG, and the large number and variety of monitors precludes a clear conclusion regarding which monitors perform best. None of the studies explicitly evaluated the monitors in patients with important comorbidities such as chronic lung disease, congestive heart failure, or with neurological disorders. The applicability of the evidence is unclear for these populations and for patients in whom there is a concern about central sleep apnea. Nevertheless, the evidence does suggest that the measured AHI (or similar measures) from portable monitors are likely to be biased and variable compared with PSG-derived AHI. Though, it is unclear to what degree this is due to the inaccuracies of the portable monitors, where the data loss ranged from 0–23 percent (not including the outlier study with a 78 percent data loss) and to what degree it is due to normal variation in AHI from night-to-night or differences related to sleeping in different settings (home versus a sleep laboratory). Night-to-night variability may be addressed by repeated measurement over several nights, which may be better addressed by the portable monitors than the PSG due to the increased cost of repeated testing. The studies did not allow us to adequately assess any issues related to night-to-night variation. Additionally, among studies that evaluated a portable device in the sleep lab (simultaneous recording of signals by device and PSG) as well as home (nonsimultaneous recording of signals by device and PSG), the range of mean bias, sensitivity and specificity reported were not different for the two settings. More to the point, however, the only truly clinically valuable assessments of portable monitors would be tests of their predictive ability for clinical outcomes or response to treatment. No such studies have been conducted.

With the assumption that screening tests and/or portable monitors are of clinical value to triage patients for the treatment of OSA, further testing for OSA, or further testing for other conditions, the question arises as to what the algorithm for diagnosing these patients should be. Ideally, any proposed algorithms of phased testing should be compared to alternative algorithms, including full testing of all patients with symptoms suggestive of OSA. However, to date, no such studies have been conducted.

An important caveat to the evidence on the diagnostic and screening tests is that almost all the studies were peformed at academic or research centers. It is not clear how the results generated in these settings, under research conditions, should be generalized to acceptance, use, and accuracy when used among the general population.

A related topic of interest to is the value of preoperative screening for OSA. As discussed in the Introduction, patients with OSA are at an increased risk of perioperative pulmonary and cardiovascular complications, but a large proportion of patients with OSA remain undiagnosed. Therefore, it has been suggested that all (or selected) patients undergoing anesthesia or surgery should routinely be screened or tested for OSA; however, the strength of evidence addressing this question is insufficient. One retrospective study of patients undergoing bariatric surgery found that a cohort of patients who had routine PSG had better perioperative outcomes than a cohort of patients who had PSG only if they were considered to be at an increased risk for OSA. There are also no adequate studies that compared phased testing (simple tests followed by more intensive tests in selected patients) to full evaluation (PSG).

#### Apnea-Hypopnea Index as a Predictor of Clinical Outcomes

As described under Key Question 4, there is a high strength of evidence that higher baseline AHI is a strong and independent predictor of all-cause mortality over several years of followup. The association was strongest among people with severe OSA (AHI over 30 events/hr). The strength of evidence for the association between baseline AHI and other long-term clinical outcomes is either low (for incident diabetes mellitus) or insufficient (for other examined outcomes). These findings would seem to imply that individuals with OSA (and particularly severe OSA) should be treated aggressively to reduce their AHI. Unfortunately, as discussed below, there are almost no trial data to support that treatment of OSA and reduction of AHI improves clinical outcomes. Thus, the clinical value of these associations remains theoretical.

#### Treatment of Obstructive Sleep Apnea

As previously noted, there is a moderate strength of evidence that fixed CPAP is an effective treatment to minimize AHI and improve sleepiness symptoms. While the relevant trials are conclusive regarding the effects of CPAP on AHI and sleepiness measures, among over 40 trials of patients treated with CPAP or no treatment, none have reported long-term clinical outcomes. However, compliance with CPAP treatment is poor. Among the large cohort studies (with multivariable analyses for predictors of noncompliance), one reported 16 and 32 percent of patients discontinued CPAP at 1 and 4 years, respectively;289 14 percent of patients had CPAP withdrawn for noncompliance at a mean of 3.2 years in a second study;290 and patients used CPAP for an average of only about 5 hours per night at 3 months in two studies.203,292 Higher baseline AHI and increased sleepiness as measured by the Epworth Sleepiness Scale are both predictors of improved compliance with CPAP (high strength and moderate strength of evidence, respectively). There are numerous reasons why patients do not tolerate CPAP, including the difficulty of dealing with the equipment and its noisiness, mask discomfort, claustrophobia, oral and nasal irritation and dryness, and others. Among reviewed studies, up to 15 percent of patients described adverse events they considered to be major (though essentially none of the adverse events resulted in long-term consequences).

Because patients frequently do not tolerate fixed CPAP, many alternative treatments have been proposed and used, including alternative CPAP devices, devices to splint the oropharynx open during sleep, surgeries to minimize airway obstructions, and numerous other less commonly used or researched interventions. As discussed in the Introduction, several alternative CPAP devices have been designed to vary the pressure during the patient’s inspiratory cycle or to titrate the pressure to a minimum level necessary to maintain airway patency. Other modifications include alternate masks, nasal pads, and humidification. The primary goal of these modifications is to improve comfort and thereby increase compliance with the treatment.

The large majority of the trials that have compared different CPAP machines have compared autotitrating CPAP (autoCPAP) with fixed CPAP. There is a moderate strength of evidence that there are no clinical differences between autoCPAP and fixed CPAP, though, again, none of these trials evaluated clinical outcomes. Meta-analysis revealed patients using autoCPAP used the machines only 11 minutes longer on average than patients using fixed CPAP. A low strength of evidence suggests no statistically significant differences between the proprietary C-Flex™ and fixed CPAP. The strength of evidence is insufficient for other comparisons. Overall, the evidence does not support the use of one device for all patients. The decision as to which CPAP device to use may depend on numerous factors such as patient preference, specific reasons for noncompliance, cost, and others.

For patients who do not tolerate CPAP, or who refuse CPAP, or for whom CPAP is determined to be inappropriate, an alternative is the use of oral devices. A wide range of these devices have been designed with the goal of splinting open the oropharynx to prevent obstruction during sleep. The most common are mandibular advancement devices (MAD), which are generally worn intraorally and force the mandible to protrude forward several millimeters. Ten trials provide a moderate strength of evidence that MAD use is an effective treatment for OSA and results in a significant reduction in AHI and a clinical improvement in ESS score (though there is no trial evidence on clinical outcomes). By indirect comparison across trials, CPAP is more effective than MAD (e.g., meta-analysis summary net AHI reduction with CPAP is −33 events/hr; with MAD −12 events/hr). This was confirmed by trials that directly compared the two types of devices (CPAP versus MAD, net AHI reduction −8 events/hr). There is a moderate strength of evidence that CPAP is superior to MAD in the relief of sleep apnea signs and symptoms. However, given the issues with CPAP compliance, the decision as to whether to use CPAP or MAD will likely depend on patient preference. The adverse events associated with MAD are different than CPAP and stem from wearing an intraoral device. Most are self-limited, though tooth damage has been reported. Given the wide range of specific oral devices and the small number of trials that have made comparisons among them, the strength of evidence regarding their relative merit remains insufficient.

The third major alternative for OSA treatment includes surgical interventions to alleviate airway obstruction. The Key Questions addressed and the studies reviewed for the present report do not address what the indications for surgery may be, nor which surgery may be the most appropriate. As is often the case for surgical interventions, very few randomized trials have been conducted on surgical treatments for OSA. It is reasonable to assume that patients who choose surgery are fundamentally different from those who are either not offered surgery or who choose a different (or no) treatment. These differences are borne out by the differences in baseline characteristics (including mean AHI and ESS, age, obesity, and others) found in the nonrandomized comparative studies reviewed herein that compare surgery to other treatments. Thus, indirect comparisons of surgical studies and CPAP or MAD studies are inappropriate and even though it was agreed upon to include retrospective comparisons of surgery and CPAP or MAD in this report, the value of these studies is highly suspect. Given these issues, the strength of evidence to determine the relative value of surgery as compared with no treatment, to CPAP, to MAD, or to alternative types of surgery remains insufficient.

Other interventions that have been tested in randomized trials (that met eligibility criteria for this review) include: weight loss programs, atrial overdrive pacing, eight different drugs, palatal implants, oropharyngeal exercises, a tongue-retaining device, a positional alarm, combination tongue-retaining device and positional alarm, bariatric surgery, nasal dilator strips, acupuncture, and auricular plaster. There is a low strength of evidence (from three trials) that some intensive weight loss programs may be an effective treatment for OSA in obese patients; however, the strength of evidence is insufficient to determine the effects of any other of these alternative potential treatments for OSA.

Notably, little evidence exists across interventions supporting any OSA treatment as improving quality of life or neurocognitive function. Although trials did report improvements in these outcomes for CPAP, MAD, and surgical intervention, overall findings were inconsistent. Too few studies evaluated functional outcomes (such as driving skills) to formulate a conclusion.

#### Potential Different Treatment Effects in Different Patient Subgroups

For all the treatment comparisons, it is of particular interest which subgroups of patients may benefit most from which specific treatments. Unfortunately, the trials reviewed are almost completely silent on this issue. Very few trials reported subgroup analyses based on baseline or patient factors, such as OSA severity or demographics. For most comparisons, there were too few studies or the interventions examined were too heterogeneous (e.g., different types of MAD) to analyze potential differences across studies based on patient characteristics.

There were, however, a large number of trials of CPAP versus control (no treatment, placebo treatment, or sham CPAP). Subgroup meta-analysis of the trials based on their implied definitions of OSA (study eligibility criteria using different minimum AHI thresholds) failed to demonstrate any clear or consistent relationships between strictness of OSA definition and effectiveness of CPAP (to reduce AHI or ESS). Though statistical heterogeneity existed across trials, we were unable to find any patient- or intervention-level factors to explain the heterogeneity. Differences also existed based on whether the study design was parallel or crossover, and whether the control was no treatment or sham CPAP; however, there are no clinical implications of these findings. A large number of trials, conducted in a wide variety of settings, with a wide range of eligibility criteria, all found statistically and clinically significant improvements in AHI with CPAP. Based on this consistency (despite statistical heterogeneity), it is our conclusion that CPAP is effective (to minimize AHI) in all patients with OSA. The relative effectiveness in different populations may then be a moot point. The one exception might be patients with mild OSA (with AHI <15 events/hr). By definition, people with a low AHI cannot have as large an improvement in their AHI as people with severe OSA. A trial examining long-term clinical outcomes is necessary to make a definitive evaluation in this population.

The other intervention comparison for which cross-study evaluation of effectiveness in different populations may be possible is autoCPAP versus fixed CPAP, for which 21 trials qualified for review. No differences could be discerned based on patient characteristics except that the relative improvement in ESS conferred by autoCPAP was larger in studies restricted to patients with AHI >20 or >30 events/hr, compared with those that included patients with less severe disease (or did not define a minimum AHI threshold).

#### Interventions to Improve Treatment Compliance

Given the difficulties with treatment compliance, an important question remains on how to improve usage of the interventions. Trials addressing this issue have investigated only interventions to improve CPAP compliance. Eighteen trials have each investigated unique interventions. These can be categorized as intensive education, telemonitoring, nursing care models, cognitive behavioral therapy, and miscellaneous interventions. Although, overall there is a low strength of evidence that some specific adjunct interventions may improve CPAP compliance, the strength of evidence is insufficient regarding any specific intervention. No trials have investigated interventions to improve compliance with any other devices.

## Limitations

The present systematic review is subject to several important limitations. The most critical is the failure of the extant research to evaluate long-term clinical outcomes. Secondly, and in a similar vein, is the meagerness of evidence with respect to several Key Questions. Almost no study of diagnostic tests or treatments attempted to assess how results may vary in different subgroups of patients.

In general, intervention trials were of quality B or C, with few quality A studies. Followup durations tended to be very short, on the order of weeks to a few months, and are clearly insufficient for the appraisal of the treatment of a life-long disease whose clinical sequelae may take decades to develop. Study dropout rates were also frequently very high, particularly given the short duration of followup. In some studies, up to 40 percent of participants were lost to followup within weeks. The ability to meaningfully interpret the findings from these studies is clearly diminished. Other frequent methodological problems with studies included incomplete reporting and/or inadequate analyses. In particular, relatively few studies provided the net differences between interventions (in parallel design studies) or the difference between final values with appropriate adjustments for correlation (in crossover studies) with their confidence intervals and P values. Thus, for the large majority of studies we had to estimate the confidence intervals of the differences between interventions. Due to incomplete reporting or analyses, we also frequently had to estimate whether there was a statistically significant difference between interventions.

Patient compliance is an important outcome within this review, being a major outcome for treatment studies (particularly those that compare different devices) and the focus of two additional Key Questions. However, many studies measured self-reported compliance (either hours of use per night or nights of use per week). This raises the concern of inaccurate reporting, although there is no obvious reason to suspect biased reporting in favor of any specific device. In addition, a variety of definitions of compliance were used, complicating interpretation of results across studies.

Publication is a possible major concern for the validity of this review. The large majority of intervention studies (particularly those of diagnostic monitors and of mechanical treatment devices) were sponsored directly or indirectly by the manufacturers of the devices. Unfortunately, due to the magnitude of this review and limited time and resources to perform the review, we were not able to attempt a grey literature search to seek unpublished studies.

Nevertheless, this concern is tempered by a number of factors. Most of our conclusions were that the strength of evidence is either low or inadequate for interventions (minimizing the concern about publication bias among the current literature). The effects of CPAP and MAD on sleep measures were generally large enough that conclusions about the effectiveness of these devices would be unlikely to change with the addition of unpublished trials. However, the reliance of the field on industry funding may partially explain the general lack of long-term trials with clinical outcomes, since these studies are not required by the Food and Drug Administration for device marketing.