# Results

The literature search in MEDLINE^®^, the Cochrane Central Trials Registry^®^, and Cochrane Database of Systematic Reviews^®^ yielded 15,816 citations. From these, 861 articles were provisionally accepted for review based on the abstracts and titles (Figure 2). After screening their full texts, 612 articles were rejected for not meeting eligibility criteria (see Appendix B for the list of rejected articles and their reasons for rejection). The most common reasons for article rejection were: inclusion in the 2007 Technology Assessment of Home Diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome;26 analysis of too few study participants; no interventions, outcomes, predictors, or analyses of interest; and retrospective, noncomparative, or cross-sectional study design. In total, 234 studies (in 249 articles) met criteria and are reviewed. All relevant studies found in previous systematic reviews, selected narrative reviews, and by domain experts had already been captured by our literature search.

Figure 2 Literature flow

Note that the numbers of studies for each Key Question do not sum to the total number of studies because some studies addressed multiple Key Questions.

This figure is a flow chart that summarizes the study retrieval and selection process of articles on obstructive sleep apnea in adults relevant to the seven key questions. The figure displays the same information as enumerated in the first paragraph of Chapter 3. In addition, the figure includes the following numbers of studies that were reviewed for each Key Question: Key Question 1, 44 studies; Key Question 2, 1 study; Key Question 3, 2 studies; Key Question 4, 11 studies; Key Question 5, 173 studies; Key Question 6, 6 studies; and Key Question 7, 18 studies.

Due to the large quantity of evidence reviewed, Summary Tables are in Appendix D.

## Key Question 1 How do different available tests compare in their ability to diagnose sleep apnea in adults with symptoms suggestive of disordered sleep? How do these tests compare in different subgroups of patients, based on: race, sex, body mass index, existing non-insulin-dependent diabetes mellitus, existing cardiovascular disease, existing hypertension, clinical symptoms, previous stroke, or airway characteristics?

The American Sleep Disorders Association classified the different monitors that have been used in sleep studies into four categories, depending on which channels they record and evaluate.34 Type I monitors are facility-based polysomnography (PSG). Type II monitors record the same information as Type I with fewer channels, and record signals that allow for the reliable identification of arousals from sleep (electroencephalography, electrooculography, electromyography, electrocardiography), and have at least two airflow channels or one airflow and one effort channel. Type III monitors contain at least two airflow channels or one airflow and one effort channel. Type IV monitors comprise all other devices that fail to fulfill criteria for Type III monitors. They include monitors that record more than two physiological measures as well as single channel monitors. We evaluate Type III monitors separately from Type IV monitors.

To address this Key Question, we evaluated three types of comparisons: portable monitoring devices (Types II, III, and IV) versus PSG, questionnaires versus PSG or portable monitors, and clinical prediction models versus PSG or portable monitors.

We searched for prospective cross-sectional or longitudinal studies of any followup duration with at least 10 study participants analyzed with each test of interest. We did not reevaluate studies included in the 2007 Technology Assessment of Home Diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome conducted by the Tufts Evidence-based Practice Center.26 We briefly summarize the findings of the previous report. We do not present studies included in the 2007 Technology Assessment in our summary tables, but we include them in graphs, when applicable.

### Comparison of Portable Devices and Polysomnography

#### Type II Monitors

The 2007 Technology Assessment identified three quality B studies that compared two different Type II monitors in the home setting to either the same monitor in the laboratory setting (two studies) or full laboratory PSG (one study). Difference versus average (mean bias) analyses of the apnea-hypopnea index (AHI) ranged from 0 to −2 events/hr. However, based on the 95 percent limits of agreement between portable and laboratory AHI measurements, discrepancies between the monitors and PSG were as wide as −36 to 36 events/hr. In one study, the difference between the two measurements was dependent on their average value; the portable monitor overestimated laboratory-based measurements for AHI<20 events/hr, but underestimated it in more severe cases. One study assessed the ability of a Type II monitor to predict an AHI>15 events/hr with laboratory-based PSG. Sensitivity was 81 percent, specificity 97 percent, and positive likelihood ratio >10.

No Type II monitors were identified in the update.

#### Type III Monitors

##### Findings of the 2007 Technology Assessment

The 2007 Technology Assessment included 22 studies that compared 13 different Type III monitors with facility-based PSG in various settings. In all studies, difference versus average analyses suggested that measurements of AHI with facility-based PSG and respiratory disturbance index (RDI) with portable monitors can differ substantially. The mean difference of AHI-RDI ranged from −10 to 24 events/hr. Based on the 95 percent limits of agreement between AHI and RDI measurements, discrepancies between the monitors and PSG varied from −39 to 54 events/hr. Such large discrepancies can affect clinical interpretation in some patients. For example, a discrepancy of 30 events/hr is important when the measurements are 4 and 34 events/hr by PSG and the device, respectively, but it may be irrelevant if the measurements are 40 and 70 events/hr. In most studies, the difference versus average analyses plots showed that the discordance between facility-based PSG and portable monitors increases as the AHI or RDI values get higher. None of the studies accounted for this in their analyses of concordance, and this makes the interpretation of the above findings difficult.

Analysis of sensitivity and specificity found that Type III monitors may have the ability to predict an elevated AHI (as determined by PSG) with high positive likelihood ratios and low negative likelihood ratios for various AHI cutoffs in laboratory-based PSG.

##### Description of Studies Published After the Completion of the 2007 Technology Assessment

(Appendix D Tables 1.1.1 & 1.1.2)

We identified seven studies66–72 published after the completion of our previous Technology Assessment (Appendix D Table 1.1.1). Three studies were performed in the sleep laboratory setting,68,70,71 with simultaneous recording of physiological parameters by both the device and the PSG machine, three studies were performed both in the sleep laboratory as well as at home66,67,69 and one study was performed in the home setting.72 When studies were performed at home, the measurements taken by the device and the PSG machine are on different nights. The seven different Type III monitors that were included were Apnoescreen II respiratory polygraph, Stardust II, Apnea Risk Evaluation System (ARES^™^) Unicorder, Morpheus Hx (bedside computerized analysis system), Embletta portable diagnostic system, CID102L8 Type II device and SOMNOcheck^®^ (SC), resulting in a total of 20 unique Type III monitors when pooled with the studies in the 2007 Technology Assessment (Appendix D Table 1.1.2). Twelve of the 20 monitors are assessed in only a single study, 7 are evaluated in 2 studies each, and one monitor is assessed in 3 studies. Therefore there is inadequate evidence to perform indirect comparisons of diagnostic efficacy between the monitors.

The number of analyzed participants in these studies ranged from 45 to 149. Three studies were graded quality A and four were graded quality B due to potential bias, the reasons for which varied across studies—incomplete reporting of population, unclear reporting of concordance results and unclear analytical strategy.

Participants were referral cases for the evaluation of suspected sleep apnea and were recruited from sleep centers or respiratory clinics. The population of subjects in the sleep laboratory setting was not different from the population of subjects assessed outside the sleep laboratory. In all studies, the majority of the participants were males. The mean ages of patients ranged from 45 to 63 years. Patients had mean Epworth Sleepiness Scale (ESS) scores (a standard measure of sleepiness symptoms) ranging from 8 to 12. At PSG, patients’ mean AHI ranged from 15 to 39.9 events/hr. The data loss, or the proportion of participants who did not complete the study, ranged from 2 to 23 percent.

##### Concordance

(Appendix D Table 1.1.2)

Six of the seven new studies provided enough information to perform analyses of the concordance between AHI readings from Type III monitors and PSG.66,67,69–72} In the seventh study, the difference versus average analyses plots were not interpretable from the figure provided.68 The Apnoescreen II, Stardust II, ARES, Morpheus Hx (bedside computerized analysis system), Embletta portable diagnostic system, CID102L8 Type II device and SOMNOcheck monitors were used in these studies.

The mean bias is the average difference between the AHI (or RDI or ODI) estimated with the portable device and the AHI measured by PSG. The mean difference of AHI-RDI ranged from −4 to 3 events/hr. Based on the 95 percent limits of agreement between AHI and RDI measurements, discrepancies between the monitors and PSG varied from −31 to 36 events/hr. Among studies that were conducted using the same monitor in both the laboratory (simultaneous recording of signals by device and PSG) and home setting (nonsimultaneous recording of signals by device and PSG), there was no major difference in the range of mean bias reported in both settings.

When we considered all studies, including the 22 studies from the 2007 Technology Assessment, the results pointed to the same direction. The mean difference of AHI-RDI ranged from −10 to 24 events/hr. Based on the 95 percent limits of agreement between AHI and RDI measurements, discrepancies between the monitors and PSG varied from −39 to 54 events/hr.

##### Sensitivity and Specificity

(Tables 2a and 2b; Appendix D Table 1.1.3; Figure 3)

Table 2a Range of sensitivity and specificity of Type III monitors (n=7)

AHI cutoff by PSG (events/hr) | Sensitivity (%) | Specificity (%)
5 | 83 – 97 | 48 – 100
15 | 64 – 100 | 41 – 100
30 | 75 – 96 | 79 – 97

AHI = apnea-hypopnea index, nd = no data, PSG = polysomnography.

Table 2b Range of sensitivity and specificity of Type IV monitors with ≥3, 2, and 1 channels (n=24)

AHI cutoff by PSG (events/hr) | ≥3 channels (n=6) Sensitivity (%) | ≥3 channels (n=6) Specificity (%) | 2 channels (n=6) Sensitivity (%) | 2 channels (n=6) Specificity (%) | 1 channel (n=12) Sensitivity (%) | 1 channel (n=12) Specificity (%)
5 | 85 – 100 | 67 – 100 | 92 – 98 | 50 – 100 | 85 – 96 | 50 – 100
15 | 75 – 92 | 50 – 100 | 67 – 91 | 78 – 96.4 | 43 – 100 | 42 – 100
30 | 88 | 100 | Nd | nd | 18 – 100 | 50 – 100

AHI = apnea-hypopnea index, nd = no data, PSG = polysomnography.

Figure 3 Diagnostic ability of Type III monitors to identify AHI cutoffs suggestive of diagnosis of OSA, and its severity, as per laboratory-based polysomnography

Sensitivity and specificity of Type III monitors in receiver operating characteristics space. Each circle represents one pair of sensitivity/specificity measurements for a given Type III monitor. Circles connected by lines represent the same monitors being tested at different thresholds within a study. The thin diagonal lines represent the thresholds for a positive likelihood ratio >10 (to the left of the near-vertical line) and negative likelihood ratio ≤0.1 (above the near-horizontal line). A high positive likelihood ratio and a low negative likelihood ratio indicate that the portable monitor has very good ability to predict the results of PSG. AHI = apnea-hypopnea index, PSG = polysomnography.

This figure is a series of receiver operating characteristics graphs that plot the sensitivity and specificity of the Type III monitors at various AHI thresholds at polysomnography (namely 5, 10, 15, 20, 30, and 40 events per hour). The figures show positive and negative likelihood ratio thresholds to demonstrate the number of studies that fall within their boundaries, and thus have a very good ability to predict the results of polysomnography. For a polysomnography AHI cutoff of 5 events per hour, 10 sensitivity-specificity pairs all fall beyond or near the likelihood ratio thresholds, and 1 farther below the thresholds. For both AHI cutoffs of 10 and 15 events per hour, a large number of studies are mostly clustered in the upper left corner, indicating high sensitivity and specificity, with some outliers with lower sensitivity and/or specificity. For an AHI cutoff of 20 events per hour, 5 of 8 sensitivity-specificity pairs fall above the likelihood ratio thresholds, with several pairs falling below the thresholds. For an AHI cutoff of 30 events per hour, 5 sensitivity-specificity pairs all fall beyond or near the likelihood ratio thresholds, and 1 below. For an AHI cutoff of 40 events per hour, 2 sensitivity-specificity pairs from the same study have 100 percent specificity, but sensitivities of about 60 and 70 percent.

All seven studies assessed the sensitivity and specificity of portable monitor recordings to identify AHI suggestive of obstructive sleep apnea (OSA).66–72 Two studies used a cutoff of AHI of 5 events/hr68,69 and one study used a cutoff of AHI of 15 events/hr70 in facility-based PSG to diagnose OSA. The other four studies did not report an AHI cutoff.66,67,71,72 They reported the sensitivity and specificity for a cutoff range of 5 to 30 events/hr.

Garcia-Diaz 2007 reported sensitivity and specificity pairs for three cutoffs of RDI derived from the Type III monitor (10, 15, and 30 events/hr), recorded independently by two observers. The sensitivity for these three cutoffs ranged from 94.6 to 100 percent, and the specificity ranged from 88 to 100 percent. To 2009 used three different cutoffs for oxygen desaturation with the ARES Unicorder (drops of 4, 3, and 1 percent). A single cutoff for diagnosing sleep apnea (≥5 events/hr) was used for all desaturation levels. The best sensitivity was found with 1 percent oxygen desaturation (sensitivity 97 percent, specificity 63 percent).

Among studies that were conducted using the same monitor in both the laboratory (simultaneous recording of signals by device and PSG) and home setting (nonsimultaneous recording of signals by device and PSG), there was no major difference in the range of sensitivity and specificity reported in both settings. Across all 29 studies, including the 22 studies from the 2007 Technology Assessment, the range of sensitivity of Type III devices for predicting OSA with an AHI cutoff of 5 was 83 to 97 percent, and the range of specificity was 48 to 100 percent (Appendix D Table 1.1.3). When the AHI cutoff was increased to 15, the range of sensitivity was 64 to 100 percent and the range of specificity was 41 to 100 percent. Raising the AHI cutoff to 30, the range of sensitivity was 75 to 96 percent and the range of specificity was 79 to 97 percent.

Across all 29 studies, including the 22 studies from the 2007 Technology Assessment, the positive and negative likelihood ratios were calculated and plotted on graphs for each AHI cutoff of 5, 10, 15, 20, 30, and 40 events/hr. These graphs are presented as a matrix of plots in Figure 3, illustrating the diagnostic ability of Type III portable monitors to predict an elevated AHI, at various AHI cutoffs as determined by PSG. Each cutoff of AHI is depicted in a separate plot in receiver operating characteristics (ROC) space. Each circle represents one study, and sensitivity/specificity pairs from the same study (from different cutoffs or a different device setting) are connected with lines. Studies to the left of the near-vertical thin diagonal line have a positive likelihood ratio ≥ 10, and studies above the near-horizontal thin diagonal line have a negative likelihood ratio ≤ 0.1. A high positive likelihood ratio and a low negative likelihood ratio indicate that testing with a portable monitor can accurately predict an elevated AHI (as determined by PSG).

With an AHI cutoff of 5 events/hr, most of the studies have a positive likelihood ratio ≥10 and a negative likelihood ratio close to 0.1. At the AHI cutoff of 10 events/hr, most of the studies have a positive likelihood ratio of ≥ 10, with some studies having a positive likelihood ratio ≥ 10 and a negative likelihood ratio ≤ 0.1. This is also seen with a cutoff of 15 events/hr. There are fewer studies evaluating the cutoff of 20 and 30 events/hr, but the results indicate a trend towards better prediction of OSA. (Figure 3)

The ROC space plots indicate that Type III monitors generally accurately diagnose OSA (determined by full PSG), and also predict different severities of OSA (defined by having AHI above different thresholds) with high positive likelihood ratios and low negative likelihood ratios for various AHI cutoffs in PSG.

#### Type IV Monitors

##### Findings of the 2007 Technology Assessment

The 2007 Technology Assessment included 46 studies that compared 11 different Type IV monitors with facility-based PSG in various settings. In all studies, difference versus average analyses suggested that measurements of AHI with facility-based PSG and of RDI with portable monitors can differ greatly. The mean difference of AHI-RDI ranged from −17 to 12 events/hr. Based on the 95 percent limits of agreement between AHI and RDI measurements, discrepancies between the monitors and PSG varied from −49 to 61 events/hr.

Analysis of sensitivity and specificity found that studies of Type IV monitors that record at least three bioparameters showed high positive likelihood ratios and low negative likelihood ratios. Studies of Type IV monitors that record one or two bioparameters also had high positive likelihood ratios and low negative likelihood ratios for selected sensitivity and specificity pairs from ROC curve analyses.

##### Description of Studies Published After the Completion of the 2007 Technology Assessment

(Appendix D Tables 1.1.2; 1.2.1–1.2.3)

We identified 24 new studies73–96 that compared Type IV monitors with facility-based PSG in various settings. Their description and findings, stratified based on their number of channels, i.e., the number of different physiological parameters that were being measured, are presented in Appendix D Table 1.2.1 (≥3 channels), Appendix D Table 1.2.2 (2 channels), and Appendix D Table 1.2.3 (1 channel). Fifteen studies were performed only in the sleep laboratory setting,74,75,77–81,83–86,89,91,93,96 six were performed in both the sleep laboratory as well as the home setting,73,87,88,92,94,95 two were performed in the home setting,76,82 and one in a community setting.90 The different Type IV monitors included were, ApneaLink™, ARES Unicorder, Apnomonitor, FlowWizard®, Holter Monitor, Oximetry devices, Embletta™ PDS (portable diagnostic system), ClearPath System Nx 301, Lifeshirt^®^, MESAM 4, RUSleeping™ RTS, SOMNIE, and WatchPAT™, resulting in a total of 23 unique monitors when pooled with the studies in the 2007 Technology Assessment (Appendix D Table 1.1.2). In one study, we reclassified a device from a Type III to a Type IV because of the particular channels used in the ARES Unicorder.73 Six devices had more than three channels,73,79,87,88,93,96 six had two channels,74,80,81,85,89,95 and 12 had only a single channel.75–78,82–84,86,90–92,94 Oximetry (either alone or in combination with snoring sound recording), ECG, or actigraphy was assessed in 22 studies. Among the remaining monitors, 14 of the 23 monitors were assessed in a single study, four (ARES, Holter ECG, Oxiflow, Sleep Strip) were assessed in two or three studies, and four (ApneaLink, Autoset, MESAM IV, WatchPAT 100) were assessed in five to eight studies. Given the heterogeneity of studies and monitors, we determined it was not appropriate to perform indirect comparisons of diagnostic efficacy between specific monitors.

The number of analyzed participants in these studies ranged from 14 to 366. Seven studies were graded quality A. Eleven studies were graded quality B due to potential bias, the reasons for which varied across studies – multiple sites with difference between sites, incomplete reporting of population, unclear reporting of results, and incomplete reporting of test blinding protocols. Six studies were graded quality C due to significant bias, with varying reasons across different studies – nonblinding of portable device tests results from PSG results, unclear reporting of results and population characteristics, and more than 50 percent dropout rate.

Participants in 19 studies were referral cases for the evaluation of suspected sleep apnea and were recruited from sleep centers or hospitals.73,75–77,79–87,89,92–96 One study enrolled commercial motor vehicle drivers,90 two studies recruited patients with heart failure,74,88 one study recruited diabetic patients,78 and one study was conducted in patients referred for uvulopalatopharyngoplasty.91 In all studies, the proportion of male participants ranged from 32 to 100 percent. The mean ages of patients ranged from 37 to 61 years. Patients had mean ESS scores (a standard measure of sleepiness symptoms) ranging from 5.8 to 13.3. At PSG, patients’ mean AHI ranged from 14 to 44 events/hr. The data loss, or the proportion of participants who did not complete the study ranged, from 0 to 78 percent. In one study among commercial truck drivers, the high rate of data loss was explained by reasons unrelated to the device performance, including termination of employment and previous history of PSG diagnosis.90 Excluding this study, the range of data loss was 0 to 18 percent.

##### Concordance

(Appendix D Tables 1.3.1–1.3.3)

Fifteen of the 24 studies provided enough information to perform analyses of the concordance between AHI readings from Type IV monitors and PSG.73,75,77–79,81,82,85,86,88,89,92,94–96 In the other nine studies, Bland-Altman analyses were either not conducted or the Bland-Altman plots were not interpretable.

The mean difference of AHI-RDI ranged from −10 to 12 events/hr. Based on the 95 percent limits of agreement between AHI and RDI measurements, discrepancies between the monitors and PSG varied from −32 to 49 events/hr. Among studies that were conducted using the same monitor in both the laboratory (simultaneous recording of signals by device and PSG) and home setting (nonsimultaneous recording of signals by device and PSG), there was no major difference in the range of mean bias reported in both settings.

When we considered all studies, including the 46 studies from the 2007 Technology Assessment, the mean difference of AHI-RDI ranged from −17 to 12 events/hr. Based on the 95 percent limits of agreement between AHI and RDI measurements, discrepancies between the monitors and PSG varied from −49 to 61 events/hr., affecting clinical interpretation. As seen in the 2007 Technology Assessment, the difference versus average analyses plots showed that the discordance between facility-based PSG and portable monitors increases as the AHI or RDI values get higher. None of the studies accounted for this in their analyses of concordance, and this makes the interpretation of the above findings difficult.

##### Sensitivity and Specificity

(Tables 2a and 2b; Appendix D Tables 1.1.3; 1.3.1–1.3.3, 1.1.3; Figure 4)

Figure 4 Diagnostic ability of Type IV monitors to identify AHI cutoffs suggestive of diagnosis of OSA, and its severity, as per laboratory-based polysomnography

Sensitivity and specificity of Type IV monitors in receiver operating characteristics space. Each circle represents one pair of sensitivity/specificity measurements for a given Type IV monitor. Circles connected by lines represent the same monitors being tested at different thresholds within a study. The thin diagonal lines represent the thresholds for a positive likelihood ratio >10 (to the left of the near-vertical line) and negative likelihood ratio ≤0.1 (above the near-horizontal line). A high positive likelihood ratio and a low negative likelihood ratio indicate that the portable monitor has very good ability to predict the results of PSG. AHI = apnea-hypopnea index, PSG = polysomnography.

Figure 4. Diagnostic ability of Type IV monitors to identify AHI cutoffs suggestive of diagnosis of OSA, and its severity as per laboratory-based polysomnography. This figure is a series of receiver operating characteristics graphs that plot the sensitivity and specificity of the Type IV monitors at various AHI thresholds at polysomnography (namely 5, 10, 15, 20, and 30 events per hour). The figure shows positive and negative likelihood ratio thresholds to demonstrate the number of studies that fall within their boundaries, and thus have a very good ability to predict the results of polysomnography. For a polysomnography AHI cutoff of 5 events per hour, most studies had high sensitivity and are beyond the likelihood ratio thresholds; 7 sensitivity-specificity pairs had lower likelihood thresholds. For a polysomnography AHI cutoffs of 10 and 20 events per hour, large numbers of studies mostly fall beyond the likelihood ratio thresholds, with a minority of studies with lower likelihood ratio thresholds. For a polysomnography AHI cutoff of 15 events per hour, the studies are spread out across the upper left half of the graph, with many studies beyond and many lower than the likelihood thresholds. For a polysomnography AHI cutoff of 30 events per hour, 3 studies had high sensitivity and specificity beyond the likelihood ratio threshold, while one study with 4 data points had generally low likelihood ratios.

All of the studies reported the sensitivity and specificity of portable monitor recordings to identify AHI suggestive of OSA. They reported the sensitivity and specificity for a range of cutoffs from 5 to 30 events/hr.

Among the devices with three or more channels,73,79,84,87,88,93,96 the range of sensitivity of these devices for predicting OSA with an AHI cutoff of 5 events/hr was 85 to 100 percent, and the range of specificity was 67 to 100 percent (Appendix D Table 1.3.1). When the AHI cutoff was increased to 15 events/hr, the range of sensitivity was 75 to 96 percent and the range of specificity was 50 to 100 percent. Raising the AHI cutoff to 30, one study reported a sensitivity of 88 percent and specificity of 100 percent.79

When evaluating devices with only two channels74–76,81,85,89,91,95 the range of reported sensitivity of these devices for predicting OSA with an AHI cutoff of 5 events/hr was 91.8 to 97.7 percent, and the range of reported specificity was 50 to 100 percent. When the AHI cutoff was increased to 15 events/hr, the range of sensitivity was 67 to 90.6 percent and the range of specificity was 78 to 96.4 percent. (Appendix D Table 1.3.2)

In studies that assessed devices with only one channel the range of reported sensitivity of these devices for predicting OSA with an AHI cutoff of 5 events/hr was 85.4 to 96 percent and the range of reported specificity was 50 to 100 percent.77,78,80,82,83,86,90–92,94 When the AHI cutoff was increased to 15 events/hr, the range of sensitivity was 42.5 to 100 percent and the range of specificity was 42 to 100 percent. Raising the AHI cutoff to 30 events/hr, the range of sensitivity was 18 to 100 percent and range of specificity was 50 to 100 percent (Appendix D Table 1.3.3).

Table 2 summarizes the range of sensitivity and specificity of Type IV devices with different channels.

Among studies that were conducted using the same monitor in both the laboratory (simultaneous recording of signals by device and PSG) and home setting (nonsimultaneous recording of signals by device and PSG), there was no major difference in the range of sensitivity and specificity reported in both settings.

Across all studies, including the 46 studies from the 2007 Technology Assessment, the range of sensitivity of Type IV devices for predicting OSA with an AHI cutoff of 5 was 85 to 100 percent, and the range of specificity was 50 to 100 percent. When the AHI cutoff was increased to 15, the range of sensitivity was 7 to 100 percent and the range of specificity was 15 to 100 percent.

There were 22 of 24 studies that had information that could be extracted for analysis.73–85,87–92,94–96 Across all studies, including the 46 studies from the 2007 Technology Assessment, the positive and negative likelihood ratios were calculated and plotted on graphs for each AHI cutoff of 5, 10, 15, 20, 30 and 40 events/hr. These graphs are presented as a matrix in Figure 4, illustrating the diagnostic ability of Type IV portable monitors to predict an elevated AHI at different thresholds (as determined by PSG). With an AHI cutoff of 5 events/hr, most of the studies have a negative likelihood ratio close to 0.1. At the AHI cutoff of 10 events/hr, the studies are equally distributed in regions that indicate either a positive likelihood ratio ≥ 10 or a negative likelihood ratio ≤ 0.1. With a cutoff of 15 events/hr, the studies are spread out in regions that indicate a positive likelihood ratio ≥ 10 or a negative likelihood ratio ≤ 0.1, as well as the intersection of these regions. The studies that fall into the intersection region have the best ability to predict an elevated AHI. Similar trends are seen when cutoffs of 20 and 30 events/hr are used (Figure 4).

The ROC space plots indicate that Type IV monitors generally accurately predict an elevated AHI (as determined by PSG), though the positive likelihood ratios are lower, and negative likelihood ratios are higher, than is seen with Type III monitors.

#### Summary

Analysis of difference versus average analyses plots suggest that substantial differences in the measured AHI may be encountered between both Type III and Type IV monitors, and PSG. Large differences compared with PSG cannot be excluded for all monitors. These studies on Type III and Type IV monitors are applicable to the general population referred to specialized sleep centers or hospitals for evaluation of suspected sleep apnea. Most of the studies are conducted either in the sleep laboratory setting or at home. Fifteen studies were graded quality A (six evaluating Type III monitors, nine assessing Type IV monitors), 45 studies were graded quality B (13 evaluating Type III monitors, 32 assessing Type IV monitors), and 39 studies were graded quality C (10 evaluating Type III monitors, 29 assessing Type IV monitors). No specific Type III monitor was evaluated by more than three studies. Among Type IV monitors, oximetry was evaluated by different monitors in 22 studies; no other monitor was evaluated by more than eight studies. No study directly compared different portable monitors to each other.

The strength of evidence is moderate that Type III and Type IV monitors may have the ability to accurately predict an elevated AHI (as determined by PSG) with high positive likelihood ratios and low negative likelihood ratios for various AHI cutoffs in PSG. Type III monitors perform better than Type IV monitors at AHI cutoffs of 5, 10 and 15 events/hr. The evidence is insufficient to adequately compare specific monitors to each other.

Based on a prior systematic review, the strength of evidence is low that Type II monitors are accurate to diagnose OSA (as defined by PSG), but have a wide and variable bias in estimating the actual AHI. The prior review concluded that “based on [three studies], type II monitors [used at home] may identify AHI suggestive of OSA with high positive likelihood ratios and low negative likelihood ratios,” though “substantial differences in the [measurement of] AHI may be encountered between type II monitors and facility-based PSG.”

### Comparison of Questionnaires and Polysomnography

We identified six studies that compared sleep questionnaires with facility-based PSG in various settings (Appendix D Table 1.4.1). Three papers described studies performed in sleep laboratory settings,36,97,98 one in a home setting,99 and two in a hospital, but not in a sleep clinic or sleep laboratory.100,101

Two of the five studies were conducted in the same group of patients visiting a preoperative clinic;36,97 one study was carried out among adult sleep disorder clinic patients;98 one study was done in patients visiting their primary care physician;99 one other study was conducted among patients attending a medical outpatient department in a tertiary care medical center;100 and, one study was conducted among patients attending a hypertension clinic of a hospital.101 The number of analyzed participants in these studies ranged from 53 to 211. The validated questionnaires that were administered in these studies included Berlin, STOP (Snoring, Tiredness during daytime, Observed apnea, and high blood Pressure), the STOP-Bang (STOP with body mass index [BMI], age, neck circumference, and sex variables), the American Society of Anesthesiologists (ASA) screening checklist for OSA in surgical patients, Hawaii Sleep Questionnaire, and the Epworth Sleepiness Scale. In all the studies, the cutoff of AHI in facility-based PSG that were considered suggestive of OSA was 5 events/hr.

One study was graded quality A as it had no issues in reporting of the study.101 However, the study was not primarily designed to evaluate the two instruments (Berlin questionnaire and the Epworth Sleepiness Scale), and it assessed the association of various clinical factors with the risk for OSA. It was included because the sensitivity and specificity for the index tests were reported. One study was graded quality B due to inadequate reporting of the results of the PSG, and four were graded quality C either due to selection bias or a dropout rate higher than 40 percent. These studies are applicable to patients visiting preoperative clinics, sleep laboratories, and primary care centers for evaluation of sleep apnea.

#### Berlin Questionnaire

(Appendix D Table 1.4.2)

Four studies assessed the sensitivity and specificity of the Berlin questionnaire in identifying AHI suggestive of OSA.97,99–101 The Berlin questionnaire predicts the risk of OSA as high or low based on a score in three categories of questions related to snoring, tiredness, and blood pressure.

The number of subjects enrolled in the three studies ranged from 53 to 2,127, but the number of subjects analyzed ranged from 53 to 211. The subjects were either patients from preoperative clinics,97 or from the population visiting their primary care physician,99 or a department in a hospital.100,101 The percentage of male subjects ranged from 42 to 80 percent, with the average age ranging from 46 to 55 years and average BMI ranging from 28 to 30 kg/m2. The mean baseline AHI ranged from 5 events/hr to 21 events/hr.

Chung 2008 reported sensitivity and specificity pairs for three cutoffs of the AHI index (5, 15, and 30 events/hr). With an AHI cutoff of 5 events/hr, sensitivity was 69 percent and specificity 56 percent. At the AHI cutoff of 15 events/hr, the sensitivity was higher (79 percent) the specificity was lower (51 percent). At an AHI cutoff of 30 events/hr, regarded as diagnostic of severe sleep apnea, the sensitivity was higher still (87 percent) and specificity lower (46 percent). The area under the receiver operating characteristics curve (AUC) for ability of the Berlin questionnaire to predict an AHI above 5, 15, and 30 events/hr ranged from 0.67 to 0.69. In Netzer 1999, with an AHI cutoff of 5 events/hr, the sensitivity of OSA prediction per the Berlin questionnaire was 86 percent and specificity was 77 percent. Changing the AHI cutoff to 15 events/hr decreased the sensitivity (54 percent) and increased the specificity (97 percent). At AHI cutoffs of 30 events/hr, the sensitivity further decreased (17 percent) and specificity remained the same (97 percent). In Sharma 2006, a cutoff of 5 events/hr resulted in a sensitivity of 86 percent and specificity of 95 percent. In Drager 2010, with an AHI cutoff of 5 events/hr, the sensitivity of OSA prediction per the Berlin Questionnaire was 93 percent and specificity was 59 percent. Figure 5 plots the sensitivity and specificity in the receiver operating characteristics space, illustrating the diagnostic ability of the Questionnaire to identify AHI cutoffs suggestive of diagnosis of OSA.

Figure 5 Diagnostic ability of the Berlin questionnaire to identify AHI cutoffs suggestive of diagnosis of OSA and its severity as per laboratory-based polysomnography

AHI = apnea-hypopnea index, PSG = polysomnography.

This figure plots the results in receiver operating characteristics space of four studies with sensitivity and specificity data. Chung 2008 reported sensitivity and specificity pairs for three cutoffs of the AHI index (5, 15, and 30 events per hour) and had sensitivities from 69 to 87 percent and specificities from 46 to 56 percent. Netzer reported sensitivity and specificity pairs for three cutoffs of the AHI index (5, 15, and 30 events per hour) and had sensitivities from 17 to 86 percent and specificities from 77 to 97 percent. Sharma 2006 reported a cutoff of 5 events per hour with a sensitivity of 86 percent and specificity of 95 percent. Drager 2010 reported a cutoff of 5 events per hour with a sensitivity of 93 percent and specificity of 59 percent.

In summary, using an AHI cutoff of 5 events/hr, sensitivity ranged was from 69 to 93 percent and specificity from 56 to 95 percent. Using an AHI cutoff of 15, the range of sensitivity was 54 percent to 79 percent, and specificity was 51 percent to 97 percent. For the definition of severe sleep apnea using a cutoff of 30, the range of reported sensitivity was 17 percent to 87 percent and specificity was 46 percent to 77 percent. The two studies were inconsistent as to whether the Berlin Questionnaire had a high positive likelihood ratio of “diagnosing” OSA or a low negative likelihood ratio of rejecting the diagnosis of sleep apnea.

#### STOP Questionnaire

(Appendix D Table 1.4.2)

Chung 2008 (Pubmed identifier 18431116) a quality C study, reported the sensitivity and specificity of the STOP Questionnaire to identify AHI suggestive of OSA.36 The STOP questionnaire predicts the risk of OSA as high or low based on answers to questions related to snoring, tiredness, witnessed apneas, and blood pressure. With an AHI cutoff of 5 events/hr, the sensitivity was 66 percent and specificity was 60 percent. Changing the AHI cutoff to 15 events/hr increased the sensitivity (74 percent) and decreased the specificity (53 percent). At AHI cutoffs of 30 events/hr, sensitivity increased (80 percent) and specificity decreased (49 percent). The AUC for the ability of the STOP questionnaire to predict an AHI above 5, 15, and 30 events/hr ranged from 0.703 to 0.769.

#### STOP-Bang Questionnaire

(Appendix D Table 1.4.2)

Chung 2008 (Pubmed identifier 18431116) a quality C study, assessed the sensitivity and specificity of the STOP-Bang questionnaire to identify AHI suggestive of OSA.36 The STOP-Bang questionnaire predicts the risk of OSA as high or low based on answers to questions related to snoring, tiredness, witnessed apneas, and blood pressure (as in the STOP questionnaire) in combination with anthropometric data, namely BMI (whether >35 kg/m^2^), age (>50 years), neck circumference (>40 centimeters), and sex. With an AHI cutoff of 5 events/hr, sensitivity was 84 percent and specificity was 56 percent. Changing the AHI cutoff to 15 events/hr sensitivity increased to 93 percent and specificity decreased to 43 percent. At AHI cutoffs of 30 events/hr, sensitivity further increased to 100 percent and specificity decreased to 37 percent. The AUC for ability of the STOP-Bang questionnaire to predict an AHI above 5, 15 and 30 events/hr ranged from 0.782 to 0.822.

#### American Society of Anesthesiologists Checklist

(Appendix D Table 1.4.2)

Chung 2008 (Pubmed identifier 18431117) a quality C study assessed the sensitivity and specificity of the ASA screening checklist to identify AHI suggestive of OSA in surgical patients.97 The ASA checklist predicts the risk of OSA as high or low based on results from three categories: predisposing physical characteristics (including BMI, neck circumference, craniofacial abnormalities, nasal obstruction, and tonsillar position), history of apparent airway obstruction during sleep, and reported or observed somnolence. With an AHI cutoff of 5 events/hr the sensitivity was 69 percent and specificity was 56 percent. An AHI cutoff of 15 increased the sensitivity to 79 percent and decreased specificity to 51 percent. Using an AHI cutoff of 30 events/hr increased sensitivity to 87 percent and decreased to specificity 46 percent. The AUC for the ability of the ASA Checklist to predict an AHI above 5, 15, and 30 events/hr ranged from 0.617 to 0.783.

#### Hawaii Sleep Questionnaire

(Appendix D Table 1.4.2)

Kapuniai 1988 (quality B) assessed the sensitivity and specificity of the apnea score derived from the Hawaii Sleep Questionnaire to identify an AHI suggestive of OSA.98 The questionnaire included queries about characteristics in sleep apnea patients including, stopping breathing during sleep, loud snoring, and waking from sleep gasping for or short of breath. Additional questions on sex, age, height, weight, sleep history, and history of tonsillectomy or adenoidectomy were also collected. The final model included self-reports of loud snoring, breathing cessation during sleep, and adenoidectomy in a regression model to calculate an Apnea Score. An apnea score ≥ 3 as per the model was considered high risk for sleep apnea. Additionally, an apnea score ≥ 2 without details about adenoidectomy was used as a cutoff to indicate a high risk of sleep apnea. With an AHI cutoff of 5 events/hr, the sensitivity of OSA prediction per an apnea score of ≥ 3 was 59 percent and the specificity 69 percent. When the apnea score cutoff of ≥ 2 was used, sensitivity was 70 percent and specificity was 65 percent. Using an AHI cutoff of 10, the sensitivity was 78 percent and specificity was 67 percent.

#### Epworth Sleepiness Scale

(Appendix D Table 1.4.2)

Drager 2010 (quality A) assessed the sensitivity and specificity of ESS to identify an AHI suggestive of OSA.101 With an AHI cutoff of 5 events/hr, the sensitivity of OSA prediction per an ESS score >10 (defined as excessive daytime sleepiness) was 49 percent and the specificity 80 percent.

#### Summary

Overall, largely because of the likely selection biases in the quality C studies, the strength of evidence is low supporting the use of the Berlin questionnaire in screening for sleep apnea. Only one study each investigated the use of the STOP, STOP-Bang, ASA Checklist, Hawaii Sleep questionnaire, and ESS each. The strength of evidence is insufficient to draw definitive conclusions concerning these questionnaires.

### Clinical Prediction Rules and Polysomnography

#### Overall Description of Studies Using Clinical Prediction Rules

(Table 3; Appendix D Table 1.5.1)

Table 3 Descriptions of clinical prediction rules

Study PMID | Clinical Prediction Rule | Description
Crocker, 1990^102^ 2368960 | Statistical model | Derived by logistic regression on data from a 24-item questionnaire and clinical features.
Gurubhagavatula, 2001^103^ 11734444 | Clinical prediction rule, derived | Combination of Multivariable Apnea Prediction (MAP) questionnaire score and oximetry results. MAP score predicts apnea risk using a score between 0 and 1, with 0 representing low risk and 1 representing high risk. Oximetry desaturation index (ODI) using a 3% drop (ODI3) as well as a 4% drop (ODI4) in oxygen saturation. Optimal model parameters obtained by the bootstrapping technique.
Kushida, 1997^104^ 9341055 | Morphometric model | Model: P + (Mx − Mn) + 3 × OJ + 3 × [Max (BMI −25, 0)] × (NC/BMI) P = palatal height (in millimeters), Mx is the maxillary intermolar distance (in millimeters) between the mesial surfaces of the crowns of the maxillary second molars, Mn is the mandibular intermolar distance (in millimeters) between the mesial surfaces of the crowns of the mandibular second molars, OJ is the overjet (in millimeters) or the horizontal overlap of the crowns of the maxillary and mandibular right central incisors, BMI is the body mass index (kg/m2; ideal BMI <25), Max (BMI −25, 0) refers to the larger of the two quantities: BMI − 25, or zero. If BMI is <= 25, then [Max (BMI − 25, 0)] is zero; if BMI >25, then BMI − 25 is inserted into the formula; NC is neck circumference (in centimeters) measured at the level of the cricothyroid membrane.
Onen, 2008^105^ 18775037 | Observation- based Nocturnal Sleep Inventory (ONSI) | Nurse observations made in five standardized hourly bedside visits over the course of one night.
Rodsutti, 2004^106^ 15283004 | Clinical prediction rule, derived | Sum of the individual scores for age, sex, snoring, stops breathing, and BMI; range = 0 −7.3.
Rowley, 2000^107^ 11083602 | Model #1 | Clinical prediction model #1: Probability of predicting AHI ≥10 = 1/(1 + e^−(− 13.9+0.06a+2.98b+0.23c+1.35d)^) where a = age; b= I if witnessed apneas present, 0 if witnessed apneas absent; c = BMI; d = 1 if patient has hypertension, 0 if hypertension absent.
Rowley, 2000^107^ 11083602 | Model #2 | Clinical prediction model #2: Probability of predicting AHI ≥10 = e^x^/(1+e^x^) where, x = −10.5132 + 0.9164*sex + 0.0470*age + 0.1869*BMI+1.932*snoring; where sex = 1 for male, 0 for female, snoring = 1 for present, 0 for absent.
Rowley, 2000^107^ 11083602 | Model #3 | Clinical prediction model #3: Probability of predicting AHI ≥10 = (10 ^(−2.132 + 0.069*NC + 0.31*H+ 0.206′*HS+0.224*PR)^ + 1) where NC=neck circumference, H=1 if hypertension, 0 if hypertension absent, HS=1 if habitual snorer, 0 if not, PR = 1 if reports nocturnal choking/gasping, 0 if no nocturnal choking/gasping.
Rowley, 2000^107^ 11083602 | Model #4 | Clinical prediction model #4: Probability of predicting AHI ≥10 = e^x^/(1+e^x^) where, x = −8.160+1.299*Index1+O.163*BMI−0.025*BMI*Index1+0.032*age +1.278*sex where, sex=1 if male, 0 if female, index1 = the mean of nonmissing values for frequency of snorting/gasping, loud snoring, breathing stops/chokes.
Zerah-Lancner, 2000^108^ 11112139 | Based on Pulmonary function data | Probability (p) of having a polysomnography positive for sleep apnea: logit (p)= −136 sGrs + 2.5 (100 − SaO_2_) + 4.2 where specific respiratory conductance (sGrs) (in cmH_2_0^−1^ * s^−1^) = respiratory conductance (Grs)/functional reserve capacity (FRC) SaO_2_ = daytime arterial oxygen saturation in %. The estimated value of p was derived from logit (p)= log_e_(p/1−p), from 0 to 1 range.

We identified seven studies that compared clinical prediction rules with facility-based PSG in various settings (Appendix D Table 1.5.1).102–108 All studies had either validated their models in a separate subgroup of study participants or had their models evaluated in subsequent studies. Thus, all examined clinical prediction rules are considered internally or externally validated. Six papers described studies performed in sleep laboratory settings102–104,106–108 and one105 in a hospital or nursing home setting.

The populations enrolled in these studies included patients referred for sleep-disordered breathing and suspected sleep apnea. The number of analyzed participants in these studies ranged from 101 to 425. The mean age of patients ranged from 47 to 79 years; the study by Onen 2008 limited enrollment to elderly individuals (≥70 years). With regard to overall methodologic quality, three studies were graded as quality A,103,106,107 three quality B,102,105,108 and one quality C.104 The main methodological concerns in the quality C study were the high risk for selection bias and the high dropout rate (29 percent).

The definition of sleep apnea was based on AHI in five studies (≥5 events/hr in one study, ≥ 10 in one study, and ≥ 15 in three studies) and on RDI in two studies (≥5 events/hr). The 10 predictive models utilized questionnaire items and clinical variables in two studies,102,103 morphometric parameters in one study,104 standardized nurse observations during the sleep study in one study,105 clinical variables and observations during the sleep study in two studies106,107 and pulmonary functional data in one study108 (Table 3).

#### Detailed Description of Clinical Prediction Rules

(Appendix D Table 1.5.2)

Gurubhagavatula 2001 developed two clinical prediction rules based on a combination of a multivariable apnea prediction questionnaire score and oximetry results in 359 patients. The clinical prediction rules were developed for two separate objectives: first, to predict the diagnosis of OSA, defined as RDI ≥ 5 events/hr and, second, to predict the diagnosis of severe OSA, defined as RDI ≥ 30 events/hr, and thus select appropriate patients for split night studies. The multivariable apnea prediction questionnaire score rates apnea risk between zero and one, with zero representing low risk and one representing high risk. The authors separated the subjects into three groups based on predefined threshold scores. Those who had high scores were predicted to have OSA, those with low scores were predicted to be free of OSA, and those with intermediate scores underwent nocturnal pulse oximetry. Among these subjects, those with oxygen desaturation index (ODI) above predefined thresholds were predicted to have OSA. The optimal model parameters for each of the two clinical prediction rules were obtained by the bootstrapping technique.

The optimal model for prediction of OSA (RDI ≥ 5 events/hr) was determined to use the following parameters: lower score threshold = 0.14, upper score threshold = 0.58, and ODI threshold = 5.02 events/hr. This model displayed a sensitivity of 94.1 percent and a specificity of 66.7 percent.

The optimal model for the prediction of severe OSA (RDI ≥ 30 events/hr) was defined using the following parameters: lower score threshold = 0.38, upper score threshold = 0.9, and ODI threshold = 21 events/hr. This model displayed a sensitivity of 83.3 percent and a specificity of 94.7 percent.

Kushida 1997 developed a prediction rule based only on morphometric parameters. These parameters included the palatal height, the maxillary intermolar distance between the mesial surfaces of the crowns of the maxillary second molars, the mandibular intermolar distance between the mesial surfaces of the crowns of the mandibular second molars, the horizontal overlap of the crowns of the maxillary and mandibular right central incisors, BMI, and neck circumference measured at the level of the cricothyroid membrane. By using a morphometric-calculated value of 70 as a threshold (range of calculated values 40–160), the model predicted the diagnosis of OSA (AHI ≥ 5 events/hr) with a sensitivity of 97.6 percent (95 percent CI 95.0, 98.9), a specificity of 100 percent (95 percent CI 92.0, 100), and an AUC of 0.996. The authors proposed the use of their model as a screening tool rather than a substitute for PSG.

Onen 2008 developed the Observation-based Nocturnal Sleep Inventory, a set of nurse observations performed in the patient’s hospital room and made in five standardized hourly bedside visits over the course of one night. As designed, at each visit, approximately 5 minutes of listening and observation is required to detect three nocturnal conditions that characterize sleep-disordered breathing: interrupted breathing (apnea), gasping, or choking; snoring; and awakening. The authors examined three different combinations of thresholds of snoring episodes and apnea to predict diagnosis of OSA, defined as AHI ≥15 events/hr. The test accuracy of these sets of observations were: ≥2 snoring episodes or ≥1 apnea episode produced a sensitivity of 89.7 percent and a specificity of 81.4 percent; ≥3 snoring episodes or ≥1 apnea episode produced a sensitivity of 74 percent and a specificity of 93 percent; and ≥5 snoring episodes or ≥1 apnea episode produced a sensitivity of 56 percent and a specificity of 100 percent.

Rodsutti 2004 developed a clinical prediction rule based on three clinical variables (age, sex, and BMI) and two items from a self report questionnaire (reported snoring, and reported cessation of breathing during sleep). Each of these variables was stratified into two or more categories and scores were assigned to each category. The sum of the individual scores for the five variables was then calculated to obtain a summary score that could range from 0 to 7.3. The calculated sensitivities and specificities for the three categories of the summary score were: <2.5—sensitivity 0 percent, specificity 89 percent; 2.5–4.2—sensitivity 44 percent, specificity 85 percent; ≥4.2—sensitivity 76 percent, specificity 60 percent.

Crocker 1990 developed a statistical model to predict the probability of a patient having an AHI >15 events/hr, based on logistic regression of data from a 24-item questionnaire and clinical characteristics on 105 patients. The regression equation that was developed included witnessed apneas, hypertension, BMI, and age. The model displayed relatively high sensitivity (92 percent), but low specificity (51 percent). The same model was examined by Rowley 2000 in an independent set of patients.

Rowley 2000 tested the performance of Crocker’s model to predict either the presence of OSA (defined as AHI ≥ 10 events/hr) or prioritize patients for a split-night protocol (defined as AHI ≥20 events/hr). In this dataset, the model displayed a sensitivity of 84 percent and a low specificity (39 percent) with a relatively low discrimination (AUC=0.669) for the prediction of OSA. For prioritizing patients for a split-night protocol (AHI ≥20 events/hr), the model had a sensitivity of 33 percent and a specificity of 90 percent with an AUC = 0.7.

In addition to the model developed by Crocker 1990, Rowley 2000 examined three other clinical prediction rules for the presence of OSA (defined as AHI ≥10 events/hr) or prioritizing patients for a split-night protocol (defined as AHI ≥20 events/hr). The models utilized different combinations of clinical, morphometric, and sleep observation variables. The second clinical prediction formula was based on snoring, BMI, age, and sex. This formula had a sensitivity of 96 percent with a specificity of 13 percent for the prediction of OSA, and a sensitivity of 34 percent and a specificity of 87 percent for prioritizing patients for a split-night protocol.

The third clinical prediction formula utilized snoring, gasping or choking, hypertension, and neck circumference. The performance characteristics of this prediction rule were: prediction of AHI ≥10 events/hr—sensitivity 76 percent, specificity 54 percent; prediction of AHI ≥20 events/hr—sensitivity 34 percent, specificity 89 percent.

Finally, the fourth clinical prediction formula using snoring, gasping, witnessed apneas, BMI, age, and sex predicted AHI ≥10 events/hr with a sensitivity of 87 percent and a specificity of 35 percent. With regards to the prediction of AHI ≥20 events/hr, the model had a high specificity (93 percent) with a low sensitivity (39 percent). The authors examined the predictive performance of these models in subgroups by sex, which was used as a variable in the second and the fourth clinical prediction formulas. In general, higher AUC values were attained in men (range 0.761–0.801) compared with women (range 0.611–0.648).

Zerah-Lancner 2000 developed a predictive index for OSA based on pulmonary function data obtained through spirometry, flow–volume curves, and arterial blood gas analysis. This model calculated probabilities of having a PSG positive for OSA based on specific respiratory conductance (derived from respiratory conductance and functional reserve capacity) and daytime arterial oxygen saturation. Using a threshold index of 0.5, the model predicted the presence of OSA (defined as AHI ≥15 events/hr) with 100 percent sensitivity and 84 percent specificity.

#### Summary

In summary, 10 different clinical prediction rules have been described in seven papers. The strength of evidence is low that some clinical prediction rules may be useful in the prediction of a diagnosis of OSA. Nine of the clinical prediction rules have been used for the prediction of diagnosis of OSA (using different criteria, AHI or RDI-based), while five of these models have been either specifically developed or also tested for the prediction of severe OSA (defined as AHI ≥20 or ≥30 events/hr), a diagnosis used for prioritizing patients for a split-night protocol. With the exception of the model by Zerah-Lancner 2000, which requires pulmonary function data, and the model by Onen 2008, which requires direct observation of patients’ sleep, all other models are parsimonious, utilizing easily attainable variables through clinical interview and examination (including oximetry and morphometric measurements) and items collected from questionnaires. Only Rowley 2000 examined different prediction rules in the same patients. In this study, no predictive rule with desirable performance characteristics (both high sensitivity and specificity) was found for the prediction of OSA (range of sensitivities 76–96 percent, range of specificities 13–54 percent) or severe OSA (ranges of sensitivities 33–39 percent, range of specificities 87–93 percent). Of the remaining models, the morphometric model by Kushida 1997 gave near perfect discrimination (AUC= 0.996), and the pulmonary function data model by Zerah-Lancner 2000 had 100 percent sensitivity with 84 percent specificity. However, while all the models were internally validated, definitive conclusions on the applicability to the population at large of these predictive rules in independent populations cannot be drawn from the available literature. It should be further noted that no study examined the potential clinical utility of applying these prediction rules to clinical practice.

## Key Question 2 How does phased testing (screening tests or battery followed by full test) compare to full testing alone?

To address this question, our literature search included any study that directly compared phased testing (a series of tests performed dependent on the results of initial tests) with full testing (overnight polysomnography [PSG]) alone. We included all prospective cross-sectional or longitudinal studies of any followup duration. At least 10 study participants had to be analyzed with each test of interest to warrant inclusion. Only one study met our inclusion criteria.109

Gurubhagavatula 2004 assessed the accuracy of phased testing with full testing among 1,329 respondents from a pool of 4,286 randomly selected commercial driver’s license holders in Pennsylvania.109 Those respondents with an existing diagnosis of obstructive sleep apnea (OSA) or obesity-hypoventilation syndrome, or using supplemental oxygen were excluded. The respondents were mostly male (94 percent) with a mean age of 44 years, and a mean body mass index (BMI) of 28.4 kg/m^2^. The study suffered from verification bias as only the participants considered to be at high risk for OSA in early testing phases were followed up with PSG. The study received a quality rating of C.

To assess the presence of sleep apnea, the study compared five case-identification strategies with PSG. Of the five strategies, one assessed a two-stage testing strategy that involved the calculation of a multivariable clinical prediction rule score (from a multivariable apnea prediction questionnaire) for all participants (Stage I). The prediction score ranged from zero (no risk) to one (maximal risk for OSA), and was calculated by combining a symptom score (symptoms included self-reported frequency of gasping or snorting, loud snoring, and the frequency of breathing stops, choking, or struggling for breath) with BMI, age, and sex. A score between 0.2 and 0.9 was defined as an intermediate risk score. Participants in this category received subsequent nocturnal pulse oximetry testing (Stage II) and those with ODI ≥5 events/hr underwent PSG. OSA was defined as an ODI ≥5 events/hr and severe OSA as ≥10 events/hr. Of the 1,329 respondents, 406 (31 percent) underwent oximetry and PSG testing.

Of the 1,329 respondents, 551 subjects had a multivariable apnea prediction score above 0.436 (considered a high-risk stratum), and 247 subjects (45 percent) were enrolled from that group for oximetry and PSG testing. From the group with a prediction score below 0.436 (considered a low-risk stratum), 159 participants (20 percent) were randomly enrolled for oximetry and PSG testing. From the pooled sample of 406 subjects, OSA was diagnosed in 28 percent of the subjects. In the low risk stratum, 11 percent of the subjects had sleep apnea as compared to 52 percent of those in the high risk stratum.

The proportion of patients with OSA among those who were classified as intermediate risk by the multivariable apnea prediction score (between 0.2 and 0.9) and had further oximetry was not reported. The proportion of OSA in patients who were considered either high risk (score >0.9) or low risk (score <0.2) were also not reported.

### Summary

The strength of evidence is insufficient to determine the utility of phased testing followed by full testing when indicated to diagnose sleep apnea, as only one study investigated this question. This prospective quality C study did not fully analyze the phased testing, thus the sensitivity and specificity of the phased strategy could not be calculated due to a verification bias because not all participants had PSG testing. The methodological problems with this study also limit the applicability to the general population of people with OSA.

## Key Question 3 What is the effect of preoperative screening for sleep apnea on surgical outcomes?

To address this question, our literature search included any prospective, cross-sectional or longitudinal study of any followup duration that compared use of routing screening with no or limited screening and reported all intraoperative events, surgical recovery events, surgical recovery times, postsurgical events, length of intensive care or hospital stays, and intubation or extubation failures among patients with no previous OSA diagnosis undergoing surgical procedures.

Two studies met selection criteria (Appendix D Table 3.1).97,110 Both studies were rated quality C as they had different selection criteria for enrolling subjects in the two comparative arms, indicating a substantial risk of selection bias.

Hallowell 2007, in a retrospective chart review of patients who had undergone bariatric surgery, compared 576 patients who had a PSG based on results from a clinical and physical examination (a positive, but undefined, Epworth Sleepiness Scale score, symptoms of loud snoring or daytime sleepiness, or clinical suspicion by the surgeon or pulmonologist) with 318 patients who underwent a mandatory PSG. The reported outcomes included intensive care unit (ICU) admission, respiratory-related ICU admission, duration of hospital stay, and mortality. The mean age of the patients (13 percent male) was 43 years and mean body mass index (BMI) of 51 kg/m^2^. The followup period was restricted to the immediate postoperative interval.

Chung 2008 was a study designed to compare different screening tools with polysomnography (PSG) in a cohort of preoperative patients (and is discussed under Key Question 1). Only about half their enrolled patients consented to PSG. The study thus compared patients who did or did not have preoperative screening with polysomnography (PSG) for complication rates (respiratory, cardiac, or neurological complications), use of prolonged oxygen therapy, requirement of additional monitoring, intensive care unit (ICU) admissions, hospital stay after surgery, readmission, and emergency department visits. The study included 416 patients scheduled to undergo elective procedures in general surgery, gynecology, orthopedics, urology, plastic surgery, ophthalmology, or neurosurgery. Subjects were 51 percent male with a mean age of 55 years and a mean BMI of 30.1 kg/m^2^. The followup period was 30 days. Though included in this review, the value of this study to address this Key Question is dubious as there was a systematic difference between those patients who did and did not have PSG. It is highly likely that those who underwent testing were (or considered themselves to be) sicker and at higher risk of having sleep apnea.

### Duration of Hospital Stay

(Appendix D Table 3.2)

The duration of stay in the hospital was evaluated in both studies. In Hallowell 2007, among bariatric surgery patients, those who underwent mandatory testing with PSG were released on average 9.6 hr earlier than those who underwent PSG based on criteria from the physical and clinical examinations. No data were reported as to whether this difference was statistically significant. In Chung 2008, among patients who had elective general surgery procedures, those who volunteered for PSG had a nonsignificantly longer median hospital stay than those who refused PSG (difference of medians 15.5 hr)

### Intensive Care Unit Admission

(Appendix D Table 3.3)

Both studies evaluated ICU admission. In Hallowell 2007, among bariatric surgery patients, those who underwent mandatory PSG testing had a somewhat lower risk of being admitted to the ICU (relative risk [RR] = 0.62; 95 percent confidence interval [CI] = 0.32, 1.22), as compared with those who underwent selective PSG testing. In Chung 2008, among patients who had elective general surgery procedures, a greater percentage of patients who volunteered for PSG were admitted to the ICU than those who refused preoperative PSG (RR = 3.16; 95 percent CI 1.05, 9.52) [The RR’s and 95 percent CI’s were calculated from reported data].

### Other Postoperative Outcomes

(Appendix D Table 3.3)

In Hallowell 2007, among bariatric surgery patients, those who underwent mandatory PSG testing had a substantially, but nonsignificantly lower risk of respiratory complications leading to ICU admission (RR = 0.16; 95 percent CI 0.02, 1.27), as compared with those who underwent selective PSG testing. In Chung 2008, those who volunteered for PSG testing had significantly more total complications, and nonsignificantly more respiratory complications, cardiac complications, prolonged oxygen therapy, and additional monitoring, but nonsignificantly fewer emergency department visits within 30 days. There were no apparent differences in neurological complications, or hospital readmission within 30 days.

### Summary

Two quality C prospective studies assessed the effect of preoperative screening for sleep apnea on surgical outcomes among patients with no prior OSA diagnosis. One study found that patients undergoing bariatric surgery who had mandatory PSG possibly had somewhat shorter hospital stays and, possibly, fewer respiratory-related ICU admissions than those patients who had (in a previous era) PSG based on clinical parameters. However, these differences were not statistically significant. The second study found that general surgery patients willing to undergo preoperative PSG were more likely to have perioperative complications, particularly cardiopulmonary complications, possibly suggesting that patients willing to undergo PSG are more ill than patients not willing to undergo the procedure. The methodological problems with the studies and their restricted eligibility criteria limit their applicability to the general population of people with OSA.

Overall, the strength of evidence is insufficient regarding postoperative outcomes with mandatory screening for sleep apnea.

## Key Question 4 In adults being screened for obstructive sleep apnea, what are the relationships between apnea-hypopnea index or oxygen desaturation index and other patient characteristics with respect to long-term clinical and functional outcomes?

To address this question, our literature search was restricted to longitudinal studies of at least 500 participants who were assessed with formal sleep testing at baseline and followed for at least 1 year. Outcomes of interest included incident clinical events, quality of life, and psychological or neurocognitive measures. Analyses of interest were restricted to multivariable analyses of apnea-hypopnea index (AHI) (or similar sleep study measure) and demographic and clinical variables. We preferentially included analyses of baseline variables only.

Eleven articles met eligibility criteria. Four evaluated predictors of all-cause mortality,1,2,111,112 two cardiovascular death,1,6 one each nonfatal cardiovascular events6 and stroke,113 two hypertension,11,114 two type 2 diabetes mellitus,115,116 and one quality of life.117 Three articles each evaluated the Sleep Heart Health Study (SHHS)2,114,117 and the Wisconsin Sleep Cohort Study.1,11,115

### All-Cause Mortality

(Appendix D Tables 4.1& 4.2)

Four studies evaluated AHI as a predictor of all-cause mortality in multivariable analyses.1,2,111,112 Among these studies, three enrolled participants primarily during the 1990s; the smallest study enrolled participants during the 1970s and 1980s (Lavie 1995). The two studies by Lavie (2005 & 1995) were restricted to adult men with sleep apnea symptoms or evidence of sleep apnea. The two other studies (SHHS [Punjabi 2009] and Wisconsin [Young 2008]) were large, prospective cohort studies of adults from the general population. Three of the four studies were rated quality A; the SHSS article was deemed to be quality B as a stratified analysis with cross-product terms was used instead of a full multivariable regression.

All four studies found that higher baseline AHI was predictive of increased mortality over about 2 to 14 years of followup. Three of the studies evaluated categories of AHI. Each found that people with AHI >30 events/hr had a statistically significant risk of death compared with those with a low AHI (<5–10 events/hr); hazard ratios ranged from about 1.5–3.0. People in these studies with an AHI of between approximately 5 to 10 and 30 events/hr had a nonsignificantly increased risk of death. The oldest study (Lavie 1995) evaluated AHI as a continuous variable and found a significant linear association (OR = 1.012 per unit of AHI).

The SHHS analysis (Punjabi, 2009) found an interaction between AHI and both age and sex such that the association between AHI and death was seen only in men up to age 70 years. In older men (>70 yr) and in women, no significant association was found. Both SHHS and Lavie 1995 reported no substantial changes in the associations between AHI and death with the iterative addition of other predictors.

### Summary

Four studies (three quality A, one quality B) found that AHI was a statistically significant independent predictor of death with long-term followup (2–14 years). The association was strongest among people with an AHI >30 events/hr. The SHHS study, however, found an interaction with sex and age such that AHI was associated with death only in men ≤70 years old.

### Cardiovascular Mortality

(Appendix D Tables 4.3 & 4.4)

Two studies evaluated AHI as a predictor of cardiovascular mortality in multivariable analyses.1,6 Both enrolled participants primarily in the 1990s. Marin 2005 was restricted to otherwise healthy men with sleep disordered breathing. The Wisconsin Sleep Cohort Study included adults from the general population. Both studies were rated quality A.

Marin 2005 found a statistically increased risk of cardiovascular death during 10 years of followup among those with a baseline AHI ≥30 events/hr who were not treated with continuous positive airway pressure (CPAP). Those with a lower AHI or who were treated with CPAP were found to not be at an increased risk of cardiovascular death. Addition of the statistically significant predictor of existing cardiovascular disease, and the nonsignificant predictor of hypertension, did not substantially alter the association between AHI and cardiovascular death risk. The Wisconsin study found no association between AHI and cardiovascular death after 14 years of followup.

### Summary

One of two studies (both quality A) found a significant independent association between an AHI ≥30 events/hr and the risk of cardiovascular death, but not lower baseline AHI, after long-term followup (10 years). The relationship was not altered by adjustment for existing cardiovascular disease or hypertension. In addition, an association was not seen in those treated with CPAP. No association was noted in the second study.

### Nonfatal Cardiovascular Disease

(Appendix D Tables 4.3 & 4.4)

Marin 2005,^6^ a study of men with sleep disordered breathing, also evaluated the risk of nonfatal cardiovascular disease (myocardial infarction, stroke, or acute coronary insufficiency requiring an invasive intervention), and was also rated quality A for this outcome. The study found a similar association with nonfatal cardiovascular disease as for cardiovascular death. Only those participants with an AHI ≥30 events/hr who were not treated with CPAP were at a statistically significant increased risk of nonfatal cardiovascular disease. Adjustment for existing cardiovascular disease or hypertension did not substantially change the observed association.

### Stroke

(Appendix D Tables 4.3 & 4.4)

One study (Arzt 2005) evaluated the risk of stroke in adults aged 30 to 60 years without a previous history of stroke.113 The participants were enrolled beginning in 1988. The study was rated quality B due to questions concerning the ascertainment of stroke. No statistically significant association was found between AHI and incident stroke during 12 years of followup. The low event rate (14/1,475) and the wide confidence intervals of the odds ratios, though, suggest that the study was highly underpowered to evaluate this outcome. However, in an analysis adjusted only for age and sex (not for body mass index [BMI]), the association between an AHI ≥20 events/hr and incident stroke was statistically significant (OR = 4.48; 95 percent CI 1.31–15.3; P=0.02), thus suggesting that AHI and stroke are confounded with elevated BMI.

### Hypertension

(Appendix D Tables 4.5 & 4.6)

The association between AHI and risk of developing hypertension was evaluated in the two large cohort studies (SHHS and the Wisconsin Sleep Cohort Study).11,114 The Wisconsin study excluded people with cardiovascular disease (but not hypertension). SHHS was rated quality A and the Wisconsin study was rated quality B for reasons discussed below.

In an overall analysis AHI was not an independent, significant predictor of incident hypertension in the SHHS at 5 years. However, AHI and hypertension were confounded by BMI. When BMI was not included in the model, an AHI of 15–30 events/hr and an AHI ≥30 events/hr were both significantly associated with incident hypertension (AHI = 15–30 events/hr: OR = 1.54, 95 percent CI 1.12–2.11; AHI ≥30 events/hr: OR = 2.19, 95 percent CI 1.39, 3.44).

Several subgroup analyses were also performed. Although the AHI × sex interaction term was not statistically significant (P=0.09), a significant association was found between an AHI ≥30 events/hr and hypertension in women but not men. Similarly the AHI × BMI interaction term was not significant (P=0.36) but an AHI>30 events/hr was in those with a BMI less than, but not above, the median 27.3 kg/m^2^. No consistent difference was found in associations of AHI and incident hypertension between those younger or older than the median age of 59 years, or with or without clinically significant sleepiness (defined as ESS ≤or >11, respectively).

The Wisconsin Sleep Cohort Study analyzed the risk of having hypertension at 4 and 8 years among people without cardiovascular disease. However, it should be noted that 28 percent of the participants had hypertension at baseline. Although the analysis adjusted for baseline hypertension, inclusion of these participants makes interpretation of the analysis unclear. Nevertheless, any AHI above 0 events/hr was found to be a statistically significant independent predictor of hypertension at 4 and 8 years of followup. Across AHI categories, it was observed that the higher the AHI the stronger the association. No interaction terms with other predictors were significant, and the results did not substantially change with the addition of sets of predictors.

### Summary

In two studies, the association between AHI and future hypertension is unclear. One study found no overall independent association with incident hypertension, but found that BMI may have been a confounding factor. There were associations in subgroups of men and those with less than the median BMI, although the interaction terms were not statistically significant. The other study found that AHI was an independent predictor of future hypertension; however, the analysis included (and adjusted for) 28 percent of participants having hypertension at baseline.

### Type 2 Diabetes

(Appendix D Tables 4.7 & 4.8)

Two studies evaluated AHI as a predictor of incident type 2 diabetes mellitus in multivariable analyses.115,116 The Wisconsin Sleep Cohort Study enrolled participants in 1988 while Botros 2009 recruited subjects with sleep disordered breathing in the early 2000s. Both excluded people with diabetes at baseline. The Wisconsin study was rated quality B due to unclear and incomplete reporting of the description of those included in the longitudinal analysis and of the results. The other study was rated quality A.

The Wisconsin study found no association between baseline AHI and the incidence of diabetes after 4 years. However, the association was confounded by waist girth. In an analysis without waist girth, a strong association was observed (AHI 5–15 events/hr: OR = 2.81, 95 percent CI 1.51–5.23, P=0.001; AHI ≥ 15 events/hr: OR = 4.06, 95 percent CI 1.86–8.85, P=0.0004). Botros 2009 found that AHI ≥ 8 events/hr was significantly associated with incident diabetes after a mean of 2.7 years in an analysis controlled for BMI and change in BMI over the 2.7 years. The association was similar both with and without adjustment for other predictors.

### Summary

Two studies suggest an association between higher AHI and incident type 2 diabetes. However, the Wisconsin study suggests that the association may be confounded by obesity, as measured by waist girth.

### Quality of Life

(Appendix D Tables 4.9 & 4.10)

The SHHS evaluated AHI as a predictor of quality of life as assessed with SF-36 after 5 years.117 This analysis was rated quality A. The study found no statistically significant association between baseline AHI and changes in either the Physical or Mental Component Summaries.

### Overall Summary

Three publications derived each from the Sleep Heart Health Study and the Wisconsin Sleep Cohort Study, and five other large cohort studies performed multivariable analyses of AHI as a predictor of long-term clinical outcomes.

A high strength of evidence indicates that an AHI >30 events/hr is an independent predictor of all-cause mortality; although one study found that this was true only in men under age 70 years. The evidence on mortality is applicable to the general population, with and without OSA, and also more specifically to men with OSA symptoms or evidence of OSA. All other outcomes were analyzed by only one or two studies. Thus only a low strength of evidence exists that a higher AHI is associated with incident diabetes. This conclusion appears to be applicable for both the general population and specifically for patients diagnosed with sleep disordered breathing. This association, however, may be confounded with obesity, which may result in both OSA and diabetes. The strength of evidence is insufficient regarding the association between AHI and other clinical outcomes. The two studies of cardiovascular mortality did not have consistent findings, and the two studies of hypertension had unclear conclusions. One study of nonfatal cardiovascular disease found a significant association with baseline AHI (as they did for cardiovascular mortality). One study each found no association between AHI and stroke or long-term quality of life.

## Key Question 5 What is the comparative effect of different treatments for obstructive sleep apnea in adults?

a. Does the comparative effect of treatments vary based on presenting patient characteristics, severity of obstructive sleep apnea, or other pretreatment factors? Are any of these characteristics or factors predictive of treatment success?
  - Characteristics: Age, sex, race, weight, bed partner, airway, other physical characteristics, and specific comorbidities
  - Obstructive sleep apnea severity or characteristics: Baseline questionnaire (and similar tools) results, formal testing results (including hypoxemia levels), baseline quality of life, positional dependency
  - Other: Specific symptoms
b. Does the comparative effect of treatments vary based on the definitions of obstructive sleep apnea used by study investigators?

With some exceptions for studies of surgical interventions, we reviewed only randomized controlled trials (RCT) of interventions used specifically for the treatment of obstructive sleep apnea (OSA). RCTs had to analyze at least 10 patients per intervention and the intervention had to be used for some period of time in the home setting (or equivalent). We also included prospective or retrospective studies that compared surgical interventions (including bariatric surgery) to nonsurgical treatments (with the same sample size restriction). In addition, we reviewed cohort (noncomparative) studies of surgical interventions with at least 100 patients with OSA that reported adverse event (or surgical complication) rates.

To address the subquestions to this Key Question, we sought within-study subgroup or regression analyses and, when the evidence base was sufficient and appropriate, looked for explanations of differences (heterogeneity) across studies.

In total, we found 155 eligible studies, reported in 167 articles. Of these, 132 were RCTs, 6 were prospective nonrandomized comparative studies, 5 were retrospective nonrandomized comparative studies, 2 were prospective surgical cohort studies, and 10 were retrospective surgical cohort studies.

Each section below focuses on a specific comparison between categories of interventions, with a final section focusing on adverse events. Most sections include a summary table describing the patient and study characteristics for all studies included in that section, and separate results summary tables for each outcome. We did not compile summary tables for comparisons evaluated by only one study.

### Comparison of CPAP and Control

We identified 22 studies (reported in 23 articles) that compared a variety of CPAP devices with a control treatment. Twelve trials had a parallel design118–130 and 10 were crossover trials.131–140 One study120 used C-Flex™ (a proprietary technology that reduces the pressure slightly at the beginning of exhalation) and the remaining trials used fixed continuous positive airway pressure (CPAP) devices. CPAP pressure was chosen manually in 13 studies, automatically determined in five, and was undefined in four. In 17 studies, it was reported that CPAP was introduced on a separate night than the diagnostic sleep study. The CPAP intervention was compared to no specific treatment in four studies, to placebo treatment (e.g., lactose tablets) in nine studies, to optimal drug treatment in one study, and to conservative measures (e.g., advice on sleep hygiene measures, weight loss) in seven studies. In four of these studies, the conservative measures were also applied to the CPAP arm.118,127,129,130

Mean baseline AHI ranged from 10 to 65 events/hr; nine trials included patients with an AHI ≥5, one with an AHI ≥10, seven with an AHI ≥15, two with an AHI ≥20, one with an AHI ≥30, and two did not report a lower AHI threshold. Most trials had unrestrictive eligibility criteria with the exception of Barbe 2010, which included hypertensive patients, Drager 2007, which included patients with severe OSA (mean baseline AHI = 65 events/hr), and two others (Kaneko 2003 and Mansfield 2004), which included only patients with symptomatic, stable, and optimally-treated congestive heart failure. The sample size of the studies ranged from 12 to 359 (total = 1,116 across studies). Eleven studies were rated quality B and 11 studies were rated quality C. The primary methodological concerns included small sample sizes with multiple comparisons, the lack of a power calculation, high dropout rates, incomplete reporting and, for certain crossover trials, the lack of a washout period. Overall, the studies are applicable to a broad range of patients with OSA.

#### Objective Clinical Outcomes

Mansfield 2004 evaluated the impact of CPAP treatment on heart failure symptomatology, as assessed by the New York Heart Association class.126 No statistically significant improvement was found after 3 months of treatment with CPAP compared with no specific treatment for OSA. No studies evaluated other objective clinical outcomes.

#### Apnea-Hypopnea Index

(Appendix D Table 5.1.2; Figure 6)

Figure 6 Meta-analysis of AHI (events/hr) in randomized controlled trials of CPAP vs. control, by study design

AHI = apnea-hypopnea index; CI = confidence interval; Fixed = fixed CPAP (continuous positive airway pressure); tx = treatment.

This forest plot displays 6 parallel design trials and 1 crossover study. The trials have heterogeneous results with net differences ranging from 46 to 10 events per hour, favoring CPAP over control. Overall, the summary net difference was 20 events per hour (95 percent confidence interval 26 to 14), P<0.001, favoring CPAP over control, with statistical heterogeneity (I-squared = 86 percent, P<0.001). The crossover study result ( 15.5 events per hour) is within the range of results of the parallel design trials.

Seven trials provided data on apnea-hypopnea index (AHI) during treatment.119,121,123,126,127,129,140 All reported that AHI was statistically significantly lower in patients on CPAP than those on no treatment. Meta-analysis found that the difference in AHI between CPAP and control was statistically significant, favoring CPAP (difference = −20 events/hr; 95 percent CI −26, −14; P<0.001). Subgroup meta-analysis by minimum threshold AHI for study eligibility revealed that the single study with a minimum threshold of 20 events/hr found a larger difference in effect (Kaneko 2003: −28 events/hr) than the other studies that included patients with a lower AHI (range −10 to −22 events/hr); although, this difference did not fully account for the observed heterogeneity.

#### Epworth Sleepiness Scale

(Appendix D Table 5.1.3; Figure 7)

Figure 7 Meta-analysis of ESS in randomized controlled trials of CPAP vs. control, by study design

AHI = apnea-hypopnea index, CI = confidence interval, ESS = Epworth Sleepiness Scale, Fixed = fixed CPAP (continuous positive airway pressure), tx = treatment.

This forest plot displays 7 parallel design trials and 5 crossover studies. The trials have heterogeneous results with net differences ranging from 6.00 to 0.10, favoring CPAP over control. Overall, the summary net difference was 2.4 (95 percent confidence interval 3.2 to 1.5), P<0.001, favoring CPAP over control, with statistical heterogeneity (I-squared = 66 percent, P=0.001). The results of the crossover studies (summary estimate 2.1 events per hour) are similar to results of the parallel design trials (summary estimate 2.7 events per hour).

Fourteen trials provided data on the Epworth Sleepiness Scale (ESS).118–120,126–131,135–138,140 Thirteen studies examined the comparison of CPAP versus control and one study of C-Flex versus control.120 Nine studies reported statistically significant differences in ESS between CPAP and control, whereas the remaining five found no significant difference. Meta-analysis of all 12 studies with available data on the comparison of CPAP versus control revealed a statistically significant difference between CPAP and control, favoring CPAP (difference = −2.4; 95 percent CI −3.2, −1.5; P<0.001). However, the results were statistically heterogeneous.

Subgroup analysis by study design showed that synthesis of parallel trials (n=7) provided a significantly larger estimate of summary effect compared with crossover trials (n=5) (differences = −2.7 and −2.1, respectively, P for interaction = 0.04). A smaller effect was seen in the seven studies that included patients with an AHI as low as 5 events/hr (−2.2) as compared with the three studies that included only patients with at least 15 AHI events/hr (−4.4), but, again, this difference was not statistically significant. The single study that tested C-Flex versus no treatment (Drager 2007) demonstrated the biggest absolute reduction in ESS for the intervention arm (difference = −7.0; 95 percent CI −10.2, −3.7; P<0.001) compared with all other studies in this group.

#### Other Sleep Study Measures

(Appendix D Table 5.1.4a–e; Figures 8 & 9)

Figure 8 Meta-analysis of arousal index (events/hr) in randomized controlled trials of CPAP vs. control, by study design

AHI = apnea-hypopnea index, AI = arousal index, CI = confidence interval, Fixed = fixed CPAP (continuous positive airway pressure), tx = treatment.

This forest plot displays 3 parallel design trials and 2 crossover studies. The trials have heterogeneous results with net differences ranging from 24 to 6.9 events per hour, favoring CPAP over control. Overall, the summary net difference was 14.7 (95 percent confidence interval 22.2 to 7.2), P<0.001, favoring CPAP over control, with statistical heterogeneity (I-squared = 84 percent, P<0.001). The crossover study results ( 15.2 events per hour) are similar to results of the parallel design trials (summary estimate 12.6 events per hour). The two crossover studies were highly heterogeneous with each other.

Figure 9 Meta-analysis of minimum oxygen saturation (%) in randomized controlled trials of CPAP vs. control, by study design

AHI = apnea-hypopnea index, CI = confidence interval, Fixed = fixed CPAP (continuous positive airway pressure), min O2 = minimum oxygen saturation, tx = treatment.

This forest plot displays 4 parallel design trials and 1 crossover study. The trials have heterogeneous results with net differences ranging from 6.5 to 26.6 percent, favoring CPAP over control. Overall, the summary net difference was 12.1 percent (95 percent confidence interval 6.4 to 17.7), P<0.001, favoring CPAP over control, with statistical heterogeneity (I-squared = 75 percent, P=0.003). The crossover study result (6.5 percent) is somewhat smaller than the results of the parallel design trials, which ranged from 8.8 to 26.6 percent.

Six studies evaluated arousal index.119,121,123,129,139,140 All studies found greater reductions in arousal index for the CPAP arm; although in one study,119 this difference was not statistically significant. Meta-analysis of the five studies with sufficient data for analysis (Figure 8) revealed that arousals were significantly lower using CPAP compared with control interventions (difference = −15 events/hr; 95 percent CI −22, −7; P<0.001). Study results were found to be significantly heterogeneous. No significant difference in effect was found in the parallel design and crossover studies.

Five studies, all testing CPAP, evaluated minimum oxygen saturation (Figure 9).121,123,126,129,140 Meta-analysis revealed the studies were heterogeneous and a statistically significant greater increase in minimum oxygen saturation while using CPAP compared with control (difference = 12 percent; 95 percent CI 6.4, 17.7; P<0.001). All studies found a statistically significant effect, although the small study by Ip 2004^121^ detected a more pronounced increase of minimum oxygen saturation in favor of CPAP (difference = 27 percent; 95 percent CI 17.4, 35.8; P<0.001). Notably, this study enrolled severely hypoxemic patients (baseline minimum oxygen saturation was 65 percent in the patients randomized to the CPAP arm), which demonstrated a dramatic improvement when receiving CPAP treatment. The remaining studies were statistically homogeneous.

Sleep efficiency (measured as percent of total sleep time) was evaluated by two studies, neither of which detected a significant effect of CPAP treatment.119,140 Five studies examined whether CPAP treatment increased the time in slow wave sleep (in absolute number of minutes or as a percentage of total sleep time) compared with control interventions.119,123,126,139,140 Three studies found no significant differences. McArdle 2001 found a statistically significant difference of 18 minutes more when on CPAP and Mansfield 2004 reported a marginally significant net increase in the percentage of total sleep time with CPAP (4 percent, P=0.046). The same five studies found no significant differences for the outcome of rapid eye movement (REM) sleep (expressed in absolute number of minutes or as a percentage of total sleep time).

#### Objective Sleepiness and Wakefulness Tests

(Appendix D Table 5.1.5a,b)

Six trials evaluated the Multiple Sleep Latency Test.127,128,131,133,135,136 Four trials found no significant difference between CPAP and control, while Engleman 1998 and Engleman 1994 reported a statistically significant result favoring CPAP (respective net differences of 2.40 and 1.10 minutes). Meta-analysis of the six trials did not show a statistically significant difference between the interventions, but may suggest (nonsignificant) improvement with CPAP (difference = 0.78; 95 percent CI −0.07, 1.63; P=0.072).

Only Engleman 1999 evaluated the Maintenance of Wakefulness test sleep onset latency; no difference between CPAP and placebo intervention was found.

#### Quality of Life

(Appendix D Table 5.1.6a,b)

Four studies evaluated results from the Functional Outcomes of Sleep Questionnaire (FOSQ).127,131,138,140 The studies generally did not provide information on the exact FOSQ subscales that were analyzed, and the scores reported were generated by different methodologies (total summed score of responses, weighted average of subscale scores, or ratio of total summed score over maximum possible score). Thus, the reported FOSQ results appeared to be highly inconsistent (with baseline values ranging from 0.8 to 101 across studies) and a meta-analysis could not be performed. Regardless, none of the studies reported a statistically significant difference between CPAP and no treatment.

Ten studies reported on quality of life measures; five used the Short Form Health Survey 36 (SF-36),126,129,131,137,140 four used various components of the Nottingham Health Profile,118,127,136,137 three used the General Health Questionnaire-28,^133,135,136^ two used the energetic arousal score of the University of Wales mood adjective list,136,137 two used the sleep apnea hypopnea syndrome-related symptoms questionnaire,118,127 and one used the Calgary sleep apnea quality of life index (SAQLI).129

Overall, 29 comparisons of different quality of life measures were reported. In six trials, 11 quality of life measures reached statistical significance. In the studies that used SF-36, CPAP showed favorable results for the vitality scale in two studies,126,137 the physical scale in two studies,129,137 and the bodily pain in one study.129 Among the various subscales of the Nottingham Health Profile, statistically significant differences in favor of CPAP for the physical scale were found only in one study.118 Of the three studies using the General Health Questionnaire-28 scale, significant results were shown in only one study.133 No significant findings were recorded for the University of Wales mood adjective list energetic arousal score in two studies, whereas one study reported significant differences for the SAQLI summary score.129

In summary, the impact of CPAP on quality of life is uncertain due to inconsistent findings across studies and the methodological issue of multiple testing of various quality of life subscales within these studies.

#### Neurocognitive and Psychological Tests

(Appendix D Table 5.1.7)

Eight studies evaluated neurocognitive and psychological tests.125,127,131,133,135–137,140 Of the 56 comparisons between CPAP and control, significant differences were detected in 10 comparisons across four studies; all significant differences were in favor of CPAP.131,133,135,137 The tests with significant results included examinations of cognitive performance (intelligence quotient, digit symbol test), executive function (trailmaking), anxiety and depression scores, processing speed (Paced Auditory Serial Addition Test), and semantic fluency (the controlled oral word association test).

#### Blood Pressure and Hemoglobin A1c

(Appendix D Table 5.1.8a,b)

Comparisons of daytime or nighttime blood pressure measurements between CPAP-treated patients and patients on control interventions were reported by seven studies.120,123,127,130–132,134 No statistically significant differences were reported. Only one crossover trial (Comondore 2009) evaluated hemoglobin A1c; no difference was found between CPAP and no treatment.

#### Study Variability

For the main sleep study outcomes of interest (AHI, ESS, minimum oxygen saturation, and arousal index), the included studies were generally consistent in their findings, showing a beneficial effect of CPAP intervention. However, meta-analysis showed that the magnitude of the detected effects in the studies were heterogeneous. In subgroup meta-analyses by study design, there was evidence of larger effect magnitudes in parallel compared with crossover trials for the ESS outcome. The baseline severity of hypoxemia (for the minimum oxygen saturation outcome) were detected as factors influencing the magnitude of effect size for CPAP. No study reported subgroup analyses for the sleep outcomes of interest.

A wide range of measures were used in a small number of studies to assess quality of life, neurocognitive, and psychological outcomes. Most of these outcomes were explored as secondary endpoints. The majority of the comparisons did not report statistically significant differences in these assessments.

#### Summary

Eleven quality B trials and 11 quality C trials compared CPAP with control interventions. Most studies used fixed CPAP devices with manual choice of pressure. The studies reviewed generally found that CPAP was superior in reducing AHI, improving ESS, reducing arousal index, and raising the minimum oxygen saturation. These findings were confirmed by meta-analysis, although results were statistically heterogeneous. There was evidence that the magnitude of the demonstrated efficacy of CPAP treatment may have been influenced by study design (parallel trials showed larger effect sizes), type of device, or baseline severity of disease. No consistent effect of CPAP versus control in improving other sleep study measures (slow wave and REM sleep or Multiple Sleep Latency Test) was observed. Most studies found no significant difference in quality of life or neurocognitive measures, although certain studies reported statistically significant results in favor of CPAP for the physical and vitality scales of SF-36 and various indices of cognitive performance. Generally, no consistent results were found for these measures. The wide variability in the quality of life and neurocognitive outcomes examined, and the multiple testing performed by small-sized studies, warrant cautious interpretation of any positive findings. A single study evaluated the impact of CPAP on the severity of symptoms of congestive heart failure and reported nonsignificant results. Similarly, no benefit from CPAP was found for lowering blood pressure.

The reviewed studies report sufficient evidence supporting large improvements in sleep measures with CPAP compared with control. There is only weak evidence that demonstrated no consistent benefit in improving quality of life, neurocognitive measures or other intermediate outcomes. Despite no or weak evidence for an effect of CPAP on clinical outcomes, given the large magnitude of effect on the intermediate outcomes of AHI and ESS, the strength of evidence that CPAP is an effective treatment to alleviate sleep apnea signs and symptoms was rated moderate.

### Comparison of CPAP and Sham CPAP

There were 24 trials (reported in 30 articles) that compared CPAP devices with sham CPAP treatment (Appendix D Table 5.2.1).141–170 Eighteen trials had a parallel design and six were crossover trials. The patients in these trials were treated with either fixed CPAP (8 trials141,145,146,150,152,153,165,167) or autoCPAP (16 trials142–144,147–149,151,153–164,166,168–170). In 19 of the 24 studies reviewed, it was reported that the CPAP was introduced on a separate full night from the night of the diagnostic sleep study.

Mean baseline AHI ranged from 22 to 68 events/hr; three trials included patients with an AHI ≥5 events/hr, five with an AHI ≥10, eight with an AHI ≥15, one with an AHI ≥20, one with an AHI ≥30, and six did not report a lower AHI threshold. Most trials had unrestrictive eligibility criteria. Exceptions were two studies (Egea 2008 and Smith 2007) that included only patients with stable and optimally-treated congestive heart failure, one study (Campos-Rodriguez 2006) that included only patients with primary hypertension and on hypertension treatment, and a final study (Robinson 2006) that included only hypertensive patients with significant OSA, but without sufficient daytime hypersomnolence. The reviewed studies were generally small with sample sizes ranging from 25 to 101 (total = 1,076 across studies), followed for 1 week to 3 months. Five studies were rated quality A, 13 studies quality B, and six studies quality C. The primary methodological concerns included small sample sizes with multiple comparisons, the lack of power calculations, high dropout rates, and incomplete reporting. Overall, the studies are applicable to a broad range of patients with OSA.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Apnea-Hypopnea Index

(Appendix D Table 5.2.2; Figure 10)

Figure 10 Meta-analysis of AHI (events/hr) in randomized controlled trials of CPAP vs. sham CPAP

AHI = apnea-hypopnea index, CI = confidence interval, CPAP = continuous positive airway pressure.

This forest plot displays 8 trials. The trials have heterogeneous results with net differences ranging from 58.9 to 25.6 events per hour, favoring CPAP over sham CPAP. Overall, the summary net difference was 46.4 events per hour (95 percent confidence interval 57.0 to 35.8), P<0.001, favoring CPAP over sham CPAP, with statistical heterogeneity (I-squared = 70 percent, P=0.002).

Nine trials provided data on AHI comparing CPAP with sham CPAP.143,147,148,153,157,160,163,167,169 All trials had a parallel design, all except one (Lam 2010) evaluated fixed CPAP, and reported that AHI was statistically significantly lower in patients on CPAP than those on sham treatment. The one RCT that evaluated autoCPAP169 did not report sufficient data to estimate the effect size; thus it was not included in meta-analysis. Meta-analysis revealed that the difference in AHI between CPAP and control was statistically significant, favoring CPAP (difference = −46 events/hr; 95 percent CI −57, −36; P<0.001). However, the results were statistically heterogeneous. Subgroup meta-analysis by minimum threshold AHI for study eligibility revealed that there was no statistical heterogeneity among four studies (Haensel 2007, Mills 2006, Loredo 2006, Norman 2006) that included patients with an AHI of at least 15 events/hr (difference = −58; 95 percent CI −68, −49; P<0.001). This difference was significantly larger than one study (Egea 2008) that included patients with an AHI of at least 10 events/hr (−25; P<0.0001), and another study (Loredo 1999) that included patients with an AHI of at least 20 events/hr (−37; P=0.02). Similarly, subgroup meta-analysis of two studies (Becker 2003 and Spicuzza 2006) that included patients with an AHI of at least 5 events/hr showed a lower net difference of AHI (difference = −43; 95 percent CI −65, −21); however, this effect was not statistically significant in difference compared with the five studies that included patients with an AHI of at least 15 events/hr.

#### Epworth Sleepiness Scale

(Appendix D Table 5.2.3; Figures 11 & 12)

Figure 11 Meta-analysis of ESS in randomized controlled trials of CPAP vs. sham CPAP, by study design

AHI = apnea-hypopnea index, CI = confidence interval, CPAP = continuous positive airway pressure.

This forest plot displays 5 crossover design trials and 11 parallel studies. The trials have heterogeneous results with net differences ranging from 7.0 to 1.0, favoring CPAP over sham CPAP. Overall, the summary net difference was 2.5 (95 percent confidence interval 3.5 to 1.5), P<0.001, favoring CPAP over sham, with statistical heterogeneity (I-squared = 80 percent, P<0.001). The results of the crossover studies (summary estimate 2.5) are similar to results of the parallel design trials (summary estimate 2.5).

Figure 12 Meta-analysis of ESS in randomized controlled trials of CPAP vs. sham CPAP, by type of CPAP

AHI = apnea-hypopnea index, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure, ESS = Epworth Sleepiness Scale.

This forest plot displays 10 trials that used fixed CPAP and 6 trials that used autotitrating CPAP. The overall results are identical with those in Figure 11. The summary estimate of the net difference of the fixed CPAP trials was 2.8, favoring CPAP over sham CPAP. The summary estimate of the net difference of the autotitrating CPAP trials was similar at –1.9, also favoring CPAP over sham.

Sixteen trials comparing CPAP with sham CPAP reported ESS data.142–145,147,150,151,157,159,162,164–166,168–170 Eleven trials had a parallel design, and the remaining five had a crossover design. Five of the six trials comparing autoCPAP versus sham autoCPAP reported statistically significant differences on the ESS, while only six of the 10 trials comparing fixed CPAP versus sham CPAP reported statistically significant findings. Meta-analysis of all 16 studies showed a statistically significant difference between CPAP and sham control, favoring CPAP (difference = −2.5; 95 percent CI −3.5, −1.5; P<0.001). However, the results were statistically heterogeneous.

Subgroup meta-analyses by study designs (Figure 11), by types of CPAP (Figure 12), and by minimum threshold ESS for study eligibility were conducted to explore possible factors that could explain the heterogeneity. We found that the same pooled estimates by trial designs (parallel versus crossover: −2.5 versus −2.5) but significant different pooled estimates by types of CPAP (autoCPAP versus CPAP: −1.9 versus −2.8; P=0.05). Subgroup meta-analysis by minimum threshold AHI for study eligibility showed significant net differences on the ESS among three studies including patients with an AHI of at least 10 events/hr (difference = −3.6; 95 percent CI −6.4, −0.9; P=0.01), among four studies including patients with an AHI of at least 15 events/hr (difference = −1.2; 95 percent CI −3.5, −0.3; P=0.02). The difference between the two subgroups (AHI ≥10 versus AHI ≥15) was marginally significant (P=0.08). However, the subgroup meta-analysis did not show significant differences on the ESS in two studies (Hui 2006 and Becker 2003) that included patients with an AHI of at least 5 events/hr (difference = −2.1; 95 percent CI −6.1, 1.9)

#### Other Sleep Study Measures

(Appendix D Tables 5.2.4–5.2.7; Figure 13)

Figure 13 Meta-analysis of arousal index (events/hr) in randomized controlled trials of CPAP vs. sham CPAP

AHI = apnea-hypopnea index, AI = arousal index, CI = confidence interval, CPAP = continuous positive airway pressure.

This forest plot displays 3 trials. The trials have heterogeneous results with net differences of 38.6, 27.2, and 13.8 events per hour, favoring CPAP over sham CPAP. Overall, the summary net difference was 26.8 events per hour (95 percent confidence interval 41.7 to 11.9), P<0.001, favoring CPAP over sham CPAP, with statistical heterogeneity (I-squared = 58 percent, P=0.09).

Three trials evaluated arousal index.143,153,157 All three had a parallel design and evaluated fixed CPAP, and all three studies found greater reductions in arousal index for the CPAP arm. In one study (Becker 2003), however, this difference was not statistically significant. Meta-analysis revealed that arousals were significantly more reduced while using CPAP as compared with sham CPAP (difference = −27 events/hr; 95 percent CI −42, −12; P<0.001). Study results were significantly heterogeneous.

Only one trial evaluated minimum oxygen saturation; no significant difference in minimum oxygen saturation was observed in a comparison of CPAP with sham CPAP.143 This trial was rated quality C due to a small sample size without a power calculation and a high dropout rate.

Sleep efficiency (measured as percent of total sleep time) was evaluated by two studies, neither of which detected a significant effect of CPAP treatment.148,153 Four studies examined whether CPAP treatment increased the time in slow wave sleep (in absolute number of minutes or as a percentage of total sleep time) compared with sham CPAP, and all found no significant effect.143,147,153,157 The same four studies also evaluated the outcome of REM sleep (expressed in absolute number of minutes or as a percentage of total sleep time). Three of the four studies did not find a significant effect of CPAP treatment; the other (Loredo 2006) reported that CPAP treatment significantly increased the time in REM sleep (difference = 7.5 percent of total sleep time; 95 percent CI 3.5, 11.5; P<0.05).

#### Objective Sleepiness and Wakefulness Tests

(Appendix D Table 5.2.8)

One study evaluated the Multiple Sleep Latency Test outcome and found no significant difference in sleep latency test score comparing CPAP with sham CPAP.142 Four studies evaluated the Maintenance of Wakefulness Test outcome,151,159,168,170 with two reporting a statistically significant result, favoring autoCPAP. The remaining study (Marshall 2005) also showed a marginally significant increase in time maintaining alertness during the day in comparing CPAP with sham CPAP (P=0.09).

#### Quality of Life

(Appendix D Tables 5.2.9 & 5.2.10)

Three studies administered the Functional Outcomes of Sleep Questionnaire (FOSQ), and all found no significant difference in test scores comparing CPAP with sham CPAP.142,159,162

Six studies (two using autoCPAP and four CPAP) measured quality of life using SF-36.^142,147,159,162,165,166^ Five of the six studies did not find significant differences in physical and mental health component summary scores. The remaining study (Siccolli 2008) reported that patients who received autoCPAP treatment had significantly increased physical and mental health component summary scores compared with those who received sham treatment (differences = 8.2 and 10.8; P=0.01 and P=0.002, respectively) This study also found a similar result for the SAQLI summary score (difference = 0.9; P=0.001).

#### Neurocognitive and Psychological Tests

(Appendix D Table 5.2.11)

Seven studies evaluated neurocognitive and psychological tests,142,148,149,153,157,159,160 Of the 26 comparisons between CPAP and sham CPAP, a significant difference was detected only in one comparison of the digit vigilance test (measure of sustained attention and psychomotor speed) in one study, favoring CPAP.160

#### Blood Pressure

(Appendix D Table 5.2.12)

Comparisons of daytime or nighttime blood pressure measurements between CPAP-treated patients and patients on sham CPAP were reported by 12 studies.141–147,150,160,163,163,164,169 Six of these studies reported mean arterial pressure, and 10 reported systolic and diastolic blood pressure. The results were inconsistent across studies. About half of the studies reported significant blood pressure reduction favoring CPAP, and the other half reported no significant differences.

#### Study Variability

One study conducted a subgroup analysis of patients who had good compliance to CPAP use (≥3.5 hr/night) and found similar outcomes on the ESS and in blood pressure, favoring autoCPAP as compared with sham CPAP.145 Trends toward larger reductions in blood pressure outcomes among this subgroup of patients were observed; however, the study did not perform a statistical analysis to test the differences between patients with good compliance and those with poor compliance.

For the main sleep study outcomes of interest (AHI, ESS, minimum oxygen saturation, and arousal index), the studies reviewed were generally consistent in their findings, showing a beneficial effect of CPAP intervention. However, our meta-analysis showed that the results of the studies were heterogeneous in terms of the magnitude of their detected effects. In subgroup meta-analyses by study designs, by types of CPAP, and by minimum threshold AHI for study eligibility to explore possible factors that may explain the heterogeneity, only minimum threshold AHI for study eligibility could account for some of the observed heterogeneity. However, no consistent patterns were seen with regard to the impacts of minimum threshold AHI for study eligibility on the main sleep study outcomes.

Regarding quality of life and neurocognitive outcomes, few studies used a wide range of tests and outcomes. In most cases, these outcomes were explored as secondary endpoints. Most of the comparisons performed did not reach statistical significance.

#### Summary

Five quality A, 13 quality B, and six quality C trials compared autoCPAP (16 trials) or fixed CPAP (8 trials) with sham treatments. The reviewed studies generally found that CPAP was superior in reducing AHI, improving ESS, and reducing arousal index. These findings were confirmed by meta-analysis, although the studies’ results were statistically heterogeneous. There was evidence that the magnitude of the demonstrated efficacy of CPAP treatment may have been influenced by baseline severity of disease, although no consistent patterns were observed regarding the impacts of baseline severity of disease on the main sleep study outcomes. Most studies did not find a significant effect of CPAP versus sham in improving other sleep study measures (slow wave and REM sleep, Multiple Sleep Latency Test), but a small number of studies did show CPAP to significantly improve Maintenance of Wakefulness Test measures. Most studies also found no significant difference in effects on quality of life or neurocognitive function. The effects of CPAP on blood pressure outcomes were mixed. About half of the studies reported significant blood pressure reduction, favoring CPAP, and the other half reported no significant differences. No study evaluated objective clinical outcomes.

There was sufficient evidence supporting large improvements in sleep measures with CPAP compared with sham CPAP, but weak evidence that there is no difference between CPAP and sham CPAP in improving quality of life, neurocognitive measures, or other intermediate outcomes. Despite no or weak evidence for an effect of CPAP on clinical outcomes, given the large magnitude of effect on the intermediate outcomes of AHI, ESS, and arousal index, the evidence that CPAP is an effective treatment for the relief of signs and symptoms of sleep apnea was rated moderate.

### Comparison of Oral and Nasal CPAP

One crossover trial171 and one parallel trial173 compared oral with nasal CPAP; one crossover trial172 compared a face mask (covering both nose and mouth) with a nasal mask (Appendix D Table 5.3.1). Mean baseline AHI or respiratory disturbance index (RDI) in the studies were 35, 61, and 85 events/hr. Most included patients were obese; the mean body mass index (BMI) across studies ranged from 32 to 43 kg/m^2^. None of the studies selectively focused on patients with other comorbidities. Study sample sizes ranged from 20 to 42 (total = 87 across studies). The duration of intervention was 1 month in two studies and 2 months in one study. One study was rated quality B and two were rated quality C. Small sample sizes and incomplete reporting were the main methodological concerns. These studies are applicable mainly to patients with AHI more than 30 events/hr and BMI more than 30 kg/m^2^.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

(Appendix D Table 5.3.2)

All three trials provided data on compliance. Mortimore 1998 reported a significant difference in compliance (hours of use per night) favoring nasal CPAP over face mask (nose and mouth) CPAP at 1 month (mean difference 1 hr/night; 95 percent CI 0.3, 1.8; P=0.01).172 The other two studies did not find a significant difference in the number of hours of use with oral or nasal CPAP.

#### Epworth Sleepiness Scale

(Appendix D Table 5.3.3)

Two trials provided data on daytime sleepiness as assessed using ESS.171,172 Anderson 2003 reported that both oral and nasal CPAP decreased daytime sleepiness, but that the difference between the two was not significant.171 Mortimore 1998 did not provide baseline ESS data, but reported that patients in the face mask group had scored significantly higher on the ESS than those in the nasal group at followup (9.8 versus 8.2; P<0.01).

#### Other Outcomes

Anderson 2003 also provided outcomes on AHI, minimum oxygen saturation, arousal index, REM sleep, and sleep efficiency. The difference between oral and nasal CPAP was not statistically significant for any of these measures. Changes after 1 month within the two arms (oral versus nasal CPAP) were: −69 versus −74 events/hr for AHI; 16 versus 17 percent minimum for oxygen saturation; −54 versus −57 events/hr for arousal index; 16 versus 12 percent of total sleep time for REM sleep; and 11 versus 10 percent of total sleep time for sleep efficiency.

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of oral versus nasal CPAP for OSA in terms of patient characteristics (age, sex, race, weight, bed partner, and airway) or severity of OSA. The two studies that described minimum AHI or RDI enrollment criteria did not examine the same efficacy outcomes.171,173 No conclusions could be drawn regarding indirect comparisons across studies on different patient characteristics or minimum AHI or RDI enrollment criteria.

#### Summary

Three small trials with inconsistent results preclude any substantive conclusions concerning the efficacy of oral versus nasal CPAP in improving compliance in patients with OSA. Largely due to small sample size, the reported effect estimates in the studies reviewed were generally imprecise. Thus, overall, the strength of evidence is insufficient regarding differences in compliance or other outcomes between oral and nasal CPAP.

### Comparison of Autotitrating CPAP and Fixed CPAP

We found 21 RCTs that compared autoCPAP with fixed CPAP treatment in patients with OSA (Appendix D Table 5.4.1).174–194 Fourteen used a crossover design and seven a parallel design. Across studies, patients’ mean AHI ranged from 15 to 55 events/hr. All the studies reviewed included patients who were either overweight or obese (body mass index [BMI] ranged from 29.9 to 42 kg/m^2^). None of the studies selectively focused on patients with other comorbidities. Study sample sizes ranged from 10 to 181 (total = 844 across studies). Study durations ranged from 0.75 to 9 months, the majority no longer than 3 months. One was rated quality A, 10 were rated quality B, and 10 quality C. Small sample sizes and incomplete data reporting were the main methodological concerns. These studies are applicable mainly to patients with AHI more than 15 events/hr and BMI more than 30 kg/m^2^.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

(Appendix D Table 5.4.2; Figure 14)

Figure 14 Meta-analysis of CPAP compliance (hr/night) in randomized controlled trials of autoCPAP vs. CPAP, by study design

AHI = apnea-hypopnea index, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure.

This forest plot displays 6 parallel design trials and 15 crossover studies. The range of net differences across studies is 0.8 to 0.8 hours. Overall, the summary net difference was 0.19 hours (95 percent confidence interval 0.06 to 0.33), P=0.006, favoring autotitrating CPAP over fixed CPAP, with no statistical heterogeneity (I-squared = 16 percent, P=0.25). The results of the crossover studies (summary estimate 0.23 hours) are similar to results of the parallel design trials (summary estimate 0 hours).

All 21 studies provided data on compliance. Seventeen studies did not find statistically significant differences in device usage (hours used per night) between autoCPAP and CPAP; four studies reported a significant increase in the use of autoCPAP compared with CPAP.181,182,186,194 Meta-analysis revealed a statistically significant, but clinically marginal difference of 11 minutes per night favoring autoCPAP (difference = 0.19 hr; 95 percent CI 0.06, 0.33; P=0.006), without statistical heterogeneity.

#### Apnea-Hypopnea Index

(Appendix D Table 5.4.3; Figure 15)

Figure 15 Meta-analysis of AHI (events/hr) in randomized controlled trials of autoCPAP vs. CPAP, by study design

AHI = apnea-hypopnea index, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure, Fixed = fixed pressure CPAP.

This forest plot displays 9 crossover studies and 6 parallel design trials. The trials have homogeneous results with net differences ranging from 2.8 to 3.5 events per hour. Overall, the summary net difference was 0.2 events per hour (95 percent confidence interval 0.2 to 0.6), P=0.27, without statistical heterogeneity (I-squared = 0 percent, P=0.53). The results of the crossover studies (summary estimate 0.24 events per hour) are similar to results of the parallel design trials (summary estimate 0.56 events per hour).

Fourteen studies provided sufficient data on AHI after treatment.174–180,184,186,188–190,192,193 Meta-analysis across all studies indicated a difference between autoCPAP and CPAP of 0.23 events/hr (95 percent CI −0.18, 0.64; P=0.27). The crossover and parallel design studies found similar results via meta-analysis (no significant difference by t test). No statistically significant heterogeneity was observed across studies, despite a broad range in the severity of OSA.

#### Epworth Sleepiness Scale

(Appendix D Table 5.4.4; Figure 16)

Figure 16 Meta-analysis of ESS in randomized controlled trials of autoCPAP vs. CPAP, by study design

AHI = apnea-hypopnea index, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure, ESS = Epworth Sleepiness Scale, Fixed = fixed pressure CPAP.

This forest plot displays 13 crossover studies and 6 parallel design trials. The trials have homogeneous results with net differences ranging from 3.0 to 1.8. Overall, the summary net difference was 0.5 (95 percent confidence interval 0.9 to 0.1), P=0.012, favoring autotitrating CPAP over fixed CPAP, with no statistical heterogeneity (I-squared = 13 percent, P=0.30). The results of the crossover studies (summary estimate 0.4) are similar to results of the parallel design trials (summary estimate 0.9).

Seventeen studies provided sufficient ESS data for meta-analysis.174,176–179,181,182,184–191,193,194 Meta-analysis across all studies yielded a difference between autoCPAP and CPAP of −0.48 (95 percent CI −0.86, −0.11; P=0.012), favoring autoCPAP. No significant difference between the study designs was shown by t- test. Despite the broad range of severity of OSA across studies, there was no statistically significant heterogeneity within the overall meta-analysis.

#### Arousal Index

(Appendix D Table 5.4.5; Figure 17)

Figure 17 Meta-analysis of arousal index (events/hr) in randomized controlled trials of autoCPAP vs. CPAP, by study design

AHI = apnea-hypopnea index, AI = arousal index, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure, Fixed = fixed pressure CPAP.

This forest plot displays 4 crossover studies and 3 parallel design trials. The trials have homogeneous results with net differences ranging from 1.7 to 3.3 events per hour. Overall, the summary net difference was 1.1 events per hour (95 percent confidence interval 2.4 to 0.2), P=0.100, with no statistical heterogeneity (I-squared = 0 percent, P=0.45). The results of the crossover studies (summary estimate 1.0 events per hour) are similar to results of the parallel design trials (summary estimate 0.7 events per hour).

Seven studies provided sufficient data on arousal index after treatment.174,176,178,184,188,190,193 Meta-analysis showed a difference of −1.09 events/hr (95 percent CI −2.4, 0.2; P=0.10), favoring autoCPAP. The summary estimates for the subgroups of studies with crossover or parallel designs were different, but neither found a statistically significant difference. Due to the large confidence intervals, no significant difference between the crossover and parallel design trials was shown (t-test, P=0.38). There was also no statistically significant heterogeneity within the overall meta-analysis as well as the subanalyses.

#### Minimum Oxygen Saturation

(Appendix D Table 5.4.6; Figure 18)

Figure 18 Meta-analysis of minimum oxygen saturation (%) in randomized controlled trials of autoCPAP vs. CPAP, by study design

AHI = apnea-hypopnea index, autoCPAP = autotitrating CPAP, CI = confidence interval, CPAP = continuous positive airway pressure, Fixed = fixed pressure CPAP, min O2 = minimum oxygen saturation.

This forest plot displays 3 parallel design trials and 4 crossover studies. The trials have homogeneous results with net differences ranging from 4.4 to 4.8 percent. Overall, the summary net difference was 1.3 percent (95 percent confidence interval 2.2 to 0.5), P=0.003, favoring autotitrating CPAP, with no statistical heterogeneity (I-squared = 0 percent, P=0.56). The results of the crossover studies (summary estimate 1.5 percent) are similar to results of the parallel design trials (summary estimate 1.2 percent).

Seven studies provided sufficient data on minimum oxygen saturation after treatment.176–178,180,184,188,190 Meta-analysis of these trials resulted in a difference between autoCPAP and CPAP of −1.3 percent total sleep time (95 percent CI −2.2, −0.5; P=0.03), favoring CPAP. The crossover and parallel design trials had similar results. There was no statistically significant heterogeneity within the overall meta-analysis.

#### Sleep Efficiency

(Appendix D Table 5.4.7)

Two studies provided data on sleep efficiency.178,188 Both found no statistically significant difference between autoCPAP and CPAP for the improvement of sleep efficiency.

#### REM Sleep

(Appendix D Table 5.4.8)

Seven studies provided data on REM sleep.177,178,184,188,190,191,193 All but one study found no statistically significant difference between autoCPAP and CPAP for REM sleep. Only Nolan 2007 reported a greater reduction in REM sleep in patients treated with autoCPAP compared with those treated with CPAP (−0.5 versus +2 percent total sleep time; P=0.06).

#### Stage 3 or 4 sleep

(Appendix D Table 5.4.9)

Six studies provided data on slow wave sleep (stage 3 or 4).177,178,184,188,190,191 All reported no statistically significant difference between autoCPAP and CPAP for Stage 3 or 4 sleep.

#### Quality of Life

(Appendix D Table 5.4.10)

Eight studies provided data on quality of life.175,177,179,181,183,186,189,194 Seven used SF-36; one used the Sleep Apnea Quality of Life Index (SAQLI);181 and two also added a modified Osler test.189,194 Massie 2003 found a significant difference in the mental health (net difference 5; 95 percent CI 0.16, 9.8; P<0.05) and vitality (net difference 7; 95 percent CI 0.6, 13.4; P<0.05) components of SF-36, favoring those who had autoCPAP.186 No other significant differences in quality of life measures between autoCPAP and CPAP were reported in the reviewed studies.

#### Blood Pressure

(Appendix D Table 5.4.11)

Two studies reported changes in blood pressure.178,180 Patruno 2007 reported significant reductions between baseline and followup in systolic and diastolic blood pressure in patients on CPAP, but not in those on autoCPAP; however, the study did not report a statistical analysis of the difference between the two interventions. Our estimates, based on the reported data, suggest a nonsignificant greater reduction in systolic blood pressure (net difference = 6 mm Hg; 95 percent CI −0.9, 12.9; P=0.09) and a significant greater reduction in diastolic blood pressure (net difference = 7.5 mm Hg; 95 percent CI 4.2, 10.8; P<0.001) with CPAP as compared to autoCPAP. Nolan 2007 reported no significant differences in systolic and diastolic blood pressure changes between autoCPAP and CPAP; however, no quantitative data were provided.

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of autoCPAP versus CPAP for OSA in terms of patient characteristics (age, sex, race, weight, bed partner, and airway characteristics) or severity of OSA. Only one study explicitly defined OSA.185 Most other studies, though, provided explicit study enrollment criteria based on a minimum AHI threshold.

We performed subgroup meta-analyses stratified by different minimum AHI threshold for the AHI and ESS outcomes. No apparent difference in AHI outcomes was observed between autoCPAP and CPAP within any of the AHI subgroups (5, 10, 15, 20, or 30 events/hr). For the ESS, there were significant differences in favor of autoCPAP for the AHI subgroups of 20 and 30 events/hr, but not for the subgroups of studies that included patients with a lower AHI.

#### Summary

Twenty-one studies (mostly quality B or C) comprising an experimental population of over 800 patients provided evidence that autoCPAP reduces sleepiness as measured by ESS by approximately 0.5 points more than fixed CPAP. The two devices were found to result in clinically similar levels of compliance (hours used per night) and changes in AHI from baseline, quality of life, and most other sleep study measures. However, there is also evidence that minimum oxygen saturation improves more with CPAP than with autoCPAP, although by only about 1 percent. Evidence is limited regarding the relative effect of CPAP and autoCPAP on blood pressure.

Overall, despite no or weak evidence on clinical outcomes, overall the strength of evidence is moderate that autoCPAP and fixed CPAP result in similar compliance and treatment effects for patients with OSA.

### Comparison of Bilevel CPAP and Fixed CPAP

Four parallel trials compared bilevel CPAP with fixed CPAP195–198 and one crossover trial compared bilevel CPAP with autoCPAP, in patients with OSA (Appendix D Table 5.5.1).199 Baseline AHI in the four studies with reported data ranged from 32 to 52 events/hr. Piper 2008 included patients with concomitant morbid obesity (mean BMI = 53 kg/m^2^) and obesity hypoventilation syndrome. Khayat 2008 included patients with concomitant heart failure (American Heart Association class II or III). Gay 2003 enrolled patients without comorbidities. About 10 percent of the patients in Reeves-Hoche 1995 had restrictive lung pattern on pulmonary function tests secondary to obesity. In the bilevel CPAP versus autoCPAP study, Randerath 2003 specifically enrolled patients who did not tolerate conventional CPAP. Study sample sizes ranged from 24 to 83 (total = 197 across studies). Study durations ranged from 1 to 12 months. One study was rated quality B197 and the remaining four were rated quality C.195,196,198,199 Small sample sizes and possible selection bias were the main methodological concerns. These studies are applicable mainly to patients with AHI more than 30 events/hr. Individual studies are applicable to patients with morbid obesity, heart failure, or no comorbidities. Only one study was restricted to patients who did not tolerate fixed CPAP.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

(Appendix D Table 5.5.2)

All five trials provided data on compliance. None of them found a statistically significant difference in usage of the machine (hours used per night or percent days used) between bilevel CPAP and CPAP, or bilevel CPAP and autoCPAP, at followup. Piper 2008 and Gay 2003 reported that patients used the devices for about 6 hours a night, on average, Reeves-Hoche 1995 about 5 hours a night, and Khayat 2008 about 4 hours a night. Randerath 2003 reported that the patients used the machines about 90 percent of the time.

#### Apnea-Hypopnea Index

Two trials provided data on AHI outcome.196,199 Khayat 2008 reported that both bilevel CPAP and CPAP decreased AHI after 3 months (−34 versus −26 events/hr, respectively). Randerath 2003 reported that both bilevel CPAP and autoCPAP decreased AHI after 1.5 months (−39 versus −35 events/hr, respectively). The difference between bilevel CPAP and CPAP or autoCPAP was not statistically significant in either trial.

#### Epworth Sleepiness Scale

(Appendix D Table 5.5.3)

Four trials provided data on changes in daytime sleepiness as assessed using ESS.195–197,199 Each reported that both bilevel CPAP and CPAP decreased daytime sleepiness. The difference between bilevel CPAP and CPAP was not statistically significant in any trial.

#### Other Sleep Study Measures

Randerath 2003 also provided outcomes on minimum oxygen saturation, arousals, and sleep stages.199 The difference between bilevel CPAP and autoCPAP was not statistically significant in any of these measures. Changes after 1.5 months within the two arms (bilevel CPAP versus autoCPAP) were 7.4 versus 9.4 percent for minimum oxygen saturation, −25.3 versus −22.5 events/hr for arousal index, −1 versus 0 percent of total sleep time for REM sleep, and 7.8 versus 4.7 percent of total sleep time for stages 3 or 4 sleep, respectively.

#### Quality of Life and Other Functional Outcomes

(Appendix D Table 5.5.4)

Three trials provided data on quality of life outcomes.195–197 Each study used a different instrument for assessment: the Minnesota Questionnaire for heart failure,196 the Functional Outcomes of Sleep Questionnaire (FOSQ),195 and the SF-36.^197^ None of the trials found significant differences between bilevel CPAP and CPAP in any quality of life measure.

#### Neurocognitive and Psychological Tests

One trial reported on neurocognitive outcomes.197 Piper 2008 found a significant difference in the “mean of slowest 10 percent reaction” subtest of the Psychomotor Vigilance Test, favoring those patients who used bilevel CPAP (change from baseline: 0.32 versus 0.07 (unclear unit); P=0.03). No statistically significant difference was found in the other two subtests.

#### Blood Pressure

Khayat 2008, which included OSA patients with heart failure, was the only trial to report changes in blood pressure.196 No significant differences were found between the two treatments; both bilevel CPAP and CPAP decreased systolic (6.3 versus 1.4 mm Hg, respectively; P=0.53) and diastolic blood pressure (7.5 versus 2.3 mm Hg, respectively; P=0.31).

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of bilevel CPAP versus CPAP for OSA in terms of patient characteristics (age, sex, race, weight, bed partner, and airway characteristics) or severity of OSA. All studies that reported a minimum AHI for inclusion eligibility used a threshold of 10 events/hr, thus no analysis of comparative effects across studies based on different AHI enrollment criteria was possible.

#### Summary

Five small trials with largely null findings did not support any substantive differences in the efficacy of bilevel CPAP versus CPAP in the treatment of patients with OSA. The studies were mostly of quality C but reported generally consistent results across outcomes. The studies were highly clinically heterogeneous in their populations, mostly with substantial comorbidities. Thus the studies, overall, have limited directness to the general OSA population. Largely due to small sample sizes, the studies mostly had imprecise estimates of the comparative effects. Due to the clinical heterogeneity and the imprecision, the overall strength of evidence was graded insufficient regarding any difference in compliance or other outcomes between bilevel CPAP and CPAP.

### Comparison of Flexible Bilevel CPAP and Fixed CPAP

Only Ballard 2007, a quality B, parallel design RCT, compared flexible bilevel CPAP with fixed CPAP. The study enrolled 104 patients with OSA (mean AHI of 42 events/hr; mean BMI 34.2 kg/m^2^) and self-estimated nightly use of CPAP of less than 4 hours.200 After 3 months, significantly more patients had used flexible bilevel CPAP for more than 4 hours a night compared with CPAP (49 versus 28 percent, respectively; P=0.03). Mean hours used per night were similarly higher in the flexible bilevel CPAP group than the CPAP group (3.7 versus 2.9 hr/night, respectively; P<0.05) The study also reported that the patients treated with flexible bilevel CPAP displayed a significant increase in mean FOSQ total score of 1.45 (P=0.004); the increase (0.45) in the CPAP group was not significant. Statistical comparison between groups on FOSQ was not reported. By our calculation (based on the reported data) the difference between the two treatments was not statistically significant. The study did not evaluate objective clinical outcomes. This study is applicable mainly to patients with AHI more than 30 events/hr and BMI more than 30 kg/m^2^ who were poorly compliant with fixed CPAP.

In conclusion, while a single study found that flexible bilevel CPAP may yield increased compliance compared with fixed CPAP, overall the strength of evidence is insufficient regarding the relative effect of the two interventions.

### Comparison of C-Flex™ and Fixed CPAP

Three parallel trials201–203 and one crossover204 trial compared C-Flex™ with fixed CPAP in patients with OSA (Appendix D Table 5.7.1). C-Flex is a proprietary CPAP technology that reduces the pressure slightly at the beginning of exhalation. Mean baseline AHI in these studies ranged from 35.4 to 53.3 events/hr. No comorbidities, with the exception of increased BMI (ranged from 31 to 34.9 kg/m^2^), were reported. Study sample sizes ranged from 30 to 184 (total = 430 across studies). Study durations ranged from 1.5 to 6 months. Two studies were rated quality B and two were rated quality C. Incomplete and unclear reporting were the main methodological concerns. These studies are applicable mainly to patients with AHI more than 30 events/hr and BMI more than 30 kg/m^2^.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

(Appendix D Table 5.7.2)

All four trials provided data on compliance. One study prescreened patients for compliance before acceptance into the study; only those with 4 or more mean hours of nightly CPAP use during a one week screening were admitted.201 None of the four trials found a statistically significant difference in the relative usage of the machines (hours used per night) at followup. Pepin 2009^203^ and Nilius 2006^202^ reported that patients used the machines for about 5 hours a night, on average. Dolan 2009^201^ and Leidag 2008^204^ reported a compliance of about 6 hours a night.

#### Epworth Sleepiness Scale

(Appendix D Table 5.7.3)

Three trials provided data on changes in daytime sleepiness as assessed using ESS.201–203 Each reported that both C-Flex and CPAP decreased daytime sleepiness. The difference between C-Flex and CPAP was not statistically significant in any trial. Meta-analysis of ESS difference between C-Flex and CPAP in these three studies resulted in a difference of −0.23 (95 percent CI −0.74, 0.27; P=0.36). No statistically significant heterogeneity was observed within the meta-analysis.

#### Other Sleep Study Measures

Leidag 2008 also provided outcomes on AHI, minimum oxygen saturation, arousals, and sleep stages.204 Final values at 1.5 months between C-Flex and CPAP were not statistically significant in any of these measures: 6.2 versus 5.4 events/hr for AHI, 87.7 versus 88 percent for minimum oxygen saturation, 9.3 versus 8.9 events/hr for arousal, 19.5 versus 21.7 percent for REM sleep, and 9 versus 10.2 percent for stage 4 sleep.

#### Quality of Life

Pepin 2009 also provided data on quality of life outcomes.203 With the exception of physical functioning and bodily pain in SF-36, both C-Flex and CPAP improved all domains in SF-36 and in the Grenoble Sleep Apnea Quality of Life questionnaire. No significant differences between C-Flex and CPAP were shown in these assessments.

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of C-Flex versus CPAP for OSA in terms of patient characteristics (age, sex, race, weight, bed partner, and airway) or severity of OSA.

All the studies used AHI as either part of the definition of OSA or as a minimum study enrollment criterion. The AHI cutoffs used were 5,^204^ 10,^201^ 15,^203^ or 20^202^ events/hr. No apparent difference in ESS was noted between C-Flex and CPAP based on different minimum AHI enrollment criteria or OSA definitions across the three studies that provided these data.201–203

#### Summary

Four trials with largely null findings did not support any substantive differences in the efficacy of C-Flex versus fixed CPAP in improving compliance (hours used per night) in patients with OSA. Overall the studies were of quality B and C, but reported generally consistent results across outcomes and had no substantive issues regarding directness to the OSA population. No statistically significant differences in compliance or other outcomes were found between C-Flex and fixed CPAP. The strength of evidence for this finding is rated low because of the mixed quality (Bs and Cs) of the primary studies.

### Comparison of Humidification in CPAP

Three parallel trials205–207 and two crossover trials208,209 compared different aspects of humidification in fixed CPAP or autoCPAP (Appendix D Table 5.8.1). Three trials compared heated humidified CPAP with dry CPAP.205,208,209 One trial provided additional data on cold passover humidified CPAP compared with dry CPAP.209 One trial compared heated-humidified autoCPAP with dry autoCPAP.207 One trial compared “always on” with “as needed” heated-humidified CPAP.206 Mean baseline AHI in these studies ranged from 29 to 54 events/hr. No comorbidities, with the exception of increased BMI (ranging from 34.4 to 37.6 kg/m^2^), were reported in these studies. Study sample sizes ranged from 42 to 123 (total = 360 across studies). Study durations ranged from 0.75 to 12 months. Three studies were rated quality B and two were rated quality C. Incomplete reporting and unclear analysis were some of the methodological concerns. These studies are applicable mainly to patients with AHI more than 30 events/hr and BMI more than 30 kg/m^2^.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

(Appendix D Table 5.8.2)

All five trials provided data on compliance (hours used per night). Two trials reported that patients who used heated-humidified CPAP had increased compliance compared with those who did not (5.7 versus 5.3 hr/night, P=0.03 in Neill 2003; 5.52 versus 4.93 hr/night, P=0.008 in Massie 1999). Ryan 2009 did not find a statistically significant difference in compliance between heated-humidified and dry CPAP. Mador 2005 did not find a statistically significant difference in compliance between “always on” and “as needed” heated-humidified CPAP. Massie 1999 did not find a statistically significant difference in compliance between cold passover CPAP and heated-humidified or dry CPAP. Salgado 2008 did not find a statistically significant difference in compliance between heated-humidified and dry autoCPAP. No consistent effect of humidification on compliance was observed across these studies.

#### Apnea-Hypopnea Index

Only Salgado 2008 provided outcomes on AHI.207 Both heated-humidified and dry autoCPAP were effective in reducing AHI; there was no statistically significant difference between them (−23.5 versus −24.1 events/hr, respectively).

#### Epworth Sleepiness Scale

(Appendix D Table 5.8.3)

All five trials provided data on changes in daytime sleepiness as assessed using ESS. The difference between the two intervention arms in each of the trials was not statistically significant. Both intervention arms in each trial reported decreased daytime sleepiness. Three trials were sufficiently similar and provided appropriate data to allow meta-analysis.205,207,208 A meta-analysis showed the difference in ESS between CPAP with and without humidification in these 3 trials to be −0.31 (95 percent CI −1.16, 0.54; P=0.47). No statistically significant heterogeneity was observed within the meta-analysis.

#### Quality of Life

Two trials provided data on quality of life outcomes.205,206 Ryan 2009 did not find any statistically significant difference in SF-36 between patients who had heated-humidified CPAP and those who had dry CPAP.205 However, nasal symptoms were more common in the dry CPAP group compared with the heated humidified group (70 versus 28 percent, P=0.002). Mador 2005 did not find any statistically significant difference in Calgary Sleep Apnea Quality of Life Index between patients who had “always on” and those who had “as needed” heated-humidified CPAP.206

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of humidified versus dry autoCPAP or CPAP for OSA in terms of patient characteristics (age, sex, race, weight, bed partner, and airway characteristics) or severity of OSA.

For variability in minimum AHI or RDI enrollment criteria, three studies used 10 events/hr and two studies did not specify a minimum value. No cross study comparisons based on minimum AHI or RDI criteria were possible.

#### Summary

Five trials examined different aspects of humidified positive airway pressure treatment for patients with OSA. While some studies reported a benefit of added humidity in positive airway pressure treatment in improving patient compliance, this effect was not consistent across all the studies. Overall the studies were clinically heterogeneous, small, and not of quality A. Thus, the strength of evidence is insufficient to determine whether there is a difference in compliance or other outcomes between positive airway pressure treatment with and without humidification.

### Comparison of Mandibular Advancement Devices and No Treatment

Five trials compared mandibular advancement devices (MAD) with different controls (Appendix D Table 5.9.1). Three were crossover trials140,210,211 and two had a parallel design.129,212 All devices were designed to advance the mandible or otherwise mechanically splint the oropharynx during sleep.

Bloch 2000 compared a one-piece MAD or a two-piece MAD with no treatment.210 Barnes 2004 compared MAD with a placebo tablet.140 Kato 2000 compared oral appliances of 2 mm, 4 mm, or 6 mm with no treatment.211 Lam 2007 compared MAD plus conservative management to conservative management alone,129 and Petri 2008 compared MAD to no treatment.212

The mean AHI at baseline ranged from 19 to 34 events/hr. Common exclusion criteria included significant coexisting diseases such as heart disease and diabetes, an unsafe level of sleepiness, and other upper airway or jaw problems. Study sample sizes ranged from 24 to 80, with a total of 301 patients across studies. Kato 2000 did not provide clear outcome reporting, and was rated quality C; all other studies were rated quality B. The main methodological concerns were small sample sizes and lack of blinding in outcome assessors. The studies are generally applicable to patients with AHI ≥15 events/hr, though less so to patients with comorbidities or excessive sleepiness.

While acknowledging the large clinical heterogeneity due to the different devices being tested, data were examined via meta-analyses. Note that the meta-analysis figures include comparisons of MAD with both no treatment and sham MAD (discussed in the next section).

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Apnea-Hypopnea Index

(Appendix D Table 5.9.2) and Oxygen Desaturation Index (Figure 19)

Figure 19 Meta-analysis of AHI (events/hr) in randomized controlled trials of mandibular advancement devices vs. control, by comparator

AHI = apnea-hypopnea index, CI = confidence interval, Cx = control, MAD = mandibular advancement device, Tx = treatment.

This forest plot displays 3 trials that used sham devices as comparators and 5 trials that used no treatment as the comparator. The trials have homogeneous results overall with net differences ranging from 16 to 6.3 events per hour, favoring mandibular advancement devices. Overall, the summary net difference was 11.8 events per hour (95 percent confidence interval 14.6 to 8.9), P<0.001, favoring mandibular advancement devices, with no statistical heterogeneity (I-squared = 31 percent, P=0.18). The results of the sham comparator trials (summary estimate 14.0 events per hour) are similar to results of the no treatment comparator trials (summary estimate 11.3 events per hour). However, within the group of no treatment comparator trials, there was statistical heterogeneity (I-squared = 55 percent, P=0.06).

Four trials with five device comparisons provided data on AHI as an outcome,129,140,210,212 while one provided data on ODI.211 All four trials reporting on AHI reported that AHI decreased significantly more in patients using a MAD compared with controls, with net differences ranging from −6.3 to −14.7 events/hr. Kato 2000 found that ODI decreased significantly in the MAD groups compared with control, with net differences of −8.7 for the 2 mm group, −11.3 for the 4 mm group, and −15.2 for the 6 mm group (P<0.05 for each comparison). Meta-analysis of AHI yielded a statistically significant effect (difference = −11 events/hr; 95 percent CI −15, −8), though with some statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices combined yielded similar results (though without statistical heterogeneity).

#### Epworth Sleepiness Scale

(Appendix D Table 5.9.3; Figure 20)

Figure 20 Meta-analysis of ESS in randomized controlled trials of mandibular advancement devices vs. control, by comparator

AHI = apnea-hypopnea index, CI = confidence interval, Cx = control, ESS = Epworth Sleepiness Scale, MAD = mandibular advancement device, Tx = treatment.

This forest plot displays 3 trials that used sham devices as comparators and 3 trials that used no treatment as the comparator. The trials have homogeneous results overall with net differences ranging from 3.3 to 0.9, favoring mandibular advancement devices. Overall, the summary net difference was 1.4 (95 percent confidence interval 1.9 to 0.8), P<0.001, favoring mandibular advancement devices, with no statistical heterogeneity (I-squared = 35 percent, P=0.18). The results of the sham comparator trials (summary estimate 1.95) are similar to results of the no treatment comparator trials (summary estimate 1.17).

Four trials with five device comparisons provided data on ESS as an outcome.129,140,210,212 All four trials reported that ESS was significantly improved in patients using a MAD compared to controls, with differences ranging from −1 to −4.5. Meta-analysis of ESS yielded a statistically significant effect (difference = −1.2; 95 percent CI −1.7, −0.6), without statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices treatment combined yielded similar results.

#### Other Sleep Study Measures

(Appendix D Table 5.9.4a–e; Figures 21 & 22)

Figure 21 Meta-analysis of minimum oxygen saturation (%) in randomized controlled trials of mandibular advancement devices vs. control, by comparator

AHI = apnea-hypopnea index, CI = confidence interval, Cx = control, MAD = mandibular advancement device, min O2 = minimum oxygen saturation, Tx = treatment.

This forest plot displays 2 trials that used sham devices as comparators and 2 trials that used no treatment as the comparator. The trials have homogeneous results overall with net differences ranging from 2.3 to 5.9 percent, favoring mandibular advancement devices. Overall, the summary net difference was 2.9 percent (95 percent confidence interval 1.9 to 3.8), P<0.001, favoring mandibular advancement devices, with no statistical heterogeneity (I-squared = 5 percent, P=0.37). The results of the sham comparator trials (summary estimate 3.1 percent) are similar to results of the no treatment comparator trials (summary estimate 3.0 percent).

Figure 22 Meta-analysis of arousal index (events/hr) in randomized controlled trials of mandibular advancement devices vs. control, by comparator

AHI = apnea-hypopnea index, AI = arousal index, CI = confidence interval, Cx = control, MAD = mandibular advancement device, Tx = treatment.

This forest plot displays 2 trials that used sham devices as comparators and 4 trials that used no treatment as the comparator. The trials have heterogeneous results overall with net differences ranging from 14.5 to 1.4 events per hour, favoring mandibular advancement devices. Overall, the summary net difference was 8.8 events per hour (95 percent confidence interval 13.8 to 3.8), P<0.001, favoring mandibular advancement devices, with statistical heterogeneity (I-squared = 81 percent, P<0.001). The results of the sham comparator trials (summary estimate 10.4 events per hour) are similar to results of the no treatment comparator trials (summary estimate 7.9 events per hour).

Three trials reported on minimum oxygen saturation.129,140,211 Kato 2000 and Barnes 2004 found a significantly higher minimum oxygen saturation in the MAD group, while Lam 2007 did not find a significant difference between any of the three MADs examined and the control group. Kato 2000 found that minimum oxygen saturation increased significantly in the MAD groups compared with control, with net differences of 2.0 percent for the 2 mm group, 2.3 percent for the 4 mm group, and 2.4 percent for the 6 mm group (P<0.05 for each comparison). Barnes 2004 found a difference of 2.4 percent (95 percent CI 1.4, 3.4; P=0.001). Meta-analysis of minimum oxygen saturation yielded a statistically significant effect (difference = 3.0 percent; 95 percent CI 0.4, 5.5), without statistical heterogeneity (Appendix D Table 5.9.4a). Meta-analysis of MAD versus no treatment or inactive devices treatment combined yielded similar results (Figure 21).

Three trials reported on arousal index (Appendix D Table 5.9.4b). Barnes 2004 found no significant difference between MAD and control; Lam 2007 found a lower arousal index in MAD compared with control (difference = −8.2; 95 percent CI −9.3, 7.1; P<0.05). Bloch 2000 found a lower arousal index for patients using a one-piece MAD compared with control (difference = −14.5; 95 percent CI −22.6, −6.4; P<0.05), but no significant difference between patients using a two-piece MAD compared with control (difference = −10.1; 95 percent CI −17.9, 2.3; NS). Bloch 2000 and Barnes 2004 reported on sleep efficiency, and found no significant difference between groups (Appendix D Table 5.9.4c) Meta-analysis of arousal index yielded a statistically significant effect (difference = −7.9 events/hr; 95 percent CI −14, −1.3), though with some statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices treatment combined yielded similar results (Figure 22).

Bloch 2000 and Barnes 2004 both reported on slow wave sleep. Barnes 2000 found no significant difference between MAD and control. Bloch 2000 found no difference between groups when comparing 2-piece MAD with control, but found a higher percentage of slow wave sleep in the 1-piece MAD group compared with control (P<0.05). Three studies reported on REM sleep; no significant difference among groups was reported (Appendix D Table 5.9.4e).140,210,212

#### Quality of Life

(Appendix D Table 5.9.5)

Barnes 2004 reported on SF-36, finding no significant difference between MAD and control in SF-36 mean score, physical component summary, or mental component summary. Lam 2007 found no difference in any SF-36 domain between MAD and control. Barnes 2004 also reported no significant difference between groups in Beck Depression Inventory score or Functional Outcomes of Sleep Questionnaire social domain score. Lam 2007 did not find a difference in Sleep Apnea Quality of Life Index (SAQLI) social interactions or treatment-related symptoms scores, but did find an improved overall SAQLI score in the MAD group compared with the control group (difference = 0.7; 95 percent CI 0.6, 0.8; P<0.001).

#### Neurocognitive Tests

Jokic 1999 did not find a significant difference between CPAP and positional therapy in the Wechsler Memory Scale, Purdue Pegboard, Trail-Making Test, Symbol Digit Modalities, Consonant Trigram, or Concentration Endurance Test scores.

#### Study Variability

No studies reported subgroup analyses. Control treatments varied by study; Bloch 2000, Kato 2000, and Petri 2008 used no treatment as a control, whereas Barnes 2004 used a placebo tablet, and Lam 2007 used conservative management. Studies were mostly consistent in their findings.

#### Summary

Four quality B trials and one quality C trial compared MAD to no treatment, using a variety of different types of MAD. Individually and by meta-analysis, studies found significant improvements with MAD in AHI, ESS, and other sleep study measures. No trial evaluated long-term objective clinical outcomes. The results of quality of life measures, and neurocognitive tests were equivocal between groups. Overall, despite no or weak evidence on clinical outcomes, overall, the strength of evidence is moderate to show that the use of MAD improves sleep apnea signs and symptoms.

### Comparison of Mandibular Advancement Devices and Inactive (Sham) Oral Devices

One parallel design RCT212 and four crossover trials compared the effects of MADs to inactive oral devices with no mandibular advancement across six publications (Appendix D Table 5.10.1).213–218 The baseline AHI (or RDI) ranged from 25 to 36 events/hr. All studies included patients with no other significant comorbidities. Study sample sizes ranged from 17 to 73 (total = 186 patients). Study durations ranged from 8 days to 6 weeks. Hans 1997 was rated quality C due to a 30 percent dropout rate and the lack of a power analysis. The other studies were rated quality B. These studies are applicable primarily to patients with AHI of more than about 25 events/hr who do not have other significant comorbidities. All studies excluded edentulous patients or those with periodontal diseases.

While acknowledging the large clinical heterogeneity due to the different devices being tested, data were examined via meta-analyses.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Apnea-Hypopnea Index and Respiratory Disturbance Index

(Appendix D Table 5.10.2; Figure 19)

Five studies provided data on AHI or RDI.212–218 All found significant improvement in AHI or RDI with MAD compared with sham devices. Net changes in AHI or RDI ranged from −13 to −25 events/hr. Meta-analysis of AHI yielded a statistically significant effect (difference = −14 events/hr; 95 percent CI −20, −8), without statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices combined yielded similar results (see Comparison of Mandibular Advancement Devices and No Treatment, above).

#### Epworth Sleepiness Scale

(Appendix D Table 5.10.3; Figure 20)

Four trials in six publications provided data on changes in daytime sleepiness assessed using ESS.212–217 Gotsopoulos 2002, in a 4 week crossover trial with 73 patients (mean age = 48 yr, 80 percent male) compared a custom-made MAD to an inactive oral device (single upper plate). It found a statistically significant reduction in daytime sleepiness with MAD compared with the inactive oral device (net change in ESS −2; P<0.001). The other studies did not find statistically significant differences between MAD and inactive oral devices. Meta-analysis of ESS yielded a statistically significant effect (difference = −1.9; 95 percent CI −2.9, −1.0), without statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices treatment combined yielded similar results (see Comparison of Mandibular Advancement Devices and No Treatment, above).

#### Other Sleep Study Measures

(Appendix D Tables 5.10.4–5.10.7; Figures 21 & 22)

Two trials in four publications reported changes in minimum oxygen saturation (Appendix D Table 5.10.4).214,215,217,218 Gotsopoulos 2002 (and associated articles) and Mehta 2001 compared MAD with inactive oral devices (single upper plate and lower dental plate) and found statistically significant improvements in minimum oxygen saturation with MAD compared with the inactive oral devices (differences of 6 and 2 percent, respectively; P<0.0001). Meta-analysis of minimum oxygen saturation yielded a statistically significant effect (difference = 3.1 percent; 95 percent CI 1.4, 4.8), without statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices treatment combined yielded similar results (see Figure 21 and Comparison of Mandibular Advancement Devices and No Treatment, above).

The same trials also reported changes in the number of arousals (Appendix D Table 5.10.5).214,215,217,218 Naismith 2005 found a significant decrease in the number of arousals in MAD compared with single plate devices (P<0.001). Meta-analysis of arousal index yielded a statistically significant effect (difference = −10 events/hr; 95 percent CI −16, −5; P=0.001), without statistical heterogeneity. Meta-analysis of MAD versus no treatment or inactive devices treatment combined yielded similar results (see Figure 22 and Comparison of Mandibular Advancement Devices and No Treatment, above).

Two trials in four publications reported sleep efficiency (Appendix D Table 5.10.6).214,215,217,218 Neither trial found statistically significant differences in sleep efficiency between MAD and sham devices.

Two trials evaluated changes in sleep stages with MAD compared with sham devices.212,218 The outcome of interest was the percentage of total sleep time spent in REM, stage 3 and stage 4 sleep. Mehta 2001 found a significant improvement in REM sleep with MAD compared with lower dental plate (P<0.005). Petri 2008 provided sufficient data for comparative calculations between MAD versus an appliance with no mandibular advancement. Our calculations showed a significant increase in percentage of total sleep time spent in stage 3 sleep with MAD compared with nonadvancement (sham) MAD (net difference 2.9 percent; P=0.045). However there was no significant difference in time spent in REM or stage 4 sleep between groups (Appendix D Table 5.10.7).

#### Quality of Life

(Appendix D Table 5.10.9)

Petri 2008 reported quality of life outcomes measured using SF-36.^212^ The study found significant improvement in the vitality dimension with MAD compared with sham MAD (P<0.001). There were no statistically significance differences between groups in other domains of SF-36.

#### Neurocognitive Tests

(Appendix D Table 5.10.8)

Gotsopoulos 2002 (and related articles), which compared MAD with an inactive oral appliance (single upper plate) with no mandibular advancement, found significant improvements in the Multiple Sleep Latency Test (P=0.01) with MAD as compared with single upper plate. In addition, the study found significant improvements in somatic items on the Beck Depression Inventory scale (P<0.05) and the choice reaction time task (a speed & vigilance test) on the neuropsychological test (P<0.001) in MAD compared with single upper plate. There were no statistically significant differences between groups in other domains of Beck Depression Inventory or other subtests of the neuropsychological tests.

#### Neurocognitive Tests

(Appendix D Table 5.10.8)

Gotsopoulos 2002 (and related articles) also found significant reductions in 24-hour systolic (P<0.05) and diastolic (P<0.001) blood pressures with MAD as compared with single upper plate.

#### Study Variability

None of these studies reported subgroup analyses. The studies were generally consistent in their findings and there were no clear differences in effect based on patient characteristics, severity of sleep apnea, other symptoms, or apparent differences in OSA definitions.

#### Summary

Five trials, most rated quality B, compared the effects of MAD with inactive devices. The studies individually and via meta-analysis showed sufficient evidence that most sleep study measures (AHI, minimum oxygen saturation, arousal index) and ESS were improved with MAD as compared with devices without mandibular advancement. No trials evaluated objective clinical outcomes. The strength of evidence is insufficient concerning other evaluated outcomes due to inconsistent results or a limited number of studies per outcome. Overall, despite no or weak evidence on clinical outcomes, overall the strength of evidence is moderate to show that the use of MAD improves sleep apnea signs and symptoms.

### Comparisons of Different Oral Devices

Two parallel design RCTs219,220 and one crossover trial221 compared the effects of different types of oral MAD in patients with OSA (Appendix D Table 5.11.1). A fourth study compared MAD with a novel tongue-stabilizing device222 and a fifth study compared two types of tongue-retaining devices.223 This study was rated quality C due to inadequate methodology and poor statistical analysis reporting. The other studies were rated quality B. These studies are applicable mostly to patients with AHI of 15 to 30 events/hr and BMI less than 30 kg/m^2^. However, one study included mainly obese patients (BMI >30 kg/m^2^). All studies were restricted to patients with sufficient number of teeth to anchor the mandibular devices in place.

Each study examined a unique comparison, and, as such, is presented separately.

#### Different Degrees of Mandibular Advancement

(Appendix D Tables 5.11.1, 5.11.2, 5.11.4)

Walker-Engstrom 2003 compared the same MAD at different degrees of mandibular advancement: 75 percent (mean mandibular advancement 7.2 mm) versus 50 percent (mean of 5.0 mm). The trial enrolled 84 male patients, mostly obese (BMI >30 kg/m^2^), with severe OSA (AHI ≥20 events/hr). The mean age was 50 years, mean baseline AHI was 50 events/hr, and mean ESS score was 11.5. After 6 months, AHI normalization (AHI<10 events/hr) was achieved by 52 percent of patients who had 75 percent mandibular advancement and 31 percent of patients with 50 percent advancement (P<0.04). However, the trial found no difference in mean AHI or ESS score between groups.

#### Self-Adjustment Versus Objective Adjustment of Devices

(Appendix D Tables 5.11.1–5.11.5)

Campbell 2009 compared two methods of adjustment of the same MAD. One group of patients used self-adjustment of the MAD during the entire study duration. The other had an “objective adjustment” at 3 weeks following PSG-based feedback. The trial included 28, predominately male patients who had a BMI ≤35 kg/m^2^. The mean age was 48 years, mean baseline AHI was 25 events/hr, and baseline ESS score was 11.6. At 6 weeks, the trial found no statistically significant difference between the two groups in the sleep study measures evaluated (AHI and minimum oxygen saturation) and no statistically significant difference in subjective sleepiness.

#### Custom-Made Versus Thermoplastic Devices

(Appendix D Tables 5.11.1, 5.11.2, 5.11.4, 5.11.5)

Vanderveken 2008 compared custom-made MAD with a premolded thermoplastic MAD. Twenty-three, predominately male patients were evaluated in a crossover study with a 1 month washout period. The mean age was 49 years, mean baseline AHI was 13 events/hr, and baseline ESS score was 8. No statistically significant differences between treatment groups in AHI, sleep efficiency, ESS, or minimum oxygen saturation were found.

#### Mandibular Advancement Devices Versus Tongue-Stabilizing Device

(Appendix D Tables 5.11.1 & 5.11.6)

Deane 2009 reported a 1 week crossover trial that compared the effects of a MAD with a novel tongue-stabilizing device.222 The MAD produced 75 percent of maximal mandibular protrusion with a 4 mm vertical interincisal opening. The tongue-stabilizing device was a nonadjustable tongue-suction device made of silicone with no mandibular advancement. This study included 22 patients (73 percent male) with an AHI ≥10 events/hr (AHI mean 27 events/hr) and no other comorbid states. The mean age of patients was 49 yr and the mean BMI was 29 kg/m^2^. The study reported that 91 percent of the subjects using MAD had a decrease in AHI compared with 77 percent of patients using a tongue-stabilizing device. Our calculations based on the reported data show no significant differences in mean AHI, minimum oxygen saturation, arousal index, or sleep efficiency between groups.

#### Tongue-Retaining Device With Versus Without Suction

(Appendix D Tables 5.11.1 & 5.11.7)

Dort 2008 reported a crossover trial that compared the effects of a tongue-retaining device with or without suction in 32 patients (69 percent male) with primary snoring (RDI <5 events/hr) or mild to moderate OSA (RDI <30 events/hr).223 The active suction device was designed to allow suction formation on the tip of the tongue when placed in the mouth. After 1 week with each device (and a 1 week washout period), a significant improvement in RDI was observed with the suction tongue-retaining device as compared with the nonsuction device (difference = −4.9 events/hr; 95 percent CI −8.9, −0.85; P=0.019). However, there were no significant differences in ESS score, SAQLI, and compliance (mean hours of use per night) between groups.

#### Study Variability

A subgroup analysis comparing males and females in Deane 2009 showed no difference between MAD and a tongue-stabilizing device. As there is only one study per comparison, we were unable to assess potential differences due to factors of interest, such as patient characteristics and severity of OSA.

#### Summary

Five studies with unique comparisons found little to no differences between different types and methods of use of MAD or other oral devices in sleep study or sleepiness measures. No study evaluated objective clinical outcomes. Only one study evaluated compliance; no significant differences were observed. One trial found that a greater degree of mandibular advancement resulted in an increased number of patients achieving an AHI <10 events/hr; however, the mean AHI was similar between groups.

As the reviewed studies were generally small, and each concerned with a unique comparison, the strength of evidence is insufficient to draw conclusions with regards to the relative efficacy of different types of oral MAD in patients with OSA.

### Comparison of Mandibular Advancement Devices and CPAP

Ten trials (11 articles) compared different MAD with CPAP (Appendix D Table 5.12.1). Seven were crossover trials140,224–229 and three had a parallel design.129,230–232 All devices were designed to advance the mandible or otherwise mechanically splint the oropharynx during sleep.

Five trials tested branded oral devices, four used custom-made oral devices, and one (Skinner 2004) used a cervicomandibular support collar, which was worn around the neck and shoulders. This latter device was compared with autoCPAP; all other devices were compared with fixed (or undefined) CPAP.

Mean baseline AHI in the reviewed trials ranged from 18 to 40 events/hr; four trials included patients with an AHI ≥5, three with an AHI ≥10, one with an AHI ≥15 events/hr, and two did not report a lower AHI threshold. Four trials included only patients with relatively less severe OSA, with an AHI <30–50 events/hr. Most trials had otherwise unrestricted eligibility criteria with the exception of Barnes 2004, which excluded patients with diabetes, and Tan 2002, which excluded patients with recent cardiovascular disease. The sample size of the studies ranged from 10 to 94 (total = 384 across studies). The smallest study, Skinner 2004, was stopped early after analyzing half the planned participants because of significant results favoring the control (autoCPAP). This study was rated quality C; the remaining studies were all rated quality B. Small sample sizes, lack of outcome assessor blinding, and incomplete reporting were the main methodological concerns. The studies are generally applicable to patients with AHI >5–10 events/hr.

While acknowledging the large clinical heterogeneity due to the different devices being tested, data were examined via meta-analyses.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

Only Gagnadoux 2009, in a crossover trial of 28 patients, assessed compliance. Patients reported statistically significantly more hours of use per night (7.0 versus 6.0 hr/night; P<0.01) and more nights of use (98 versus 90 percent of nights; P>0.01) with MAD as compared with CPAP.

#### Treatment Response

(Appendix D Table 5.12.2)

Two studies measured treatment response (as a dichotomous outcome). In a 2 month crossover study of 28 patients, Gagnadoux 2009 found that significantly more patients on CPAP, as compared with MAD, had a complete response, defined as a ≥50 percent reduction in AHI to <5 events/hr (risk difference = −29 percent; 95 percent CI −53, −4; P=0.02). However, the large majority of the remaining patients experienced a partial response (≥50 percent reduction in AHI to >5 events/hr) and thus no significant difference in combined or partial response was observed.

Hoekema 2008 evaluated several related outcomes in a 2–3 month parallel trial of 103 patients comparing CPAP with oral appliance. “Effective treatment”, defined as a final AHI <5 events/hr or a >50 percent reduction to an AHI<20 events/hr without symptoms, was similar in both groups and in the subgroups of patients with baseline AHI below and above 30 events/hr. However, CPAP was more effective than oral appliance at achieving an AHI of <5 events/hr in all patients (risk difference= −20 percent; 95 percent CI −37, −2; P=0.02).

In the subgroup analyses, a larger, significant effect was found in patients with a baseline AHI >30 events/hr; no difference was observed in those with less severe OSA. The study also did not find a difference in this subgroup in achieving an AHI <10 events/hr.

#### Apnea-Hypopnea Index

(Appendix D Table 5.12.3; Figure 23)

Figure 23 Meta-analysis of AHI (events/hr) in randomized controlled trials of mandibular advancement devices vs. CPAP, by study design

AHI = apnea-hypopnea index, CI = confidence interval, CPAP = continuous positive airway pressure, MAD = mandibular advancement device.

This forest plot displays 7 crossover studies and 2 parallel design trials. The trials have heterogeneous results with net differences ranging from 4.0 to 16.9 events per hour, favoring CPAP over mandibular advancement devices. Overall, the summary net difference was 7.7 events per hour (95 percent confidence interval 5.3 to 10.1), P<0.001, favoring CPAP over mandibular advancement devices, with statistical heterogeneity (I-squared = 60 percent, P=0.010). The results of the crossover studies (summary estimate 7.4 events per hour) are similar to results of the parallel design trials (summary estimate 9.9 events per hour).

Nine trials provided data on AHI outcomes.129,140,224,226–232 All trials reported that AHI was lower in patients on CPAP than when using MADs. The results were statistically significant in seven of the trials. Meta-analysis of the eight trials with adequate data found that the difference in AHI between MAD and CPAP was statistically significant, favoring CPAP (difference = 7.7 events/hr; 95 percent CI 5.3, 10.1; P<0.001). Analysis of the net difference assessed in the two parallel trials and of the difference of final values in the six crossover trials yielded similar findings. However, the trial results were statistically heterogeneous.

#### Epworth Sleepiness Scale

(Appendix D Table 5.12.4; Figure 24)

Figure 24 Meta-analysis of ESS in randomized controlled trials of mandibular advancement devices vs. CPAP, by study design

AHI = apnea-hypopnea index, CI = confidence interval, CPAP = continuous positive airway pressure, ESS = Epworth Sleepiness Scale, MAD = mandibular advancement device.

This forest plot displays 2 parallel design trials and 5 crossover studies. The trials have heterogeneous results with net differences ranging from 1.9 to 6.0. Overall, the summary net difference was 1.3 (95 percent confidence interval 0.2 to 2.8), P=0.098, marginally favoring CPAP over mandibular advancement devices, with statistical heterogeneity (I-squared = 89 percent, P<0.001). The results of the parallel design trials (summary estimate 2.1) are similar to results of the crossover studies (summary estimate 0.95).

Seven trials provided data on ESS outcomes.129,140,225,227,229,230,232 Four trials found no significant difference in ESS between the two interventions, while three found a significantly lower ESS in patients on CPAP (net difference 2 and 6 units). However, only Gagnadoux 2009 found a statistically significant lower ESS (−0.5 units) while patients were using MAD. Meta-analysis revealed no significant difference between the two interventions but indicated a trend somewhat favoring CPAP (difference = 1.3; 95 percent CI −0.2, 2.8; P=0.098). A large degree of the statistical heterogeneity across studies was due to Engleman 2002, which found a considerably larger difference favoring CPAP (net difference = 6; estimated 95 percent CI 4.2, 7.8; P<0.001). It is unclear why this study found a different magnitude effect; the study shared features with several other studies that had reported smaller effects. Excluding this one study, meta-analysis indicated no difference between the interventions, though statistical heterogeneity remained (difference = 0.4, 95 percent CI −0.6, 1.3).

#### Other Sleep Study Measures

(Appendix D Table 5.12.5a–c; Figures 25 & 26)

Figure 25 Meta-analysis of arousal index (events/hr) in randomized controlled trials of mandibular advancement devices vs. CPAP, by study design

AHI = apnea-hypopnea index, AI = arousal index, CI = confidence interval, CPAP = continuous positive airway pressure, MAD = mandibular advancement device.

This forest plot displays 4 crossover studies and 1 parallel design trial. The trials may have heterogeneous results with net differences ranging from 1.8 to 15.2 events per hour, favoring CPAP. Overall, the summary net difference was 3.5 events per hour (95 percent confidence interval 1.5 to 5.5), P<0.001, favoring CPAP over mandibular advancement devices, with borderline statistical heterogeneity (I-squared = 47 percent, P=0.109). The result of the parallel design trial (2.4 events per hour) falls within the range of results of the crossover studies (1.8 to 15.2 events per hour).

Figure 26 Meta-analysis of minimum oxygen saturation (%) in randomized controlled trials of mandibular advancement devices vs. CPAP, by study design

AHI = apnea-hypopnea index, CI = confidence interval, CPAP = continuous positive airway pressure, MAD = mandibular advancement device, min O2 = minimum oxygen saturation.

This forest plot displays 5 crossover studies and 2 parallel design trials. The trials have homogeneous results with net differences ranging from 9.8 to 2.1 percent, favoring CPAP. Overall, the summary net difference was 3.5 percent (95 percent confidence interval 4.6 to 2.5), P<0.001, favoring CPAP over mandibular advancement devices, with no statistical heterogeneity (I-squared = 35 percent, P=0.17). The results of the crossover studies (summary estimate 3.6 percent) are similar to results of the parallel design trials (summary estimate 2.7 percent).

Five studies evaluated arousal index (Figure 25). Meta-analysis revealed that arousals were significantly more common while using MAD than CPAP (difference = 3.5 events/hr; 95 percent CI 1.5, 5.5; P=0.001). All studies reported a higher arousal index on MAD than CPAP, though only Barnes 2004 found a statistically significant difference (and Skinner 2004, discontinued early, which found a large, but marginally nonsignificant difference between the cervicomandibular support collar and autoCPAP) (Appendix D Table 5.12.5a).

Seven studies evaluated minimum oxygen saturation (Figure 26). Meta-analysis revealed that the studies were homogeneous and indicated a statistically significant lower oxygen saturation while using MAD than CPAP (difference = −3.5 percent; 95 percent CI −4.6, −2.4; P<0.001). All studies found a consistent effect, though only two trials were statistically significant (Appendix D Table 5.12.5b).

Six studies found no significant difference in sleep efficiency (range of effects −2.9 percent, 0.4 percent total sleep time) (Appendix D Table 5.12.5c). Five of these studies found a consistent (though nonsignificant) trend toward less time in slow wave sleep with MAD (range of effects −3.9 percent, −0.6 percent total sleep time) (Appendix D Table 5.12.5d).

Seven studies evaluated REM sleep (Appendix D Table 5.12.5e). No statistically significant difference in percentage of time spent in REM sleep was reported, although the range of differences between the two interventions was large (−4.7 to 6.1). There was no clear explanation for the different results across studies.

#### Objective Sleepiness and Wakefulness Tests

(Appendix D Table 5.12.6)

Two studies evaluated wakefulness tests. Engleman 2002 found no difference in the Maintenance of Wakefulness Test sleep onset latency. Gagnadoux 2009 found no difference in the Oxford Sleep Resistance test sleep latency.

#### Quality of Life

(Appendix D Table 5.12.7a–b; Figure 27)

Figure 27 Meta-analysis of FOSQ in randomized controlled trials of mandibular advancement devices vs. CPAP, by study design

AHI = apnea-hypopnea index, CI = confidence interval, CPAP = continuous positive airway pressure, FOSQ = Functional Outcomes Sleep Questionnaire, MAD = mandibular advancement device.

This forest plot displays 1 parallel design trial and 2 crossover studies. The trials have heterogeneous results with net differences of 0.10 (parallel trial), 0.10, and 3.0. Overall, the summary net difference was 0.9 (95 percent confidence interval 2.5 to 0.8), P=0.30, with statistical heterogeneity (I-squared = 78 percent, P=0.011).

Three studies measured FOSQ (Appendix D Table 5.12.7a) with inconsistent findings. Hoekema 2008 (in a trial of an oral MAD versus CPAP) and Skinner 2004 (in an aborted trial of a cervicomandibular support collar versus autoCPAP) found no difference in quality of life as measured by FOSQ. In contrast, Engleman 2002 (in a trial of oral MAD versus CPAP) found that quality of life improved significantly less while patients were using MAD than while using CPAP. Meta-analysis revealed no significant effect on FOSQ (difference = −0.86; 95 percent CI −2.5, 0.8).

Seven studies measured various quality of life tests (Appendix D Table 5.12.7b); five used SF-36, two used the Hospital Anxiety and Depression Scale, and one study each used the Beck Depression Index, the Calgary Sleep Apnea Quality of Life Index (SAQLI), the Nottingham Health Profile, a “General Health” measure, and the Scottish National Sleep Laboratory symptom questionnaire. Five of the studies found no significant difference in quality of life among patients using MAD or CPAP. The remaining two studies found differences in components of SF-36 favoring CPAP: Engleman 2002 found significant differences in various components of SF-36, and Lam 2007 found a large net difference in only the Bodily Pain component (−16 points). Lam 2007 also found differences in SAQLI, which separately measures the effect of treatment on quality of life and any treatment-related symptoms (adverse effects). The study found that, overall, CPAP was better at improving quality of life, but that patients treated with CPAP had more treatment-related symptoms. Combining quality of life findings and treatment-related symptoms (the analysis SAQLI A-E), neither intervention was superior.

#### Neurocognitive Tests

(Appendix D Table 5.12.8)

Two studies evaluated neurocognitive tests. Neither Engleman 2002 nor Gagnadoux 2009 found any significant differences in a range of tests of cognitive performance (IQ), executive function (Trailmaking), processing speed (Paced Auditory Serial Addition Test), error making (Oxford sleep resistance), or driving skills (SteerClear).

#### Study Variability

Only one study reported subgroup analyses. As discussed above, Hoekema 2008 found no difference in the effective treatment rate between interventions in either those with more or less severe OSA (at an AHI threshold of 30 events/hr) after 2 to 3 months. However, those patients with a baseline AHI >30 events/hr were more likely to achieve an AHI of <5 events/hr with CPAP than MAD, as compared with those with a lower baseline AHI. An evaluation using a final AHI of <10 events/hr did not confirm this difference. This trial was a parallel design RCT, enrolling 103 patients with a minimum AHI of 5 events/hr but a relatively high mean AHI of 40 events/hr and with relatively severe sleepiness (mean ESS = 14.2).

For most evaluated outcomes, the reviewed studies were generally consistent in their findings. Where there were outliers, no clear differences in effect based on patient characteristics, severity of sleep apnea, other symptoms, or apparent differences in OSA definitions (particularly minimum AHI threshold) were observed.

The only consistent difference across studies and outcomes reported was that of the aborted study comparing a cervicomandibular support collar with autoCPAP. This study reported differences in effects (which favored autoCPAP) that were generally larger than the differences for the intraoral MADs compared with CPAP. This, apparently, was the reason that the study was prematurely terminated.

#### Summary

Ten trials (most quality B) compared MAD with CPAP; nine compared intraoral devices with CPAP and one compared an extraoral device with autoCPAP. The reviewed studies generally found that CPAP was superior in reducing AHI, reducing arousal index, raising minimum oxygen saturation. The evidence regarding relative effects on ESS is unclear due to heterogeneity of results across studies. These findings were confirmed by meta-analysis. No difference in effect was found for other sleep measures. Most studies found no significant difference in effects on quality of life or neurocognitive function, although one study found that the benefits of CPAP over MAD, as measured by SAQLI, were counterbalanced by an increase in perceived treatment-related symptoms under CPAP. Only one of two studies found a difference (favoring CPAP) in treatment response. Only one study evaluated compliance, finding that patients were more compliant with MAD than CPAP. No consistent or substantive differences in effects were found based on patient characteristics, disease severity, or other baseline symptoms.

There was sufficient evidence supporting greater improvements in sleep measures with CPAP as compared to MAD, but only weak evidence indicating no or only small differences favoring CPAP for improving compliance, treatment response, quality of life, or neurocognitive measures. There were no data on objective clinical outcomes. Nevertheless, overall there remains a moderate strength of evidence that CPAP is superior to MAD to improve sleep study measures. However, the strength of evidence is insufficient to address which patients might benefit most from either treatment.

### Comparison of Positional Therapy and CPAP

Three crossover trials compared three different positional devices with CPAP. One trial compared a shoulder head elevation pillow with autoCPAP,233 and two compared devices worn on the back to prevent sleeping supine with either autoCPAP234 or CPAP235 (Appendix D Table 5.16.1). Across studies, mean baseline AHI ranged from 18 to 27 events/hr. Skinner 2004 included patients with an AHI ≥10 events/hr, Skinner 2008 included patients with AHI ≥5, and Jokic 1999 included only patients who were shown to have an AHI <15 events/hr while in the lateral position. All patients had positional OSA; none were patients for whom positional therapy might be contraindicated due to conditions such as chronic musculoskeletal pain or other conditions affecting sleep. Study sample sizes ranged from 13 to 20 patients (total = 47 across studies). All studies were rated quality B. Small sample sizes and lack of patient and outcome assessor blinding were the main methodological quality concerns. These studies are applicable mainly to patients with AHI less than 30 events/hr who have positional OSA, and for whom positional therapy would not be contraindicated due to comorbid conditions.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Compliance

No study evaluated compliance.

#### Apnea-Hypopnea Index

(Appendix D Table 5.16.2a–b)

All three trials provided data on AHI as an outcome. Each trial reported that AHI decreased significantly more in patients on CPAP as compared with those on positional therapy. Jokic 1999 found a difference of 6.1 events/hr (95 percent CI 2.0, 10; P=0.007), Skinner 2004 found a difference of 16 events/hr (95 percent CI 4.2, 28; P=0.008), and Skinner 2008 found a difference of 7.1 (95 percent CI 1.1, 13; P=0.02). Skinner 2008 also reported statistically significantly more patients achieved an AHI of ≤10 events/hr with CPAP (89 percent) than with a Thoracic anti-supine band (72 percent; P=0.004, by Wilcoxin sign-rank test), though the relative risk of achieving a low AHI was nonsignificant (0.81; 95 percent CI 0.58, 1.13).

#### Epworth Sleepiness Scale

(Appendix D Table 5.16.3)

All three trials provided data on ESS as an outcome. Each trial reported that ESS scores were higher in patients on positional therapy than those on CPAP (differences ranged from 0.7 to 1.5), although none of these findings were statistically significant.

#### Other Sleep Measures

(Appendix D Table 5.16.4)

Jokic 1999 reported a nonsignificantly larger drop in arousal index in patients on CPAP as compared with those on positional therapy. No significant differences in maintenance of wakefulness testing, sleep latency, sleep efficiency, percentage of time spent in stage 3–4 sleep, and percentage of time spent in REM sleep were observed. Arousal index was nonsignificantly higher in patients on positional therapy (difference = 4.5 events/hr; 95 percent CI −0.7, 9.4; P=0.08).

#### Quality of Life

(Appendix D Tables 5.16.5 & 5.16.6)

Skinner 2004 and Skinner 2008 both reported no significant difference in SF-36 mental component and physical component summaries for patients in the CPAP group compared with those in the positional therapy group (Appendix D Table 5.16.5a–b). Skinner 2004 also found no significant difference in FOSQ score between the two groups (Appendix D Table 5.16.6).

Jokic 1999 found a lower score in the Nottingham Health Profile energy subscale in the positional therapy group (difference = −1; P=0.04; Appendix D Table 5.16.7a), but no difference between treatments in the Hospital Anxiety and Depression Scale (Appendix D Table 5.16.7b), University of Wales Institute of Science and Technology (UWIST) mood adjective checklist (Appendix D Table 5.16.7c), or General Health Questionnaire (Appendix D Table 5.16.7d).

#### Neurocognitive Tests

(Appendix D Table 5.16.7)

Jokic 1999 found no significant difference between CPAP and positional therapy in the Wechsler Memory Scale, Purdue Pegboard, Trail-Making Test, Symbol Digit Modalities, Consonant Trigram, or Concentration Endurance Test scores.

#### Study Variability

No studies performed subgroup analyses. As study treatments were heterogeneous, we were unable to examine differences in outcomes based on patient characteristics.

#### Summary

Three small quality B crossover trials compared different positional treatments with CPAP. AHI was found to be lower in patients using CPAP than in those on positional therapy. ESS scores were not significantly different between groups. Additionally, quality of life measurements and neurocognitive tests showed no difference between positional therapy and CPAP.

Because of the small number of studies and because each study evaluated a different device, the strength of evidence is insufficient to determine the relative merit of positional therapy compared with CPAP in the treatment of OSA.

### Comparison of Weight Loss Interventions and Control Interventions

Three parallel trials compared weight loss interventions with control interventions (Appendix D Table 5.17.1).236–238 Foster 2009 enrolled patients with type 2 diabetes and randomized them to an intensive lifestyle intervention (a behavioral weight loss program involving portion-controlled diets and physical activity prescription) or a diabetes support and education program (three educational sessions on diabetes management over a 1 year period on diet, physical activity, and social support). Johannson 2009 randomized patients to a group following a 9 week low energy diet or a group that was instructed to adhere to their usual diet. Tuomilehto 2009 enrolled obese patients and randomized them to a group following a very low calorie diet complemented with lifestyle changes or a group subject to general counseling on diet and exercise only. Mean baseline AHI in these studies ranged from 9 to 37 events/hr. Study sample sizes ranged from 63 to 264 (total = 345 across studies). Study durations ranged from 2.3 to 12 months. Johansson 2009 was rated quality A, while the other two were rated quality B. The main methodological concerns were the lack of clarity on whether the outcome data included all initial participants and unclear reporting of outcomes. The inclusion criteria used in these studies varied considerably in terms of baseline OSA severity, presence of comorbidities, and severity of obesity. The studies are generally applicable to people with BMI >30 kg/m^2^.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Treatment Response

(Appendix D Table 5.17.2)

Tuomilehto 2009 examined cure from OSA as a dichotomous outcome. OSA was considered objectively cured when the AHI was <5 events/hr at 1 year. Treatment with a very low calorie diet was associated with a 4-fold increase in the odds of being cured from OSA at 1 year compared with the control intervention (adjusted odds ratio 4.2; 95 percent CI 1.4, 12; P=0.011).

#### Apnea-Hypopnea Index

(Appendix D Table 5.17.3)

All three studies examined AHI and demonstrated statistically significant reductions in AHI for the arms randomized to weight loss interventions. The reductions ranged from −4 to −23 events/hr. Johansson 2009 showed the largest net reduction in AHI. This study enrolled patients with no comorbidities but with more severe OSA (baseline AHI = 37) as compared to the other two studies; it also involved a much shorter duration of followup (9 weeks).

#### Epworth Sleepiness Scale

(Appendix D Table 5.17.4)

Two trials provided data on changes in daytime sleepiness as assessed using the ESS. Johansson 2009 reported a statistically significant reduction in ESS scores for the low energy diet group, while Tuomilehto 2009 found no significant difference.

#### Minimum Oxygen Saturation

(Appendix D Table 5.17.5)

Only Johansson 2009 reported changes in minimum oxygen saturation; the lower energy diet was associated with a statistically significant net increase in the minimum oxygen saturation as compared to usual diet (5 percent; 95 percent CI 2, 7; P=0.002).

#### Other Outcomes

(Appendix D Tables 5.17.6–5.17.8)

Tuomilehto 2009 examined the impact of a weight loss intervention on blood pressure measurements (Appendix D Table 5.17.6). No statistically significant changes were detected for systolic or diastolic blood pressure. Foster 2009, which was conducted exclusively in diabetic patients, examined the impact of an intensive lifestyle intervention on hemoglobin A1c concentration (Appendix D Table 5.17.7) and reported a statistically significant net difference (−0.5 percent; P<0.001) at 1 year followup.

In all three studies, the weight loss program resulted in large reductions in weight (Appendix D Table 5.17.8) of −10.7, −10.8, and −18.7 kg; the control interventions resulted in near stable weight (changes ranging from −2.4 to +1.1 kg). These differences were all highly statistically significant (P<0.001).

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of weight loss interventions versus control interventions for OSA in terms of patient characteristics (age, sex, race, weight, bed partner, and airway) or severity of OSA.

Given the small number of studies and the variability of interventions, no conclusions could be reached regarding whether effects of weight loss interventions varied for different subgroups of patients.

#### Summary

Findings from three parallel RCTs supported a benefit of intensive weight loss interventions in reducing AHI. The reviewed studies were quality A or B and reported consistent results supporting the improvement of AHI with weight loss interventions, either as a continuous outcome (three studies) or as a dichotomous outcome for cure based on an AHI of less than 5 events/hr (one study). It should be noted, however, that the study that showed the largest benefit had relatively few participants. Conclusive statements cannot be made about other outcomes evaluated due to inconsistent results or a limited number of studies per outcome. No data on objective clinical outcomes were reported. Overall, there is a low strength of evidence to show that some intensive weight loss programs may be effective in relieving the signs and symptoms of sleep apnea in obese patients with OSA.

### Comparison of Oropharyngeal Exercise and Control

Three trials compared different methods of oropharyngeal exercise with CPAP (Appendix D Table 5.18.1).239–241 All three had a parallel design, and tested methods intended to train aspects of the upper airway and reduce symptoms of OSA. These methods included didgeridoo training, oropharyngeal exercise, and tongue training.

Mean baseline AHI ranged from 20 to 27 events/hr. Study sample sizes ranged from 25 to 57 patients. Both Puhan 2005 and Randerath 2004 were rated quality A, while Guimaraes 2009 was rated quality B due to a small sample size and unclear reporting. The studies are generally applicable to patients with AHI ≥15 events/hr.

#### Study Results

(Appendix D Tables 5.18.2–5.18.10)

As the devices compared varied considerably and each study examined different outcomes, trials are described separately below. No study evaluated objective clinical outcomes.

Guimaraes 2009^240^ compared oropharyngeal exercise (consisting of exercise of the soft palate, tongue, and facial muscles plus stomatognathic function exercises) to sham therapy (consisting of deep breathing, nasal lavage, and recommendations for bilateral chewing). The sample consisted of 31 patients with moderate OSA (AHI 15–30 events/hr). Patients were excluded if they had a BMI >40 kg/m^2^ or major comorbidities. Patients in the oropharyngeal exercise group were 64 percent male and had a mean age of 52 years. Those in the control group were 73 percent male and had a mean age of 48 years. The study found that oropharyngeal exercise resulted in a significantly lower AHI (difference = −12 events/hr, 95 percent CI −19, −5; P<0.001) (Appendix D Table 5.18.2), as well as lower ESS scores (difference = −4.0; 95 percent CI −8, −0.02; P<0.05) (Appendix D Table 5.18.3). No significant differences between groups were observed in minimum oxygen saturation (Appendix D Table 5.18.4) or sleep efficiency (Appendix D Table 5.18.5). The oropharyngeal exercise group had a significantly lower Pittsburgh Quality of Sleep Index score (difference = −3.4; P<0.01) (Appendix D Table 5.18.9).

Randerath 2004^241^ compared tongue training (using a muscle stimulator placed under the tongue and chin) to sham training (using the same device but without electrical stimulation). The study consisted of 57 newly diagnosed OSA patients with an AHI of 10–40 events/hr. Patients had no other significant comorbidities. Patients in the tongue training group were 57 percent male and had a mean age of 51 years. Those in the control group were 73 percent male and had a mean age of 53 years. The study found no significant difference between groups in AHI, ESS, minimum oxygen saturation (Appendix D Tables 5.18.2–5.18.4), slow-wave or REM sleep (Appendix D Table 5.18.6), arousal index (Appendix D Table 5.18.6), FOSQ score (Appendix D Table 5.18.8), or Attention Test score (Appendix D Table 5.18.10).

Puhan 2005^239^ compared didgeridoo training to no treatment. The study consisted of 25 mostly male patients (mean age: 49 years) with an AHI range of 15–30 events/hr and a mean BMI ≤30 kg/m^2^. All patients complained of snoring. Training consisted of instruction on the didgeridoo, which involves learning a breathing technique called circular breathing. Patients practiced for 30 minutes daily, 6 days a week. After 4 months, the didgeridoo group had a significantly lower AHI (difference = −6.2 events/hr; 95 percent CI −12.3, −0.1; P=0.05; Appendix D Table 5.18.2) and ESS score (difference = −2.8; 95 percent CI −5.7, −0.3; P=0.04; Appendix D Table 5.18.3). No differences between groups were observed in any domain of SF-36 or in the Pittsburgh Quality of Sleep Index (Appendix D Table 5.18.9).

#### Study Variability

None of the studies reviewed performed subgroup analyses. No comparisons could be made across studies.

#### Summary

Three trials with unique comparisons compared oropharyngeal exercise to control for treatment of patients with OSA. One study on a specific form of oropharyngeal exercise and one study on didgeridoo training reported improved sleep study measures. A third study found tongue training to not be beneficial in relieving the symptoms of OSA. Overall, due to the limited number of studies, the strength of evidence is insufficient to determine a definitive benefit of oropharyngeal exercise in the treatment of OSA.

### Comparison of Palatal Implant and Placebo Implant

Two RCTs compared palatal implants and placebo implants in patients with OSA (Appendix D Table 5.19.1).242,243 Both studies included only patients with mild to moderate sleep apnea and no other significant comorbidities. Mean baseline AHI was 20 events/hr in Friedman 2008 and 16 events/hr in Steward 2008; mean ESS values were 11.7 and 10.6, respectively. While Friedman 2008 had an equal sex distribution, Steward 2008 included a majority (79 percent) of men most of whom had retropalatal pharyngeal obstruction. The mean ages of patients in the studies were 39 years (Friedman 2008) and 49 years (Steward 2008). Friedman 2008, a quality A study, enrolled 62 patients and Steward 2008, a quality B study, enrolled 100 patients. Both studies were double-blinded and had a 3 month followup (Appendix D Table 5.19.1). Neither study evaluated objective clinical outcomes. These studies are applicable to patients with AHI of 5 to 40 events/hr and BMI less than 30 kg/m^2^.

#### Study Results

(Appendix D Tables 5.19.2–5.19.6)

Friedman 2008 found significant improvements in AHI (P<0.0001; Appendix D Table 5.19.2a), ESS values (P=0.0002; Appendix D Table 5.19.3), and SF-36 total score (P<0.0001) with palatal implants as compared to placebo. The study did not find significant differences in minimum oxygen saturation (Appendix D Table 5.19.4) or REM sleep as a percentage of total sleep time (Appendix D Table 5.19.5) between groups. This study was rated quality A.

In contrast, Steward 2008 did not find statistically significant differences in mean AHI (Appendix D Table 5.19.2a) or ESS values (Appendix D Table 5.19.3) between palatal implants and placebo. However, the study did find that a clinically meaningful reduction in AHI (≥50 percent reduction to <20 events/hr) was more common in the palatal implant group as compared to placebo (26 versus 10 percent, P=0.04; Appendix D Table 5.19.2b). The study also reported significant improvements in minimum oxygen saturation (P=0.007; Appendix D Table 5.19.4) and FOSQ (P<0.05; Appendix D Table 5.19.6) with palatal implants as compared to placebo. This study was rated quality B.

#### Study Variability

Neither study performed subanalyses. Due to the limited number of studies, we were unable to assess potential differences with regards to factors of interest such as patient characteristics and severity of obstructive sleep apnea.

#### Summary

Two studies in patients with mild to moderate OSA compared treatment effects of palatal implants to placebo implants. Both studies found significantly greater improvements in sleep study measures and quality of life with palatal implants; however, the studies disagreed as to which specific outcomes palatal implants significantly improved. Overall, due to the limited number of studies reviewed, the strength of evidence is insufficient to determine the relative efficacy of palatal implants versus sham implants in patients with mild to moderate OSA.

### Comparison of Surgery and Control Treatments

Six trials in seven publications and one prospective nonrandomized comparative study investigated the effects of several surgical interventions compared to control (Appendix D Table 5.20.1).124,125,244–249 Each study used a different intervention: uvulopalatopharyngoplasty (UPPP), laser-assisted uvulopalatoplasty (LAUP), radiofrequency ablation (RFA), and combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty, radiofrequency ablation of the inferior nasal turbinates, or combination nasal surgery. The control treatments were sham surgery, conservative therapy, or no treatment.

Patients included in the surgery comparisons were reported to have prior treatment failures with nonsurgical techniques or declined their usage. The mean baseline AHI ranged from 5 to 40 events/hr; three trials included patients with an AHI ≥5, one with an AHI ≥10, and one did not report an AHI threshold. One trial reported ODI (mean at baseline 21–72 events/hr). All included only patients with relatively less severe OSA (AHI <30–50). Study sample sizes ranged from 26 to 52 (total = 223 across studies). Three studies were rated quality A, one quality B, and two quality C. Guilleminault 2008 was reported as a crossover study comparing several surgical combinations to cognitive behavioral therapy. This study was rated quality C due to an inappropriate study design as the effects of surgery could not be reversed. These studies are applicable mostly to patients with a range of baseline AHI and BMI less than 35 kg/m^2^.

#### Study Results

(Appendix D Tables 5.20.2–5.20.7)

As each study evaluated a different surgical technique, each study is described individually. No studies evaluated objective clinical outcomes.

Back 2009 compared a single session of RFA surgery of the soft palate to sham surgery (simulated surgery with no energy administered). The study included 32 male patients with mild sleep apnea (AHI 5–15 events/hr) and habitual snoring following a failed trial of conservative treatment (weight loss, positional therapy, restriction of alcohol and sedatives). Patients were between the ages of 30 and 65 years. At 4 month followup, no statistically significant difference between groups in AHI (Appendix D Table 5.20.2), ESS (Appendix D Table 5.20.3), minimum oxygen saturation (Appendix D Table 5.20.4), and quality of life (as measured by SF-36; Appendix D Table 5.20.7) were found. This study was rated quality A.

Koutsourelakis 2008 randomized patients to either nasal surgery (submucous resection of the deviated septum and bilateral resection of inferior turbinates) or sham surgery (simulated nasal surgery under anesthesia). In addition to OSA (defined as AHI ≥5 events/hr), all patients had fixed nasal obstruction due to deviated nasal septum. The study was conducted on 49, predominately male patients with a mean baseline AHI of 31 events/hr. After 4 months followup, the study found no statistically significant difference between groups in AHI (Appendix D Table 5.20.2) or on ESS (Appendix D Table 5.20.3). This study was rated quality A.

Woodson 2003 conducted a three-arm RCT that included a comparison of multilevel temperature controlled RFA of the soft palate with sham surgery (simulated RFA with no energy delivered). The study was conducted in 51, predominately male patients. Notably, the age of participants between groups was significantly different at baseline. (49 years (RFA) versus 51 years (sham), P=0.04). The mean baseline AHI also differed among groups (21 (RFA) versus 15 (sham) events/hr; P=0.06, including the CPAP study group). After 8 weeks followup, the study found a significantly greater improvement in sleep quality as measured by FOSQ with RFA as compared to sham surgery (P=0.04; Appendix D Table 5.20.6), but no statistically significant difference in AHI (Appendix D Table 5.20.2), ESS (Appendix D Table 5.20.3), minimum oxygen saturation (Appendix D Table 5.20.4), or quality of life as measured by SF-36 (Appendix D Table 5.20.7). This study was rated quality A.

Ferguson 2003 randomized patients to either LAUP or no treatment. In LAUP, the uvula and a specified portion of the palate is vaporized under local anesthesia in an outpatient setting. The goal is to relieve obstruction in patients with mild OSA or snoring. The study included 44 mostly male patients with mild OSA (AHI 10–27 events/hr) and snoring. The patients had a mean age of 45 years and a mean BMI of 31.6 kg/m^2^. This study reported disparate followup durations of 15 months in the LAUP group and 8 months in the control group. A statistically significant improvement in AHI was observed following LAUP as compared with no treatment (net change −10.5 events/hr; P=0.04; Appendix D Table 5.20.2). However, there was no statistically significant difference between groups on the ESS (Appendix D Table 5.20.3) or in quality of life as measured by SAQLI (Appendix D Table 5.20.7). This study was rated quality B.

Guilleminault 2008 was reported as a crossover study comparing several surgical combinations to cognitive behavioral therapy in 30 patients with insomnia and mild OSA (mean AHI 10 events/hr). Based on anatomy, disease severity, and comorbidity, patients received combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty, and RFA of the inferior nasal turbinates. Since the surgery could not be undone during the second phase of the study, we evaluated only the first phase as a parallel trial. Results showed that surgery led to improvements in AHI (−6.2 events/hr; P=0.0001; Appendix D Table 5.20.2), ESS (−1.1; P=0.002; Appendix D Table 5.20.3), minimum oxygen saturation (4.4 percent; P=0.0001; Appendix D Table 5.20.4), REM (2.9 percent of total sleep time; P=0.0001; Appendix D Table 5.20.5), and slow wave sleep (3.5 percent of total sleep time; P=0.0001; Appendix D Table 5.20.5) as compared to cognitive behavioral therapy. This study was rated quality C due to the design issues described above.

Lojander 1996 & 1999 compared UPPP with or without mandibular osteotomy to conservative treatment (weight loss, positional therapy, and avoidance of tranquilizers and alcohol at bedtime). The study included 32, predominately male patients with a mean age of 47 years and a mean baseline BMI of 31 kg/m^2^. Baseline ODI ranged from 10 to 72 events/hr. A significant improvement in daytime somnolence (net difference −25 on a visual analogue scale ranging from 0 (no somnolence) to 100 (worst); P<0.05) was observed after 12 months; no statistically significant difference was found between groups in cognitive function (Wechsler test; Appendix D Table 5.20.7). This study was rated quality C due to problems with the power calculation, a small sample size, and a possible selection bias stemming from the use of an expert panel to determine which patients would be most suitable for UPPP.

Li 2009, in a nonrandomized prospective study (quality C), compared correction of nasal septum and volume reduction of the inferior turbinates to conservative nasal treatments in patients with snoring, nasal obstruction, and OSA. The study included 66 patients, 44 of whom had surgery. The patients were almost all male, with a mean age of 38 years and a mean BMI of 26.2 kg/m^2^. Baseline AHI was 38 events/hr in the surgically treated group and 26 in the conservative treatment group (no significant difference), and baseline ESS was 10.6. The article did not report at what timepoint followup data were collected. The study found a statistically significant difference in ESS, favoring surgery (net difference −3.6; 95 percent CI −6.1, −1.1; P=0.02; Appendix D Table 5.20.3). The study found no difference in AHI, minimum oxygen saturation, slow wave sleep, or REM sleep (Appendix D Tables 5.20.2, 5.20.4, 5.20.5) However, seven of 44 patients receiving surgery had success by the Sher criteria (followup AHI <30 events/hr and reduction in AHI of at least 50 percent) and none of the 22 patients on conservative treatment (P=0.048 per the article). The study did note that six of the seven patients with surgical success had, at baseline, low ESS (<10.5), a low Friedman tongue position (grade II or III), and a low BMI (<25.8 kg/m^2^).

#### Study Variability

None of the studies performed subgroup analyses. As there is only one study per comparison, we were unable to assess potential differences with regards to factors of interest such as patient characteristics and severity of OSA

#### Summary

Seven studies with unique interventions compared surgery with control treatment for the management of patients with OSA. Due to the heterogeneity of the studies reviewed and inconsistency as to which outcomes were improved with surgery as compared to no or sham surgery, the strength of evidence is insufficient to evaluate the relative efficacy of surgical interventions for the treatment of OSA.

### Comparison of Surgery and CPAP Treatments

Two parallel RCTs,247,250 four prospective studies,251–254 and six retrospective studies255–260 investigated the effects of several surgical interventions compared with CPAP in adults with OSA (Appendix D Table 5.21.1). The surgery modalities compared include temperature-controlled radiofrequency tissue volume reduction of the soft palate, UPPP, maxillomandibular advancement osteotomy, and radiofrequency ablation (RFA). Only one trial (Woodson 2003) included patients who had neither prior surgery nor prior CPAP. The other trial (Vicini 2010) excluded patients with prior surgery but did not report on prior CPAP use. The remaining studies either explicitly or implicitly were biased in that the patients receiving surgery had already failed or refused CPAP or other nonsurgical interventions, in contrast with the patients who were being treated with CPAP.

Mean baseline AHI ranged from 5 to 80 events/hr across the studies. Most studies had a mean age above 45 years and a mean BMI ≤35 kg/m^2^. The studies enrolled predominately male subjects (≥70 percent). Although Conradt 1998 included patients with craniofacial abnormalities, all other studies included patients with no important comorbidity. Study sample sizes ranged from 25 to 22,898 patients (total = 24,215 across studies). One study was rated quality A and the remainder rated quality C due to inadequate reporting of eligibility criteria, inconsistent reporting, small sample sizes, and discrepancies between followup periods. Studies included patients with a wide range of baseline AHI, but were heterogeneous in the severity of OSA within each study, thus limiting the applicability of most studies. Studies mostly included patients with BMI ≤35 kg/m^2^.

#### Mortality

(Appendix D Tables 5.21.2 & 5.21.3)

Two retrospective studies evaluated the effects of UPPP compared with CPAP on long-term survival.257,260 No studies evaluated any other objective clinical outcomes.

Weaver 2004 compared 20,826 patients using CPAP to 2072 patients who had UPPP. All patients were followed for at least 6 years in a database at Veterans Affairs medical facilities. In addition to UPPP, about one-quarter to one-third of patients also received tonsillectomy, septoplasty, or, turbinate procedures, and about 2 percent of patients had tracheotomy or tongue procedures, each. After adjusting for age, sex, race, date of initial treatment, and comorbidities, the study found a higher mortality in the CPAP than in the UPPP group at all time periods throughout the study. The adjusted hazard ratio of death for CPAP versus UPPP was 1.31 (95 percent CI 1.03, 1.67; P=0.03).

Keenan 1994 found no difference in age-adjusted 5 year survival between the cohorts of 275 patients who had received UPPP or CPAP. Compared with those who used CPAP, patients who received UPPP had a significantly lower BMI (30 versus 36 kg/m^2^; P<0.001) and a higher arousal index at baseline (25 versus 20 events/hr; P<0.01). However, the results are difficult to interpret as the followup for UPPP patients was significantly longer than that of patients receiving CPAP (43 versus 28 months; P<0.001).

#### Apnea-Hypopnea Index or Respiratory Disturbance Index

(Appendix D Table 5.21.4)

One RCT250 and four prospective studies reported outcomes on AHI, RDI, or a combination of AHI and RDI.251,254,256,258 Vicini 2010 randomly assigned 50 patients to either maxillomandibular advancement or autoCPAP therapy and compared treatment effects at the end of 12 months. They found no statistically significant difference in AHI between groups (−48.7 versus −44 events/hr; P=0.21). Ceylan 2009, a prospective, nonrandomized comparative study, reported AHI. This study compared single-stage, multilevel temperature-controlled radiofrequency tissue volume reduction of the soft palate and base of the tongue to CPAP and found no significant difference in changes in AHI between the two groups after 12 months followup. The other studies reported RDI. As each study evaluated a different surgical technique, each study result is described separately.

After 3 months followup, Conradt 1998 found essentially the same large declines in RDI (−54 events/hr) after maxillomandibular advancement osteotomy and CPAP in prospectively followed cohorts of patients. Lin 2006, in a retrospective analysis comparing extended uvulopalatoplasty (UPP) found a significantly larger improvement in RDI in patients on CPAP as compared to surgery (−63 versus −32 events/hr; P<0.001). However this study also had significant differences between groups in several baseline characteristics including age (51 yr versus 45 yr; P=0.005), BMI (28.1 versus 26.4 kg/m^2^; P=0.025), RDI (65.3 versus 43.6 events/hr; P<0.001), and ESS (14.1 versus 11.8; P=0.005).

Katsantonis 1988, using retrospective data, compared patients who had UPPP with those who were treated with CPAP (other reported interventions are not included from this retrospective study). They analyzed 98 mostly male patients with moderate to severe OSA who had UPPP and a sample of 44 of 138 patients who received CPAP. Patients were categorized as good responders (>50 percent improvement in AHI and 85 percent improvement in severity index [number of abnormal breathing events/hr with <85 percent oxygen saturation]), poor responders (<50 percent decrease in AHI and severity index), and moderate responders (those in between). After 18 months followup, the study reported 100 percent of patients using CPAP were good responders. In contrast, of those who received UPPP, 38 percent were good responders, 34 percent moderate responders, and 28 percent poor responders. The study was rated quality C due to poor reporting and a lack of reported eligibility criteria.

#### Epworth Sleepiness Scale

(Appendix D Table 5.21.5)

Two RCTs,247,250 one prospective nonrandomized study,252 and three retrospective studies254,258,259 compared various surgical techniques with CPAP for the treatment of OSA. None of the studies found statistically significant differences in ESS values between surgery and CPAP.

#### Objective Sleepiness and Wakefulness Tests

(Appendix D Tables 5.21.2 & 5.21.6)

Two studies reported objective sleepiness using the Multiple Sleep Latency Test.253,255 Zorick 1990 compared UPPP with CPAP and found no statistically significant improvement in excessive daytime sleepiness (net difference −4.5; P<0.05). Anand 1991 found that 30 percent of UPPP patients and 41 percent of CPAP patients increased their Multiple Sleep Latency Test score by at least 3 minutes. No statistical analysis was reported.

#### Other Sleep Study measures

(Appendix D Tables 5.21.6 & 5.21.7)

Two studies reported REM and stage 3 and 4 sleep as a percentage of total sleep time,251,253 one study reported arousal index,251 and one study reported minimum oxygen saturation.254 Zorick 1990 found that after 6 weeks of followup there was a statistically significant relative increase in REM and stage 3 or 4 sleep in the CPAP as compared to the UPPP group. Conradt 1998 found no difference in arousal index, sleep efficiency, REM sleep, or stage 3 and 4 sleep 3 months after maxillomandibular advancement osteotomy or CPAP. Ceylan 2009 found a nonsignificant difference of 2.7 percent between temperature-controlled radiofrequency tissue volume reduction of the soft palate and CPAP.

#### Quality of Life

(Appendix D Tables 5.21.6 & 5.21.8)

Three studies, two of which compared temperature-controlled radiofrequency tissue volume reduction of the soft palate and base of the tongue to CPAP and one which compared extended uvulopalatoplasty to CPAP, found no difference between groups in all domains of SF-36.^247,252,258^ Both Woodson 2001 and Woodson 2003 found no difference in FOSQ after 2 to 3 months of follow up.247,252

#### Study Variability

One study reported a subgroup analysis. Keenan 1994 retrospectively analyzed data from 208 patients with OSA over a 6 year period. Patients were stratified by apnea index. For patients with an apnea index >20 events/hr, the study found no significant differences in cumulative survival between UPPP and CPAP. No data were reported separately for those patients with apnea index ≤20 events/hr.

#### Summary

Of 12 studies comparing surgical modalities with CPAP, two were RCTs. The quality A trial was the only unbiased comparison of surgery and CPAP (patients had previously received neither treatment) did not find statistically significant differences in ESS and quality of life measures between patients with mild to moderate OSA (AHI 10 to 30 events/hr) who had temperature-controlled radiofrequency tissue volume reduction of the soft palate and those who had CPAP at 2 months followup. Similarly, the other trial found nonstatistically significant differences in AHI and ESS in patients with severe OSA (AHI ≥30 events/hr) between maxillomandibular advancement osteotomy and CPAP.

For the nonrandomized studies, comparisons between surgery and CPAP are difficult to interpret since baseline patient characteristics (including sleep apnea severity) differed significantly between groups (and not always in a consistent manner, i.e., the surgical group could have a higher AHI than the CPAP group in one study and vice versa in another study). The reported findings on sleep study and quality of life measures were heterogeneous across studies.

Due to the heterogeneity of interventions and outcomes examined, the variability of findings across studies, and the inherent bias of all but one study regarding which patients received surgery, it is not possible to draw useful conclusions comparing surgical interventions with CPAP in the treatment of patients with OSA at this time. Therefore the strength of evidence is insufficient to determine the relative merits of surgical treatments versus CPAP.

### Comparison of Surgery and Mandibular Advancement Devices

One parallel design RCT across three publications compared the effects of a MAD with uvulopalatopharyngoplasty (UPPP) in patients with mild to moderate OSA and no other significant comorbidities.261–263 Subjects were 95 men with a mean age of 50 years and a mean BMI of 27 kg/m^2^. Mean baseline AHI was 19 events/hr. Patients were followed for up to 4 years. Results at 12 months showed that 80 percent of patients using MAD achieved a decrease in AHI of ≥50 percent compared to 60 percent who had UPPP (P<0.05). A statistically significant reduction in AHI was also observed in the MAD group as compared to the UPPP group at 4 years (−11 versus −6 events/hr; net difference −5 events/hr; 95 percent CI [estimated] −9, −1; P<0.001 [P analyzed for final values, not net difference]). Objective clinical outcomes were not evaluated. This study was rated quality B. This study is applicable mainly to patients with apnea index scores between 5 and 25 events/hr. It was restricted to patients with sufficient number of teeth to anchor the mandibular devices in place. With only one study that evaluated only AHI, the strength of evidence is insufficient regarding the relative merit of MAD versus surgery in the treatment of OSA.

### Comparison of Drug Therapy and Control

Seven RCTs compared different drug treatments with controls (Appendix D Table 5.23.1).205,264,265,265–268 All but Ryan 2009 were crossover trials. The studied drugs included mirtazapine, xylometazoline, fluticasone, paroxetine, pantoprazole, steroid plus CPAP (versus CPAP alone), acetazolamide, and protriptyline (Appendix D Table 5.23.1). All trials used placebo controls except for Ryan 2009, which used CPAP without steroid as a control.

Mean baseline AHI ranged from 10 to 36 events/hr. Study sample sizes ranged from 10 to 81, with a total of 231 across the studies. One study was rated quality A, five were rated quality B, and one was rated quality C. Whyte 1988 was rated quality C because of its lack of exclusion criteria and a washout period.

#### Study Results

(Appendix D Tables 5.23.2–5.23.9)

As each study evaluated a different drug therapy, each study is described individually. No study evaluated objective clinical outcomes.

Carley 2007^264^ compared two mirtazapine doses (4.5 mg and 15 mg) to control. Both groups on mirtazapine had a significantly lower AHI than the control group (P=0.004). The 15 mg mirtazapine group had a significantly lower arousal index (P=0.02), higher sleep efficiency (P=0.05), and lower REM sleep percentage (P=0.04) than the controls; however, the 4.5 mg group did not differ from the control group in these outcomes. Neither drug group differed from controls in slow wave sleep, minimum oxygen saturation, or Stanford Sleepiness Scale score.

Clarenbach 2008^269^ did not find a difference in AHI, ESS, arousal index, sleep efficiency, slow wave sleep, or REM sleep between the xylometazoline group and control.

Kiely 2004^265^ found a significantly lower AHI in the fluticasone group as compared to the placebo group, both in patients with an AHI ≥10 events/hr (median difference = −6.5 events/hr; P<0.05) and in patients with an AHI ≥5 events/hr (median difference = −5.6 events/hr; P=0.01). The drug group did no differ from controls in REM sleep or minimum oxygen saturation.

Kraiczi 1999^266^ found a lower AHI in the paroxetine group than in the control group (95 percent CI −17.9, 0.6; P=0.021^i^). The drug group did not differ from the control group in sleep efficiency, slow wave sleep, REM sleep, or Comprehensive Psychopathological Rating Scale (CPRS) score.

Whyte 1988 did not find a significant difference in AHI, arousal index, sleep efficiency, slow wave sleep, REM sleep, or minimum oxygen saturation between acetazolamide and control, or between protriptyline and control.

Suurna 2008 found a lower ESS score in the pantoprazole group as compared to control (difference = −0.5; 95 percent CI −0.98, −0.02; P=0.04), but no significant difference in FOSQ score (difference = 0.06; 95 percent CI −5.3, 0.1; P=0.06).

Ryan 2009 did not find a statistically significant difference in ESS, SF-36 score, or Mini Rhinoconjunctivitis Quality of Life Questionnaire score between the steroid plus CPAP and dry CPAP groups.

#### Study Variability

None of the studies reviewed performed subgroup analyses. As the drugs used were different in each study, we were not able to examine differences with regard to patient characteristics across studies.

#### Summary

Seven trials compared different drugs with control for the treatment of patients with OSA. Due to the heterogeneous nature of the drugs examined and the different findings reported, it is not possible to draw any general conclusions about the effects of drugs on the treatment of OSA at this time. As only one study examined each drug, the strength of evidence is insufficient to evaluate the effectiveness of any individual drug for the treatment of OSA.

### Comparison of Atrial Overdrive Pacing and Control or CPAP

Two crossover trials examined atrial overdrive pacing in the treatment of OSA (Appendix D Table 5.24.1).270,271 Both trials evaluated patients who had pacemakers that had been implanted for an underlying arrhythmia. The pacemakers were capable of specific scheduling for overnight atrial overdrive pacing. Melzer 2006 compared atrial overdrive pacing of 75 beats per minute with sham pacing of 45 beats per minute in 20 patients.270 Simantirakis 2009 compared atrial overdrive pacing (pacing at 14 beats per minute greater than spontaneous mean nocturnal heart rate) with CPAP (and no atrial overdrive pacing) in 16 patients.271 The mean baseline AHI in the trials were 27^270^ and 49 events/hr.271 Melzer 2006 excluded patients with other ventilatory OSA interventions. This study was rated quality A. Simantirakis 2009 excluded those with left ventricular dysfunction or heart failure. This study was rated quality B, as it did not provide a description of how CPAP pressure was titrated and had a small sample size. The studies are applicable to patients who already have implanted pacemakers without cardiac dysfunction.

#### Objective Clinical Outcomes

No study evaluated objective clinical outcomes.

#### Apnea-Hypopnea Index

(Appendix D Table 5.24.2)

Both trials provided data on AHI outcomes. Melzer 2006 did not find a statistically significant difference between atrial overdrive pacing and control. Simantirakis 2009 did not find a statistically significant difference between atrial overdrive pacing and CPAP.

#### Epworth Sleepiness Scale

(Appendix D Table 5.24.3)

Simantirakis 2009 did not find a statistically significant difference between atrial overdrive pacing and CPAP in ESS score.

#### Other Sleep Measures

(Appendix D Table 5.24.4)

Melzer 2006 did not find a statistically significant difference between atrial overdrive pacing and CPAP in slow wave sleep or REM sleep.

#### Study Variability

No study reported subgroup analyses with respect to the comparative effect of atrial overdrive pacing versus no pacing in terms of patient characteristics (age, sex, race, weight, bed partner, and airway) or severity of OSA.

#### Summary

Two trials examined atrial overdrive pacing in the treatment of OSA. Each trial used a different control comparator (sham pacing or CPAP). Neither trial reported a benefit in sleep study measures with atrial overdrive pacing as compared to the control. As each comparison was unique and the respective sample sizes small, the strength of evidence is insufficient to determine the effect of atrial overdrive pacing on sleep apnea signs and symptoms.

### Comparison of Other Interventions and Controls

Five trials, each a parallel design, compared a variety of miscellaneous interventions with different controls.272–276 Freire 2006 compared acupuncture to sham acupuncture. Wang 2009 compared auricular plaster to vitamin C. Cartwright 1991 compared a tongue-retaining device, a posture alarm, or a combination of the two with no intervention. Krakow 2006 compared nasal dilator strip therapy to no treatment. Grunstein 2007 compared bariatric surgery to another weight loss protocol.

As each study evaluated different, unrelated interventions, each study is described individually. No study evaluated objective clinical outcomes. Each study’s applicability is suggested by its eligibility criteria.

#### Tongue-Retaining Device, Posture Alarm, or Combination Versus No Treatment

Cartwright 1991 compared a tongue-retaining device, posture alarm, or a combination of these therapies against no intervention in an RCT.273 The study consisted of 60 male patients with positional sleep apnea and an AHI >12.5 events/hr. Neither of the devices nor their combination resulted in significantly different changes in AHI compared to control. From reported data, the odds ratio for achieving an AHI <5.5 events/hr was nonsignificant for each intervention.

The study was rated quality C due to unclear reporting, the lack of an appropriate statistical analysis, and an inadequate description of the interventions.

#### Bariatric Surgery Versus Routine Management

The Grunstein 2007 study was a nonrandomized comparison of bariatric surgery (gastric bypass, vertical banded gastroplasty, or gastric banding) and routine obesity management (consisting of diet and exercise advice and behavior modification).272 Patients were included if they had a BMI ≥38 kg/m^2^, and were excluded if they had undergone previous bariatric surgery. Patients had previously responded to a baseline questionnaire that they had frequent apneas. There were 694 total patients, with 382 patients in the bariatric surgery group and 312 in the control group. Patients were able to choose which treatment they would receive, and were computer-matched to patients in the other treatment group. No baseline data were collected on OSA severity.

After 2 years of followup, patients who had bariatric surgery experienced significantly less persistence of sleep apnea, as defined by fewer symptoms noted on a followup questionnaire (OR = 0.16; 95 percent CI 0.10, 0.23; P<0.001).

The study was rated quality C due to a lack of randomization, a high dropout rate, and dissimilar baseline characteristics between groups.

#### Nasal Dilator Strip Versus No Treatment

Krakow 2006 compared nasal dilator strip therapy with no treatment in an RCT.275 Enrolled were 80 patients with nonsevere OSA. The nasal dilator strip group had a significantly better Pittsburgh Sleep Quality Index score (difference = 2.7; P<0.001), better Quality of Life Enjoyment and Satisfaction Questionnaire score (difference = 0.46; P=0.01), improved Insomnia Severity Index score (difference = −0.78; P<0.001), and better FOSQ score (difference = 1.3; P<0.02) than the no treatment group. The study was rated quality C due to the lack of an objective measurement of sleep apnea and unclear reporting.

#### Acupuncture Versus Control

Freire 2006 compared acupuncture (10 weekly sessions including needle manipulation) to sham acupuncture (10 weekly sessions with needles, but not at acupuncture sites, and no manipulation) or no treatment.274 Patients (N=26) were included if they had not received acupuncture before and had an AHI of 15–30 events/hr, and were excluded if they had a history of CPAP or oral device use. The mean baseline AHI was 19 events/hr.

Treatment with acupuncture resulted in statistically significant net differences in AHI compared with both sham acupuncture (net difference = −13 events/hr; 95 percent CI −21, −5; P<0.05) and no treatment (net difference = −18 events/hr; 95 percent CI −29, −6; P=0.002). The acupuncture group had no significant difference in ESS scores as compared to sham acupuncture, but a significant net reduction in ESS compared with no treatment (net difference = −5.9 events/hr; 95 percent CI −11.1, −0.7; P<0.05). Patients in the acupuncture group did not differ in sleep efficiency, REM sleep, or SF-36 total score as compared to the other groups.

The study was rated quality C due to a small sample size, an unequal number of dropouts per group, and lower quality of life measurements in the controls at baseline compared with the active treatment group.

#### Auricular Plaster Therapy

Wang 2009 compared auricular plaster therapy with vitamin C in 45 males with OSA.276 After 10 days of followup, the group randomized to auricular plaster group was found to have a lower AHI than the vitamin C group (net difference = −13 events/hr; 95 percent CI −18, −8). The study was rated quality B due to incomplete reporting.

#### Summary

Five studies examined miscellaneous interventions compared with controls in the treatment of OSA. Four of these studies were rated quality C and one was rated quality B. No consistent effects on sleep study measures were reported across different interventions as compared to inactive controls or routine treatments. As each intervention was studied only once, the strength of evidence is insufficient to determine the benefit of each intervention compared with control in the treatment of patients with OSA.

### Adverse Events

Across all studies and interventions, the reporting of adverse events (or side effects) was sparse. Almost no RCT was sufficiently large to adequately compare rates of adverse events between different interventions, particularly if analysis is focused on RCTs of actual treatments (as opposed to RCTs with placebo or sham treatment groups). Furthermore, as will be described, the types of adverse events related to different categories of treatments vary considerably, further hampering direct comparisons.

Adverse events are, therefore, evaluated here based on the cohorts of patients who received specific treatments within RCTs (e.g., CPAP), rather than by the RCT comparisons (e.g., CPAP versus surgery). In addition, based on discussions with the Technical Expert Panel about the likely dearth of RCTs and other comparative studies of surgical treatments, it was also decided that adverse events data would be collected from prospective or retrospective cohort studies of surgical treatments for OSA with at least 100 patients. It should also be noted that the summary tables include adverse event rate data for only those findings study authors reported to be (or we determined to be) clinically important and/or severe outcomes. Less clinically significant adverse events were listed for each intervention in table footnotes. In addition, data concerning a lack of adverse events (e.g., no perioperative deaths) or general results (e.g., “major adverse events”) were extracted only from studies with at least 100 patients. We did not collect data on adverse events from control, placebo, or sham treatments.

Of the 143 otherwise eligible comparative studies of two or more interventions for OSA and 13 surgical cohort studies with at least 100 treated patients, 19 comparative studies, and 12 surgical cohort studies reported adverse event data.

#### Positive Airway Pressure Devices

(Appendix D Table 5.25.1)

Only six trials of CPAP reported adverse event (or side effect) data.171,173,179,183,207,259 Trials enrolled between 21 and 73 patients using CPAP. Four of the trials compared different CPAP devices to each other; the remaining two compared CPAP to other interventions. Four studies evaluated CPAP (two compared nasal to oral CPAP) and three evaluated autoCPAP (one compared humidified to nonhumidified autoCPAP). No study of other types of CPAP reported adverse event data.

The most commonly reported adverse event was claustrophobia. In four studies with 1 to 4 month followups, claustrophobia was reported by one to three patients, representing 1.4 to 23 percent of patients. Epistaxis was reported among patients in two studies: two of 22 patients (9 percent) using nonhumidified autoCPAP, but none of the patients using humidified autoCPAP, and two of 17 patients (12 percent) using nasal CPAP (but implied no patients using oral CPAP). Excessive pressure or pressure intolerance was reported in two studies: five of 55 patients (9 percent) on CPAP in one study and 2 (4 percent) on autoCPAP in the other. Major or excessive oral dryness was reported in two studies of oral CPAP, with one study noting 11 patients (52 percent) and the other 3 (14 percent), complaining of excessive oral dryness. Only one trial reported excessive nasal dryness, with 2 (12 percent) patients noting the complaint. Severe gum pain was also reported in one study of oral CPAP in 3 of 21 (14 percent) patients. A major excess of salivation and sore gums or lips were reported in one trial of oral CPAP in 1 (5 percent) and 2 (10 percent) patients, respectively. Other more minor adverse events reported included skin irritation, nasal irritation or obstruction, dry nose or mouth, excess salivation, minor or moderate sore gums or lips, minor aerophagia, abdominal distension, minor chest wall discomfort, pressure discomfort, and transient or minor epistaxis.

Generally, about 5 to 15 percent of patients reported specific adverse events they considered to be a major problem while using CPAP. However, no study reported a severe adverse event that would not resolve quickly upon discontinuing CPAP or that may be amenable to alleviation with ancillary treatments (such as humidification).

#### Mandibular Advancement Devices

(Appendix D Table 5.25.2)

Only five RCTs of MAD reported adverse event data.212,216,225,226,262 The trials included between 19 and 48 patients using these devices. Four studies evaluated custom-made devices, with ranges of maximal mandibular advancement from 50 to 100 percent and 2–5 mm interdental clearance, and one study evaluated the Snore-Guard™ (mandible set at 3 mm posterior to maximal acceptable advance with a 7 mm opening). Four studies lasted 1 to 4 months, while one study followed patients for 4 years. All major adverse events were related to tooth, mouth, or jaw pain or damage. In one study with a device with 80 percent mandibular advancement, 3 of 48 patients (6 percent) had a dental crown damaged. One of 31 patients using a maximal advancement device had loosening of teeth. Temporomandibular joint (TMJ) or jaw pain was reported in one patient each of four studies (between 2.2 and 5.2 percent of patients). An aphthous ulcer due to acrylic polymer allergy was also reported by one patient (2.2 percent) in one study. Other more minor adverse events included a sensation of pressure in the mouth, transient morning mouth and TMJ discomfort or sounds, minor sore teeth or jaw, transient mild mucosal erosions, minor excessive salivation, tooth grinding, and sleep disruption.

Overall, about 2 to 4 percent of patients complained of jaw or temporomandibular joint pain with MAD. There were an insufficient number of patients evaluated to determine whether the likelihood of jaw pain might be related to the degree of jaw opening. More permanent damage, namely dental crown damage, occurred in 6 percent of patients in one study, but was not reported in other studies. One patient had an allergic reaction to acrylic polymer.

#### Airway Surgery Interventions

Ten eligible studies of UPPP (and related surgeries), two studies of RFA, six studies of combinations or other surgeries, and one study of palatal implants alone reported adverse events (or complications).

##### Uvulopalatopharyngoplasty

(Appendix D Table 5.25.3)

Ten eligible studies reported adverse events related to UPPP.124,245,255,262,277–282 The largest cohort study analyzed 3,130 patients who received UPPP with or without tonsil, nasal, or turbinate surgery. The remaining nine studies ranged in sample size from 18 to 158 patients and generally included similar surgeries, or tracheostomy, or, in one study, osteotomy; one study performed laser assistant uvulopalatoplasty.

Perioperative death (up to 30 days of surgery) was reported by five studies and ranged from 0/158 to 2/132 (1.5 percent) of patients. The largest cohort (Kezirian 2004) reported 7/3,130 (0.2 percent) perioperative mortality. This study reported serious complications (including death) in 51/3,130 (1.6 percent) of patients. These complications included reintubation (17 patients), pneumonia (11), hemorrhage (9), cardiovascular complication (8), emergency tracheotomy (7), and mechanical ventilation for >48 hr (6). No patients suffered deep vein thromboses or kidney failure.

Across studies, reintubation was reported in 0.5 to 5.2 percent of patients (three studies, with no long-term sequelae in one study), pneumonia in 0.4 and 1.5 percent of patients (two studies), major hemorrhage in 0.3 to 5.5 percent of patients (eight studies), and tracheotomy in 0.2 to 5.6 percent of patients (four studies). Other major perioperative adverse events reported across studies included respiratory events (six patients), substantial laryngeal edema (two patients), pulmonary edema (one patient), and postextubation asystole (one patient). Individual studies reported no perioperative airway complications, abscesses requiring surgical interventions, or rehospitalizations (in 134 patients), or infections or arrhythmias (in 101 patients).

Adverse events reported over the long term (3 months to 1, 4, or 7.25 years) included difficulty with speech or change in voice (0.6 to 15 percent; three studies); velopharyngeal incompetence (11 and 12 percent; two studies); infection requiring surgical intervention (0 and 11 percent; two studies); difficulty swallowing (5 to 10 percent; three studies); pronounced nasal regurgitation of fluids (8 percent; one study); and breathing difficulties, nasal synechiae, loss of taste, and tracheal stenosis in 5 percent of patients or fewer. One study with 158 patients reported no long-term sequelae from complications were reported.

Other adverse events (or side effects or harms) reported by studies included: unplanned medications, mild transient pain and swallowing difficulty, postoperative (minor) hematomas or ulcerations, mild bleeding, mild and transient tongue deviation, transient swelling sensation, pharyngeal dryness, nasal regurgitation (transient), increased mucus secretion, gagging, cough, infection (self-limited), antibiotic-related diarrhea, burning sensation, anosmia, temporary vocal quality change, and difficulty singing, playing saxophone, etc.

##### Radiofrequency Ablation

(Appendix D Table 5.25.4)

Two studies reported adverse events following radiofrequency ablation of the tongue base (or other sites in one study) in 497 and 73 patients, respectively.252,283 The larger cohort experienced no long-term complications (after 8 days) and the following short-term adverse events: dysphagia requiring hospitalization (4 patients; 0.8 percent), tongue base ulceration requiring surgical intervention (3 patients; 0.6 percent), and in one patient each (0.2 percent) soft palate mucosa ulceration requiring surgical intervention, temporary hypoglossal nerve palsy, and tongue base abscess requiring surgical intervention. The smaller study reported that seven patients (10 percent) had an infection or cellulitis during 6 weeks of followup, four patients (5.5 percent) had severe, suppurative tongue base infections (two of which required surgical intervention), and one patient (1.4 percent) had a tongue abscess.

Other adverse events (or side effects or harms) reported by studies included: unplanned medications, mild transient pain and swallowing difficulty, postoperative (minor) hematomas or ulcerations, mild and transient tongue deviation, transient swelling sensation, and asymptomatic fibrotic narrowing.

##### Combination or Various Surgeries

(Appendix D Table 5.25.5)

Six studies reported adverse events in patients who received a variety of other surgeries.280,284–287 These included combinations of UPPP and geniotubercle advancement, hyoid suspension, maxillary and/or mandibular osteotomy, and tongue RFA, and multilevel surgeries without UPPP, or stepwise multilevel surgeries.

The studies analyzed between 64 and 233 patients. Only one study specifically reported on perioperative death, noting that no deaths occurred. Two studies reported no major complications, though one also reported five patients (4 percent) with Pillar implant extrusion requiring removal and replacement, two patients (1.6 percent) with turbinate bone exposure, and one patient (0.8 percent) with nasal septum perforation, tongue mucosal ulceration, and hypoglossal nerve weakness lasting less than 1 month. With the exception of the smallest study, all other adverse events were reported in <2 percent of patients, including undescribed bleeding (1.9 percent), new onset atrial fibrillation (1.9 percent), transient nerve paralysis (1.4 percent), bleeding requiring anesthesia (1.3 percent), hypoglossal nerve paralysis (0.7 percent), and new unstable angina (0.5 percent). The largest study reported no long-term speech or swallowing problems and another study reported no airway complications, abscesses requiring surgical interventions, or rehospitalizations. The smallest study, examining stepwise surgery in 64 patients, had the highest reported complication rates, including paresthesia (not described; 17 percent), dysphagia (not described; 11 percent), voice change (3 percent), infection (not described; 3 percent), taste alteration (1.6 percent), wound dehiscence (1.6 percent), and transient palatal fistula (1.6 percent).

Other adverse events (or side effects or harms) reported by studies included: aspiration, neck seroma, transient dysphagia, transient tongue base ulceration, suture removal for foreign body reaction, and transient facial anesthesia.

##### Palatal Implants Alone

(Appendix D Table 5.25.6)

One study reported adverse events following insertion of Pillar palatal implants in 50 patients.243 During 1 week of followup, one patient had an undefined infection and two had extrusion of their implants. Other reported adverse events included sore throat and foreign body sensation.

#### Bariatric surgery

(Appendix D Table 5.25.7)

One large study of 1,592 patients reported adverse events following bariatric surgery performed in patients with OSA.272 Perioperative mortality was 0.21 percent, and 13 percent had bleeding, embolus and/or thrombosis, wound complications, deep infections, pulmonary, and/or other complications.

#### Weight Loss Diet

(Appendix D Table 5.25.8)

One study evaluated a liquid, very low energy diet for 30 patients with OSA.237 After 9 weeks, one patient had transient gout and two had transient elevated liver enzymes. Other reported adverse events included dizziness, dry lips, and constipation.

#### Drugs

(Appendix D Table 5.25.9)

Three studies evaluating four drugs used for OSA treatment reported adverse events.266,267,288 Acetazolamide resulted in the largest number of reported adverse events: any paresthesia in 8/10 patients and intolerable paresthesia in one patient. Protriptyline caused severe dry mouth requiring drug discontinuation in 2/10 patients and “visual upset,” urinary symptoms, and altered sexual potency with testicular discomfort in one patient each. Paroxetine use was associated with ejaculation disturbance (15 percent), decreased libido (10 percent), headache (10 percent), and constipation (10 percent). (Other reported adverse events included fatigue, mouth dryness, somnolence, and dizziness with both paroxetine and placebo, and sweating, nervousness, infectious pneumonia and Lyme disease during paroxetine treatment.) During zolpidem use, 1/72 patients (1.4 percent) experienced episodes of sleep walking.

#### Summary

Each type of OSA treatment carries its own set of potential adverse events. Based on the evidence reported among the eligible (mostly comparative) studies, with only a few exceptions, the only truly serious long-term adverse consequences from OSA treatments occurred among patients having oronasopharyngeal or bariatric surgery. These included perioperative death in up to 1.5 and 1.6 percent of patients undergoing UPPP in two studies. Most studies, however, reported no deaths. Other major postsurgical complications also included infections, hemorrhage, nerve palsies, emergency surgical treatments, cardiovascular events, respiratory failure, and rehospitalizations. Long-term adverse events included speech or voice changes, difficulties swallowing, airway stenosis, and others. In smaller studies, these events were found to occur in about 2 to 15 percent of patients (when reported). The largest studies (Kezirian 2004 with 3,130 UPPP surgeries and Stuck 2003 with 422 RFA surgeries) reported no long-term complications (not including perioperative death or cardiovascular complications).

All adverse events related to CPAP treatment were potentially transient and could be alleviated with either cessation of treatment or with adjunct interventions. Approximately 5 to 15 percent of patients reported specific adverse events they considered to be a major problem while using CPAP. These included claustrophobia, oral or nasal dryness, epistaxis, irritation, pain, or excess salivation. No adverse event with potentially long-term consequences was reported in patients receiving CPAP.

Among studies of MAD, four patients in two studies (with 79 patients total) incurred dental crown damage or loosening of teeth. TMJ or jaw pain was reported in about 2 to 4 percent of patients, although no study reported on the long-term consequences of these symptoms. It was also not clear whether the severity or frequency of TMJ symptoms was related to the degree of mandibular advancement or jaw opening.

Adverse events related to a very low energy weight loss diet or to various drugs were treatment specific. None appeared to be an adverse event with long-term consequences.

## Key Question 6 In OSA patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance?

To address this question, our literature search was restricted to longitudinal studies of at least 100 participants all of whom were prescribed nonsurgical OSA treatments and followed for at least 3 months. Only multivariable analyses of continuous positive airway pressure (CPAP) compliance were included. Because of the small number of potentially eligible mandibular advancement device (MAD) studies, all were included for review. Six studies met criteria. Five evaluated compliance with CPAP,203,289–292 one compliance with MAD.293

### Compliance with CPAP

Four of the five eligible studies were prospective cohort studies and one was a randomized control trial (RCT) of C-Flex™ versus fixed CPAP (Appendix D Table 6.1a–b).203 The patients in the cohort studies were treated with either fixed CPAP, a variety of CPAP devices, or, in one study,292 autotitrating CPAP (autoCPAP). The number of patients in the studies ranged from 112 to 1,103, and followup ranged from 3 months to 4 years. The studies were conducted mostly from the mid 1980s through the 1990s (or possibly later based on publication dates in two studies). All patients were enrolled at the beginning of their CPAP therapy. The demographics of the five studies were generally similar: a large majority of men, mean age around 50 years, mean BMI about 30 kg/m^2^, and, in four of the studies, a mean AHI between 44 and 50 events/hr (Krieger 1996 apparently included patients with more severe OSA, as their mean AHI was 70 events/hr). Three of the studies (McArdle 1999, Krieger 1996, and Wild 2004) described an active followup program to improve CPAP usage. Hui 2001 described only an initial training session. The lone RCT (Pepin 2009) did not describe the initial ancillary care for CPAP usage (Appendix D Table 6.1a). In general, the studies are applicable to patients initiating CPAP whose AHI is greater than 30 events/hr.

Each study defined compliance differently. Three studies used thresholds of 1, 2, or 3 hours of use per night (or voluntary discontinuation). The RCT used “objective compliance,” which was measured by the device, but was not defined. The smallest study evaluated hours of use per night as a continuous variable.

McArdle 1999, the largest study, provided a well documented, complete, and appropriate analysis, with no obvious selection or ascertainment biases; it was rated quality A. Wild 2004 suffered from some incomplete reporting and was rated quality B. The remaining three studies did not adequately define predictors, outcomes, or statistical analyses used, and were rated quality C (Appendix D Table 6.1b).

In McArdle 1999, 16 percent of patients discontinued CPAP at 1 year and 32 percent at 4 years. Krieger 1996 had somewhat better compliance; 14 percent withdrew from CPAP at a mean of 3.2 years. Pepin 2009 and Hui 2001 both found mean CPAP usage of about 5 hr/night at 3 months. Wild 2004 did not report compliance rates.

The four studies that evaluated baseline AHI as a predictor of compliance with CPAP all found a significant association such that a higher baseline AHI was associated with greater compliance. Krieger 1996 and McArdle 1999 found significant associations between an AHI>15 events/hr and greater compliance at 1–4 years (though the latter study found no significant association with an AHI threshold of 30 events/hr). The other two studies reported that a higher AHI (analyzed as a continuous variable) was associated with greater adherence or more hours of use per night at 1 and 3 months. In a secondary analysis, McArdle 1999 also found that AHI, analyzed as a continuous variable, was significantly associated with compliance across the range of AHI.

Three studies evaluated baseline ESS as a predictor of compliance. McArdle 1999, the quality A and largest study with the longest followup duration (4 yr), found that an ESS score >10 (and as a continuous variable) was associated with greater compliance. Wild 2004 found the same significant association, but Krieger 1996 did not find ESS to be an independent predictor, after adjusting for AHI and age. Only Krieger 1996 found that younger age (as a continuous variable) was associated with greater compliance. McArdle 1999 and Pepin 2009 did not find age to be an independent predictor.

Several potential predictors were evaluated by two studies each. In all cases the studies disagreed as to whether the factors were independent predictors of compliance. Snoring was a predictor in McArdle 1999, but not Hui 2001; lower CPAP pressure a predictor in Wild 2004, but not McArdle 1999; and higher BMI a predictor in Wild 2005, but not McArdle 1999.

Pepin 2009 focused primarily on a sleep apnea-specific quality of life scale, and did not report on potential predictors evaluated by the other studies (except age). This study found that at 3 months, higher baseline mean oxygen saturation and greater sleepiness as measured by the Grenoble Sleep Apnea Quality of Life test were associated with greater compliance.

#### Summary

Across studies, there is a moderate strength of evidence that more severe OSA as measured by higher AHI is associated with greater compliance with CPAP use. There is a moderate strength of evidence that a higher ESS score is also associated with improved compliance. There are low strengths of evidence that younger age, snoring, lower CPAP pressure, higher BMI, higher mean oxygen saturation, and the sleepiness domain on the Grenoble Sleep Apnea Quality of Life test are each possible independent predictors of compliance.

It is important to note, however, that selective reporting, particularly nonreporting of nonsignificant associations, cannot be ruled out. The heterogeneity of analyzed and reported potential predictors greatly limits these conclusions. Differences across studies as to which variables were independent predictors may be due to the adjustment for different variables, in addition to differences in populations, outcomes, CPAP machines, and CPAP training and followup.

### Compliance with Mandibular Advancement Devices

Only one retrospective cohort with 144 patients met criteria for studies evaluating predictors of compliance with MAD (Appendix D Table 6.2a–b).293 All patients received a custom-made MAD and received “standard” education concerning its use, including adjustment of the device until it was workable. Patients were predominately male with a mean age of 51 years and a mean baseline AHI of 23 events/hr. Notably, 8 percent of the patients were nonapneic snorers with an AHI <5 events/hr. The study was rated quality C as only univariable analyses were reported, predictors were poorly defined, and results were not clearly reported (Appendix D Table 6.2a). No explicit definition of compliance was provided. The study is generally applicable to patients initiating use of custom-made MAD.

The study failed to identify potential predictors that were significantly associated with MAD compliance. Variables that were analyzed included age, sex, occupation, “marital situation,” snoring, feeling refreshed after sleep, daytime somnolence, driving problems, ESS, AHI, and CPAP failure or refusal (Appendix D Table 6.2b).

## Key Question 7 What is the effect of interventions to improve compliance with device (positive airway pressure, oral appliances, positional therapy) use on clinical and intermediate outcomes?

To address this question, we included only prospective comparative studies that enrolled more than 10 subjects per intervention arm and with 2 weeks or more of followup. We accepted any measure of compliance with a device, whether categorical (compliance versus no compliance) or continuous (time spent using device). We restricted the analysis to those interventions whose primary purpose was to improve compliance with treatment. We also included three studies that evaluated different care models (nurse led care versus others) for patients who had continuous positive airway pressure (CPAP) treatments that also reported compliance outcomes.

Eighteen studies met inclusion criteria (Appendix D Table 7.1).174,288,294–309 All studies were RCTs, of parallel or crossover design, that evaluated outcomes of compliance with CPAP use. No trials evaluated measures to improve compliance with oral appliances or positional therapy. Fifteen studies examined a wide variety of interventions whose primary purpose was to improve compliance. For the purpose of this report, we categorized these interventions into four broad groups: 1) nine studies on extra support or education;174,294,296–301,303 2) three studies on telemonitoring care;295,304,305 3) one study on a behavioral intervention;302 and 4) two studies on miscellaneous interventions.288,306 The remaining three studies evaluated different care models (nurse led care versus others) for patients who had CPAP treatments.307–309 These are reviewed separately.

### Interventions To Improve Compliance With CPAP Use

#### Extra Support or Education

Nine studies evaluated the effects of extra support or education on the outcomes of compliance with CPAP use (Appendix D Tables 7.2 & 7.3).174,294,296–301,303 The patients in these studies were treated with either fixed CPAP or autotitrating CPAP (autoCPAP). Eight studies enrolled new CPAP users or patients who were newly diagnosed with OSA. The remaining study (Chervin 2007) enrolled mostly (69 percent) people who, at study baseline, were already regular CPAP users. The studies were generally small with sample sizes ranging from 10 to 112 patients followed for 3 weeks to 1 year. Seven studies enrolled patients with similar demographics: mostly men, mean age between 45 and 63 years, mean BMI between 30 and 38 kg/m^2^, and mean AHI between 42 and 58 events/hr. Wiese 2005 enrolled a nearly equal mix of men and women with mild OSA (mean AHI 9.3 events/hr). Therefore, these studies are applicable mainly to patients initiating CPAP with an AHI above about 30 events/hr and BMI greater than 30 kg/m^2^. Of the nine studies, one was rated quality A, four quality B, and the remaining four quality C. Common quality issues in quality C studies included large dropout rates, different dropout rates between compared groups, and a more complete followup in the active intervention arm than the usual care arm.

Seven studies evaluated compliance as a continuous outcome (hours of use per night). These studies compared a variety of extra support protocols (e.g., telephone calls, videotape, literature) or education programs to usual support/care. Findings were generally inconsistent. Three studies showed that intensive support or literature (designed for patient education) significantly increased hours of CPAP use per night (by an average of 1.1 to 2.7 additional hours) compared with usual care.174,294,297 However, the other four studies found no significant differences in hours of CPAP use per night between the intervention and control groups.296,298,300,301

Three studies reported categorical compliance outcomes using different definitions. Hui 2000 defined compliance with CPAP as at least 4 hours of use per night for more than 70 percent of the nights per week. The study found no significant difference in compliance rates between the augmented support and basic support groups. Smith 2009 defined compliance with CPAP use as 4 or more hours per night on at least 9 of each 14 nights (or at least an 80 percent use rate). This study found that the audio-based intervention packet significantly decreased the rate of short-term (1 month) noncompliance compared with placebo intervention (11 versus 45 percent, respectively; P<0.01). However, there was no significant difference in noncompliance rates between groups at 6 month followup. It should be noted that all dropouts without CPAP use data were counted as nonadherent patients. Wiese 2005 analyzed return to clinic for 1 month followup as a measure of compliance among patients with mild OSA, and found that significantly more patients in the control group did not return to clinic for followup than patients in the group that received an educational videotape about CPAP use (51 versus 27 percent, P=0.02). The authors noted that the CPAP usage data from the device were available only for patients who returned to clinic for the followup, thus the usefulness of these data is limited.

#### Telemonitoring Care

Three studies evaluated the effects of telemonitoring care on the outcomes of compliance with CPAP use.295,304,305 Telemonitoring care is a computer-based telecommunications system that functions as an at-home monitor, educator, and counselor to improve health-related behaviors. All studies enrolled new CPAP users or patients who were newly diagnosed with OSA. Studies were generally small with sample sizes ranging from 30 to 93 patients who were followed for 30 days to 2 months. All three studies enrolled patients with similar demographics: mostly men, mean age between 45 and 59 years, mean BMI between 32 and 38 kg/m^2^, and mean AHI 42 events/hr. Of the gthree studies, one was rated quality B and two were rated quality C.

All three studies compared telemonitoring care to usual care, and reported continuous compliance outcome as hours of CPAP use per night. Two studies found that telemonitoring increased hours of CPAP use per night (average 1.3 and 1.5 additional hours; P=0.07 and 0.08, respectively) compared with usual care at 2 month followup.295,304 The third study did not find a significant difference in hours of CPAP use per night at 30 days between patients who received telemonitoring support and those who received usual care.305 It should be noted, however, that patients in this study who had difficulties in using telemonitoring support were excluded from the analyses.

#### Behavioral Interventions

Only Richards 2007 (quality A) evaluated the effect of cognitive behavioral therapy (given to patients and their partners) on compliance outcomes in 96 patients (mean age 58 years old; mean AHI 26 events/hr) who were treated with CPAP.302 This study found that cognitive behavioral therapy significantly increased hours of CPAP use per night compared with usual care (difference = 2.8 hours; 95 percent CI 1.8, 3.9; P<0.0001). This study also performed logistic regression modeling to explore predictors of CPAP compliance at 28 days, and found that psychological factors were not independent predictors of compliance. In addition, patients in the cognitive behavioral therapy group were 6.9 times more likely to comply with CPAP use (at least 4 hours per night) than the usual care group (95 percent CI 2.8, 18.2).

#### Miscellaneous Interventions

Bradshaw 2006, in a quality B study, compared the effects of an oral hypnotic agent (zolpidem 10 mg) to placebo or standard care (without a pill) in 72 patients newly using CPAP (mean age 38 years; mean AHI 43 events/hr). The hypnotic was prescribed with the purpose of improving CPAP compliance. The study found no significant differences in hours of CPAP use or categorical CPAP compliance outcomes (using three different definitions) between groups. In a quality B crossover trial, Massie 2003 compared CPAP with nasal pillows (designed to improve the comfort of the CPAP device) to CPAP with a regular nasal mask in 39 patients newly using CPAP (mean age 49 years; mean AHI 47 events/hr). The results showed that there was no significant difference in hours of CPAP use between the two different CPAP nasal appliances.

#### Summary

Fifteen RCTs examined a wide variety of interventions to improve compliance among mostly new CPAP users. Studies generally had small sample sizes with less than 1 year of followup. Results from these 15 studies were mixed. Compared to usual care, several interventions were shown to significantly increase hours of CPAP use per night in some studies. These included intensive support or literature (designed for patient education), cognitive behavioral therapy (given to patients and their partners), telemonitoring, and a habit-promoting audio-based intervention. However, the majority of studies did not find a significant difference in CPAP compliance between patients who received interventions to promote compliance with device use and those who received usual care. Overall, there is a low strength of evidence that some specific adjunct interventions may improve CPAP compliance, but studies are heterogeneous and no general type of intervention (e.g., education) was more promising than others. In addition, no intervention has had its effect on compliance verified.

### Studies That Evaluated Different Care Models for Patients Who Had CPAP Treatments

Three RCTs that evaluated different care models (nurse led care versus others) for patients who had CPAP treatments also reported compliance outcomes (Appendix D Tables 7.2 & 7.3).307–309 Although all three studies compared a nurse-led model of care to usual care (by clinician), the components of both interventions and usual care differed across the studies. These interventions were not designed specifically to improve CPAP compliance and are thus evaluated separately.

A total of 467 patients were analyzed in these studies, which lasted from 3 months to 2 years. Of the three studies, one was rated quality B and two were rated quality C. Common quality issues in quality C studies include differential dropout rates between comparative groups and poor reporting of patient characteristics.

All three studies found no significant differences in CPAP compliance comparing nurse-led models of care to usual care.307–309

#### Summary

Three RCTs did not find improvements in patient compliance with CPAP with nurse-led care compared with usual care models. However, it should be noted that improved CPAP compliance was not a primary goal of the intervention but rather to evaluate whether nurse-led model of care would produce similar health outcomes compared to the usual care models. There is a low strength of evidence that nurse-led care does not improve CPAP compliance.