# References

1 Young T, Finn L, Peppard PE, et al. (2008). Sleep disordered breathing and mortality: eighteen-year follow-up of the Wisconsin sleep cohort. Sleep.
2 Punjabi NM, Caffo BS, Goodwin JL, et al. (2009). Sleep-disordered breathing and mortality: a prospective cohort study. PLoS Medicine/Public Library of Science.
3 Hiestand DM, Britz P, Goldman M, et al. (2006). Prevalence of symptoms and risk of sleep apnea in the US population: Results from the national sleep foundation sleep in America 2005 poll. Chest.
4 Polysomnography Task Force, American Sleep Disorders Association Standards of Practice Committee. (1997). Practice parameters for the indications for polysomnography and related procedures. Sleep.
5 Victor LD. (1999). Obstructive sleep apnea. Am Fam Physician.
6 Marin JM, Carrizo SJ, Vicente E, et al. (2005). Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lance.
7 Punjabi NM. (2008). The epidemiology of adult obstructive sleep apnea. Proc Am Thorac Soc.
8 Shahar E, Whitney CW, Redline S, et al. (2001). Sleep-disordered breathing and cardiovascular disease: cross-sectional results of the Sleep Heart Health Study. Am J Respir Crit Care Med.
9 Yaggi HK, Concato J, Kernan WN, et al. (2005). Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med.
10 Nieto FJ, Young TB, Lind BK, et al. (2000). Association of sleep-disordered breathing, sleep apnea, and hypertension in a large community-based study. Sleep Heart Health Study. JAMA.
11 Peppard PE, Young T, Palta M, et al. (2000). Prospective study of the association between sleep-disordered breathing and hypertension. New Engl J Med.
12 Young T, Peppard P, Palta M, et al. (1997). Population-based study of sleep-disordered breathing as a risk factor for hypertension. Arch Intern Med.
13 Babu AR, Herdegen J, Fogelfeld L, et al. (2005). Type 2 diabetes, glycemic control, and continuous positive airway pressure in obstructive sleep apnea. Arch Intern Med.
14 Caples SM, Gami AS, Somers VK. (2005). Obstructive sleep apnea. Ann Intern Med.
15 Gruber A, Horwood F, Sithole J, et al. (2006). Obstructive sleep apnoea is independently associated with the metabolic syndrome but not insulin resistance state. Cardiovasc Diabetol.
16 Young T, Peppard PE, Gottlieb DJ. (2002). Epidemiology of obstructive sleep apnea: a population health perspective. Am J Respir Crit Care Med.
17 Howard ME, Desai AV, Grunstein RR, et al. (2004). Sleepiness, sleep-disordered breathing, and accident risk factors in commercial vehicle drivers. Am J Respir Crit Care Med.
18 Teran-Santos J, Jimenez-Gomez A, Cordero-Guevara J. (1999). The association between sleep apnea and the risk of traffic accidents. Cooperative Group Burgos-Santander. N Engl J Med.
19 Young T, Palta M, Dempsey J, et al. (1993). The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med.
20 Young T, Shahar E, Nieto FJ, et al. (2002). Predictors of sleep-disordered breathing in community-dwelling adults: the Sleep Heart Health Study. Arch Intern Med.
21 Young T, Peppard PE, Taheri S. (2005). Excess weight and sleep-disordered breathing. J Appl Physiol.
22 Ancoli-Israel S, Kripke DF, Klauber MR, et al. (1991). Sleep-disordered breathing in community-dwelling elderly. Sleep.
23 Bixler EO, Vgontzas AN, Ten HT, et al. (1998). Effects of age on sleep apnea in men: I. Prevalence and severity. Am J Respir Crit Care Med.
24 Bixler EO, Vgontzas AN, Lin HM, et al. (2001). Prevalence of sleep-disordered breathing in women: effects of gender. Am J Respir Crit Care Med.
25 Duran J, Esnaola S, Rubio R, et al. (2001). Obstructive sleep apnea-hypopnea and related clinical features in a population-based sample of subjects aged 30 to 70 yr. Am J Respir Crit Care Med.
26 Tufts-New England Medical Center EPC. Home diagnosis of obstructive sleep apnea-hypopnea syndrome, Health Technology Assessment Database.
27 Pagel JF. (2007). Obstructive sleep apnea (OSA) in primary care: evidence-based practice. J Am Board Fam Med.
28 Vakulin A, Baulk SD, Catcheside PG, et al. (2009). Effects of alcohol and sleep restriction on simulated driving performance in untreated patients with obstructive sleep apnea. Ann Intern Med.
29 Katz ES, D’Ambrosio CM. (2010). Pediatric obstructive sleep apnea syndrome. Clin Chest Med.
30 Institute of Medicine (US) Committee on Sleep Medicine and Research, Colten HRABe. (2006). Sleep Disorders and Sleep Deprivation: An Unmet Public Health Problem, The National Academies Collection: Reports funded by National Institutes of Health.
31 American Academy of Sleep Medicine. (2005). The International Classification of Sleep Disorders, 2nd Edition: Diagnostic and Coding Manual.
32 Epstein LJ, Kristo D, Strollo PJ, et al. (2009). Clinical guideline for the evaluation, management and long-term care of obstructive sleep apnea in adults. Journal of Clinical Sleep Medicine.
33 Flemons WW, Littner MR, Rowley JA, et al. (2003). Home diagnosis of sleep apnea: a systematic review of the literature. An evidence review cosponsored by the American Academy of Sleep Medicine, the American College of Chest Physicians, and the Aerican Thoracic Society. Chest.
34 Ferber R, Millman R, Coppola M, et al. (1994). Portable recording in the assessment of obstructive sleep apnea. ASDA standards of practice. Sleep.
35 Johns MW. (1991). A new method for measuring daytime sleepiness: the Epworth sleepiness scale. Sleep.
36 Chung F, Yegneswaran B, Liao P, et al. (2008). STOP questionnaire: a tool to screen patients for obstructive sleep apnea. Anesthesiology.
37 Chung SA, Yuan H, Chung F. (2008). A systemic review of obstructive sleep apnea and its implications for anesthesiologists. Anesth Analg.
38 Finkel KJ, Searleman AC, Tymkew H, et al. (2009). Prevalence of undiagnosed bstructive sleep apnea among adult surgical patients in an academic medical center. Sleep Med.
39 Gupta RM, Parvizi J, Hanssen AD, et al. (2001). Postoperative complications in patients with obstructive sleep apnea syndrome undergoing hip or knee replacement: a case-control study. Mayo Clin Proc.
40 Loube DI, Gay PC, Strohl KP, et al. (1999). Indications for positive airway pressure treatment of adult obstructive sleep apnea patients: a consensus statement. Chest.
41 Veasey SC, Guilleminault C, Strohl KP, et al. (2006). Medical therapy for obstructive sleep apnea: a review by the Medical Therapy for Obstructive Sleep Apnea Task Force of the Standards of Practice Committee of the American Academy of Sleep Medicine. Sleep.
42 Parthasarathy S, Haynes PL, Budhiraja R, et al. (2006). A national survey of the effect of sleep medicine specialists and American Academy of Sleep Medicine Accreditation on management of obstructive sleep apnea. Journal of Clinical Sleep Medicine.
43 Chasens ER, Pack AI, Maislin G, et al. (2005). Claustrophobia and adherence to CPAP treatment. Western Journal of Nursing Research.
44 Kushida CA, Littner MR, Hirshkowitz M, et al. (2006). Practice parameters for the use of continuous and bilevel positive airway pressure devices to treat adult patients with sleep-related breathing disorders. Sleep.
45 Kushida CA, Chediak A, Berry RB, et al. (2008). Clinical guidelines for the manual titration of positive airway pressure in patients with obstructive sleep apnea. Journal of Clinical Sleep Medicine.
46 Sanders MH, Kern NB, Costantino JP, et al. (1993). Adequacy of prescribing positive airway pressure therapy by mask for sleep apnea on the basis of a partial-night trial. American Review of Respiratory Disease.
47 Freedman N. (2010). Treatment of obstructive sleep apnea syndrome. Clin Chest Med.
48 Masa JF, Jimenez A, Duran J, et al. (2004). Alternative methods of titrating continuous positive airway pressure: a large multicenter study. American Journal of Respiratory & Critical Care Medicine.
49 West SD, Jones DR, Stradling JR. (2006). Comparison of three ways to determine and deliver pressure during nasal CPAP therapy for obstructive sleep apnoea. Thorax.
50 Ferguson KA, Cartwright R, Rogers R, et al. (2006). Oral appliances for snoring and obstructive sleep apnea: a review. Sleep.
51 Kushida CA, Morgenthaler TI, Littner MR, et al. (2006). Practice parameters for the treatment of snoring and Obstructive Sleep Apnea with oral appliances: an update for 2005. Sleep.
52 Garrigue S, Barold SS, Cazeau S, et al. (1998). Prevention of atrial arrhythmias during DDD pacing by atrial overdrive. Pacing Clin Electrophysiol.
53 Garrigue S, Bordier P, Jais P, et al. (2002). Benefit of atrial pacing in sleep apnea syndrome. N Engl J Med.
54 Benumof JL. (2002). Obstructive sleep apnea in the adult obese patient: implications for airway management. Anesthesiol Clin North America.
55 Agency for Healthcare Research and Quality. (2010). Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0.
56 Wallace BC, Trikalinos TA, Lau J, et al. (2010). Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics.
57 Johns M, Hocking B. (1997). Daytime sleepiness and sleep habits of Australian workers. Sleep.
58 Johns MW. (2000). Sensitivity and specificity of the multiple sleep latency test (MSLT), the maintenance of wakefulness test and the epworth sleepiness scale: failure of the MSLT as a gold standard. Journal of Sleep Research.
59 Richardson GS, Carskadon MA, Flagg W, et al. (1978). Excessive daytime sleepiness in man: multiple sleep latency measurement in narcoleptic and control subjects. Electroencephalography & Clinical Neurophysiology.
60 Mitler MM, Gujavarty KS, Browman CP. (1982). Maintenance of wakefulness test: a polysomnographic technique for evaluation treatment efficacy in patients with excessive somnolence. Electroencephalography & Clinical Neurophysiology.
61 Bland JM, Altman DG. (1986). Statistical methods for assessing agreement between two methods of clinical measurement. Lancet.
62 Bland JM, Altman DG. (1995). Comparing methods of measurement: why plotting difference against standard method is misleading. Lancet.
63 Jaeschke R, Guyatt GH, Sackett DL. (1994). Users’ guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA.
64 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
65 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology.
66 Garcia-Diaz E, Quintana-Gallego E, Ruiz A, et al. (2007). Respiratory polygraphy with actigraphy in the diagnosis of sleep apnea-hypopnea syndrome. Chest.
67 Santos-Silva R, Sartori DE, Truksinas V, et al. (2009). Validation of a portable monitoring system for the diagnosis of obstructive sleep apnea syndrome. Sleep.
68 To KW, Chan WC, Chan TO, et al. (2009). Validation study of a portable monitoring device for identifying OSA in a symptomatic patient population. Respirology.
69 Tonelli de Oliveira AC, Martinez D, Vasconcelos LF, et al. (2009). Diagnosis of obstructive sleep apnea syndrome and its outcomes with home portable monitoring. Chest.
70 Amir O, Barak-Shinar D, Amos Y, et al. (2010). An automated sleep-analysis system operated through a standard hospital monitor. Journal of Clinical Sleep Medicine.
71 Ng SS, Chan TO, To KW, et al. (2010). Validation of Embletta portable diagnostic system for identifying patients with suspected obstructive sleep apnoea syndrome (OSAS). Respirology.
72 Planes C, Leroy M, Bouach KN, et al. (2010). Home diagnosis of obstructive sleep apnoea in coronary patients: validity of a simplified device automated analysis. Sleep & Breathing.
73 Ayappa I, Norman RG, Seelall V, et al. (2008). Validation of a self-applied unattended monitor for sleep disordered breathing. Journal of Clinical Sleep Medicine.
74 Abraham WT, Trupp RJ, Phillilps B, et al. (2006). Validation and clinical utility of a simple in-home testing tool for sleep-disordered breathing and arrhythmias in heart failure: results of the Sleep Events, Arrhythmias, and Respiratory Analysis in Congestive Heart Failure (SEARCH) study. Congestive Heart Failure.
75 Chen H, Lowe AA, Bai Y, et al. (2009). Evaluation of a portable recording device (ApneaLink) for case selection of obstructive sleep apnea. Sleep & Breathing.
76 Clark AL, Crabbe S, Aziz A, et al. (2009). Use of a screening tool for detection of sleep-disordered breathing. Journal of Laryngology & Otology.
77 de Almeida FR, Ayas NT, Otsuka R, et al. (2006). Nasal pressure recordings to detect obstructive sleep apnea. Sleep & Breathing.
78 Erman MK, Stewart D, Einhorn D, et al. (2007). Validation of the ApneaLink for the screening of sleep apnea: a novel and simple single-channel recording device. Journal of Clinical Sleep Medicine.
79 Goodrich S, Orr WC. (2009). An investigation of the validity of the Lifeshirt in comparison to standard polysomnography in the detection of obstructive sleep apnea. Sleep Medicine.
80 Heneghan C, de CP, Ryan S, et al. (2008). Electrocardiogram recording as a screening tool for sleep disordered breathing. Journal of Clinical Sleep Medicine.
81 Heneghan C, Chua CP, Garvey JF, et al. (2008). A portable automated assessment tool for sleep apnea using a combined Holter-oximeter. Sleep.
82 Nakano H, Tanigawa T, Ohnishi Y, et al. (2008). Validation of a single-channel airflow monitor for screening of sleep-disordered breathing. European Respiratory Journal.
83 Nigro CA, Aimaretti S, Gonzalez S, et al. (2009). Validation of the WristOx 3100 oximeter for the diagnosis of sleep apnea/hypopnea syndrome. Sleep & Breathing.
84 Pang KP, Gourin CG, Terris DJ. (2007). A comparison of polysomnography and the WatchPAT in the diagnosis of obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
85 Pepin JL, Defaye P, Vincent E, et al. (2009). Sleep apnea diagnosis using an ECG Holter device including a nasal pressure (NP) recording: validation of visual and automatic analysis of nasal pressure versus full polysomnography. Sleep Medicine.
86 Reda M, Gibson GJ, Wilson JA. (2001). Pharyngoesophageal pressure monitoring in sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
87 Schafer H, Ewig S, Hasper E, et al. (1997). Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration.
88 Smith LA, Chong DW, Vennelle M, et al. (2007). Diagnosis of sleep-disordered breathing in patients with chronic heart failure: evaluation of a portable limited sleep study system. Journal of Sleep Research.
89 Szyszko A, Franceschini C, Gonzalez-Zuelgaray J. (2009). Reliability of a Holter-based methodology for evaluation of sleep apnoea syndrome. Europace.
90 Watkins MR, Talmage JB, Thiese MS, et al. (2009). Correlation between screening for obstructive sleep apnea using a portable device versus polysomnography testing in a commercial driving population. Journal of Occupational & Environmental Medicine.
91 White JE, Smithson AJ, Close PR, et al. (1994). The use of sound recording and oxygen saturation in screening snorers for obstructive sleep apnoea. Clinical Otolaryngology & Allied Sciences.
92 Wong KK, Jankelson D, Reid A, et al. (2008). Diagnostic test evaluation of a nasal flow monitor for obstructive sleep apnea detection in sleep apnea research. Behavior Research Methods.
93 Yagi H, Nakata S, Tsuge H, et al. (2009). Significance of a screening device (Apnomonitor 5) for sleep apnea syndrome. Auris, Nasus, Larynx.
94 Agatsuma T, Fujimoto K, Komatsu Y, et al. (2009). A novel device (SD-101) with high accuracy for screening sleep apnoea-hypopnoea syndrome. Respirology.
95 Ragette R, Wang Y, Weinreich G, et al. (2010). Diagnostic performance of single airflow channel recording (ApneaLink) in home diagnosis of sleep apnea. Sleep Breath.
96 Ng SS, Chan TO, To KW, et al. (2009). Validation of a portable recording device (ApneaLink) for identifying patients with suspected obstructive sleep apnoea syndrome. Internal Medicine Journal.
97 Chung F, Yegneswaran B, Liao P, et al. (2008). Validation of the Berlin questionnaire and American Society of Anesthesiologists checklist as screening tools for obstructive sleep apnea in surgical patients. Anesthesiology.
98 Kapuniai LE, Andrew DJ, Crowell DH, et al. (1988). Identifying sleep apnea from self-reports. Sleep.
99 Netzer NC, Stoohs RA, Netzer CM, et al. (1999). Using the Berlin Questionnaire to identify patients at risk for the sleep apnea syndrome. Annals of Internal Medicine.
100 Sharma SK, Vasudev C, Sinha S, et al. (2006). Validation of the modified Berlin questionnaire to identify patients at risk for the obstructive sleep apnoea syndrome. Indian Journal of Medical Research.
101 Drager LF, Genta PR, Pedrosa RP, et al. (2010). Characteristics and predictors of obstructive sleep apnea in patients with systemic hypertension. American Journal of Cardiology.
102 Crocker BD, Olson LG, Saunders NA, et al. (1990). Estimation of the probability of disturbed breathing during sleep before a sleep study. American Review of Respiratory Disease.
103 Gurubhagavatula I, Maislin G, Pack AI. (2001). An algorithm to stratify sleep apnea risk in a sleep disorders clinic population. American Journal of Respiratory & Critical Care Medicine.
104 Kushida CA, Efron B, Guilleminault C. (1997). A predictive morphometric model for the obstructive sleep apnea syndrome. Annals of Internal Medicine.
105 Onen SH, Dubray C, Decullier E, et al. (2008). Observation-based nocturnal sleep inventory: screening tool for sleep apnea in elderly people. Journal of the American Geriatrics Society.
106 Rodsutti J, Hensley M, Thakkinstian A, et al. (2004). A clinical decision rule to prioritize polysomnography in patients with suspected sleep apnea. Sleep.
107 Rowley JA, Aboussouan LS, Badr MS. (2000). The use of clinical prediction formulas in the evaluation of obstructive sleep apnea. Sleep.
108 Zerah-Lancner F, Lofaso F, d’Ortho MP, et al. (2000). Predictive value of pulmonary function parameters for sleep apnea syndrome. American Journal of Respiratory & Critical Care Medicine.
109 Gurubhagavatula I, Maislin G, Nkwuo JE, et al. (2004). Occupational screening for obstructive sleep apnea in commercial drivers. American Journal of Respiratory & Critical Care Medicine.
110 Hallowell PT, Stellato TA, Petrozzi MC, et al. (2007). Eliminating respiratory intensive care unit stay after gastric bypass surgery[erratum appears in Surgery 2008 Feb;143(2):301]. Surgery.
111 Lavie P, Lavie L, Herer P. (2005). All-cause mortality in males with sleep apnoea syndrome: declining mortality rates with age. European Respiratory Journal.
112 Lavie P, Here P, Peled R, et al. (1995). Mortality in sleep apnea patients: a multivariate analysis of risk factors. Sleep.
113 Arzt M, Young T, Finn L, et al. (2005). Association of sleep-disordered breathing and the occurrence of stroke. American Journal of Respiratory & Critical Care Medicine.
114 O’Connor GT, Caffo B, Newman AB, et al. (2009). Prospective study of sleep-disordered breathing and hypertension: the Sleep Heart Health Study. American Journal of Respiratory & Critical Care Medicine.
115 Reichmuth KJ, Austin D, Skatrud JB, et al. (2005). Association of sleep apnea and type II diabetes: a population-based study. American Journal of Respiratory & Critical Care Medicine.
116 Botros N, Concato J, Mohsenin V, et al. (2009). Obstructive sleep apnea as a risk factor for type 2 diabetes. American Journal of Medicine.
117 Silva GE, An MW, Goodwin JL, et al. (2009). Longitudinal evaluation of sleep-disordered breathing and sleep symptoms with change in quality of life: the Sleep Heart Health Study (SHHS). Sleep.
118 Ballester E, Badia JR, Hernandez L, et al. (1999). Evidence of the effectiveness of continuous positive airway pressure in the treatment of sleep apnea/hypopnea syndrome [erratum appears in Am J Respir Crit Care Med 1999 May;159(5 Pt 1):1688]. Am J Respir Crit Care Med.
119 Chakravorty I, Cayton RM, Szczepura A. (2002). Health utilities in evaluating intervention in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal.
120 Drager LF, Bortolotto LA, Figueiredo AC, et al. (2007). Effects of continuous positive airway pressure on early signs of atherosclerosis in obstructive sleep apnea. Am J Respir Crit Care Med.
121 Ip MS, Tse HF, Lam B, et al. (2004). Endothelial function in obstructive sleep apnea and response to treatment. Am J Respir Crit Care Med.
122 Kajaste S, Brander PE, Telakivi T, et al. (2004). A cognitive-behavioral weight reduction program in the treatment of obstructive sleep apnea syndrome with or without initial nasal CPAP: a randomized study. Sleep Medicine.
123 Kaneko Y, Floras JS, Usui K, et al. (2003). Cardiovascular effects of continuous positive airway pressure in patients with heart failure and obstructive sleep apnea. New Engl J Med.
124 Lojander J, Maasilta P, Partinen M, et al. (1996). Nasal-CPAP, surgery, and conservative management for treatment of obstructive sleep apnea syndrome. A randomized study. Chest.
125 Lojander J, Kajaste S, Maasilta P, et al. (1999). Cognitive function and treatment of obstructive sleep apnea syndrome. Journal of Sleep Research.
126 Mansfield DR, Gollogly NC, Kaye DM, et al. (2004). Controlled trial of continuous positive airway pressure in obstructive sleep apnea and heart failure. Am J Respir Crit Care Med.
127 Monasterio C, Vidal S, Duran J, et al. (2001). Effectiveness of continuous positive airway pressure in mild sleep apnea-hypopnea syndrome. Am J Respir Crit Care Med.
128 Redline S, Adams N, Strauss ME, et al. (1998). Improvement of mild sleep-disordered breathing with CPAP compared with conservative therapy. Am J Respir Crit Care Med.
129 Lam B, Sam K, Mok WY, et al. (2007). Randomised study of three non-surgical treatments in mild to moderate obstructive sleep apnoea. Thorax.
130 Barbe F, Duran-Cantolla J, Capote F, et al. (2010). Long-term effect of continuous positive airway pressure in hypertensive patients with sleep apnea. Am J Respir Crit Care Med.
131 Barnes M, Houston D, Worsnop CJ, et al. (2002). A randomized controlled trial of continuous positive airway pressure in mild obstructive sleep apnea. Am J Respir Crit Care Med.
132 Comondore VR, Cheema R, Fox J, et al. (2009). The impact of CPAP on cardiovascular biomarkers in minimally symptomatic patients with obstructive sleep apnea: a pilot feasibility randomized crossover trial. Lung.
133 Engleman HM, Martin SE, Deary IJ, et al. (1994). Effect of continuous positive airway pressure treatment on daytime function in sleep apnoea/hypopnoea syndrome. Lancet.
134 Engleman HM, Gough K, Martin SE, et al. (1996). Ambulatory blood pressure on and off continuous positive airway pressure therapy for the sleep apnea/hypopnea syndrome: effects in “non-dippers”. Sleep.
135 Engleman HM, Martin SE, Deary IJ, et al. (1997). Effect of CPAP therapy on daytime function in patients with mild sleep apnoea/hypopnoea syndrome. Thorax.
136 Engleman HM, Martin SE, Kingshott RN, et al. (1998). Randomised placebo controlled trial of daytime function after continuous positive airway pressure (CPAP) therapy for the sleep apnoea/hypopnoea syndrome. Thorax.
137 Engleman HM, Kingshott RN, Wraith PK, et al. (1999). Randomized placebo-controlled crossover trial of continuous positive airway pressure for mild sleep Apnea/Hypopnea syndrome. Am J Respir Crit Care Med.
138 Faccenda JF, Mackay TW, Boon NA, et al. (2001). Randomized placebo-controlled trial of continuous positive airway pressure on blood pressure in the sleep apnea-hypopnea syndrome. Am J Respir Crit Care Med.
139 McArdle N, Douglas NJ. (2001). Effect of continuous positive airway pressure on sleep architecture in the sleep apnea-hypopnea syndrome: a randomized controlled trial. Am J Respir Crit Care Med.
140 Barnes M, McEvoy RD, Banks S, et al. (2004). Efficacy of positive airway pressure and oral appliance in mild to moderate obstructive sleep apnea. Am J Resp Crit Care Med.
141 Arias MA, Garcia-Rio F, Alonso-Fernandez A, et al. (2005). Obstructive sleep apnea syndrome affects left ventricular diastolic function: effects of nasal continuous positive airway pressure in men. Circulation.
142 Barbe F, Mayoralas LR, Duran J, et al. (2001). Treatment with continuous positive airway pressure is not effective in patients with sleep apnea but no daytime sleepiness. a randomized, controlled trial. Annals of Internal Medicine.
143 Becker HF, Jerrentrup A, Ploch T, et al. (2003). Effect of nasal continuous positive airway pressure treatment on blood pressure in patients with obstructive sleep apnea. Circulation.
144 Campos-Rodriguez F, Grilo-Reina A, Perez-Ronchel J, et al. (2006). Effect of continuous positive airway pressure on ambulatory BP in patients with sleep apnea and hypertension: a placebo-controlled trial. Chest.
145 Coughlin SR, Mawdsley L, Mugarza JA, et al. (2007). Cardiovascular and metabolic effects of CPAP in obese males with OSA. European Respiratory Journal.
146 Cross MD, Mills NL, Al-Abri M, et al. (2008). Continuous positive airway pressure improves vascular function in obstructive sleep apnoea/hypopnoea syndrome: a randomised controlled trial. Thorax.
147 Egea CJ, Aizpuru F, Pinto JA, et al. (2008). Cardiac function after CPAP therapy in patients with chronic heart failure and sleep apnea: a multicenter study. Sleep Medicine.
148 Haensel A, Norman D, Natarajan L, et al. (2007). Effect of a 2 week CPAP treatment on mood states in patients with obstructive sleep apnea: a double-blind trial. Sleep & Breathing.
149 Henke KG, Grady JJ, Kuna ST. (2001). Effect of nasal continuous positive airway pressure on neuropsychological function in sleep apnea-hypopnea syndrome. A randomized, placebo-controlled trial. Am J Respir Crit Care Med.
150 Hui DS, To KW, Ko FW, et al. (2006). Nasal CPAP reduces systemic blood pressure in patients with obstructive sleep apnoea and mild sleepiness. Thorax.
151 Jenkinson C, Davies RJ, Mullins R, et al. (1999). Comparison of therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised prospective parallel trial. Lancet.
152 Hack M, Davies RJ, Mullins R, et al. (2000). Randomised prospective parallel trial of therapeutic versus subtherapeutic nasal continuous positive airway pressure on simulated steering performance in patients with obstructive sleep apnoea. Thorax.
153 Loredo JS, Ancoli-Israel S, Dimsdale JE. (1999). Effect of continuous positive airway pressure vs placebo continuous positive airway pressure on sleep quality in obstructive sleep apnea. Chest.
154 Yu BH, Ancoli-Israel S, Dimsdale JE. (1999). Effect of CPAP treatment on mood states in patients with sleep apnea. Journal of Psychiatric Research.
155 Bardwell WA, Ancoli-Israel S, Berry CC, et al. (2001). Neuropsychological effects of one-week continuous positive airway pressure treatment in patients with obstructive sleep apnea: a placebo-controlled study. Psychosomatic Medicine.
156 Profant J, Ancoli-Israel S, Dimsdale JE. (2003). A randomized, controlled trial of 1 week of continuous positive airway pressure treatment on quality of life. Heart & Lung.
157 Loredo JS, Ancoli-Israel S, Kim EJ, et al. (2006). Effect of continuous positive airway pressure versus supplemental oxygen on sleep quality in obstructive sleep apnea: a placebo-CPAP-controlled study. Sleep.
158 Bardwell WA, Norman D, Ancoli-Israel S, et al. (2007). Effects of 2-week nocturnal oxygen supplementation and continuous positive airway pressure treatment on psychological symptoms in patients with obstructive sleep apnea: a randomized placebo-controlled study. Behavioral Sleep Medicine.
159 Marshall NS, Neill AM, Campbell AJ, et al. (2005). Randomised controlled crossover trial of humidified continuous positive airway pressure in mild obstructive sleep apnoea. Thorax.
160 Mills PJ, Kennedy BP, Loredo JS, et al. (2006). Effects of nasal continuous positive airway pressure and oxygen supplementation on norepinephrine kinetics and cardiovascular responses in obstructive sleep apnea. Journal of Applied Physiology.
161 Lim W, Bardwell WA, Loredo JS, et al. (2007). Neuropsychological effects of 2-week continuous positive airway pressure treatment and supplemental oxygen in patients with obstructive sleep apnea: a randomized placebo-controlled study. Journal of Clinical Sleep Medicine.
162 Montserrat JM, Ferrer M, Hernandez L, et al. (2001). Effectiveness of CPAP treatment in daytime function in sleep apnea syndrome: a randomized controlled study with an optimized placebo. Am J Respir Crit Care Med.
163 Norman D, Loredo JS, Nelesen RA, et al. (2006). Effects of continuous positive airway pressure versus supplemental oxygen on 24-hour ambulatory blood pressure. Hypertension.
164 Robinson GV, Smith DM, Langford BA, et al. (2006). Continuous positive airway pressure does not reduce blood pressure in nonsleepy hypertensive OSA patients. European Respiratory Journal.
165 Siccoli MM, Pepperell JC, Kohler M, et al. (2008). Effects of continuous positive airway pressure on quality of life in patients with moderate to severe obstructive sleep apnea: data from a randomized controlled trial. Sleep.
166 Smith LA, Vennelle M, Gardner RS, et al. (2007). Auto-titrating continuous positive airway pressure therapy in patients with chronic heart failure and obstructive sleep apnoea: a randomized placebo-controlled trial. European Heart Journal.
167 Spicuzza L, Bernardi L, Balsamo R, et al. (2006). Effect of treatment with nasal continuous positive airway pressure on ventilatory response to hypoxia and hypercapnia in patients with sleep apnea syndrome. Chest.
168 West SD, Nicoll DJ, Wallace TM, et al. (2007). Effect of CPAP on insulin resistance and HbA1c in men with obstructive sleep apnoea and type 2 diabetes. Thorax.
169 Lam JC, Lam B, Yao TJ, et al. (2010). A randomised controlled trial of nasal continuous positive airway pressure on insulin sensitivity in obstructive sleep apnoea. European Respiratory Journal.
170 West SD, Kohler M, Nicoll DJ, et al. (2009). The effect of continuous positive airway pressure treatment on physical activity in patients with obstructive sleep apnoea: A randomised controlled trial. Sleep Medicine.
171 Anderson FE, Kingshott RN, Taylor DR, et al. (2003). A randomized crossover efficacy trial of oral CPAP (Oracle) compared with nasal CPAP in the management of obstructive sleep apnea. Sleep.
172 Mortimore IL, Whittle AT, Douglas NJ. (1998). Comparison of nose and face mask CPAP therapy for sleep apnoea. Thorax.
173 Khanna R, Kline LR. (2003). A prospective 8 week trial of nasal interfaces vs. a novel oral interface (Oracle) for treatment of obstructive sleep apnea hypopnea syndrome. Sleep Medicine.
174 Damjanovic D, Fluck A, Bremer H, et al. (2009). Compliance in sleep apnoea therapy: influence of home care support and pressure mode. European Respiratory Journal.
175 Fietze I, Glos M, Moebus I, et al. (2007). Automatic pressure titration with APAP is as effective as manual titration with CPAP in patients with obstructive sleep apnea. Respiration.
176 Galetke W, Anduleit N, Richter K, et al. (2008). Comparison of automatic and continuous positive airway pressure in a night-by-night analysis: a randomized, crossover study. Respiration.
177 Meurice JC, Cornette A, Philip-Joet F, et al. (2007). Evaluation of autoCPAP devices in home treatment of sleep apnea/hypopnea syndrome. Sleep Medicine.
178 Nolan GM, Doherty LS, Mc Nicholas WT. (2007). Auto-adjusting versus fixed positive pressure therapy in mild to moderate obstructive sleep apnoea. Sleep.
179 Nussbaumer Y, Bloch KE, Genser T, et al. (2006). Equivalence of autoadjusted and constant continuous positive airway pressure in home treatment of sleep apnea. Chest.
180 Patruno V, Aiolfi S, Costantino G, et al. (2007). Fixed and autoadjusting continuous positive airway pressure treatments are not similar in reducing cardiovascular risk factors in patients with obstructive sleep apnea. Chest.
181 To KW, Chan WC, Choo KL, et al. (2008). A randomized cross-over study of auto-continuous positive airway pressure versus fixed-continuous positive airway pressure in patients with obstructive sleep apnoea. Respirology.
182 Hudgel DW, Fung C. (2000). A long-term randomized, cross-over comparison of auto-titrating and standard nasal continuous airway pressure. Sleep.
183 Hukins C. (2004). Comparative study of autotitrating and fixed-pressure CPAP in the home: a randomized, single-blind crossover trial. Sleep.
184 Hussain SF, Love L, Burt H, et al. (2004). A randomized trial of auto-titrating CPAP and fixed CPAP in the treatment of obstructive sleep apnea-hypopnea. Respiratory Medicine.
185 Marrone O, Resta O, Salvaggio A, et al. (2004). Preference for fixed or automatic CPAP in patients with obstructive sleep apnea syndrome. Sleep Medicine.
186 Massie CA, McArdle N, Hart RW, et al. (2003). Comparison between automatic and fixed positive airway pressure therapy in the home. Am J Respir Crit Care Med.
187 Noseda A, Kempenaers C, Kerkhofs M, et al. (2004). Constant vs auto-continuous positive airway pressure in patients with sleep apnea hypopnea syndrome and a high variability in pressure requirement. Chest.
188 Resta O, Carratu P, Depalo A, et al. (2004). Effects of fixed compared to automatic CPAP on sleep in Obstructive Sleep Apnoea Syndrome. Monaldi Archives for Chest Disease.
189 Senn O, Brack T, Matthews F, et al. (2003). Randomized short-term trial of two autoCPAP devices versus fixed continuous positive airway pressure for the treatment of sleep apnea. Am J Respir Crit Care Med.
190 Randerath WJ, Schraeder O, Galetke W, et al. (2001). Autoadjusting CPAP therapy based on impedance efficacy, compliance and acceptance. Am J Respir Crit Care Med.
191 Series F, Marc I. (1997). Efficacy of automatic continuous positive airway pressure therapy that uses an estimated required pressure in the treatment of the obstructive sleep apnea syndrome. Annals of Internal Medicine.
192 Teschler H, Wessendorf TE, Farhat AA, et al. (2000). Two months auto-adjusting versus conventional nCPAP for obstructive sleep apnoea syndrome. European Respiratory Journal.
193 Planes C, d’Ortho MP, Foucher A, et al. (2003). Efficacy and cost of home-initiated auto-nCPAP versus conventional nCPAP. Sleep.
194 Vennelle M, White S, Riha RL, et al. (2010). Randomized controlled trial of variable-pressure versus fixed-pressure continuous positive airway pressure (CPAP) treatment for patients with obstructive sleep apnea/hypopnea syndrome (OSAHS). Sleep.
195 Gay PC, Herold DL, Olson EJ. (2003). A randomized, double-blind clinical trial comparing continuous positive airway pressure with a novel bilevel pressure system for treatment of obstructive sleep apnea syndrome. Sleep.
196 Khayat RN, Abraham WT, Patt B, et al. (2008). Cardiac effects of continuous and bilevel positive airway pressure for patients with heart failure and obstructive sleep apnea: a pilot study. Chest.
197 Piper AJ, Wang D, Yee BJ, et al. (2008). Randomised trial of CPAP vs bilevel support in the treatment of obesity hypoventilation syndrome without severe nocturnal desaturation. Thorax.
198 Reeves-Hoche MK, Hudgel DW, Meck R, et al. (1995). Continuous versus bilevel positive airway pressure for obstructive sleep apnea. Am J Respir Crit Care Med.
199 Randerath WJ, Galetke W, Ruhle KH. (2003). Auto-adjusting CPAP based on impedance versus bilevel pressure in difficult-to-treat sleep apnea syndrome: a prospective randomized crossover study. Medical Science Monitor.
200 Ballard RD, Gay PC, Strollo PJ. (2007). Interventions to improve compliance in sleep apnea patients previously non-compliant with continuous positive airway pressure. Journal of Clinical Sleep Medicine.
201 Dolan DC, Okonkwo R, Gfullner F, et al. (2009). Longitudinal comparison study of pressure relief (C-Flex) vs. CPAP in OSA patients. Sleep & Breathing.
202 Nilius G, Happel A, Domanski U, et al. (2006). Pressure-relief continuous positive airway pressure vs constant continuous positive airway pressure: a comparison of efficacy and compliance. Chest.
203 Pepin JL, Muir JF, Gentina T, et al. (2009). Pressure reduction during exhalation in sleep apnea patients treated by continuous positive airway pressure. Chest.
204 Leidag M, Hader C, Keller T, et al. (2008). Mask leakage in continuous positive airway pressure and C-Flex. Journal of Physiology & Pharmacology.
205 Ryan S, Doherty LS, Nolan GM, et al. (2009). Effects of heated humidification and topical steroids on compliance, nasal symptoms, and quality of life in patients with obstructive sleep apnea syndrome using nasal continuous positive airway pressure. Journal of Clinical Sleep Medicine.
206 Mador MJ, Krauza M, Pervez A, et al. (2005). Effect of heated humidification on compliance and quality of life in patients with sleep apnea using nasal continuous positive airway pressure. Chest.
207 Salgado SM, Boleo-Tome JP, Canhao CM, et al. (2008). Impact of heated humidification with automatic positive airway pressure in obstructive sleep apnea therapy. Jornal Brasileiro De Pneumologia: Publicacao Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia.
208 Neill AM, Wai HS, Bannan SP, et al. (2003). Humidified nasal continuous positive airway pressure in obstructive sleep apnoea. European Respiratory Journal.
209 Massie CA, Hart RW, Peralez K, et al. (1999). Effects of humidification on nasal symptoms and compliance in sleep apnea patients using continuous positive airway pressure. Chest.
210 Bloch KE, Iseli A, Zhang JN, et al. (2000). A randomized, controlled crossover trial of two oral appliances for sleep apnea treatment. Am J Respir Crit Care Med.
211 Kato J, Isono S, Tanaka A, et al. (2000). Dose-dependent effects of mandibular advancement on pharyngeal mechanics and nocturnal oxygenation in patients with sleep-disordered breathing. Chest.
212 Petri N, Svanholt P, Solow B, et al. (2008). Mandibular advancement appliance for obstructive sleep apnoea: results of a randomised placebo controlled trial using parallel group design. Journal of Sleep Research.
213 Hans MG, Nelson S, Luks VG, et al. (1997). Comparison of two dental devices for treatment of obstructive sleep apnea syndrome (OSAS). American Journal of Orthodontics & Dentofacial Orthopedics.
214 Gotsopoulos H, Chen C, Qian J, et al. (2002). Oral appliance therapy improves symptoms in obstructive sleep apnea: a randomized, controlled trial. Am J Respir Crit Care Med.
215 Gotsopoulos H, Kelly JJ, Cistulli PA. (2004). Oral appliance therapy reduces blood pressure in obstructive sleep apnea: a randomized, controlled trial. Sleep.
216 Johnston CD, Gleadhill IC, Cinnamond MJ, et al. (2002). Mandibular advancement appliances and obstructive sleep apnoea: a randomized clinical trial. European Journal of Orthodontics.
217 Naismith SL, Winter VR, Hickie IB, et al. (2005). Effect of oral appliance therapy on neurobehavioral functioning in obstructive sleep apnea: a randomized controlled trial. Journal of Clinical Sleep Medicine.
218 Mehta A, Qian J, Petocz P, et al. (2001). A randomized, controlled study of a mandibular advancement splint for obstructive sleep apnea. Am J Respir Crit Care Med.
219 Campbell AJ, Reynolds G, Trengrove H, et al. (2009). Mandibular advancement splint titration in obstructive sleep apnoea. Sleep & Breathing.
220 Walker-Engstrom ML, Ringqvist I, Vestling O, et al. (2003). A prospective randomized study comparing two different degrees of mandibular advancement with a dental appliance in treatment of severe obstructive sleep apnea. Sleep & Breathing.
221 Vanderveken OM, Devolder A, Marklund M, et al. (2008). Comparison of a custom-made and a thermoplastic oral appliance for the treatment of mild sleep apnea. Am J Respir Crit Care Med.
222 Deane SA, Cistulli PA, Ng AT, et al. (2009). Comparison of mandibular advancement splint and tongue stabilizing device in obstructive sleep apnea: a randomized controlled trial. Sleep.
223 Dort L, Brant R. (2008). A randomized, controlled, crossover study of a noncustomized tongue retaining device for sleep disordered breathing. Sleep & Breathing.
224 Clark GT, Blumenfeld I, Yoffe N, et al. (1996). A crossover study comparing the efficacy of continuous positive airway pressure with anterior mandibular positioning devices on patients with obstructive sleep apnea. Chest.
225 Engleman HM, McDonald JP, Graham D, et al. (2002). Randomized crossover trial of two treatments for sleep apnea/hypopnea syndrome: continuous positive airway pressure and mandibular repositioning splint. Am J Respir Crit Care Med.
226 Ferguson KA, Ono T, Lowe AA, et al. (1996). A randomized crossover study of an oral appliance vs nasal-continuous positive airway pressure in the treatment of mild-moderate obstructive sleep apnea. Chest.
227 Gagnadoux F, Fleury B, Vielle B, et al. (2009). Titrated mandibular advancement versus positive airway pressure for sleep apnoea. European Respiratory Journal.
228 Randerath WJ, Heise M, Hinz R, et al. (2002). An individually adjustable oral appliance vs continuous positive airway pressure in mild-to-moderate obstructive sleep apnea syndrome. Chest.
229 Tan YK, L’Estrange PR, Luo YM, et al. (2002). Mandibular advancement splints and continuous positive airway pressure in patients with obstructive sleep apnoea: a randomized cross-over trial. European Journal of Orthodontics.
230 Hoekema A, Stegenga B, Wijkstra PJ, et al. (2008). Obstructive sleep apnea therapy. Journal of Dental Research.
231 Hoekema A, Stel AL, Stegenga B, et al. (2007). Sexual function and obstructive sleep apnea-hypopnea: a randomized clinical trial evaluating the effects of oral-appliance and continuous positive airway pressure therapy. Journal of Sexual Medicine.
232 Skinner MA, Kingshott RN, Jones DR, et al. (2004). Lack of efficacy for a cervicomandibular support collar in the management of obstructive sleep apnea. Chest.
233 Skinner MA, Kingshott RN, Jones DR, et al. (2004). Elevated posture for the management of obstructive sleep apnea. Sleep & Breathing.
234 Skinner MA, Kingshott RN, Filsell S, et al. (2008). Efficacy of the ‘tennis ball technique’ versus nCPAP in the management of position-dependent obstructive sleep apnoea syndrome. Respirology.
235 Jokic R, Klimaszewski A, Crossley M, et al. (1999). Positional treatment vs continuous positive airway pressure in patients with positional obstructive sleep apnea syndrome. Chest.
236 Foster GD, Borradaile KE, Sanders MH, et al. (2009). A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Archives of Internal Medicine.
237 Johansson K, Neovius M, Lagerros YT, et al. (2009). Effect of a very low energy diet on moderate and severe obstructive sleep apnoea in obese men: a randomised controlled trial. BMJ.
238 Tuomilehto HP, Seppa JM, Partinen MM, et al. (2009). Lifestyle intervention with weight reduction: first-line treatment in mild obstructive sleep apnea. Am J Respir Crit Care Med.
239 Puhan MA, Suarez A, Lo CC, et al. (2006). Didgeridoo playing as alternative treatment for obstructive sleep apnoea syndrome: randomised controlled trial. BMJ.
240 Guimaraes KC, Drager LF, Genta PR, et al. (2009). Effects of oropharyngeal exercises on patients with moderate obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
241 Randerath WJ, Galetke W, Domanski U, et al. (2004). Tongue-muscle training by intraoral electrical neurostimulation in patients with obstructive sleep apnea. Sleep.
242 Friedman M, Schalch P, Lin HC, et al. (2008). Palatal implants for the treatment of snoring and obstructive sleep apnea/hypopnea syndrome. Otolaryngology - Head & Neck Surgery.
243 Steward DL, Huntley TC, Woodson BT, et al. (2008). Palate implants for obstructive sleep apnea: multi-institution, randomized, placebo-controlled study. Otolaryngology - Head & Neck Surgery.
244 Back LJ, Liukko T, Rantanen I, et al. (2009). Radiofrequency surgery of the soft palate in the treatment of mild obstructive sleep apnea is not effective as a single-stage procedure: A randomized single-blinded placebo-controlled trial. Laryngoscope.
245 Ferguson KA, Heighway K, Ruby RR. (2003). A randomized trial of laser-assisted uvulopalatoplasty in the treatment of mild obstructive sleep apnea. Am J Respir Crit Care Med.
246 Koutsourelakis I, Georgoulopoulos G, Perraki E, et al. (2008). Randomised trial of nasal surgery for fixed nasal obstruction in obstructive sleep apnoea. European Respiratory Journal.
247 Woodson BT, Steward DL, Weaver EM, et al. (2003). A randomized trial of temperature-controlled radiofrequency, continuous positive airway pressure, and placebo for obstructive sleep apnea syndrome. Otolaryngology-Head & Neck Surgery.
248 Guilleminault C, Davis K, Huynh NT. (2008). Prospective randomized study of patients with insomnia and mild sleep disordered breathing. Sleep.
249 Li HY, Lee LA, Wang PC, et al. (2009). Can nasal surgery improve obstructive sleep apnea: subjective or objective?. American Journal of Rhinology & Allergy.
250 Vicini C, Dallan I, Campanini A, et al. (2010). Surgery vs ventilation in adult severe obstructive sleep apnea syndrome. American Journal of Otolaryngology.
251 Conradt R, Hochban W, Heitmann J, et al. (1998). Sleep fragmentation and daytime vigilance in patients with OSA treated by surgical maxillomandibular advancement compared to CPAP therapy. Journal of Sleep Research.
252 Woodson BT, Nelson L, Mickelson S, et al. (2001). A multi-institutional study of radiofrequency volumetric tissue reduction for OSAS. Otolaryngology - Head & Neck Surgery.
253 Zorick FJ, Roehrs T, Conway W, et al. (1990). Response to CPAP and UPPP in apnea. Henry Ford Hospital Medical Journal.
254 Ceylan K, Emir H, Kizilkaya Z, et al. (2009). First-choice treatment in mild to moderate obstructive sleep apnea: single-stage, multilevel, temperature-controlled radiofrequency tissue volume reduction or nasal continuous positive airway pressure. Archives of Otolaryngology -- Head & Neck Surgery.
255 Anand VK, Ferguson PW, Schoen LS. (1991). Obstructive sleep apnea: a comparison of continuous positive airway pressure and surgical treatment. Otolaryngology - Head & Neck Surgery.
256 Katsantonis GP, Schweitzer PK, Branham GH, et al. (1988). Management of obstructive sleep apnea: comparison of various treatment modalities. Laryngoscope.
257 Keenan SP, Burt H, Ryan CF, et al. (1994). Long-term survival of patients with obstructive sleep apnea treated by uvulopalatopharyngoplasty or nasal CPAP. Chest.
258 Lin SW, Chen NH, Li HY, et al. (2006). A comparison of the long-term outcome and effects of surgery or continuous positive airway pressure on patients with obstructive sleep apnea syndrome. Laryngoscope.
259 Robinson S, Chia M, Carney AS, et al. (2009). Upper airway reconstructive surgery long-term quality-of-life outcomes compared with CPAP for adult obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
260 Weaver EM, Maynard C, Yueh B. (2004). Survival of veterans with sleep apnea: continuous positive airway pressure versus surgery. Otolaryngology - Head & Neck Surgery.
261 Wilhelmsson B, Tegelberg A, Walker-Engstrom ML, et al. (1999). A prospective randomized study of a dental appliance compared with uvulopalatopharyngoplasty in the treatment of obstructive sleep apnoea. Acta Oto-Laryngologica.
262 Walker-Engstrom ML, Tegelberg A, Wilhelmsson B, et al. (2002). 4-year follow-up of treatment with dental appliance or uvulopalatopharyngoplasty in patients with obstructive sleep apnea: a randomized study. Chest.
263 Walker-Engstrom ML, Wilhelmsson B, Tegelberg A, et al. (2000). Quality of life assessment of treatment with dental appliance or UPPP in patients with mild to moderate obstructive sleep apnoea. A prospective randomized 1-year follow-up study. Journal of Sleep Research.
264 Carley DW, Olopade C, Ruigt GS, et al. (2007). Efficacy of mirtazapine in obstructive sleep apnea syndrome. Sleep.
265 Kiely JL, Nolan P, McNicholas WT. (2004). Intranasal corticosteroid therapy for obstructive sleep apnoea in patients with coexisting rhinitis. Thorax.
266 Kraiczi H, Hedner J, Dahlof P, et al. (1999). Effect of serotonin uptake inhibition on breathing during sleep and daytime symptoms in obstructive sleep apnea. Sleep.
267 Whyte KF, Gould GA, Airlie MA, et al. (1988). Role of protriptyline and acetazolamide in the sleep apnea/hypopnea syndrome. Sleep.
268 Suurna MV, Welge J, Surdulescu V, et al. (2008). Randomized placebo-controlled trial of pantoprazole for daytime sleepiness in GERD and obstructive sleep disordered breathing. Otolaryngology - Head & Neck Surgery.
269 Clarenbach CF, Kohler M, Senn O, et al. (2008). Does nasal decongestion improve obstructive sleep apnea?. Journal of Sleep Research.
270 Melzer C, Fietze I, Duru F, et al. (2006). Nocturnal overdrive pacing for the treatment of sleep apnea syndrome. Sleep.
271 Simantirakis EN, Schiza SE, Chrysostomakis SI, et al. (2005). Atrial overdrive pacing for the obstructive sleep apnea-hypopnea syndrome. New Engl J Med.
272 Grunstein RR, Stenlof K, Hedner JA, et al. (2007). Two year reduction in sleep apnea symptoms and associated diabetes incidence after weight loss in severe obesity. Sleep.
273 Cartwright R, Ristanovic R, Diaz F, et al. (1991). A comparative study of treatments for positional sleep apnea. Sleep.
274 Freire AO, Sugai GC, Chrispin FS, et al. (2007). Treatment of moderate obstructive sleep apnea syndrome with acupuncture: a randomised, placebo-controlled pilot trial. Sleep Medicine.
275 Krakow B, Melendrez D, Sisley B, et al. (2006). Nasal dilator strip therapy for chronic sleep-maintenance insomnia and symptoms of sleep-disordered breathing: a randomized controlled trial. Sleep & Breathing.
276 Wang XH, Xiao LY, Wang BF, et al. (2009). Influence of auricular plaster therapy on sleeping structure in OSAS patients. Journal of Traditional Chinese Medicine.
277 Kezirian EJ, Weaver EM, Yueh B, et al. (2004). Incidence of serious complications after uvulopalatopharyngoplasty. Laryngoscope.
278 Lundkvist K, Januszkiewicz A, Friberg D. (2009). Uvulopalatopharyngoplasty in 158 OSAS patients failing non-surgical treatment. Acta Oto-Laryngologica.
279 Esclamado RM, Glenn MG, McCulloch TM, et al. (1989). Perioperative complications and risk factors in the surgical treatment of obstructive sleep apnea syndrome. Laryngoscope.
280 Friedman M, Ibrahim H, Joseph NJ. (2004). Staging of obstructive sleep apnea/hypopnea syndrome: a guide to appropriate treatment. Laryngoscope.
281 Harmon JD, Morgan W, Chaudhary B. (1989). Sleep apnea: morbidity and mortality of surgical treatment. Southern Medical Journal.
282 Haavisto L, Suonpaa J. (1994). Complications of uvulopalatopharyngoplasty. Clinical Otolaryngology & Allied Sciences.
283 Stuck BA, Starzak K, Verse T, et al. (2003). Complications of temperature-controlled radiofrequency volumetric tissue reduction for sleep-disordered breathing. Acta Oto-Laryngologica.
284 Riley RW, Powell NB, Guilleminault C. (1993). Obstructive sleep apnea syndrome: a review of 306 consecutively treated surgical patients. Otolaryngology - Head & Neck Surgery.
285 Riley RW, Powell NB, Guilleminault C, et al. (1997). Obstructive sleep apnea surgery: risk management and complications. Otolaryngology - Head & Neck Surgery.
286 Friedman M, Lin HC, Gurpinar B, et al. (2007). Minimally invasive single-stage multilevel treatment for obstructive sleep apnea/hypopnea syndrome. Laryngoscope.
287 Benazzo M, Pagella F, Matti E, et al. (2008). Hyoidthyroidpexia as a treatment in multilevel surgery for obstructive sleep apnea. Acta Oto-Laryngologica.
288 Bradshaw DA, Ruff GA, Murphy DP. (2006). An oral hypnotic medication does not improve continuous positive airway pressure compliance in men with obstructive sleep apnea. Chest.
289 McArdle N, Devereux G, Heidarnejad H, et al. (1999). Long-term use of CPAP therapy for sleep apnea/hypopnea syndrome. Am J Respir Crit Care Med.
290 Krieger J, Kurtz D, Petiau C, et al. (1996). Long-term compliance with CPAP therapy in obstructive sleep apnea patients and in snorers. Sleep.
291 Wild MR, Engleman HM, Douglas NJ, et al. (2004). Can psychological factors help us to determine adherence to CPAP? A prospective study. European Respiratory Journal.
292 Hui DS, Choy DK, Li TS, et al. (2001). Determinants of continuous positive airway pressure compliance in a group of Chinese patients with obstructive sleep apnea. Chest.
293 Izci B, McDonald JP, Coleman EL, et al. (2005). Clinical audit of subjects with snoring & sleep apnoea/hypopnoea syndrome fitted with mandibular repositioning splint. Respiratory Medicine.
294 Chervin RD, Theut S, Bassetti C, et al. (1997). Compliance with nasal CPAP can be improved by simple interventions. Sleep.
295 DeMolles DA, Sparrow D, Gottlieb DJ, et al. (2004). A pilot trial of a telecommunications system in sleep apnea management. Medical Care.
296 Fletcher EC, Luckett RA. (1991). The effect of positive reinforcement on hourly compliance in nasal continuous positive airway pressure users with obstructive sleep apnea. American Review of Respiratory Disease.
297 Hoy CJ, Vennelle M, Kingshott RN, et al. (1999). Can intensive support improve continuous positive airway pressure use in patients with the sleep apnea/hypopnea syndrome?. Am J Respir Crit Care Med.
298 Hui DS, Chan JK, Choy DK, et al. (2000). Effects of augmented continuous positive airway pressure education and support on compliance and outcome in a Chinese population. Chest.
299 Jean WH, Boethel C, Phillips B, et al. (2005). CPAP compliance: video education may help!. Sleep Medicine.
300 Lewis KE, Bartle IE, Watkins AJ, et al. (2006). Simple interventions improve re-attendance when treating the sleep apnoea syndrome. Sleep Medicine.
301 Meurice JC, Ingrand P, Portier F, et al. (2007). A multicentre trial of education strategies at CPAP induction in the treatment of severe sleep apnoea-hypopnoea syndrome. Sleep Medicine.
302 Richards D, Bartlett DJ, Wong K, et al. (2007). Increased adherence to CPAP with a group cognitive behavioral treatment intervention: a randomized trial. Sleep.
303 Smith CE, Dauz E, Clements F, et al. (2009). Patient education combined in a music and habit-forming intervention for adherence to continuous positive airway (CPAP) prescribed for sleep apnea. Patient Education & Counseling.
304 Stepnowsky CJ, Palau JJ, Marler MR, et al. (2007). Pilot randomized trial of the effect of wireless telemonitoring on compliance and treatment efficacy in obstructive sleep apnea. Journal of Medical Internet Research.
305 Taylor Y, Eliasson A, Andrada T, et al. (2006). The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep & Breathing.
306 Massie CA, Hart RW. (2003). Clinical outcomes related to interface type in patients with obstructive sleep apnea/hypopnea syndrome who are using continuous positive airway pressure. Chest.
307 Antic NA, Buchan C, Esterman A, et al. (2009). A randomized controlled trial of nurse-led care for symptomatic moderate-severe obstructive sleep apnea. Am J Respir Crit Care Med.
308 Holmdahl C, Schollin IL, Alton M, et al. (2009). CPAP treatment in obstructive sleep apnoea: a randomised, controlled trial of follow-up with a focus on patient satisfaction. Sleep Medicine.
309 Palmer S, Selvaraj S, Dunn C, et al. (2004). Annual review of patients with sleep apnea/hypopnea syndrome— a pragmatic randomised trial of nurse home visit versus consultant clinic review. Sleep Medicine.