# Invited Peer Reviewers

Donna L. Arand, PhD

Clinical Director

Kettering Sleep Disorders Center

Dayton, OH

Douglas C. McCrory, MD, MHS

Scientific Director

Duke Evidence-based Practice Center

Duke Center for Clinical Health Policy Research

Durham, NC

Edmundo R. Rubio, MD

Section Chief, Pulmonary & Critical Care Medicine

Carilion Clinic Sleep Center

Roanoke, VA 24016

Michael J. Sateia, MD

Director, Sleep Medicine

Dartmouth-Hitchcock Psychiatric Associates

Sleep Disorders Center

Lebanon, NH

Carl Stepnowski, PhD

Assistant Professor

University of California San Diego

VA San Diego Healthcare System

San Diego, CA