# Additional Key Informants

Benjamin Chambers

Patient/consumer

Edward Grandi

Executive Director

American Sleep Apnea Assocation

Washington, DC

Leah Hole-Curry, JD

Director, HTA Program

Health Care Authority, State of Washington

Seattle, WA

Amir Qaseem, MD, PhD, MHA, FACP

Senior Medical Associate

Medical Education and Publishing Division

American College of Physicians

Philadelphia, PA

Susan Redline, MD, MPH

Professor of Medicine

Brigham and Women's Hospital

Boston, MA

Paul Shekelle, MD, PhD

RAND Corporation

Director, RAND-Southern California EPC

Santa Monica, CA

John W. Winkelman, MD, PhD

Medical Director

Sleep Health Center

Brigham and Women’s Hospital

Boston, MA