# Appendix D Summary Tables

Table 1.1.1 Type III monitors vs. PSG: study characteristics

Study PMID | Participants | Country (enrollment years) | N | Baseline AHI (SD) [range] | Baseline ESS (SD) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Setting | Sleep Apnea Definition | Denominator | Quality Issues
Amir, 2010^70^ 20191939 | Suspected sleep apnea- hypopnea syndrome patients | USA(nd) | 53 | 15.4 [0,106.6] | nd | 48 | 68% | 32 | Sleep lab | AHI ≥15 | Total sleep time (AHI)
Garcia- Diaz, 2007^66^ 17356086 | Suspected sleep apnea- hypopnea syndrome patients | Spain (nd) | 65 | 30 (33) [nd] | 12 (3.7) | 54 | 87% | 30.1 | Sleep lab & Home | nd | Total recording time (RDI) | No clear population description
Ng, 2010^71^ 20199644 | Suspected OSA referred to respiratory clinic | China (nd) | 80 | 21.6 (19.1) | 9.7 (5.3) | 51 | 79% | 27.1 | Sleep lab | nd | Total recording time (RDI)
Planès, 2010^72^ 19533191 | Pts with coronary artery disease | France (Apr 2004 – July 2007) | 45 | 23.8 (15.3) [2,67] | 8 (8.3) | 63 | 98% | 26.4 | Home | nd | Total recording time (RDI) | Selection bias
Santos- Silva, 2009^67^ 19480230 | Suspected OSA and healthy subjects | Brazil (nd) | 82 | 23 (34) [nd] | 10.4 (5.8) | 47 | 57% | 28 | Sleep lab & Home | nd | Total recording time | No clear population description – baseline severity by AHI
To, 2009^68^ 19210658 | Suspected OSA referred to respiratory clinic | China (2005) | 184 | 40 | 10.4 | 49 | 75% | 28.7 | Sleep lab | AHI > 5 | Total recording time | B-A plots are not interpretable; no clear population description
Tonelli de Oliveira, 2009^69^ 19201709 | Referred for sleep center | Brazil (2004–2006) | 157 | 30 (28) | 11 (5.0) | 45 | 73% | 29.1 | Sleep lab & Home | AHI ≥5 | Total recording time | Analytical problem – no adjustment for multiple measures on same patient

Respiratory events across all studies were of at least 10 seconds duration. As mentioned in the header row, respiratory events were defined identically in for the portable monitors as with laboratory-based PSG. Studies are ordered by decreasing number of analyzed people.

Table 1.1.2 Complete list of type III and type IV monitors from our previous report26 as well as in the update

Name of Monitor | Monitor Classification | No. of studies | Studies
ApneaScreen II | III | 2 | Quintana-Gallego 2004, Garcia- Diaz 2007
ARES Unicorder | III | 1 | To 2009
Bedbugg | III | 1 | Claman 2001
CID102L8 Type III system | III | 1 | Planès 2010
Edent 4700 | III | 1 | Redline 1991
Edentrace | III | 3 | Parra 1997, Whittle 1997, Emsellem 1990
Embletta | III | 2 | Dingli 2003, Ng 2010
Merlin | III | 2 | Calleja 2002, Fietze 2002
Micro Digitraper-S | III | 1 | Zucconi 1996
Morpheus Hx bedside computer analysis system | III | 1 | Amir 2010
Nightwatch | III | 2 | Ancoli-Israel 1997, White 1995
NovaSom QSG | III | 1 | Reichert 2003
Poly Mesam | III | 2 | Marrone 2001, Verse 2000
PolyG | III | 1 | Man 1995
Sibel Home-300 | III | 1 | Ballester 2000
SNAP | III | 1 | Su 2004
Somno check | III | 2 | Ficker 2001, Tonelli de Oliveira 2009,
Stardust II | III | 2 | Yim 2006, Santos-Silva 2009
Unnamed Monitors - Respiratory Monitoring | III | 2 | Carasco 1996, Llobres 1996
Apnealink | IV | 5 | Erman 2007, Ng 2009, Ragette 2010, Chen 2009, Clark 2009
Apnomonitor 5 | IV | 1 | Yagi 2009
Apno screen I | IV | 1 | Golpe 2002
ARES | IV | 2 | Ayappa 2008, Westbrook 2005
Autoset | IV | 8 | Bagnato 2000, Bradley 1995, Gugger 1995, Gugger 1997, Kiely 1996, Mayer 1998, Rees 1998, Fleury 1996
CID102 | IV | 1 | vanSurell 1995
ClearPath | IV | 1 | Abraham 2006
Embletta | IV | 1 | Smith 2007
FlowWizard | IV | 1 | Wong 2008
Holter (with and without ECG) | IV | 3 | Szyszko 2009, Pepin 2009, Heneghan 2008
Lifeshirt | IV | 1 | Goodrich 2009
MESAM IV | IV | 5 | Esnaola 1996, Stoohs 1992, Koziej 1994, Schafer 1997, Rauscher 1991
Oxiflow | IV | 2 | Baltzan 2000, Ayappa 2004
Oximeter with or without snoring sound recording, ECG and actigraphy | IV | 22 | Adachi 2003, Alvarez 2006, Bonsignore 1990, Bradley 1995, Chiner 1999, Cooper 1991, Douglas 1992, Gurubhagavatula 2004, Gyulay 1987, Heneghan 2008, Issa 1993, Levy 1996, Pepin 1991, Rauscher 1993, Ryan 1995, Series 1993, Vazquez 2000, White 1994, Williams 1991, Wiltshire 2001, Zamarron 1999, Zamarron 2003,
Reggie | IV | 1 | Overland 2005
RUSleeping RTS | IV | 1 | Watkins 2009
SD-101 (respiratory effort) | IV | 1 | Agatsuma 2009
Sleep Strip | IV | 2 | Shochat 2002, Pang 2006
Sleep Check | IV | 1 | de Almeida 2006
SNAP | IV | 1 | Michaelson 2006
SOMNIE | IV | 1 | Nakano 2008
Watch PAT 100 | IV | 7 | Ayas 2003, Bar 2003, Bar 1995 Penzel 2004, Pittman 2004, Pang 2007, Pillar 2003
WristOx 3100 | IV | 1 | Nigro 2009

Table 1.1.3 Type III monitors vs. PSG: study results

Study PMID | Index Test (vs. PSG) | N | Setting | Bland-Altman | | ROC Analysis | | | | | Quality
Study PMID | Index Test (vs. PSG) | N | Setting | Metric | Result, events/hr | Threshold, events/hr | | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Study PMID | Index Test (vs. PSG) | N | Setting | Metric | Result, events/hr | Index | PSG | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 2.8 (−18, 23) | RDI≥10 | AHI≥10 | 94.6 (87.3, 100) | 96 (88.3, 100) | 0.977 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 2.8 (−18, 23) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 2.8 (−18, 23) | RDI≥15 | AHI≥15 | 100 | 96.7 (90.2, 100) | 0.998 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 2.8 (−18, 23) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 2.8 (−18, 23) | RDI≥30 | AHI≥30 | 95.8 (87.8, 100) | 94.7 (87.6, 100) | 0.986 | A
Garcia-Diaz, 2007^66^ 17356086 | | 62 | Sleep lab (& home) | 95% LOA | | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.03 (−19, 21) | RDI≥10 | AHI≥10 | 94.6 (87.3, 100) | 88 (75.2, 100) | 0.974 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.03 (−19, 21) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.03 (−19, 21) | RDI≥15 | AHI≥15 | 100 | 96.7 (90.2, 100) | 0.997 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.03 (−19, 21) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II in Lab (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.03 (−19, 21) | RDI≥30 | AHI≥30 | 95.8 (87.8, 100) | 94.7 (87.6, 100) | 0.987 | A
Garcia-Diaz, 2007^66^ 17356086 | | 62 | Sleep lab (& home) | 95% LOA | | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 3.1 (−30, 36) | RDI≥10 | AHI≥10 | 86.4 (75.4, 97.5) | 100 | 0.969 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 3.1 (−30, 36) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 3.1 (−30, 36) | RDI≥15 | AHI≥15 | 87.5 (76, 98.9) | 96.7 (90.2, 100) | 0.972 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 3.1 (−30, 36) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs A) | 62 | Sleep lab (& home) | 95% LOA | 3.1 (−30, 36) | RDI≥30 | AHI≥30 | 91.7 (80.6, 100) | 94.7 (87.6, 100) | 0.986 | A
Garcia-Diaz, 2007^66^ 17356086 | | 62 | Sleep lab (& home) | 95% LOA | | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.6 (−31, 34) | RDI≥10 | AHI≥10 | 83.8 (71.9, 95.6) | 92 (81.3, 100) | 0.976 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.6 (−31, 34) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.6 (−31, 34) | RDI≥15 | AHI≥15 | 84.4 (71.8, 96.9) | 96.7 (90.2, 100) | 0.977 | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.6 (−31, 34) | | | | | | A
Garcia-Diaz, 2007^66^ 17356086 | Respiratory Polygraph – Apnoescreen II at Home (Obs B) | 62 | Sleep lab (& home) | 95% LOA | 1.6 (−31, 34) | RDI≥30 | AHI≥30 | 95.8 (87.8, 100) | 94.7 (87.6, 100) | 0.985 | A
Amir, 2010^70^ 20191939 | Morpheus Hx (bedside computerized analysis system) vs PSG | 53 | Sleep Lab | 95% CI | −0.06 (−14.3, 14.2) | ≥5 | ≥5 | 97.2 (nd) | 94.1 (nd) | | A
Amir, 2010^70^ 20191939 | Morpheus Hx (bedside computerized analysis system) vs PSG | 53 | Sleep Lab | 95% CI | −0.06 (−14.3, 14.2) | | | | | | A
Amir, 2010^70^ 20191939 | Morpheus Hx (bedside computerized analysis system) vs PSG | 53 | Sleep Lab | 95% CI | −0.06 (−14.3, 14.2) | ≥15 | ≥15 | 100 (nd) | 92.7 (nd) | | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −0.7 (−24, 22.6) | ≥5 | ≥5 | 93 (nd) | 59 (nd) | 0.90 | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −0.7 (−24, 22.6) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −0.7 (−24, 22.6) | ≥15 | ≥15 | 85 (nd) | 80 (nd) | 0.92 | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −0.7 (−24, 22.6) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −0.7 (−24, 22.6) | ≥30 | ≥30 | 77 (nd) | 93 (nd) | 0.95 | A
Santos-Silva, 2009^67^ 19480230 | | 80 | Sleep Lab & Home | 95% LOA | | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −4.0 (−26.6, 18.6) | ≥5 | ≥5 | 92 (nd) | 48 (nd) | 0.91 | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −4.0 (−26.6, 18.6) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −4.0 (−26.6, 18.6) | ≥15 | ≥15 | 94 (nd) | 71 (nd) | 0.93 | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −4.0 (−26.6, 18.6) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab | 80 | Sleep Lab & Home | 95% LOA | −4.0 (−26.6, 18.6) | ≥30 | ≥30 | 86 (nd) | 79 (nd) | 0.95 | A
Santos-Silva, 2009^67^ 19480230 | | 80 | Sleep Lab & Home | 95% LOA | | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | 1.6 (−22.2, 25.4) | ≥5 | ≥5 | 95 (nd) | 62 (nd) | 0.95 | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | 1.6 (−22.2, 25.4) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | 1.6 (−22.2, 25.4) | ≥15 | ≥15 | 86 (nd) | 78 (nd) | 0.95 | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | 1.6 (−22.2, 25.4) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD at-home vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | 1.6 (−22.2, 25.4) | ≥30 | ≥30 | 74 (nd) | 96 (nd) | 0.96 | A
Santos-Silva, 2009^67^ 19480230 | | 80 | Sleep Lab & Home | 95% LOA | | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | −1.1 (−24.9, 22.8) | ≥5 | ≥5 | 98 (nd) | 62 (nd) | 0.97 | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | −1.1 (−24.9, 22.8) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | −1.1 (−24.9, 22.8) | ≥15 | ≥15 | 97 (nd) | 74 (nd) | 0.98 | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | −1.1 (−24.9, 22.8) | | | | | | A
Santos-Silva, 2009^67^ 19480230 | STD in-lab (done with PSG) vs. PSG in-lab (done with STD) | 80 | Sleep Lab & Home | 95% LOA | −1.1 (−24.9, 22.8) | ≥30 | ≥30 | 96 (nd) | 92 (nd) | 0.98 | A
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | ≥5 | ≥5 | 92.4 (nd) | 85.7 (nd) | 0.948 | B
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | | | | | | B
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | ≥10 | ≥10 | 90 (nd) | 86.7 (nd) | 0.975 | B
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | | | | | | B
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | ≥15 | ≥15 | 87.8 (nd) | 94.9 (nd) | 0.985 | B
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | | | | | | B
Ng, 2010^71^ 20199644 | Embletta portable diagnostic system vs PSG | 80 | Sleep lab | 95% CI | 1.0 (−7, 8.6) ^**^ | ≥20 | ≥20 | 85.3 (nd) | 95.7 (nd) | 0.984 | B
Planès, 2010^72^ 19533191 | Type III device (CID102L8) vs Type II PSG (extended version of CID102L8) | 45 | Sleep lab | 95% CI | −3.4 (−18.4, 11.6) ^**^ | ≥5 | ≥5 | 95 (82, 99) | 67 (12, 98) | | B
Planès, 2010^72^ 19533191 | Type III device (CID102L8) vs Type II PSG (extended version of CID102L8) | 45 | Sleep lab | 95% CI | −3.4 (−18.4, 11.6) ^**^ | | | | | | B
Planès, 2010^72^ 19533191 | Type III device (CID102L8) vs Type II PSG (extended version of CID102L8) | 45 | Sleep lab | 95% CI | −3.4 (−18.4, 11.6) ^**^ | ≥15 | ≥15 | 71 (52, 85) | 93 (64, 100) | | B
Planès, 2010^72^ 19533191 | Type III device (CID102L8) vs Type II PSG (extended version of CID102L8) | 45 | Sleep lab | 95% CI | −3.4 (−18.4, 11.6) ^**^ | | | | | | B
Planès, 2010^72^ 19533191 | Type III device (CID102L8) vs Type II PSG (extended version of CID102L8) | 45 | Sleep lab | 95% CI | −3.4 (−18.4, 11.6) ^**^ | ≥30 | ≥30 | 75 (43, 93) | 97 (82, 100) | | B
To, 2009^68^ 19210658 | ARES Unicorder vs. PSG | 141 | Hospital | nd | Data not interpretable from figure | ≥5 at 4% O_2_ desat | ≥5 | 84 (77, 90) | 100 | 0.96 | B
To, 2009^68^ 19210658 | ARES Unicorder vs. PSG | 141 | Hospital | nd | Data not interpretable from figure | | | | | | B
To, 2009^68^ 19210658 | ARES Unicorder vs. PSG | 141 | Hospital | nd | Data not interpretable from figure | ≥5 at 3% O_2_ desat | ≥5 | 89 (84, 94) | 100 | 0.97 | B
To, 2009^68^ 19210658 | ARES Unicorder vs. PSG | 141 | Hospital | nd | Data not interpretable from figure | | | | | | B
To, 2009^68^ 19210658 | ARES Unicorder vs. PSG | 141 | Hospital | nd | Data not interpretable from figure | ≥5 at 1% O_2_ desat | ≥5 | 97 (94, 99) | 63 (55, 71) | 0.98 | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-lab vs. PSG | 149 | Sleep lab & Home | 95% LOA | 2.6 (−17.7, 22.8) | | | | | | B
Tonelli de Oliveira, 2009^69^ 19201709 | | 149 | Sleep lab & Home | 95% LOA | | | | | | | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | ≥7 | AHI≥5 | 96.15 (92.5, 99.8) | 64.7 (42.0, 87.4) | 0.96 | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | | | | | | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | ≥9 | AHI≥10 | 90.7 (82.7, 95.2) | 82.9 (67.3, 91.9) | 0.92 | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | | | | | | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | ≥9 | AHI≥15 | 81.3 (71.1, 88.5) | 88.4 (78.8, 94.0) | 0.91 | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | | | | | | B
Tonelli de Oliveira, 2009^69^ 19201709 | Somnocheck-Home vs. PSG | 149 | Sleep lab & Home | 95% LOA | 3.2(−28, 34.3) | ≥33 | AHI≥30 | 80 (68.3, 91.7) | 92.1 (86, 98.2) | 0.92 | B

Table 1.2.1 Type IV monitors (≥3 channels) vs. PSG: study characteristics

Study PMID | Participants | Country (enrollment years) | N | Baseline AHI (SD) [range] | Baseline ESS (SD) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Setting | Sleep Apnea Definition | Denominator | Quality Issues
Ayappa, 2008^73^ 18350959 | Referred to specialized center | US (2005–2006) | 80 | nd | 8.8 (nd) | 46 | 78% | 30 | Sleep lab & Home | nd | Total sleep time as well as total recording time | Baseline AHI not reported
Goodrich, 2009^79^ 18083629 | Symptoms suggestive of OSA & GERD | US (nd) | 50 | [5–105] | nd | 44 | 73% | nd | Sleep lab | nd | Total recording time (RDI) | No data on test reader blinding
Ng, 2009^96^ 19220528 | Suspected sleep apnea patients | China (nd) | 50 | nd | 10.1 (5.5) | 50 | 88% | 27.9 | Sleep lab | nd | Total recording time (RDI) | Incomplete reporting of population
Pang, 2007^84^ 17903588 | Referred to sleep center | US (nd) | 37 | 35 (20) [nd] | 13.9 | 50 | 32% | 34.6 | Sleep lab | nd | Total sleep time * | Unclear results reporting; unclear population description
Schafer, 1997^87^ 9154670 | Suspected sleep-related breathing disorders | Germany (nd) | 114 | 29 (24) [nd] | nd | 56 | 88% | 30.8 | Sleep lab & Home | RDI≥10 | Total recording time | Nonconsecutive subjects
Smith, 2007^88^ 18036089 | Chronic heart failure | UK (nd) | 20 | 26 (22) [nd] | 8 (4.0) | 61 | 70% | 29 | Sleep lab & Home | AHI >20 | Total recording time | OSA cut-off different for PSG device
Yagi, 2009^93^ 18635324 | Suspected sleep apnea syndrome | Japan (2005–2006) | 22 | 44 (21) [nd] | nd | 53 | 77% | 25.7 | Sleep lab | AHI≥15 | Total recording time | Incomplete reporting of population, OSA severity, methods, or analyses

* As described, the device should only be capable of using the total recording time

** Estimated from Figure of plot in the publication, using the Engauge Digitizer software program

Table 1.2.2 Type IV monitors (2 channels) vs. PSG: study characteristics

Study PMID | Participants | Country (enrollment years) | N | Baseline AHI (SD) [range] | Baseline ESS (SD) | Mean Age, yr | Male,% | Mean BMI, kg/m^2^ | Setting | Sleep Apnea Definition | Denominator | Quality Issues
Abraham, 2006^74^ 17033271 | Heart failure | US & UK (nd) | 50 | [0–92] | 10.6 (4.4) | 56 | 68% | 32.6 | Sleep lab & Home | RDI ≥5 | Total sleep time | Significant difference among sites; home test data not presented; unclear criteria for tests
Chen, 2009^75^ 19052790 | Suspected sleep disordered breathing patients | Canada(nd) | 54 | 30 (26) [1–86] | nd | 49 | 64% | 32.2 | Sleep lab | OSA: AHI≥5 | Total sleep time
Clark, 2009^76^ 19222876 | Suspected sleep disordered breathing patients | UK (nd) | 67 | 22 (23) [0–87] | 13.3 (5.2) | 51 | 76% | 35.0 | Home | CPAP Tx needed: AHI ≥ 15 | Total recording time (RDI) | B-A plots are not interpretable; no clear population description
Heneghan, 2008^81^ 18853941 | Suspected OSA | Ireland (nd) | 63 | nd | 11.3 | 51 | 88% | 30.9 | Sleep lab | AHI≥15 | Total recording time
Pepin, 2009^85^ 19028140 | Referred for sleep center | France (nd) | 34 | 20 (19) [nd] | 10 (6.0) | 47 | 63% | 25.4 | Sleep lab | AHI >20 | Total recording time | Unclear population description
Ragette, 2010^95^ 19714380 | Referred for sleep lab | Germany (Jul – Oct 2003) | 102 | nd | nd | 54 | 76% | 29.5 | Sleep lab | nd | Total recording time | Unclear population description
Ragette, 2010^95^ 19714380 | Referred for sleep lab day clinic | Germany (Jan 2005 – Feb 2006) | 131 | nd | nd | 59 | 73% | 28 | Home | nd | Total recording time | Unclear population description
Szyszko, 2009^89^ 18971289 | Suspected OSA | Argentina (nd) | 20 | 24 (26) [5–119] | 10.9 (5.2) | 49 | 50% | 41.3 | Sleep lab | AHI ≥10 | Total recording time
White, 1994^91^ 7923843 | Referred for UPPP | UK (nd) | 37 | nd | nd | 37 | 68% | nd | Sleep lab | AHI ≥10 | Total sleep time | Unclear description of population and tests; discrepancy in results reporting

Table 1.2.3 Type IV monitors (1 channel) vs. PSG: study characteristics

Study PMID | Participants | Country (enrollment years) | N | Baseline AHI (SD) [range] | Baseline ESS (SD) | Mean Age, yr | Male,% | Mean BMI, kg/m^2^ | Setting | Sleep Apnea Definition | Denominator | Quality Issues
Agatsuma, 2009^94^ 19818056 | Suspected disordered sleep patients and healthy truck drivers | Japan (Mar 2004 – Aug 2007) | 366 | 19.7 ††† | 5.8 ‡‡‡ | 49 | 87 | 25.2 | Sleep lab & Home | AHI ≥ 15 w/o symptoms or AHI ≥ 5– < 15 w/symptoms | Total recording time (RDI) | Data from two dissimilar groups was combined to estimate sens and sp for the device
de Almeida, 2006^77^ 16502297 | Patients referred to sleep center for suspected sleep- related breathing disorders | Canada(nd) | 35 | 19 (22) [nd] | nd | 44 | 77% | 31.1 | Sleep lab | AHI >5 | Total recording time (RDI) | 16% of sample was excluded without reason
Erman, 2007^78^ 17694728 | Patients with type 2 diabetes mellitus | USA (nd) | 68 | nd | nd | 57 | 49% | 32.6 | Sleep lab & Home | nd | Total recording time (RDI)
Heneghan, 2008^80^ 18595434 | Suspected OSA and healthy male subjects | Ireland (nd) | 98 | 33 (nd) [nd] | 11.9 (nd) | 42 | 100% | 33.9 | Sleep lab | AHI≥15 | Total recording time | Results not interpretable
Nakano, 2008^82^ 18480104 | Patients referred for sleep disorders | Japan (nd) | 100 | 30 [10–65] | nd | 45.3 * | 80% | 26.9 | Sleep lab & Home | nd | Total recording time
Nigro, 2009^83^ 18830731 | Suspected OSA | Argentina (nd) | 166 | 14 [4–29]^†^ | nd | 51 | 77% | 28.3 | Sleep lab | AHI ≥5 | Total recording time | Unclear description of population
Watkins, 2009^90^ 19786903 | Commercial motor drivers at high risk for OSA | USA (Sept 2007 – Oct 2008) | 159 | 19 (nd) [1–117] | nd | nd | nd | nd | Sleep lab & Community | AHI ≥ 5 | Total recording time | No clear population description; 78% drop outs; no clear description of PSG
Reda, 2001^86^ 11593166 | Sleep-related breathing disorders | UK (nd) | 59 | nd | nd | Range: 20–70 | nd | nd | Sleep lab | AHI ≥15 | Total recording time | Unclear population description; test readers not blinded
White, 1994^91^ 7923843 | Referred for UPPP | UK (nd) | 37 | nd | nd | 37 | 68% | nd | Sleep lab | AHI ≥10 | Total sleep time | Unclear description of population and tests; discrepancy in results reporting
Wong, 2008^92^ 18411561 | Referred for sleep center | Australia (nd) | 34 | 32 (27) [0–100] | 11.9 (4.7) | 42 | 97% | 30.2 | Sleep lab & Home | AHI ≥10 | Total recording time | Unclear description of population

††† weighted mean; suspected disordered sleep gp: 28.6 ± 23.0; healthy truck drivers group: 8.9 ± 14.3

‡‡‡ weighted mean

* Average of the mean values of the two centers of the study

† Median and interquartile range

Table 1.3.1 Type IV monitors (≥3 channels) vs. PSG: study results

Study PMID | Index Test (vs PSG) | N | Setting | Bland-Altman | | ROC Analysis | | | | | Quality
Study PMID | Index Test (vs PSG) | N | Setting | Metric | Result, events/hr | Threshold, events/hr | | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Study PMID | Index Test (vs PSG) | N | Setting | Metric | Result, events/hr | Index | PSG | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Ayappa 2008^73^ 18350959 | ARES^*^ in-Lab vs PSG | 73 | Sleep lab (& home) | 95% LOA | 0.7 (−1.2, 2.6) | AHI >5 4% O_2_ des | AHI >5 4% O _2_ des | 0.98 (0.88, 1) | 0.76(0.52, 0.91) | | A
Ayappa 2008^73^ 18350959 | ARES^*^ in-Lab vs PSG | 73 | Sleep lab (& home) | 95% LOA | 0.7 (−1.2, 2.6) | | | | | | A
Ayappa 2008^73^ 18350959 | ARES^*^ in-Lab vs PSG | 73 | Sleep lab (& home) | 95% LOA | 0.7 (−1.2, 2.6) | AHI >5 4% O_2_ des | AHI >10 4% O_2_ des | 0.97 (0.84, 1) | 0.78(0.6, 0.89) | | A
Ayappa 2008^73^ 18350959 | ARES^*^ in-Lab vs PSG | 73 | Sleep lab (& home) | 95% LOA | 0.7 (−1.2, 2.6) | | | | | | A
Ayappa 2008^73^ 18350959 | ARES^*^ in-Lab vs PSG | 73 | Sleep lab (& home) | 95% LOA | 0.7 (−1.2, 2.6) | AHI >5 4% O_2_ des | AHI >15 4% O_2_ des | 0.91 (0.75, 0.98) | 0.92 (0.78, 0.98) | | A
Ayappa 2008^73^ 18350959 | | | Sleep lab (& home) | 95% LOA | | | | | | | A
Ayappa 2008^73^ 18350959 | ARES in-Lab vs PSG (RDI) | 73 | Sleep lab (& home) | 95% LOA | 3.3 (0.8, 5.9) | AHI >10 1% O_2_ des | RDI >10 | 0.95 (0.86, 0.99) | 0.73 (0.39, 0.93) | | A
Ayappa 2008^73^ 18350959 | ARES in-Lab vs PSG (RDI) | 73 | Sleep lab (& home) | 95% LOA | 3.3 (0.8, 5.9) | | | | | | A
Ayappa 2008^73^ 18350959 | ARES in-Lab vs PSG (RDI) | 73 | Sleep lab (& home) | 95% LOA | 3.3 (0.8, 5.9) | AHI ≥ 15 1% O_2_ des | RDI ≥15 | 0.94 (0.84, 0.99) | 0.89 (0.65, 0.98) | | A
Ayappa 2008^73^ 18350959 | | | Sleep lab (& home) | 95% LOA | | | | | | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG | 67 | Sleep lab (& home) | 95% LOA | 5.2 (1.0, 9.4) | AHI >5 4% O_2_ des | AHI >5 4% O_2_ des | 0.92 (0.8, 0.97) | 0.67 (0.41, 0.86) | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG | 67 | Sleep lab (& home) | 95% LOA | 5.2 (1.0, 9.4) | | | | | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG | 67 | Sleep lab (& home) | 95% LOA | 5.2 (1.0, 9.4) | AHI >5 4% O_2_ des | AHI >10 4% O_2_ des | 0.89 (0.72, 0.96) | 0.72 (0.53, 0.86) | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG | 67 | Sleep lab (& home) | 95% LOA | 5.2 (1.0, 9.4) | | | | | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG | 67 | Sleep lab (& home) | 95% LOA | 5.2 (1.0, 9.4) | AHI >5 4% O_2_ des | AHI >15 4% O_2_ des | 0.76 (0.57, 0.88) | 0.82 (0.65, 0.93) | | A
Ayappa 2008^73^ 18350959 | | | Sleep lab (& home) | 95% LOA | | | | | | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG (RDI) | 67 | Sleep lab (& home) | 95% LOA | 10.3 (5.9, 14.6) | AHI >10 1% O_2_ des | RDI >10 | 0.9 (0.78, 0.96) | 0.78 (0.4, 0.96) | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG (RDI) | 67 | Sleep lab (& home) | 95% LOA | 10.3 (5.9, 14.6) | | | | | | A
Ayappa 2008^73^ 18350959 | ARES at-home vs PSG (RDI) | 67 | Sleep lab (& home) | 95% LOA | 10.3 (5.9, 14.6) | AHI ≥ 15 1% O_2_ des | RDI ≥15 | 0.84 (0.71, 0.93) | 0.81 (0.54, 0.95) | | A
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | ≥5 | ≥5 | 85 (nd) | 67 (nd) | 0.76 | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | | | | | | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | ≥10 | ≥10 | 92 (nd) | 88 (nd) | 0.90 | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | | | | | | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | ≥15 | ≥15 | 87 (nd) | 82 (nd) | 0.84 | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | | | | | | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | ≥20 | ≥20 | 85 (nd) | 94 (nd) | 0.90 | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | | | | | | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | ≥25 | ≥25 | 100 (nd) | 97 (nd) | 0.99 | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | | | | | | B
Goodrich 2009^79^ 18083629 | Lifeshirt | 48 | Lab | 95% LOA | 1.02 (−16.4, 16.4) | ≥30 | ≥30 | 88 (nd) | 100 (nd) | 0.94 | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | ≥5 | ≥5 | 100 (nd) | 100 (nd) | 1.000 | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | ≥10 | ≥10 | 97.7 (nd) | 100 (nd) | 1.000 | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | ≥15 | ≥15 | 94.7 (nd) | 100 (nd) | 0.998 | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (AHI) vs PSG | 50 | Sleep lab | 95% CI | 2.0 (−6.7, 10.5) ** | ≥20 | ≥20 | 96.9 (nd) | 100 (nd) | 1.000 | B
Ng, 2009^96^ 19220528 | | | | | | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | ≥5 | ≥5 | 95.8 (nd) | 50 (nd) | 0.964 | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | ≥10 | ≥10 | 88.3 (nd) | 85.7 (nd) | 0.935 | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | ≥15 | ≥15 | 73.7 (nd) | 91.7 (nd) | 0.931 | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | | | | | | B
Ng, 2009^96^ 19220528 | ApneaLink (ODI) vs PSG | 50 | Sleep Lab | 95% CI | 10.9 (−8.6, 30) ** | ≥20 | ≥20 | 75 (nd) | 88.9 (nd) | 0.922 | B
Yagi 2009^93^ 18635324 | Apnomonitor vs PSG | 22 | Sleep Lab | | | ≥15 | ≥15 | 95 | | | C
Pang 2007^84^ 17903588 | WatchPAT | 32 | Sleep Lab | | | >5 | >5 | 94 (nd) | 80 (nd) | | C
Pang 2007^84^ 17903588 | WatchPAT | 32 | Sleep Lab | | | | | | | | C
Pang 2007^84^ 17903588 | WatchPAT | 32 | Sleep Lab | | | >15 | >15 | 96 (nd) | 79 (nd) | | C
Pang 2007^84^ 17903588 | WatchPAT | 32 | Sleep Lab | | | | | | | | C
Pang 2007^84^ 17903588 | WatchPAT | 32 | Sleep Lab | | | >35 | >35 | 83 (nd) | 72 (nd) | | C
Smith 2007^88^ 18036089 | Embletta in- Lab | 20 | Sleep lab & Home | 95% LOA | 6 (−11, 24) | | | | | | B
Smith 2007^88^ 18036089 | | | | 95% LOA | | | | | | | B
Smith 2007^88^ 18036089 | Embletta at- home | 20 | Sleep lab & Home | 95% LOA | 12 (−25, 49) | AHI≥10 | AHI ≥ 15 | 87.5 (nd) | 58.3 | | B
Smith 2007^88^ 18036089 | Embletta at- home | 20 | Sleep lab & Home | 95% LOA | 12 (−25, 49) | | | | | | B
Smith 2007^88^ 18036089 | Embletta at- home | 20 | Sleep lab & Home | 95% LOA | 12 (−25, 49) | AHI≥20 | AHI ≥ 15 | 75 (nd) | 50 | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | ≥5 | ≥5 | 96 (nd) | 15 (nd) | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | | | | | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | ≥10 | ≥10 | 95 (nd) | 41 (nd) | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | | | | | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | ≥15 | ≥15 | 83 (nd) | 62 (nd) | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | | | | | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | ≥20 | ≥20 | 68 (nd) | 74 (nd) | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | | | | | | B
Schafer 1997^87^ 9154670 | MESAM 4 | 114 | Sleep lab & Home | nd | Data not interpretable from figure | ≥25 | ≥25 | 60 (nd) | 85 (nd) | | B

* ARES: Apnea Risk Evaluation System Unicorder

** Estimated from Figure of plot in the publication, using the Engauge Digitizer software program

Table 1.3.2 Type IV monitors (2 channels) vs. PSG: study results

Study PMID | Index Test (vs PSG) | N | Setting | Bland-Altman | | Threshold, events/hr | | ROC Analysis Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Study PMID | Index Test (vs PSG) | N | Setting | Metric | Result, events/hr | Threshold, events/hr | | ROC Analysis Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Pepin 2009^85^ 19028140 | ECG/nasal pressure holter monitoring visual | 19 | Sleep lab | 95% CI | 5.8 (−3.9, 15.5) | >35 | >20 | 57 (nd) | 100 (nd) | 0.97 | B
Pepin 2009^85^ 19028140 | | | | 95% CI | | | | | | | B
Pepin 2009^85^ 19028140 | ECG/nasal pressure holter monitoring automated | 19 | Sleep lab | 95% CI | 2.3 (−18.9, 23.4) | >35 | >20 | 71 (nd) | 100 (nd) | 0.85 | B
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | AHI≥5 | AHI≥5 | 97.7 (nd) | 66.7 (nd) | 0.964 | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | AHI≥10 | AHI≥10 | 95.0 (nd) | 90.0 (nd) | 0.978 | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | AHI≥15 | AHI≥15 | 87.5 (nd) | 88.9 (nd) | 0.944 | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | AHI≥20 | AHI≥20 | 88.0 (nd) | 88.0 (nd) | 0.944 | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (AASM criteria *) | 50 | Sleep lab | 95% LOA | −6.3 (−25.5, 12.9) | AHI≥30 | AHI≥30 | 88.2 (nd) | 93.9 (nd) | 0.954 | A
Chen 2009^75^ 19052790 | | 50 | Sleep lab | 95% LOA | | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | AHI≥5 | AHI≥5 | 93.2 (nd) | 83.3 (nd) | 0.951 | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | AHI≥10 | AHI≥10 | 97.5 (nd) | 90.0 (nd) | 0.983 | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | AHI≥15 | AHI≥15 | 90.6 (nd) | 77.8 (nd) | 0.944 | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | AHI≥20 | AHI≥20 | 92.0 (nd) | 84.0 (nd) | 0.934 | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | | | | | | A
Chen 2009^75^ 19052790 | ApneaLink (Sandman setting^†^) | 50 | Sleep lab | 95% LOA | −0.5 (−17.9, 16.9) | AHI≥30 | AHI≥30 | 94.1 (nd) | 81.8 (nd) | 0.955 | A
Ragette, 2010^95^ 19714380 | Apnealink-in Lab vs PSG | 102 | Sleep lab | 95% CI | −0.7 (−14,12) ** | ≥5 | ≥5 | 93.9 (nd) | 50 (nd) | | B
Ragette, 2010^95^ 19714380 | Apnealink-in Lab vs PSG | 102 | Sleep lab | 95% CI | −0.7 (−14,12) ** | | | | | | B
Ragette, 2010^95^ 19714380 | Apnealink-in Lab vs PSG | 102 | Sleep lab | 95% CI | −0.7 (−14,12) ** | ≥10 | ≥10 | 91.9 (nd) | 87.5 (nd) | | B
Ragette, 2010^95^ 19714380 | Apnealink-in Lab vs PSG | 102 | Sleep lab | 95% CI | −0.7 (−14,12) ** | | | | | | B
Ragette, 2010^95^ 19714380 | Apnealink-in Lab vs PSG | 102 | Sleep lab | 95% CI | −0.7 (−14,12) ** | ≥15 | ≥15 | 92 (nd) | 88.5 (nd) | | B
Ragette, 2010^95^ 19714380 | | | | | | | | | | | B
Ragette, 2010^95^ 19714380 | Apnealink-at Home vs PSG | 131 | Home | 95% CI | 1.2 (−18.8,18.7) ** | ≥5 | ≥5 | 91.8 (nd) | 76.5 (nd) | | B
Ragette, 2010^95^ 19714380 | Apnealink-at Home vs PSG | 131 | Home | 95% CI | 1.2 (−18.8,18.7) ** | | | | | | B
Ragette, 2010^95^ 19714380 | Apnealink-at Home vs PSG | 131 | Home | 95% CI | 1.2 (−18.8,18.7) ** | ≥10 | ≥10 | 80 (nd) | 85.5 (nd) | | B
Ragette, 2010^95^ 19714380 | Apnealink-at Home vs PSG | 131 | Home | 95% CI | 1.2 (−18.8,18.7) ** | | | | | | B
Ragette, 2010^95^ 19714380 | Apnealink-at Home vs PSG | 131 | Home | 95% CI | 1.2 (−18.8,18.7) ** | ≥15 | ≥15 | 73.1 (nd) | 84.7 (nd) | | B
Clark 2009^76^ 19222876 | ApneaLink^‡^ | 50 | Home | nd | Data not interpretable from figure | AHI≥15 | AHI≥15 | 92 (nd) | 96.7 (nd) | | B
Abraham 2006^74^ 17033271 | Home Cardiorespiratory system (ClearPath System Nx-301) | 50 | Sleep lab | | | RDI≥5 | RDI≥5 | 92 (nd) | 52 (nd) | | B
Abraham 2006^74^ 17033271 | Home Cardiorespiratory system (ClearPath System Nx-301) | 50 | Sleep lab | | | | | | | | B
Abraham 2006^74^ 17033271 | Home Cardiorespiratory system (ClearPath System Nx-301) | 50 | Sleep lab | | | RDI≥10 | RDI≥10 | 88 (nd) | 63 (nd) | | B
Abraham 2006^74^ 17033271 | Home Cardiorespiratory system (ClearPath System Nx-301) | 50 | Sleep lab | | | | | | | | B
Abraham 2006^74^ 17033271 | Home Cardiorespiratory system (ClearPath System Nx-301) | 50 | Sleep lab | | | RDI≥15 | RDI≥15 | 67 (nd) | 78 (nd) | | B
Heneghan 2008^81^ 18853941 | ECG-Oximetry analysis | 59 | Sleep lab | 95% LOA | −0.9/hr (−18, 16.2) | ≥5 | ≥5 | 93.8 (86.9, 100) | 100 | | A
Heneghan 2008^81^ 18853941 | ECG-Oximetry analysis | 59 | Sleep lab | 95% LOA | −0.9/hr (−18, 16.2) | | | | | | A
Heneghan 2008^81^ 18853941 | ECG-Oximetry analysis | 59 | Sleep lab | 95% LOA | −0.9/hr (−18, 16.2) | ≥10 | ≥10 | 81.6 (69.3, 93.9) | 90.5 (77.9, 100) | | A
Heneghan 2008^81^ 18853941 | ECG-Oximetry analysis | 59 | Sleep lab | 95% LOA | −0.9/hr (−18, 16.2) | | | | | | A
Heneghan 2008^81^ 18853941 | ECG-Oximetry analysis | 59 | Sleep lab | 95% LOA | −0.9/hr (−18, 16.2) | ≥15 | ≥15 | 74.2 (58.8, 89.6) | 96.4 (89.6, 100) | | A
Heneghan 2008^81^ 18853941 | | | | 95% LOA | | | | | | | A
Heneghan 2008^81^ 18853941 | Oximetry | 59 | Sleep lab | 95% LOA | 1.1/hr (−16.5, 18.4) | | | | | | A
Heneghan 2008^80^ 18595434 | Holter ECG analysis algorithm | 92 | Sleep lab | nd | Data not interpretable from figure | ≥15 | ≥15 | 92 (nd) | 69 (nd) | | B
Heneghan 2008^80^ 18595434 | Holter ECG analysis algorithm | 92 | Sleep lab | nd | Data not interpretable from figure | | | | | | B
Heneghan 2008^80^ 18595434 | Holter ECG analysis algorithm | 92 | Sleep lab | nd | Data not interpretable from figure | ≥5 – <15 | ≥5 – <15 | 60^§^ (nd) | 86 (nd) | | B
Heneghan 2008^80^ 18595434 | Holter ECG analysis algorithm | 92 | Sleep lab | nd | Data not interpretable from figure | | | | | | B
Heneghan 2008^80^ 18595434 | Holter ECG analysis algorithm | 92 | Sleep lab | nd | Data not interpretable from figure | < 5 | < 5 | 37 (nd) | 95 (nd) | | B
Szyszko 2009^89^ 18971289 | Holter Monitor | 20 | Sleep lab | 95% LOA | 4.7 (−30.1, 39.4) | RDI ≥10 | AHI ≥10 | 78.5 (48.2, 94.2) | 83.3 (25.8, 89.7) | 0.81 | A
White 1994^91^ 7923843 | O_2_ saturation & snoring sound vs PSG | 37 | Sleep lab | | | nd | AHI≥10 | 62 | 100 | | C
White 1994^91^ 7923843 | O_2_ saturation & snoring sound vs PSG | 37 | Sleep lab | | | | | | | | C
White 1994^91^ 7923843 | O_2_ saturation & snoring sound vs PSG | 37 | Sleep lab | | | nd | AHI≥15 | 86 | 78 | | C
White 1994^91^ 7923843 | O_2_ saturation & snoring sound vs PSG | 37 | Sleep lab | | | | | | | | C
White 1994^91^ 7923843 | O_2_ saturation & snoring sound vs PSG | 37 | Sleep lab | | | nd | AHI≥20 | 100 | 76 | | C

* Apnea: Reduction of inspiratory airflow by 80% to 100% over 10 secs (max 80 ss); Hypopnea: Reduction of tidal breathing of 50% from baseline tidal breathing lasting (Max100 secs)

† Sandman Sleep Diagnostic System setting - Apnea: 85% or more reduction of normal flow that lasts (max 100 s); Hypopnea: 40% reduction of normal flow lasting 10 s (max 120 s)

‡ Using home-based PSG (Embletta)

§ Calculated from data provided

** Estimated CI from Figure of plot in the publication, using the Engauge Digitizer software program

Table 1.3.3 Type IV monitors (1 channel) vs. PSG: study results

Study PMID | Index Test (vs PSG) | N | Setting | Bland-Altman | | ROC Analysis | | | | | Quality
Study PMID | Index Test (vs PSG) | N | Setting | Metric | Result, events/hr | Threshold, events/hr | | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | AHI >5 | AHI >5 | 85.4 (nd) | 50.0 (nd) | 0.863 | A
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | | | | | | A
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | AHI >10 | AHI >10 | 82.1 (nd) | 83.9 (nd) | 0.862 | A
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | | | | | | A
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | AHI >15 | AHI >15 | 90.9 (nd) | 94.6 (nd) | 0.977 | A
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | | | | | | A
Erman 2007^78^ 17694728 | ApneaLink | 58 | Lab | 95% LOA | ~ −2 (−22, 18) * | AHI >20 | AHI >20 | 83.3 (nd) | 92.7 (nd) | 0.967 | A
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | >5 | >5 | 86.4 | 75 | 0.886 | B
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | | | | | | B
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | >10 | >10 | 85.7 | 87.5 | 0.915 | B
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | | | | | | B
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | >15 | >15 | 83.5 | 83.5 | 0.898 | B
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | | | | | | B
de Almeida 2006^77^ 16502297 | Sleep Check | 30 | Sleep lab | 95% LOA | 0 (−26.6, 26.6) | >20 | >20 | 88.9 | 81 | 0.910 | B
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Home | 95% LOA | −9.5 (−30.4,11.4) | >5.3 | >5 | 96 (91,100) | 82 (59,100) | 0.95 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Home | 95% LOA | −9.5 (−30.4,11.4) | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Home | 95% LOA | −9.5 (−30.4,11.4) | >11.4 | >15 | 91 (84, 98) | 82 (70, 95) | 0.96 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Home | 95% LOA | −9.5 (−30.4,11.4) | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Home | 95% LOA | −9.5 (−30.4,11.4) | >19.6 | >30 | 89 (80, 97) | 96 (90,100) | 0.98 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Female | 95% LOA | | >5.3 | >5 | 88 (nd) | 67 (nd) | 0.88 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Female | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Female | 95% LOA | | >11.4 | >15 | 75 (nd) | 83 (nd) | 0.89 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Female | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | Female | 95% LOA | | >19.6 | >30 | 100 | 94 (nd) | 1.0 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | BMI <25 kg/m^2^ | 95% LOA | | >5.3 | >5 | 97 (nd) | 71 (nd) | 0.94 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | BMI <25 kg/m^2^ | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | BMI <25 kg/m^2^ | 95% LOA | | >11.4 | >15 | 78 (nd) | 89 (nd) | 0.92 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | BMI <25 kg/m^2^ | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | BMI <25 kg/m^2^ | 95% LOA | | >19.6 | >30 | 91 (nd) | 92 (nd) | 0.97 | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | | 95% LOA | | | | | | | A
Nakano 2008^82^ 18480104 | SOMNIE single-channel airflow monitor | 100 | AHI <15 | 95% LOA | | >5.3 | >5 | 83 (nd) | 82 (nd) | 0.81 | A
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | >5 | >15 | 100 | 42 | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | | | | | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | >10 | >15 | 100 | 71 | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | | | | | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | >15 | >15 | 70 | 83 | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | | | | | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | >20 | >15 | 70 | 83 | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | | | | | | C
Watkins 2009^90^ 19786903 | RUSleeping RTS vs. PSG | 34 | Sleep lab & Community | | | >30 | >15 | 43 | 96 | | C
Wong 2008^92^ 18411561 | FlowWizard in lab vs PSG | 31 | Sleep lab | 95% LOA | 1.8 (−32.4, 36.0) | AHI>18 | AHI≥10 | 96 | 71 | 0.95 | A
Wong 2008^92^ 18411561 | | | | 95% LOA | | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>8 | AHI≥10 | 100 | 43 | 0.96 | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>12 | | 96 | 71 | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>18 | | 92 | 86 | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>21 | | 88 | 100 | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>21 | AHI≥30 | 100 | 50 | 0.85 | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>28 | | 91 | 75 | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>45 | | 36 | 90 | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI>59 | | 18 | 100 | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (3 night average) vs PSG | 31 | Sleep lab & Home | 95% LOA | 7.1 (−14.8, 29.0) | AHI from first night on FlowWizard | AHI≥30 | | | 0.89 | A
Wong 2008^92^ 18411561 | | | | 95% LOA | | | | | | | A
Wong 2008^92^ 18411561 | FlowWizard at home (1 night) vs PSG | 31 | Sleep lab & Home | 95% LOA | | AHI from first night on FlowWizard | AHI≥10 | | | 0.92 | A
Wong 2008^92^ 18411561 | | | | 95% LOA | | | | | | | A
Wong 2008^92^ 18411561 | MAPI v PSG | 31 | Sleep lab & Home | 95% LOA | | | AHI≥10 | | | 0.68 | A
Wong 2008^92^ 18411561 | | | | 95% LOA | | | | | | | A
Wong 2008^92^ 18411561 | Combined FlowWizard (home, 3 night) & MAPI v PSG | 31 | Sleep lab & Home | 95% LOA | | | AHI≥10 | | | 0.96 | A
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI2^†^ >12.2 | AHI ≥5 | 100 (96.4, 100) | 57.69 (43.2, 71.3) | 0.959 | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI2 >19.3 | AHI ≥5 | 89.22 (81.5, 94.5) | 94.23 (84.0, 98.7) | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI5 >4.3 | AHI ≥5 | 92.75 (52.6, 72.1) | 100 (93.1, 100) | 0.907 | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI2 >12.2 | AHI ≥10 | 100 (95.8, 100) | 44.12 (32.1, 56.7) | 0.957 | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI3 >10.5 | AHI ≥10 | 88.37 (79.6, 94.3) | 94.12 (85.6, 98.3) | 0.965 | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI5 >4.3 | AHI ≥10 | 74.42 (63.9, 83.2) | 100 (94.7, 100) | 0.930 | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI3 >4.4 | AHI ≥15 | 100 (95.0, 100) | 49.38 (38.1, 60.7) | 0.945 | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI3 >13.4 | AHI ≥15 | 87.67 (77.9, 94.2) | 90.12 (81.5, 95.6) | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | | | | | | B
Nigro 2009^83^ 18830731 | O_2_ saturation (WristOx 3100) | 154 | Sleep lab | | | ADI3 >32 | AHI ≥15 | 42.47 (31.0, 54.6) | 100 (95.5, 100) | | B
White 1994^91^ 7923843 | O_2_ saturation vs PSG | 37 | Sleep lab | | | nd | AHI≥10 | 30 | 100 | | C
White 1994^91^ 7923843 | O_2_ saturation vs PSG | 37 | Sleep lab | | | | | | | | C
White 1994^91^ 7923843 | O_2_ saturation vs PSG | 37 | Sleep lab | | | nd | AHI≥15 | 71 | 94 | | C
White 1994^91^ 7923843 | O_2_ saturation vs PSG | 37 | Sleep lab | | | | | | | | C
White 1994^91^ 7923843 | O_2_ saturation vs PSG | 37 | Sleep lab | | | nd | AHI≥20 | 100 | 94 | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | 95% LOA | 0.22 (−8.68, 9.02) | <15 | <15 | 100 (nd) | 100 (nd) | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | 95% LOA | 0.22 (−8.68, 9.02) | | | | | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | 95% LOA | 0.22 (−8.68, 9.02) | 15–20 | 15–20 | 80 (nd) | 96 (nd) | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | | | | | | | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | 95% CI | (−0.93, 1.38) | 20–40 | 20–40 | 90 (nd) | 97 (nd) | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | 95% CI | (−0.93, 1.38) | | | | | | C
Reda 2001^86^ 11593166 | Pharyngoesophageal monitoring | 59 | Sleep lab | 95% CI | (−0.93, 1.38) | >40 | >40 | 100 (nd) | 100 (nd) | | C
Agatsuma, 2009^94^ 19818056^‡^ | SD-101 (Resp. effort) vs PSG | 366 | Sleep Lab and Home | 95% CI | −4.7 (−19.7, 10.4) | 12.4 | ≥5 | 87.5 (nd) | 88 (nd) | 0.96 | C
Agatsuma, 2009^94^ 19818056^‡^ | SD-101 (Resp. effort) vs PSG | 366 | Sleep Lab and Home | 95% CI | −4.7 (−19.7, 10.4) | | | | | | C
Agatsuma, 2009^94^ 19818056^‡^ | SD-101 (Resp. effort) vs PSG | 366 | Sleep Lab and Home | 95% CI | −4.7 (−19.7, 10.4) | 18.6 | ≥15 | 89.7 (nd) | 90.5 (nd) | 0.97 | C

* Estimated from Figure of plot in the publication, using the Engauge Digitizer software program

† ADI - Adjusted O_2_ desaturation index (ADI): mean number of O_2_ desaturations per hour of analyzed recording ≥2%, 3%, 5% (ADI2, ADI3, ADI5)

‡ Results from the two separate groups were reported but not presented.

Table 1.4.1 Questionnaires vs. PSG: study characteristics

Study PMID | Participants | Country (years) | N | Baseline AHI (SD) [range] | Baseline ESS (SD) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Setting | Sleep Apnea Definition | Quality issues
Chung, 2008^36^ 18431116 | Preoperative | Canada (nd) | 211 | 20 (6) [nd] | nd | 55 | 50 | 30 | Hospital | AHI>5 | Selection bias
Chung, 2008^97^ 18431117 | Preoperative | Canada (nd) | 211 | 20 (6) [nd] | nd | 55 | 50 | 30 | Hospital | AHI>5 | Selection bias
Kapuniai, 1988^98^ 3227223 | Sleep disorder center | US (nd) | 53 | nd | nd | 46 | 79 | nd | Sleep lab | AI/AHI >5 | PSG results not reported
Netzer, 1999^99^ 10507956 | General population visiting primary care physician | US (nd) | 1008 | High-risk group: 21 (18) [0, 101] Low-risk group: 5 (7) [0, 37] | nd | 49 | 42 | 29 | Home | RDI ≥5 | Probable selection bias
Sharma, 2006^100^ 17085831 | Attending the medical outpatient department | India (2000–02) | 180 | nd | nd | 40 | 80 | 28.2 | Sleep lab and hospital | AHI >5 | Modified questionnaire not validated, 42% dropout rate
Drager, 2010^101^ 20381666 | Patiens attending a hypertension clinic of a hoslital | Brazil (2009) | 99 | 7.9 (2.3,29.1) | 9 (5) | 46 | 53 | 28.8 * | Hospital | AHI > 5 | None^†^

* Median

† No quality issues in reporting. The study was not primarily designed to evaluate the two instruments; the study assessed the association of various clinical factors with the risk for OSA. The sensitivity and specificity for the index tests was reported, along with other anthropometric and clinical indicators.

Table 1.4.2 Questionnaires vs. PSG: study results

Study PMID | Index test | Reference test | N | Setting | Bland-Altman | | ROC Analysis | | | | | Quality
Study PMID | Index test | Reference test | N | Setting | Metric^A^ | Result | Threshold, events/hr | | Sensitivity (95% CI) | Specificity (95% CI) | AUC | Quality
Study PMID | Index test | Reference test | N | Setting | Metric^A^ | Result | Index | PSG | Sensitivity (95% CI) | Specificity (95% CI) | AUC | Quality
Chung, 2008^36^ 18431116 | STOP | PSG | 177 | Sleep lab | | | High vs. low | >5 | 65.6 (56.4, 73.9) | 60 (45.9, 73.0) | 0.703 | C
Chung, 2008^36^ 18431116 | STOP | PSG | 177 | Sleep lab | | | High vs. low | >15 | 74.3 (62.4, 84.0) | 53.3 (43.4, 63.0) | 0.722 | C
Chung, 2008^36^ 18431116 | STOP | PSG | 177 | Sleep lab | | | High vs. low | >30 | 79.5 (63.5, 90.7) | 48.6 (40.0, 63.0) | 0.769 | C
Chung, 2008^36^ 18431116 | STOP-Bang | PSG | 177 | Sleep lab | | | High vs. low | >5 | 83.6 (75.8, 89.7) | 56.4 (42.3, 69.7) | 0.806 | C
Chung, 2008^36^ 18431116 | STOP-Bang | PSG | 177 | Sleep lab | | | High vs. low | >15 | 92.9 (84.1, 97.6) | 43 (33.5, 52.9) | 0.782 | C
Chung, 2008^36^ 18431116 | STOP-Bang | PSG | 177 | Sleep lab | | | High vs. low | >30 | 100 (91.0, 100.0) | 37 (28.9, 45.6) | 0.822 | C
Chung, 2008^97^ 18431117 | Berlin | PSG | 211 | Sleep lab | | | High vs. low | >5 | 68.9 (59.8, 76.9) | 56.4 (42.3, 69.7) | 0.69 | C
Chung, 2008^97^ 18431117 | Berlin | PSG | 211 | Sleep lab | | | High vs. low | >15 | 78.6 (67.1, 87.5) | 50.5 (40.6, 62.3) | 0.672 | C
Chung, 2008^97^ 18431117 | Berlin | PSG | 211 | Sleep lab | | | High vs. low | >30 | 87.2 (72.6, 95.7) | 46.4 (37.9, 55.1) | 0.668 | C
Chung, 2008^97^ 18431117 | ASA checklist | PSG | 211 | Sleep lab | | | High vs. low | >5 | 72.1 (63.3, 79.9) | 38.2 (25.4, 52.3) | 0.783 | C
Chung, 2008^97^ 18431117 | ASA checklist | PSG | 211 | Sleep lab | | | High vs. low | >15 | 78.6 (67.1, 87.5) | 37.4 (28.2, 47.3) | 0.73 | C
Chung, 2008^97^ 18431117 | ASA checklist | PSG | 211 | Sleep lab | | | High vs. low | >30 | 87.2 (72.6, 95.7) | 36.2 (28.2, 44.8) | 0.617 | C
Kapuniai, 1988^98^ 3227223 | Apnea score derived from the Hawaii Sleep Questionnaire * | PSG | 53 | Sleep lab | | | ≥3 | >5 | 59 (nd) | 69 (nd) | | B
Kapuniai, 1988^98^ 3227223 | Apnea score derived from the Hawaii Sleep Questionnaire * | PSG | 53 | Sleep lab | | | ≥2 (no adenoidectomy score) | >5 | 70 (nd) | 65 (nd) | | B
Kapuniai, 1988^98^ 3227223 | Apnea score derived from the Hawaii Sleep Questionnaire * | PSG | 53 | Sleep lab | | | ≥2 (no adenoidectomy score) | >10 | 78 (nd) | 67 (nd) | | B
Netzer, 1999^99^ 10507956 | Berlin | PSG | 100 | Home | | | High-risk (high risk in 2/3 categories) vs. low-risk^†^ | ≤5 | 77 (nd) | 89 (nd) | | C
Netzer, 1999^99^ 10507956 | Berlin | PSG | 100 | Home | | | High-risk (high risk in 2/3 categories) vs. low-risk^†^ | >5 | 86 (nd) | 77 (nd) | | C
Netzer, 1999^99^ 10507956 | Berlin | PSG | 100 | Home | | | High-risk (high risk in 2/3 categories) vs. low-risk^†^ | >15 | 54 (nd) | 97 (nd) | | C
Netzer, 1999^99^ 10507956 | Berlin | PSG | 100 | Home | | | High-risk (high risk in 2/3 categories) vs. low-risk^†^ | >30 | 17 (nd) | 97 (nd) | | C
Sharma, 2006^100^ 17085831 | Berlin Questionnaire,^‡^ modified | PSG | 104 | Sleep lab & Hospital | | | High risk vs. low risk | >5 | 86 (nd) | 95 (nd) | | C
Drager, 2010^101^ 20381666 | Berlin Questionnaire | PSG | 99 | Hospital | | | High risk vs. low risk | ≥5 | 93 (82,98) | 59 (43,73) | | A
Drager, 2010^101^ 20381666 | ESS | PSG | 99 | Hospital | | | 10 | ≥5 | 49 (36,63) | 80 (64,90) | | A

* The HSQ includes questions on characteristics in sleep apnea patients: (a) stopping breathing during sleep, (b) loud snoring, and (c) waking from sleep gasping or short of breath. Additional questions on sex, age, height, weight, sleep history and history of tonsillectomy or adenoidectomy. The final model included self-reports of loud snoring, breathing cessation during sleep and adenoidectomy.

† High Risk: classified as “high risk” in 2 of 3 symptom categories - (a) snoring (b) wake time sleepiness and drowsy driving (c) hr/o high blood pressure or BMI >30 kg/m^2^; Low Risk: all others.

‡ The Berlin Questionnaire was customized to the Indian setting (re: questions on driving) but the scoring remained the same. The screening questionnaire used was not a validated one.

Table 1.5.1 Clinical prediction rules vs. PSG: study characteristics

Study PMID | Participants | Country (years) | N | Baseline AHI (SD) [range] | Baseline ESS (SD) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Setting | Sleep Apnea Definition | Quality Issues
Crocker, 1990^102^ 2368960 | Referred for suspected abnormal breathing | Australia (1987–88) | 114 | nd | nd | 51 | 82 | 30.4 | Sleep lab | AHI >15 | Baseline AHI severity not reported
Gurubhagavatula, 2001^103^ 11734444 | Referred for suspected OSA | US (nd) | 421 | 26 (30) [nd] | nd | 47 | 68 | 32.4 | Sleep lab | RDI ≥5
Kushida, 1997^104^ 9341055 | Referred for sleep disorders | US (nd) | 423 | 35 [nd] | 10.9 | 47 | 75 | 32 | Sleep lab | RDI ≥5 | Selection bias; 29% dropout rate
Onen, 2008^105^ 18775037 | Elderly (≥70 y) referred to a sleep center | France (2005–06) | 121 | nd | nd | 79 | 50 | 29.4 | Sleep lab & Hospital | AHI ≥15 | Incomplete ROC data; other thresholds not reported
Rodsutti, 2004^106^ 15283004 | Referred for suspected sleep-disordered breathing | Australia (2003) | 243 | nd | nd | 51 | 63 | 32.8 | Sleep lab | AHI ≥5
Rowley, 2000^107^ 11083602 | Referred for sleep-disordered breathing | US (1996–97) | 425 | 19 (7–52)^*^ | nd | Median 47 | 52 | 37.1 | Sleep lab | AHI ≥10
Zerah-Lancner, 2000^108^ 11112139 | Referred for snoring and suspected sleep apnea | France (nd) | 101 | Group with AHI <15: 6 (4) Group with AHI≥15:42 (24) | nd | nd | nd | 28.8 | Sleep lab | AHI ≥15 | Unclear description of population

* Median and inter-quartile range

Table 1.5.2 Clinical prediction rules vs. PSG: study results

Study PMID | Index test | Reference test | N | Setting | Subgroup | ROC Analysis | | | | | Quality
Study PMID | Index test | Reference test | N | Setting | Subgroup | Threshold, events/hr | | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Study PMID | Index test | Reference test | N | Setting | Subgroup | Index | PSG | Sensitivity, % (95% CI) | Specificity, % (95% CI) | AUC | Quality
Crocker, 1990^102^ 2368960 | Statistical model * | PSG | 105 | Sleep lab | | Probability of OSA >0.15 | >15 | 92 (nd) | 51 (nd) | | B
Gurubhagavatula, 2001^103^ 11734444 | Clinical prediction rule,^†^ derived | PSG | 359 | Sleep lab | | Upper bound= 0.58 Lower bound= 0.14 ODI threshold= 5.02 | ≥5 | 94.1 (nd) | 66.7 (nd) | | A
Gurubhagavatula, 2001^103^ 11734444 | Clinical prediction rule,^†^ derived | PSG | 359 | Sleep lab | | Upper bound = 0.9 Lower bound = 0.38 ODI threshold = 21 | ≥30 | 83.3 (nd) | 94.7 (nd) | | A
Kushida, 1997^104^ 9341055 | Morphometric model^‡^ | PSG | 300 | Sleep lab | | ≥70 | ≥5 | 97.6 (95, 98.9) | 100 (92,100) | 0.996 | C
Onen, 2008^105^ 18775037 | Observation-based Nocturnal Sleep Inventory (ONSI)^§^ | PSG | 115 | Hospital | | ≥2 snoring episodes or ≥1 apnea episode | AHI≥15 | 89.7 (82, 97) | 81.4 (70,93) | | B
Onen, 2008^105^ 18775037 | Observation-based Nocturnal Sleep Inventory (ONSI)^§^ | PSG | 115 | Hospital | | ≥5 snoring or ≥1 apnea | AHI≥15 | 56 (44, 68) | 100 | | B
Onen, 2008^105^ 18775037 | Observation-based Nocturnal Sleep Inventory (ONSI)^§^ | PSG | 115 | Hospital | | ≥3 snoring or ≥1 apnea | AHI≥15 | 74 (63, 84) | 93 (85,100) | | B
Rodsutti, 2004^106^ 15283004 | Clinical prediction rule, ** derived | PSG | 243 | Sleep lab | | < 2.5 | ≥5 | 0 (nd) | 89 (nd) | 0.789 | A
Rodsutti, 2004^106^ 15283004 | Clinical prediction rule, ** derived | PSG | 243 | Sleep lab | | 2.5 – < 4.2 | ≥5 | 44 (nd) | 85 (nd) | 0.789 | A
Rodsutti, 2004^106^ 15283004 | Clinical prediction rule, ** derived | PSG | 243 | Sleep lab | | ≥4.2 | ≥5 | 76 (nd) | 60 (nd) | 0.789 | A
Rowley, 2000^107^ 11083602 | Model #1^††^ | PSG | 370 | Sleep lab | All | 0.15 | ≥10 | 84 (nd) | 39 (nd) | 0.669 | A
Rowley, 2000^107^ 11083602 | Model #1^††^ | PSG | 370 | Sleep lab | All | 0.95 | ≥20 | 33 (nd) | 90 (nd) | 0.7 | A
Rowley, 2000^107^ 11083602 | Model #1^††^ | PSG | 370 | Sleep lab | Men | 0.15 | ≥10 | | | 0.761 | A
Rowley, 2000^107^ 11083602 | Model #1^††^ | PSG | 370 | Sleep lab | Women | 0.15 | ≥10 | | | 0.633 | A
Rowley, 2000^107^ 11083602 | Model #2^‡‡^ | PSG | 370 | Sleep lab | All | 0.20 | ≥10 | 96 (nd) | 13 (nd) | 0.695 | A
Rowley, 2000^107^ 11083602 | Model #2^‡‡^ | PSG | 370 | Sleep lab | All | 0.95 | ≥20 | 34 (nd) | 87 (nd) | 0.722 | A
Rowley, 2000^107^ 11083602 | Model #2^‡‡^ | PSG | 370 | Sleep lab | Men | 0.2 | ≥10 | | | 0.801 | A
Rowley, 2000^107^ 11083602 | Model #2^‡‡^ | PSG | 370 | Sleep lab | Women | 0.2 | ≥10 | | | 0.626 | A
Rowley, 2000^107^ 11083602 | Model #3^§§^ | PSG | 370 | Sleep lab | All | 10 | ≥10 | 76 (nd) | 54 (nd) | 0.696 | A
Rowley, 2000^107^ 11083602 | Model #3^§§^ | PSG | 370 | Sleep lab | All | 35 | ≥20 | 34 (nd) | 89 (nd) | 0.733 | A
Rowley, 2000^107^ 11083602 | Model #3^§§^ | PSG | 370 | Sleep lab | Men | 10 | ≥10 | | | 0.707 | A
Rowley, 2000^107^ 11083602 | Model #3^§§^ | PSG | 370 | Sleep lab | Women | 10 | ≥10 | | | 0.648 | A
Rowley, 2000^107^ 11083602 | Model #4 *** | PSG | 370 | Sleep lab | All | 0.5 | ≥10 | 87 (nd) | 35 (nd) | 0.736 | A
Rowley, 2000^107^ 11083602 | Model #4 *** | PSG | 370 | Sleep lab | All | 0.85 | ≥20 | 39 (nd) | 93 (nd) | 0.757 | A
Rowley, 2000^107^ 11083602 | Model #4 *** | PSG | 370 | Sleep lab | Men | 0.5 | ≥10 | | | 0.801 | A
Rowley, 2000^107^ 11083602 | Model #4 *** | PSG | 370 | Sleep lab | Women | 0.5 | ≥10 | | | 0.611 | A
Zerah-Lancner, 2000^108^ 11112139 | Based on Pulmonary function data^†††^ | PSG | 101 | Sleep Lab | | 0.5 | ≥15 | 100 (nd) | 84 (nd) | | B

Bland-Altman column omitted. No study reported Bland-Altman data.

* Derived by logistic regression on data from a 24-item questionnaire and clinical features.

† Combination of Multivariable Apnea Prediction (MAP) questionnaire score and oximetry results. MAP score predicts apnea risk using a score between 0 and 1, with 0 representing low risk and 1 representing high risk. Oximetry desaturation index (ODI) using a 3% drop (ODI3) as well as a 4% drop (ODI4) in oxygen saturation. Optimal model parameters obtained by the bootstrapping technique.

‡ Model: P + (Mx - Mn) + 3 × OJ + 3 × [Max (BMI -25, 0)] × (NC/BMI)

P = palatal height (in millimeters); Mx is the maxillary intermolar distance (in millimeters) between the mesial surfaces of the crowns of the maxillary second molars; Mn is the mandibular intermolar distance (in millimeters) between the mesial surfaces of the crowns of the mandibular second molars; OJ is the overjet (in millimeters) or the horizontal overlap of the crowns of the maxillary and mandibular right central incisors; BMI is the body mass index (kg/m2; ideal BMI < 25); Max (BMI -25, 0) refers to the larger of the two quantities: BMI - 25, or zero. If BMI is <= 25, then [Max (BMI - 25, 0)] is zero; if BMI >25, then BMI - 25 is inserted into the formula; NC is neck circumference (in centimeters) measured at the level of the cricothyroid membrane.

§ Nurse observations made in five standardized hourly bedside visits over the course of one night.

** Sum of the individual scores for age, sex, snoring, stops breathing, and BMI; range = 0–7.3.

†† Clinical prediction model #1: Probability of predicting AHI ≥10 = 1/(1 + e^−(−13.9+0.06a+2.98b+0.23c+1.35d)^) where a = age; b= I if witnessed apneas present, 0 if witnessed apneas absent; c = BMI; d = 1 if patient has hypertension, 0 if hypertension absent.

‡‡ Clinical prediction model #2: Probability of predicting AHI ≥10 = e^x^/(1+e^x^) where, x = −10.5132 + 0.9164*sex + 0.0470*age + 0.1869*BMI+1.932*snoring; where sex = 1 for male, 0 for female, snoring = 1 for present, 0 for absent.

§§ Clinical prediction model #3: Probability of predicting AHI≥10 = (10 ^(−2.132 + 0.069*NC + 0.31*H+ 0.206′*HS+0.224*PR)^ + 1) where NC=neck circumference; H=1 if hypertension, 0 if hypertension absent, HS=1 if habitual snorer, 0 if not, PR = 1 if reports nocturnal choking/gasping, 0 if no nocturnal choking/gasping.

*** Clinical prediction model #4: Probability of predicting AHI≥10 = e^x^/ (1+e^x^) where, x = −8.160+1.299*Index1+O.163*BMI-0.025*BMI*Index1+0.032*age +1.278*sex where, sex=1 if male, 0 if female, index1 = the mean of non-missing values for frequency of snorting/gasping; loud snoring; breathing stops/chokes.

††† Probability (p) of having a polysomnography positive for SAS: logit (p)= −136 sGrs + 2.5 (100 - SaO_2_) + 4.2 where specific respiratory conductance (sGrs) (in cmH_2_0−1 * s^−1^) = respiratory conductance (Grs) / functional reserve capacity (FRC) SaO_2_ = daytime arterial oxygen saturation in %. The estimated value of p was derived from logit (p)= log_e_(p/1-p), from 0 to 1 range.

Table 3.1 Comparative studies of preoperative sleep apnea screening prior to surgical intervention: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Hallowell, 2007^110^ 17950355 | Mandatory PSG | 43 | 13 | 51 | Patients who have undergone bariatric surgery | US (1998–2005) | Selection bias; discrepancy in reporting of results
Hallowell, 2007^110^ 17950355 | PSG based on ESS or clinical suspicion | 43 | 13 | 51 | Patients who have undergone bariatric surgery | US (1998–2005) | Selection bias; discrepancy in reporting of results
Chung, 2008^97^ 18431117 | PSG | 55 | 51 | 30.1 | All pre-op patients in general surgery, gynecology, orthopedics, urology, plastic surgery, ophthalmology, or neurosurgery | Canada (nd) | Selection bias in participants who underwent PSG
Chung, 2008^97^ 18431117 | No PSG | 55 | 51 | 30.1 | All pre-op patients in general surgery, gynecology, orthopedics, urology, plastic surgery, ophthalmology, or neurosurgery | Canada (nd) | Selection bias in participants who underwent PSG

Table 3.2 Duration of hospital stay (hr) in comparative studies of preoperative PSG testing

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hallowell, 2007^110^ 17950355 | nd | nd | Immediate postoperative (retrospective chart review) | Mandatory PSG | 318 | nd | 74.4 (2.4) | −9.6 | nd | nd | 0 | C
Hallowell, 2007^110^ 17950355 | nd | nd | Immediate postoperative (retrospective chart review) | PSG only after clinical indications | 576 | nd | 84.0 (4.8) | | | | 0 | C
Chung, 2008^97^ 18431117 | 20 (6) [nd] | nd | 30 d (prospective case series) | Accepted preoperative PSG | 211 | nd | Median 44.8 (IQR: 0.2–352.8) | +15.5 (difference of medians) | nd | NS | 0 | C
Chung, 2008^97^ 18431117 | 20 (6) [nd] | nd | 30 d (prospective case series) | Refused preoperative PSG | 205 | nd | Median 29.3 (IQR: 0.1–299.8) | | | | 0 | C

Table 3.3 Postsurgical outcomes in comparative studies of preoperative screening with PSG

Study PMID | Outcome | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | n Event | N Total | Outcome metric | Result * | 95% CI | P Btw | Dropout, % | Study Quality
Hallowell, 2007^110^ 17950355 | ICU admission | nd | nd | Immediate post-operative (retro-spective chart review) | Mandatory PSG | 11 | 318 | RR | 0.62 | 0.32, 1.22 | nd | 0 | C
Hallowell, 2007^110^ 17950355 | ICU admission | nd | nd | Immediate post-operative (retro-spective chart review) | Indicated PSG | 32 | 576 | | | | | 0 | C
Hallowell, 2007^110^ 17950355 | Respiratory related ICU admission | | | Immediate post-operative (retro-spective chart review) | Mandatory PSG | 1 | 318 | RR | 0.16 | 0.02, 1.27 | nd | 0 | C
Hallowell, 2007^110^ 17950355 | Respiratory related ICU admission | | | Immediate post-operative (retro-spective chart review) | Indicated PSG | 11 | 576 | | | | | 0 | C
Chung, 2008^97^ 18431117 | ICU admission | 20 (6) [nd] | nd | 30 d (case series) | Preop PSG | 13 | 211 | RR | 3.16 | 1.05, 9.52 | nd | 0 | C
Chung, 2008^97^ 18431117 | ICU admission | 20 (6) [nd] | nd | 30 d (case series) | No Preop PSG | 4 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Total complications | | | | Preop PSG | 48 | 211 | RR | 1.55 | 1.03, 2.35 | 0.03 | 0 | C
Chung, 2008^97^ 18431117 | Total complications | | | | No Preop PSG | 30 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Respiratory complication | | | | Preop PSG | 39 | 211 | RR | 1.52 | 0.95, 2.41 | 0.08 | 0 | C
Chung, 2008^97^ 18431117 | Respiratory complication | | | | No Preop PSG | 25 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Cardiac complication | | | | Preop PSG | 12 | 211 | RR | 1.94 | 0.74, 5.08 | 0.11 | 0 | C
Chung, 2008^97^ 18431117 | Cardiac complication | | | | No Preop PSG | 6 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Neurologic complication | | | | Preop PSG | 2 | 211 | RR | 0.65 | 0.11, 3.84 | 0.68 | 0 | C
Chung, 2008^97^ 18431117 | Neurologic complication | | | | No Preop PSG | 3 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Prolonged O _2_ therapy | | | | Preop PSG | 24 | 211 | RR | 1.46 | 0.80, 2.66 | 0.22 | 0 | C
Chung, 2008^97^ 18431117 | Prolonged O _2_ therapy | | | | No Preop PSG | 16 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Additional monitoring | | | | Preop PSG | 9 | 211 | RR | 1.46 | 0.53, 4.02 | 0.46 | 0 | C
Chung, 2008^97^ 18431117 | Additional monitoring | | | | No Preop PSG | 6 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | Readmission within 30 d | | | | Preop PSG | 4 | 211 | RR | 0.78 | 0.21, 2.85 | 0.75 | 0 | C
Chung, 2008^97^ 18431117 | Readmission within 30 d | | | | No Preop PSG | 5 | 205 | | | | | 0 | C
Chung, 2008^97^ 18431117 | ED visit within 30 d | | | | Preop PSG | 1 | 211 | RR | 0.24 | 0.03, 2.15 | 0.21 | 0 | C
Chung, 2008^97^ 18431117 | ED visit within 30 d | | | | No Preop PSG | 4 | 205 | | | | | 0 | C

* Top row intervention vs. bottom row intervention. Calculated from reported data.

Table 4.1 Multivariable analyses of AHI as a predictor of all-cause mortality: study characteristics

Study PMID | Design Country (study years) | eligibility | N (followup) | Factor | Value | Quality
Lavie 2005^111^ 15738297 | Retrospective Israel (1991–2000) | Men, >20 yr, OSA symptoms | 13,853 (4.7 yr) | Male | 100% | A
Lavie 2005^111^ 15738297 | Retrospective Israel (1991–2000) | Men, >20 yr, OSA symptoms | 13,853 (4.7 yr) | Age | 48 yr | A
Lavie 2005^111^ 15738297 | Retrospective Israel (1991–2000) | Men, >20 yr, OSA symptoms | 13,853 (4.7 yr) | BMI (kg/m^2^) | 28.8 | A
Punjabi 2009^2^ 19688045 | Prospective US (1995–1998) | ≥40 yr, no Tx | 6441 (8.2 yr) | Male | 47% | B
Punjabi 2009^2^ 19688045 | Prospective US (1995–1998) | ≥40 yr, no Tx | 6441 (8.2 yr) | Age | 63 yr | B
Punjabi 2009^2^ 19688045 | Prospective US (1995–1998) | ≥40 yr, no Tx | 6441 (8.2 yr) | BMI | 28.4 | B
Young 2008^1^ 18714778 | Prospective US (1988-nd) | General population | 1522 (14 yr) | Male | 55% | A
Young 2008^1^ 18714778 | Prospective US (1988-nd) | General population | 1522 (14 yr) | Age | 48 yr | A
Young 2008^1^ 18714778 | Prospective US (1988-nd) | General population | 1522 (14 yr) | BMI | 28.6 | A
Lavie 1995^112^ 7610310 | Retrospective Israel (1976–1988) | Men, apnea index ≥10 | 1140 (2–14 yr) | Male | 100% | A
Lavie 1995^112^ 7610310 | Retrospective Israel (1976–1988) | Men, apnea index ≥10 | 1140 (2–14 yr) | Age | 48 yr | A
Lavie 1995^112^ 7610310 | Retrospective Israel (1976–1988) | Men, apnea index ≥10 | 1140 (2–14 yr) | BMI | nd | A

Table 4.2 Results of multivariable analyses of AHI as a predictor of all-cause mortality

Study PMID | Baseline AHI | n/ | N | Adjusted HR | 95% CI | P Trend | Other Predictors
Study PMID | Baseline AHI | n/ | N | Adjusted HR | 95% CI | P Trend | Significant | P | NS | nd P * | NS Univariable † | Interactions
Lavie 2005^111^ 15738297 | ≤10 | 34/ | 3227 | Ref | | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | | | | | | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | 11–20 | 88/ | 4154 | 1.52 | NS | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | | | | | | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | 21–30 | 65/ | 2601 | 1.34 | NS | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | | | | | | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | 31–40 | 50/ | 1204 | 2.13 | 1.36–3.34 | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | | | | | | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Lavie 2005^111^ 15738297 | >40 | 126/ | 2667 | 2.59 | 1.73–3.87 | 0.0001 | | | | Age BMI (kg/m^2^) | | nd
Punjabi 2009^2^ SHHS 19688045 | All | | | | | | Age | <0.05 | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | <5 | 477/ | 3429 | Ref | | <0.05 ‡ | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 5–15 | 320/ | 1797 | 0.93 | 0.80–1.08 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 15–30 | 165/ | 727 | 1.17 | 0.97–1.42 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | ≥30 | 86/ | 341 | 1.46 | 1.14–1.86 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | Men≤70^§^ | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | <5 | 91/ | 985 | Ref | | <0.05 ** | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 5–15 | 82/ | 694 | 1.24 | 0.90–1.71 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 15–30 | 47/ | 322 | 1.45 | 0.98–2.14 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | ≥30 | 28/ | 168 | 2.09 | 1.31–3.33 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | Men>70 | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | <5 | 125/ | 277 | Ref | | NS | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 5–15 | 111/ | 282 | 0.92 | 0.70–1.20 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 15–30 | 67/ | 140 | 1.23 | 0.90–1.68 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | ≥30 | 36/ | 75 | 1.27 | 0.86–1.86 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | Women | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | <5 | 261/ | 2167 | Ref | | NS | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 5–15 | 126/ | 821 | 0.83 | 0.66–1.04 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | 15–30 | 51/ | 265 | 1.01 | 0.73–1.38 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | | | | | | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Punjabi 2009^2^ SHHS 19688045 | ≥30 | 22/ | 99 | 1.40 | 0.89–2.22 | | | | Cholesterol | Sex Race BMI Smoking BP HTN Diabetes CVD | | No substantive difference with addition of other predictors Interaction of Age × AHI significant P<0.005 Interaction of Sex × AHI implied
Young, 2008^1^ WSCS 18714778 | <5 | 46/ | 1157 | Ref | | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | | | | | | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | 5–15 | 16/ | 220 | 1.6 | 0.9–2.8 | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | | | | | | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | 15–30 | 6/ | 82 | 1.4 | 0.6–3.3 | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | | | | | | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | ≥30 | 12/ | 63 | 3.0 | 1.4–6.3 | 0.008 | | | Age Sex BMI (kg/m^2^) | | | nd
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | Older age | 0.0001 | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | | | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | Higher BMI | 0.006 | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | | | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | HTN | 0.009 | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | | | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | CVD | <0.04 | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | | | Diabetes | | | No substantive difference with addition of comorbidities
Lavie 1995^112^ 7610310 | Per unit^††^ | 51/ | 1140 | OR=1.012 | 1.001 –1.024 | 0.04 | Lung dz | <0.01 | Diabetes | | | No substantive difference with addition of comorbidities

* Included in multivariable analysis. No data on whether statistically significant independent predictor.

† Not statistically significant in univariable analysis. Not included in multivariable analysis.

‡ Implied

§ Results also reported for all men combined, and women divided above and below age 70 yr.

** Implied

†† Analyzed in a multivariable logistic regression with apnea index (continuous) included as a predictor.

Table 4.3 Multivariable analyses of AHI as a predictor of cardiovascular events: study characteristics

Study PMID | Design Country (study years) | eligibility | N (followup) | Factor | Value | Quality
CVD Death
Marin 2005^6^ 15781100 | Prospective Spain (1992–1994) | Men, healthy w/ SDB | 1651 (10 yr) | Male | 100% | A
Marin 2005^6^ 15781100 | Prospective Spain (1992–1994) | Men, healthy w/ SDB | 1651 (10 yr) | Age | 50 yr | A
Marin 2005^6^ 15781100 | Prospective Spain (1992–1994) | Men, healthy w/ SDB | 1651 (10 yr) | BMI (kg/m^2^) | 28.7 | A
Young, 2008^1^ 18714778 | Prospective US (1988-nd) | General population | 1522 (14 yr) | Male | 55% | A
Young, 2008^1^ 18714778 | Prospective US (1988-nd) | General population | 1522 (14 yr) | Age | 48 yr | A
Young, 2008^1^ 18714778 | Prospective US (1988-nd) | General population | 1522 (14 yr) | BMI | 28.6 | A
Nonfatal CVD
Marin 2005^6^ 15781100 | Prospective Spain (1992–1994) | Men, healthy w/ SDB | 1651 (10 yr) | Male | 100% | A
Marin 2005^6^ 15781100 | Prospective Spain (1992–1994) | Men, healthy w/ SDB | 1651 (10 yr) | Age | 50 yr | A
Marin 2005^6^ 15781100 | Prospective Spain (1992–1994) | Men, healthy w/ SDB | 1651 (10 yr) | BMI | 28.7 | A
Stroke
Arzt 2005^113^ 16141444 | Prospective US (≥1988) | 30–60 yr, no stroke | 1475 (4, 8, 12 yr) | Male | 55% | B
Arzt 2005^113^ 16141444 | Prospective US (≥1988) | 30–60 yr, no stroke | 1475 (4, 8, 12 yr) | Age | 47 yr | B
Arzt 2005^113^ 16141444 | Prospective US (≥1988) | 30–60 yr, no stroke | 1475 (4, 8, 12 yr) | BMI | 30 | B

Table 4.4 Results of multivariable analyses of AHI as a predictor of cardiovascular events

Study PMID | Baseline AHI | n/ | N | Adjusted HR | 95% CI | P trend | Other Predictors
Study PMID | Baseline AHI | n/ | N | Adjusted HR | 95% CI | P trend | Significant | P | NS | nd P * | NS Univariable^†^ | Interactions
CVD Death
Marin, 2005^6^ 15781100 | “Healthy” | 12/ | 264 | Ref | | nd | Older age | 0.001 | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | <5 | 22/ | 377 | 1.03 | 0.31, 1.84 | nd | CVD | 0.02 | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | 5–30 | 36/ | 403 | 1.15 | 0.34, 2.69 | nd | Higher SBP | 0.04 | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | ≥30 | 50/ | 235 | 2.87 | 1.17, 7.51 | nd | Smoker | 0.04 | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | CPAP | 24/ | 372 | 1.05 | 0.39, 2.21 | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Alcohol use DBP Glucose TC & Tg Prescriptions ‡ | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Young, 2008^1^ WSCS 18714778 | <5 | 12/ | 1157 | Ref | | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | | | | | | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | 5–15 | 6/ | 220 | 1.8 | 0.7, 4.9 | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | | | | | | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | 15–30 | 2/ | 82 | 1.2 | 0.3, 5.8 | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | | | | | | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Young, 2008^1^ WSCS 18714778 | ≥30 | 5/ | 63 | 2.9 | 0.8, 10.0 | 0.12 | | | Age Sex BMI (kg/m^2^) | | | nd
Nonfatal CVD
Marin, 2005^6^ 15781100 | “Healthy” | 8/ | 264 | Ref | | nd | Older age | 0.001 | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | <5 | 13/ | 377 | 1.32 | 0.64, 3.01 | nd | CVD | 0.005 | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | 5–30 | 22/ | 403 | 1.57 | 0.62, 3.16 | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | ≥30 | 25/ | 235 | 3.17 | 1.12, 7.52 | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | CPAP | 13/ | 372 | 1.42 | 0.52, 3.40 | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Marin, 2005^6^ 15781100 | | | | | | nd | | | HTN Diabetes Dyslipidemia Smoking Alcohol use BP Glucose TC & Tg Prescriptions § | | BMI (implied) (kg/m^2^) | No substantive difference in AHI with or without CVD and HTN in model
Stroke
Arzt, 2005^113^ 16141444 | <5 | 9/ | 1121 | Ref | | nd | | | | Age Sex BMI | | AHI≥20 significant w/o BMI in model
Arzt, 2005^113^ 16141444 | | | | | | nd | | | | Age Sex BMI | | AHI≥20 significant w/o BMI in model
Arzt, 2005^113^ 16141444 | 5–20 | 1/ | 255 | 0.29 | 0.04, 2.36 | nd | | | | Age Sex BMI | | AHI≥20 significant w/o BMI in model
Arzt, 2005^113^ 16141444 | | | | | | nd | | | | Age Sex BMI | | AHI≥20 significant w/o BMI in model
Arzt, 2005^113^ 16141444 | ≥20 | 4/ | 99 | 3.08 | 0.74, 13.0 | nd | | | | Age Sex BMI | | AHI≥20 significant w/o BMI in model

* Included in multivariable analysis. No data on whether statistically significant independent predictor.

† Not statistically significant in univariable analysis. Not included in multivariable analysis.

‡ Antihypertensive, lipid-lowering, and antidiabetic drugs.

§ Antihypertensive, lipid-lowering, and antidiabetic drugs.

Table 4.5 Multivariable analyses of AHI as a predictor of incident HTN: study characteristics

Study PMID | Design Country (study years) | eligibility | N (followup) | Factor | Value | Quality
O’Connor 2009^114^ 19264976 | Prospective US (1995–1998) | ≥40 y | 2470 (5 yr) | Male | 45% | A
O’Connor 2009^114^ 19264976 | Prospective US (1995–1998) | ≥40 y | 2470 (5 yr) | Age | 60 yr | A
O’Connor 2009^114^ 19264976 | Prospective US (1995–1998) | ≥40 y | 2470 (5 yr) | BMI (kg/m^2^) | 27.9 | A
Peppard 2000^11^ 10805822 | Prospective US (1989–1995) | No CVD | 709 (4, 8 yr) | Male | 46% | B
Peppard 2000^11^ 10805822 | Prospective US (1989–1995) | No CVD | 709 (4, 8 yr) | Age | 47 yr | B
Peppard 2000^11^ 10805822 | Prospective US (1989–1995) | No CVD | 709 (4, 8 yr) | BMI | 29 | B

Table 4.6 Results of multivariable analyses of AHI as a predictor of incident HTN

Study PMID | Baseline AHI | n/ | N | Adjusted OR | 95% CI | P Trend | Other Predictors
Study PMID | Baseline AHI | n/ | N | Adjusted OR | 95% CI | P Trend | Significant | P | NS | nd P *,‡ | NS Univariable †,§ | Interactions
O’Connor 2009^114^ SHHS 19264976 | All | | | | | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | <5 | 296/ | 1510 | Ref | | NS | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | 5–15 | 156/ | 629 | 0.94 | 0.73–1.22 | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | 15–30 | 77/ | 234 | 1.09 | 0.77–1.54 | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | ≥30 | 33/ | 97 | 1.50 | 0.91–2.46 | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI WHR Neck girth | | AHI significant without BMI in model. No substantive change with WHR or girth
O’Connor 2009^114^ SHHS 19264976
O’Connor 2009^114^ SHHS 19264976 | Men | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 505 | Ref | | nd | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 341 | 0.96 | 0.68–1.36 | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 155 | 0.89 | 0.57–1.39 | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 56 | 1.10 | 0.57–2.10 | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | Women | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 950 | Ref | | nd | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 261 | 0.83 | 0.59–1.18 | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 72 | 1.59 | 0.95–2.64 | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 31 | 2.27 | 1.07–4.80 | | | | | Age Race BMI (kg/m^2^) | | AHI × sex interaction term NS P=0.09
O’Connor 2009^114^ SHHS 19264976
O’Connor 2009^114^ SHHS 19264976 | BMI≤27.3 | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 887 | Ref | | nd | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 213 | 0.89 | 0.59–1.34 | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 58 | 0.93 | 0.46–1.90 | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 21 | 2.71 | 1.24–5.93 | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | BMI>27.3 | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 541 | Ref | | nd | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 378 | 0.92 | 0.67–1.27 | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 164 | 1.13 | 0.76–1.68 | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 65 | 1.18 | 0.64–2.19 | | | | | Age Sex Race BMI | | AHI × BMI interaction term NS P=0.36
O’Connor 2009^114^ SHHS 19264976
O’Connor 2009^114^ SHHS 19264976 | Age≤59 yr | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 879 | Ref | | nd | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 262 | 1.02 | 0.70–1.50 | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 96 | 1.79 | 1.08–2.95 | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 33 | 1.47 | 0.64–3.37 | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | Age>59 yr | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 576 | Ref | | nd | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 340 | 0.85 | 0.62–1.16 | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 131 | 0.82 | 0.53–1.26 | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 54 | 1.53 | 0.84–2.79 | | | | | Sex Race BMI | | No difference in association stratified by age
O’Connor 2009^114^ SHHS 19264976
O’Connor 2009^114^ SHHS 19264976 | ESS≤11 | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 1189 | Ref | | nd | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 472 | 0.83 | 0.63–1.09 | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 178 | 0.90 | 0.62–1.31 | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 58 | 1.57 | 0.87–2.83 | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | ESS>11 | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | <5 | nd | 221 | Ref | | nd | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | 5–15 | nd | 119 | 1.31 | 0.72–2.38 | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | 15–30 | nd | 47 | 2.32 | 1.09–4.97 | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | | | | | | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
O’Connor 2009^114^ SHHS 19264976 | ≥30 | nd | 27 | 1.50 | 0.58–3.85 | | | | | Age Sex Race BMI (kg/m^2^) | | AHI × ESS interaction term NS P=0.11
Peppard, 2000^11^ WSCS 10805822 | 0 | 32/ | 187 | Ref | | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | | | | | | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | <5 | 142/ | 507 | 1.42 | 1.13–1.78 | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | | | | | | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | 5–15 | 64/ | 132 | 2.03 | 1.29–3.17 | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | | | | | | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | ≥15 | 40/ | 67 | 2.89 | 1.46–5.64 | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | | | | | | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.
Peppard, 2000^11^ WSCS 10805822 | | | | | | 0.002 | | | | Baseline HT N Age Sex BMI Neck girth Waist girth Alcohol use Smoking | | No substantive changes in association with addition of predictors. No interaction terms were significant.

* Included in multivariable analysis. No data on whether statistically significant independent predictor.

† Not statistically significant in univariable analysis. Not included in multivariable analysis.

‡ Included in multivariable analysis. No data on whether statistically significant independent predictor.

§ Not statistically significant in univariable analysis. Not included in multivariable analysis.

Table 4.7 Multivariable analyses of AHI as a predictor in incident type 2 diabetes: study characteristics

Study PMID | Design Country (study years) | eligibility | N (followup) | Factor | Value | Quality
Reichmuth 2005^115^ 16192452 | Prospective US (1988) | 30–60 yr, no DM | 978 (4 yr) | Male | 56% | B
Reichmuth 2005^115^ 16192452 | Prospective US (1988) | 30–60 yr, no DM | 978 (4 yr) | Age | 49 yr | B
Reichmuth 2005^115^ 16192452 | Prospective US (1988) | 30–60 yr, no DM | 978 (4 yr) | BMI (kg/m^2^) | 28.9 | B
Botros 2009^116^ 19958890 | Prospective US (2000–2005) | SDB, no DM | 544 (2.7 yr) | Male | 93% | A
Botros 2009^116^ 19958890 | Prospective US (2000–2005) | SDB, no DM | 544 (2.7 yr) | Age | 62 yr | A
Botros 2009^116^ 19958890 | Prospective US (2000–2005) | SDB, no DM | 544 (2.7 yr) | BMI | 33.2 | A

Table 4.8 Results of multivariable analyses of AHI as a predictor in incident type 2 diabetes

Study PMID | Baseline AHI | n/ | N | Adjusted OR/HR | 95% CI | P trend | Other Predictors
Study PMID | Baseline AHI | n/ | N | Adjusted OR/HR | 95% CI | P trend | Significant | P | NS | nd P * | NS Univariable † | Interactions
Reichmuth 2005^115^ WSCS 16192452 | <5 | nd | nd | Ref (OR) | | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Reichmuth 2005^115^ WSCS 16192452 | | | | | | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Reichmuth 2005^115^ WSCS 16192452 | 5–15 | nd | nd | 1.56 | 0.80–3.02 | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Reichmuth 2005^115^ WSCS 16192452 | | | | | | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Reichmuth 2005^115^ WSCS 16192452 | ≥15 | nd | nd | 1.62 | 0.67–3.65 | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Reichmuth 2005^115^ WSCS 16192452 | ≥15 | nd | nd | | | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Reichmuth 2005^115^ WSCS 16192452 | ≥15 | nd | nd | | | nd | | | | Age, sex, waist girth | | AHI significant w/o waist girth in the model
Botros 2009^116^ 19958890 | <8 | 6/ | 142 | Ref (HR) | | 0.008 | Glucose | <0.001 | Age Sex Race BMI ‡ | | | AHI similar with or without adjustment
Botros 2009^116^ 19958890 | | | | | | 0.008 | | | Age Sex Race BMI ‡ | | | AHI similar with or without adjustment
Botros 2009^116^ 19958890 | ≥8 | 55/ | 402 | 1.43 | 1.10–1.86 | 0.008 | | | Age Sex Race BMI ‡ | | | AHI similar with or without adjustment
Botros 2009^116^ 19958890 | | | | | | 0.008 | | | Age Sex Race BMI ‡ | | | AHI similar with or without adjustment
Botros 2009^116^ 19958890 | | | | | | 0.008 | | | Age Sex Race BMI ‡ | | | AHI similar with or without adjustment

* Included in multivariable analysis. No data on whether statistically significant independent predictor.

† Not statistically significant in univariable analysis. Not included in multivariable analysis.

‡ Change in BMI during follow-up was statistically significant

Table 4.9 Multivariable analyses of AHI as a predictor of quality of life SF-36: study characteristics

Study PMID | Design Country (study years) | eligibility | N (followup) | Factor | Value | Quality
Silva 2009^117^ 19725256 | Prospective US (1995) | All | 3078 (5 yr) | Male | 45% | A
Silva 2009^117^ 19725256 | Prospective US (1995) | All | 3078 (5 yr) | Age | 62 yr | A
Silva 2009^117^ 19725256 | Prospective US (1995) | All | 3078 (5 yr) | BMI (kg/m^2^) | 28.7 | A

Table 4.10 Results of multivariable analyses of AHI as a predictor of quality of life (SF-36)

Study PMID | Baseline AHI | N | Score * | Adjusted RR | 95% CI | P Trend | Other Predictors
Study PMID | Baseline AHI | N | Score * | Adjusted RR | 95% CI | P Trend | Significant | P | NS | nd P † | NS Univariable ‡ | Interactions
Silva 2009^117^ 19725256 | PCS | | | Continuous | | | Age, | <0.001 | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | | | | | | | | | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | <5 | 1662 | 49/48 | 1.008 | nd | NS | sleeping pills | 0.003 | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | | | | 1.008 | nd | NS | sleeping pills | 0.003 | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | 5–15 | 893 | 48/46 | 1.008 | nd | NS | sleeping pills | 0.003 | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | | | | 1.008 | nd | NS | | | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | 15–30 | 339 | 47/45 | 1.008 | nd | NS | | | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | | | | 1.008 | nd | NS | | | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256 | ≥30 | 154 | 45/44 | 1.008 | nd | NS | | | BMI (kg/m^2^) CHD Resp dz Smoking Sex | | | nd
Silva 2009^117^ 19725256
Silva 2009^117^ 19725256 | MCS | | | Continuous | | | Smoking | 0.02 | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | | | | | | | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | <5 | 1662 | 54/55 | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | | | | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | 5–15 | 893 | 54/55 | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | | | | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | 15–30 | 339 | 55/54 | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | | | | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex
Silva 2009^117^ 19725256 | ≥30 | 154 | 55/56 | 0.98 | nd | NS | | | Age BMI CHD Resp dz Sex

* Baseline/Final

† Included in multivariable analysis. No data on whether statistically significant independent predictor.

‡ Not statistically significant in univariable analysis. Not included in multivariable analysis.

Table 5.1.1 Randomized clinical trials of CPAP vs. control: study characteristics

Study PMID | Interventions | CPAP Pressure *, † (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Ballester 1999^118^ 9927363 | CPAP + conservative measures | Auto (separate) | 53 | 88 | 32.7 | | Spain (nd) | No power calculation
Ballester 1999^118^ 9927363 | Conservative measures | Auto (separate) | 53 | 88 | 32.7 | | Spain (nd) | No power calculation
Barbe 2010^130^ 20007932 | CPAP + conservative treatment | Auto (Separate) | 55 | 82 | 32 | Hypertensive patients | Spain (2004–2006)
Barbe 2010^130^ 20007932 | Conservative treatment | Auto (Separate) | 55 | 82 | 32 | Hypertensive patients | Spain (2004–2006)
Barnes 2004^140^ 15201136 | CPAP | nd (nd) | 47 | 80 | 31.1 | | Australia (nd)
Barnes 2004^140^ 15201136 | Placebo | nd (nd) | 47 | 80 | 31.1 | | Australia (nd)
Barnes 2002^131^ 11897643 | CPAP | nd (nd) | 46 | 86 | 30.9 | | Australia (nd)
Barnes 2002^131^ 11897643 | Placebo | nd (nd) | 46 | 86 | 30.9 | | Australia (nd)
Chakravorty 2002^119^ 12449179 | CPAP | Auto (separate) | 50 | nd | 37 | | UK (1998–1999) | No power calculation
Chakravorty 2002^119^ 12449179 | Lifestyle intervention | Auto (separate) | 50 | nd | 37 | | UK (1998–1999) | No power calculation
Comondore 2009^132^ 18795367 | CPAP | Auto (nd) | 56 | 69 | 31.1 | | Canada (nd) | Multiple comparisons in a small pilot study
Comondore 2009^132^ 18795367 | No treatment | Auto (nd) | 56 | 69 | 31.1 | | Canada (nd) | Multiple comparisons in a small pilot study
Drager 2007^120^ 17556718 | C-flex CPAP | Manual (separate) | 46 | 100 | 29.8 | Severe OSA patients free of co-morbidities | Brazil (2004–2006)
Drager 2007^120^ 17556718 | No treatment | Manual (separate) | 46 | 100 | 29.8 | Severe OSA patients free of co-morbidities | Brazil (2004–2006)
Engleman 1994^133^ 7906330 | CPAP | Manual (separate) | 49 | 74 | 33 | | UK (nd) | Baseline data not reported, no wash out period, nd on blinding
Engleman 1994^133^ 7906330 | Placebo | Manual (separate) | 49 | 74 | 33 | | UK (nd) | Baseline data not reported, no wash out period, nd on blinding
Engleman 1996^134^ 8843528 | CPAP | Manual (separate) | 51 | 85 | 36 | | UK (nd) | No power calculation
Engleman 1996^134^ 8843528 | Placebo | Manual (separate) | 51 | 85 | 36 | | UK (nd) | No power calculation
Engleman 1997^135^ 9059469 | CPAP | Manual (separate) | 52 | 85 | 29.8 | | UK (nd) | Baseline data not reported, no wash out period, nd on blinding
Engleman 1997^135^ 9059469 | Placebo | Manual (separate) | 52 | 85 | 29.8 | | UK (nd) | Baseline data not reported, no wash out period, nd on blinding
Engleman 1998^136^ 9708223 | CPAP | Manual (separate) | 47 | 91 | 30 | | UK (nd) | No adverse event data
Engleman 1998^136^ 9708223 | Placebo | Manual (separate) | 47 | 91 | 30 | | UK (nd) | No adverse event data
Engleman 1999^137^ 9927358 | CPAP | Manual (separate) | 44 | 62 | 30 | | UK (nd)
Engleman 1999^137^ 9927358 | Placebo | Manual (separate) | 44 | 62 | 30 | | UK (nd)
Faccenda 2001^138^ 11179104 | CPAP | Auto (separate) | 50 | 81 | 30 | | UK (nd) | No wash out period, but no measurements were made until 26 days after crossover; no power calculations reported.
Faccenda 2001^138^ 11179104 | Placebo | Auto (separate) | 50 | 81 | 30 | | UK (nd) | No wash out period, but no measurements were made until 26 days after crossover; no power calculations reported.
Ip 2004^121^ 14551167 | CPAP | Manual (unclear) | 43 | 100 | 29.4 | Very healthy | Hong Kong (nd)
Ip 2004^121^ 14551167 | No treatment | Manual (unclear) | 43 | 100 | 29.4 | Very healthy | Hong Kong (nd)
Kajaste 2004^122^ 15033131 | CPAP | Manual (separate) | 49 | 100 | 43.8 | Obese male | Finland (nd) | No power calculation
Kajaste 2004^122^ 15033131 | No treatment | Manual (separate) | 49 | 100 | 43.8 | Obese male | Finland (nd) | No power calculation
Kaneko 2003^123^ 12660387 | CPAP | Manual (separate) | 56 | 88 | 31.4 | Symptomatic, stable, optimally treated CHF | Canada (nd) | No power calculation
Kaneko 2003^123^ 12660387 | Optimal drug treatment | Manual (separate) | 56 | 88 | 31.4 | Symptomatic, stable, optimally treated CHF | Canada (nd) | No power calculation
Lam 2007^129^ 17121868 | CPAP + conservative measures | nd (nd) | 47 | 79 | 27.3 | | Hong Kong (nd)
Lam 2007^129^ 17121868 | Conservative measures | nd (nd) | 47 | 79 | 27.3 | | Hong Kong (nd)
Lojander 1996^124^ 8681614 Lojander 1999^125^ 10188139 | CPAP | Manual (separate) | 51 | 93 | 31.1 | | Finland (1987–1992) | Large drop out; expert panel decided patients would be more suitable for nasal CPAP but no objective criteria stated
Lojander 1996^124^ 8681614 Lojander 1999^125^ 10188139 | Conservative measures | Manual (separate) | 51 | 93 | 31.1 | | Finland (1987–1992) | Large drop out; expert panel decided patients would be more suitable for nasal CPAP but no objective criteria stated
Mansfield 2004^126^ 14597482 | CPAP | Manual (separate) | 58 | 95 | 33.5 | Symptomatic, stable, optimally treated CHF | Australia (nd) | No power calculation
Mansfield 2004^126^ 14597482 | No treatment | Manual (separate) | 58 | 95 | 33.5 | Symptomatic, stable, optimally treated CHF | Australia (nd) | No power calculation
McArdle 2001^139^ 11704596 | CPAP | nd (separate) | 53 | 87 | 31 | | Australia (nd)
McArdle 2001^139^ 11704596 | Placebo | nd (separate) | 53 | 87 | 31 | | Australia (nd)
Monasterio 2001^127^ 11587974 | CPAP + conservative measures | Manual (separate) | 54 | 86 | 29.4 | | Spain (nd) | Did not enroll enough to meet power calculations
Monasterio 2001^127^ 11587974 | Conservative measures | Manual (separate) | 54 | 86 | 29.4 | | Spain (nd) | Did not enroll enough to meet power calculations
Redline 1998^128^ 9517603 | CPAP | Manual (separate) | 48 | 52 | 33 | | US (nd) | Power calculation: needed sample size -112; no. analyzed- 97
Redline 1998^128^ 9517603 | Conservative measures | Manual (separate) | 48 | 52 | 33 | | US (nd) | Power calculation: needed sample size -112; no. analyzed- 97

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

† Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.1.2 AHI (events/hr) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | CPAP + conservative measures | 34 | 23.8 (16.7) | 2.8 (9.7) | −22.2 | −27.6, −16.7 | <0.001 | 0 | B
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | Conservative measures | 33 | 19.3 (16.7) | 20.5 (21.9) | | | | 0 | B
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | CPAP + conservative measures | 66 | 20.0 (6.0) | 6.0 (8.0) | −10 | −12.8, −7.2 | <0.001 | 12 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | Conservative measures | 59 | 21 (6.0) | 17.0 (10.0) | | | | 12 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 55 (28.7) | 8 (28) | −46 | −59.0, −32.9 | <0.001 | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 35 (19.1) | 34 (21) | | | | 25 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | CPAP | 19 | 25 (17.9) | 2.9 (3.5) | −13.7 | −24.4, −3.0 | 0.012 | 27 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | No treatment | 21 | 26.6 (20.6) | 18.2 (12.8) | | | | 27 | C
Ip 2004^121^ 14551167 | 46 (15) [>15] | 11.1 (6.2) | 1 mo (PL) | CPAP | 14 | 47.7 (15.3) | 1.7 (1.8) | −16.8 | −27.9, −5.7 † | 0.003 | 7 | C
Ip 2004^121^ 14551167 | 46 (15) [>15] | 11.1 (6.2) | 1 mo (PL) | No treatment | 14 | 45.1 (14.3) | 15.9 (15.5) | | | | 7 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 37.1 (22.2) | 8.3 (9.9) | −28.3 | −45.2, −11.4 ‡ | 0.001 | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 45.2 (18.4) | 44.7 (23.6) | | | | 0 | C
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 21.3 (11.6) | 4.8 (4.5) | −15.5 | −18.7, −12.2 | <0.001 | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 21.3 (11.6) | 20.3 (9.8) | | | | 23 | B

* Estimated from reported data.

† Estimated from reported P value.

‡ Estimated from reported P value.

Table 5.1.3 ESS in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI *, ** | P Btw | Dropout, % | Study Quality
Barbe 2010^130^ 20007932 | 43 (19) [>19] | 6.4 (2.4) | 12 mo (PL) | CPAP + conservative treatment | 178 | 6.4 (2.3) | 4.87 (nd) | −1.26 | −1.9, −0.6 | nd | 4 | B
Barbe 2010^130^ 20007932 | 43 (19) [>19] | 6.4 (2.4) | 12 mo (PL) | Conservative treatment | 181 | 6.4 (2.4) | 6.13 (nd) | | | | 4 | B
Ballester 1999^118^ 9927363 | 58 (20) [>15] | 11.4 (5.0) | 3 mo (PL) | AutoCPAP + conservative measures | 68 | 12.1 (8.2) | 5.6 (nd) | −5.7 | −8.1, −3.3 | <0.001 | 0 | B
Ballester 1999^118^ 9927363 | 58 (20) [>15] | 11.4 (5.0) | 3 mo (PL) | Conservative measures | 37 | 11.4 (3.6) | 10.6 (nd) | | | | 0 | B
Redline 1998^128^ 9517603 | 12 (10) [>5] | 10.6 (5.6) | 10 wk (PL) | CPAP | 51 | 10.4 (4.3) | nd | −1.1 | −2.5, 0.3 | nd | 15 | B
Redline 1998^128^ 9517603 | 12 (10) [>5] | 10.6 (5.6) | 10 wk (PL) | Conservative measures | 46 | 10.6 (5.6) | nd | | | | 15 | B
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | CPAP + conservative measures | 34 | 12 (8.8) | 7 (8.8) | −3 | −5.7, −0.2 † | 0.034 | 0 | B
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | Conservative measures | 33 | 12 (8.8) | 10 (8.8) | | | | 0 | B
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | C-Flex | 12 | 14.0 (4.0) | 7.0 (2.0) | −7 | −10.2, −3.7 | <0.001 | 0 | B
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | No treatment | 12 | 13.0 (5.0) | 13.0 (4.0) | | | | 0 | B
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | CPAP + conservative measures | 66 | 12.1 (4.9) | 9.6 (5.5) | −1.1 | −2.9, 0.7 | NS | 12 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | Conservative measures | 59 | 13.2 (4.3) | 11.8 (5.2) | | | | 12 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0(4.2) | 3 mo (PL) | AutoCPAP | 32 | 16 (5.6) | 8 (6.4) | −5.0 | −7.9, −2.1 | 0.001 | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0(4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 14 (4.2) | 11 (5.0) | | | | 25 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | CPAP | 19 | 9.5 (3.9) | 6.9 (4.5) | −4.2 ‡ | −7.4, −1.0 § | 0.01 | 27 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | No treatment | 21 | 8.8 (3.9) | 9.9 (4.5) | | | | 27 | C
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 10.7 (3.6) | 9.2 (3.6) | −1 | −2.1, 0.1 | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 10.7 (3.6) | 10.2 (3.6) | | | | 23
Faccenda 2001^138^ 11179104 | 35 (15–129) [>15] | 15 (6–24) | 1 mo (XO) | AutoCPAP | 68 | nd | 10.1 (0.7) | −2.0 | −3.2, −0.8 †† | 0.001 | 5 | B
Faccenda 2001^138^ 11179104 | 35 (15–129) [>15] | 15 (6–24) | 1 mo (XO) | Placebo | 68 | nd | 12.5 (0.8) | | | | 5 | B
Engleman 1999^137^ 9927358 | 10 (nd) [>5] | 13.0 (3.0) | 4 wk (XO) | CPAP | 34 | 13.0 (3.0) | 8.0 (4.0) | −3 | −4.8, −1.2 ‡‡ | 0.001 | 8 | B
Engleman 1999^137^ 9927358 | 10 (nd) [>5] | 13.0 (3.0) | 4 wk (XO) | Placebo | 34 | 13.0 (3.0) | 11.0 (4.0) | | | | 8 | B
Engleman 1998^136^ 9708223 | 43 (nd) [>15] | 12.0 (4.0) | 4wk (XO) | CPAP | 23 | 12.0 (4.0) | 6.0 (3.0) | −6 | −9.5, −2.4 §§ | 0.001 | 0 | B
Engleman 1998^136^ 9708223 | 43 (nd) [>15] | 12.0 (4.0) | 4wk (XO) | Placebo | 23 | 12.0 (4.0) | 12.0 (4.0) | | | | 0 | B
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | CPAP | 28 | 11.2 (5.0) | −2.7 *** | −0.6 | nd | NS | 33 | C
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | Placebo | 28 | 11.2 (5.0) | −2.1 ††† | | | | 33 | C
Engleman 1997^135^ 9059469 | 11 (4) [>5] | nd | 4 wk (XO) | CPAP | 16 | nd | 10.1 (5.6) | 0.1 | −3.5, 3.7 | NS | 11 | C
Engleman 1997^135^ 9059469 | 11 (4) [>5] | nd | 4 wk (XO) | Placebo | 16 | nd | 10.0 (4.8) | | | | 11 | C

* Estimated from reported data

† Estimated from reported P value.

‡ Based on reported within-group changes.

§ Estimated from reported P value.

** Estimated from reported data

†† Estimated from reported P value.

‡‡ Estimated from reported P value.

§§ Estimated from reported P value.

*** Reported change.

††† Reported change.

Table 5.1.4a Arousal index (events/hr) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | CPAP + conservative measures | 34 | 21.6 (14.9) | 16.3 (15.7) | −10.6 | −16.3, −4.83 | <0.001 | 0 | B
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | Conservative measures | 33 | 23.5 (19.3) | 28.8 (21.9) | | | | 0 | B
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 64.0 (28.0) | 38.9 (28.6) | −9.8 | −25.4, 4.9 | nd | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 52.2 (28.5) | 36.9 (21.5) | | | | 25 | C
Ip 2004^121^ 14551167 | 46 (15) [>15) | 11.1 (6.2) | 1 mo (PL) | CPAP | 14 | 33.4 (17.2) | 17.5 (10.7) | −17.6 | −29.3, −5.9 | 0.003 | 7 | C
Ip 2004^121^ 14551167 | 46 (15) [>15) | 11.1 (6.2) | 1 mo (PL) | No treatment | 14 | 33.8 (15.0) | 35.5 (17.7) | | | | 7 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 31.4 (21.1) | 12.6 (5.9) | −18.0 | −33.7, −2.3 | 0.025 | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 42.9 (19.1) | 42.3 (21.5) | | | | 0 | C
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 22.0 (10.7) | 18.3 (8.0) | −6.9 | −9.9, −3.8 | <0.001 | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 22.0 (10.7) | 25.2 (9.8) | | | | 23 | B
McArdle 2001^139^ 11704596 | 40 (25–65) [>15] | 14.0 (10–17) | 1 mo (XO) | CPAP | 22 | nd | 21.0 | −24.0 | −38.3, −9.7 † | <0.001 | 4 | B
McArdle 2001^139^ 11704596 | 40 (25–65) [>15] | 14.0 (10–17) | 1 mo (XO) | Placebo | 22 | nd | 45.0 | | | | 4 | B

* Estimated from reported data.

† Estimated from reported P value.

Table 5.1.4b Minimum O_2_ saturation (%) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | CPAP + conservative measures | 34 | 75.0 (12.3) | 87.2 (25.4) | 10.9 | 4.2, 17.7 | 0.002 | 0 | B
Lam 2007^129^ 17121868 | 19 (17) [>5] | 12.0 (8.8) | 10 wk (PL) | Conservative measures | 33 | 76.1 (22.8) | 77.4 (17.5) | | | | 0 | B
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | CPAP | 19 | 79.6 (11.3) | 91.1 (3.9) | 11.5 | 2.9, 20.1 | 0.008 | 27 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | No treatment | 21 | 77.2 (17.8) | 77.2 (16.0) | | | | 27 | C
Ip 2004^121^ 14551167 | 46 (15) [>15) | 11.1 (6.2) | 1 mo (PL) | CPAP | 14 | 64.9 (11.9) | 91.4 (2.6) | 26.6 | 17.4, 35,8 | <0.001 | 7 | C
Ip 2004^121^ 14551167 | 46 (15) [>15) | 11.1 (6.2) | 1 mo (PL) | No treatment | 14 | 66.6 (12.2) | 66.5 (15.0) | | | | 7 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 82.3 (4.2) | 89.6 (3.8) | 8.8 | 2.2, 15.3 | 0.009 | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 78.4 (7.6) | 76.9 (12.4) | | | | 0 | C
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 86.7 (5.4) | 91.9 (2.7) | 6.5 | 4.9, 8.0 | <0.001 | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 86.7 (5.4) | 85.4 (5.4) | | | | 23 | B

* Estimated from reported data

Table 5.1.4c Sleep efficiency (% total sleep time) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | BaselineESS (SD) | Duration(design) | Interventions | No. Analyzed | Baseline(SD) | Final(SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 79.5 (9.83) | 82.1 (7.15) | 1.4 | −1.4, 4.2 | NS | 23% | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo tablets | 80 | 79.5 (9.83) | 80.7 (8.04) | | | | 23% | B
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 67.7 (18.2) | 67.5 (15.7) | −3 | −10.8, 4.8 | nd | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 71.6 (12.8) | 74.4 (11.1) | | | | 25 | C

* Estimated from reported data

Table 5.1.4d Slow wave sleep (% total sleep time or minutes) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | BaselineESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 16.6% (nd) | 21.0 (nd) | −1 | nd | nd | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 18.7% (nd) | 22.0 (nd) | | | | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 64.7 min (50.2) | 69.5 (50.1) | 0.7 | −26.7, 28.1 | nd | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 81.2 min (52.5) | 85.3 (46.6) | | | | 25 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | CPAP | 19 | 5% (4.4) | 7.0 (8.7) | 4.0 | 0.1, 7.9 | 0.046 | 27 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | No treatment | 21 | 6% (4.6) | 4.0 (4.6) | | | | 27 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 10.0% (9.0) | 12.7 (11.4) | 3.2 | −5.5, 11.9 | NS | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 8.5% (10.4) | 8.0 (3.5) | | | | 0 | C
McArdle 2001^139^ 11704596 | 40 (25–65) [>15] | 14 (10–17) | 1 mo (XO) | CPAP | 22 | nd (min) | 41.0 (nd) | 18 | 4.9, 31.1 † | 0.007 | 4 | B
McArdle 2001^139^ 11704596 | 40 (25–65) [>15] | 14 (10–17) | 1 mo (XO) | Placebo | 22 | nd (min) | 23.0 (nd) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 17.9% (10.7) | 20.7 (9.8) | 2.2 | −1.1, 5.5 | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 17.9% (10.7) | 18.5 (10.7) | | | | 23 | B

* Estimated from reported data.

† Estimated from reported P value.

Table 5.1.4e REM sleep (% total sleep time or minutes) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | BaselineESS (SD) | Duration(design) | Interventions | No. Analyzed | Baseline(SD) | Final(SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 20.7% (nd) | 24.9 (nd) | nd | nd | nd | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 20.1% (nd) | 23.9 (nd) | | | | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | AutoCPAP | 32 | 80.6 min (39.3) | 81.9 (35.8) | −4.1 | −27.2, 19.0 | nd | 25 | C
Chakravorty 2002^119^ 12449179 | 35 (19) [>15] | 14.0 (4.2) | 3 mo (PL) | Lifestyle intervention | 21 | 87.1 min (40.5) | 92.5 (47.8) | | | | 25 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | CPAP | 19 | 14.0% (4.4) | 13.0 (8.7) | 0 | −4,8, 4.8 | NS | 27 | C
Mansfield 2004^126^ 14597482 | 27 (21) [>5] | 8.8 (0.9) | 3 mo (PL) | No treatment | 21 | 12.0% (9.2) | 11.0 (4.6) | | | | 27 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 7.7% (5.5) | 12.2 (7.3) | 5.9 | −0.1, 11.9 | NS | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 13.2% (6.2) | 11.6 (9.4) | | | | 0 | C
McArdle 2001^139^ 11704596 | 40 (25–65) [>15] | 14 (10–17) | 1 mo (XO) | CPAP | 22 | nd (min) | 86.0 (30.0) | 12 | −2.3, 26.3 † | NS | 4 | B
McArdle 2001^139^ 11704596 | 40 (25–65) [>15] | 14 (10–17) | 1 mo (XO) | Placebo | 22 | nd (min) | 74.0 (29.0) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 18.8% (6.2) | 18.9 (4.4) | 0 | −1.8, 1.8 | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 18.8% (6.2) | 18.9 (5.3) | | | | 23 | B

* Estimated from reported data.

† Estimated from reported P value.

Table 5.1.5a Multiple sleep latency test (min) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | Baseline ESS (SD) | Duration(design) | Interventions | No. Analyzed | Baseline(SD) | Final(SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Redline 1998^128^ 9517603 | 12 (10) [>5] | 10.6 (5.6) | 10 wk (PL) | CPAP | 51 | 9.9 (4.8) | nd | 0.39 | −1.7, 2.5 | nd | 15 | B
Redline 1998^128^ 9517603 | 12 (10) [>5] | 10.6 (5.6) | 10 wk (PL) | Conservative measures | 46 | 10.3 (5.0) | nd | | | | 15 | B
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | CPAP +Conservative measures | 40 | 10.0 (5.0) | 10.0 (5.0) | 0 | −2.2, 2.2 | NS | 12 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | Conservative measures | 40 | 11.0 (5.0) | 11.0 (5.0) | | | | 12 | C
Engleman 1998^136^ 9708223 | 43 (nd) [>15] | 12.0 (4.0) | 4wk (XO) | CPAP | 23 | nd | 9.2 (3.9) | 2.4 | 0.8, 4.0 | <0.001 | 0 | B
Engleman 1998^136^ 9708223 | 43 (nd) [>15] | 12.0 (4.0) | 4wk (XO) | Placebo | 23 | nd | 6.8 (4.3) | | | | 0 | B
Engleman 1994^133^ 7906330 | 28 (7–129) [>5] | nd | 1 mo (XO) | CPAP | 32 | nd | 7.2 (4.0) | 1.1 | 0.1, 2.1 † | 0.03 | 9 | C
Engleman 1994^133^ 7906330 | 28 (7–129) [>5] | nd | 1 mo (XO) | Placebo | 32 | nd | 6.1 (4.0) | | | | 9 | C
Barnes2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | CPAP | 28 | 12.5(4.8) | −1.8 ‡ | −1.0 | nd | NS | 33 | C
Barnes2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | Placebo | 28 | 12.5(4.8) | −0.8 § | | | | 33 | C
Engleman 1997^135^ 9059469 | 11 (4) [>5] | nd | 4 wk (XO) | CPAP | 16 | nd | 10.0 (4.8) | 0.1 | −3.6, 3.9 | NS | 11 | C
Engleman 1997^135^ 9059469 | 11 (4) [>5] | nd | 4 wk (XO) | Placebo | 16 | nd | 9.9 (6.0) | | | | 11 | C

* Estimated from reported data

† Estimated from reported P value

‡ Reported change

§ Reported change

Table 5.1.5b Maintenance of wakefulness test (min) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | BaselineESS (SD) | Duration(design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Engleman 1999^137^ 9927358 | 10 (nd) [>5] | 13.0 (3.0) | 4 wk (XO) | CPAP | 34 | nd | 16.2 (10.6) | 1.8 | −4.2, 7.8 * | NS | 8 | B
Engleman 1999^137^ 9927358 | 10 (nd) [>5] | 13.0 (3.0) | 4 wk (XO) | Placebo tablet | 34 | nd | 14.4 (8.5) | | | | 8 | B

* Estimated from reported data.

Table 5.1.6a FOSQ in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | BaselineESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | CPAP + conservative measures | 66 | 101 (18) † | 106 (20) ‡ | 3 | −3.6, 9.6 | NS | 12 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | Conservative measures | 59 | 100 (15) § | 102 (21) ** | | | | 12 | C
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | CPAP | 80 | 3.1 (0.9) †† | 3.3 (0.9) ‡‡ | 0 | −0.3, 0.3 | NS | 27 | B
Barnes 2004^140^ 15201136 | 21 (12) [>5] | 10.7 (3.5) | 3 mo (XO) | Placebo | 80 | 3.1 (0.9) †† | 3.3 (0.9) §§ | | | | 27 | B
Faccenda 2001^138^ 11179104 | 35 (15–129) [>15] | 15 (6–24) | 1 mo (XO) | AutoCPAP | 68 | nd | 12.4(4.1) *** | +0.8 | −0.2, 1.4 ††† | NS | 5 | B
Faccenda 2001^138^ 11179104 | 35 (15–129) [>15] | 15 (6–24) | 1 mo (XO) | Placebo | 68 | nd | 11.6 (5.7) ‡‡‡ | | | | 5 | B
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | CPAP | 28 | 0.8 (0.1) §§§ | +0.07 **** | +0.01 | nd | NS | 33 | C
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | Placebo | 28 | 0.8 (0.1) §§§ | +0.06 †††† | | | | 33 | C

* Estimated from reported data.

† Total summed score of FOSQ responses.

‡ Total summed score of FOSQ responses.

§ Total summed score of FOSQ responses.

** Total summed score of FOSQ responses.

†† Weighted average of FOSQ subscale scores.

‡‡ Weighted average of FOSQ subscale scores.

§§ Weighted average of FOSQ subscale scores.

*** Summed score of FOSQ subscale averages.

††† Estimated from reported P value.

‡‡‡ Summed score of FOSQ subscale averages.

§§§ Ratio of total summed score over maximum possible score.

**** Reported change.

†††† Reported change.

Table 5.1.6b Quality of life in randomized controlled trials of CPAP vs. control

Study PMID | Baseline Test (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | If Significant Difference | | | P Btw | Study Quality
Study PMID | Baseline Test (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | 95% CI *,§ | Test range | | P Btw | Study Quality
Study PMID | Baseline Test (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | 95% CI *,§ | “Worst” | “Best” | P Btw | Study Quality
Ballester 1999^118^ 9927363 | AHI 58 (20) | 3 mo (PL) | AutoCPAP + CM | 68 | SAHS-related symptoms questionnaire | AutoCPAP | −12.3 | −14.6, −9.9 | 15 | −16 | <0.001 | B
Ballester 1999^118^ 9927363
Ballester 1999^118^ 9927363 | ESS 11.4 (5.0) | | CM | 37 | NHP – Emotional reactions | 0
Ballester 1999^118^ 9927363
Ballester 1999^118^ 9927363 | | | | | NHP - Sleep | 0
Ballester 1999^118^ 9927363
Ballester 1999^118^ 9927363 | | | | | NHP - Physical | 0
Ballester 1999^118^ 9927363
Ballester 1999^118^ 9927363 | | | | | NHP – Social isolation | 0 † | −3.7 | −11.2, 3.8 | 0 | 100 | 0.33
Ballester 1999^118^ 9927363
Ballester 1999^118^ 9927363 | | | | | NHP – Pain | 0
Ballester 1999^118^ 9927363
Ballester 1999^118^ 9927363 | | | | | NHP - Energy | AutoCPAP | −20.6 | −33.1, −8.1 | 0 | 100 | <0.001
Lam 2007^129^ 17121868 | AHI 19 (17) | 10 wk (PL) | CPAP + CM | 34 | SAQLI summary score (A–D)^a^ | CPAP | 1 | 0.7, 1.2 | 0 | 7 | <0.001 | B
Lam 2007^129^ 17121868
Lam 2007^129^ 17121868 | ESS 12 (8.8) | | CM | 33 | SAQLI summary score (A–E)^a^ | CPAP | nd | nd | 0 | 7 | <0.05
Lam 2007^129^ 17121868
Lam 2007^129^ 17121868 | | | | | SF-36 Physical function | CPAP | 6.9 | 1.6, 12.1 ‡ | 0 | 100 | <0.05
Lam 2007^129^ 17121868
Lam 2007^129^ 17121868 | | | | | SF-36 Bodily Pain | CPAP | 11.7 | | 0 | 100 | <0.05
Monasterio 2001^127^ 11587974 | AHI 21 (5) | 6 mo (PL) | CPAP + CM | 66 | SAHS related symptoms | CPAP | −5 | −6.4, −3.6 | 8 | 32 | <0.001 | C
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | ESS 13.2 (4.3) | | CM | 59 | NHP | 0 | | | | | NS
Mansfield 2004^126^ 14597482 | AHI 27 (21) | 3 mo (PL) | CPAP | 19 | SF-36 role-physical | 0 | | | | | NS | C
Mansfield 2004^126^ 14597482
Mansfield 2004^126^ 14597482 | ESS 8.8 (0.9) | | No treatment | 21 | SF-36 vitality | CPAP | 20 | 5.2, 34.8 | 0 | 100 | 0.008
Mansfield 2004^126^ 14597482
Mansfield 2004^126^ 14597482 | | | | | SF-36 mental health | 0 | | | | | NS
Barnes 2002^131^ 11897643 | AHI 13 (6) | 8 wk (XO) | CPAP | 28 | SF-36 physical functioning | 0 | | | | | NS | B
Barnes 2002^131^ 11897643 | | | | 28
Barnes 2002^131^ 11897643 | ESS 11.3 (5.0) | | Placebo | 28 | SF-36 mental health | 0 | | | | | NS
Barnes 2004^140^ 15201136 | AHI 21 (12) ESS 10.7 (3.5) | 3 mo (XO) | CPAP Placebo | 80 | SF-36 mean score | 0 | | | | | NS ** | B
Engleman 1994^133^ 7906330 | AHI 28 (7–129) ESS nd | 1 mo (XO) | CPAP Placebo | 32 | GHQ 28 total score | CPAP | −3.4 | −5.6, −1.2 †† | 0 | 28 | 0.003 | C
Engleman 1997^135^ 9059469 | AHI 11 (4) ESS nd | 4 wk (XO) | CPAP Placebo | 16 | GHQ 28 total score | 0 | | | | | NS | C
Engleman 1998^136^ 9708223 | AHI 43 (nd) | 4 wk (XO) | CPAP Placebo | 23 | UMACL Energetic Arousal Score | 0 | | | | | NS | B
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | ESS 12.0 (nd) | | | | GHQ-28 | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | NHP Part 2 score | 0 | | | | | NS
Engleman 1999^137^ 9927358 | AHI 10 (nd) | 4 wk (XO) | CPAP Placebo | 34 | SF-36 Role-physical | CPAP | 17 | 0.9, 33.0 | 0 | 100 | 0.038 | B
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | ESS 13.0 (3.0) | | | | SF-36 mental health | 0 | | | | | NS
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | SF-36 Vitality | CPAP | 12 | 2.6, 24.1 | 0 | 100 | 0.014
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | UMACL Energetic Arousal Score | 0 | | | | | NS
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | NHP Part 2 score | 0 | | | | | NS

* Estimated from reported data.

† Contrary to the reported P-value for this outcome (P=0.03), our calculations showed no statistical significance (P=0.33).

‡ Estimated from reported P value.

§ Estimated from reported data.

** Our estimated does not match with reported statistical significance.

†† Estimated from reported P value.

Table 5.1.7 Neurocognitive and psychological tests in randomized controlled trials of CPAP vs. control

Study PMID | Baseline Test (SD) | Duration(design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | If Significant Difference | | | P Btw | Study Quality
Study PMID | Baseline Test (SD) | Duration(design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | Test Range | | P Btw | Study Quality
Study PMID | Baseline Test (SD) | Duration(design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | “Worst” | “Best” | P Btw | Study Quality
Monasterio 2001^127^ 11587974 | AHI 21 (5) | 6 mo (PL) | CPAP + CM | 66 | Attention - digit symbol (WAIS) SS | 0 | | | | | NS | C
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | ESS 13.2 (4.3) | | CM | 59 | Attention - digits forward and backward (WAIS) SS | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Attention - mental control (WMS) p | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Memory - verbal paired associated(WMS) p | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Memory - visual memory (WMS), SS | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Executive function - Verbal fluency, p | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Executive function - Block Design (WAIS), SS | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Trailmaking A (sec) | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Trailmaking B (sec) | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | PASAT 4-s, | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | PASAT 3-s | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | PASAT 2-s | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | PASAT 1-s | 0 | | | | | NS
Monasterio 2001^127^ 11587974
Monasterio 2001^127^ 11587974 | | | | | Vigilance -Steer-clear, % hits | 0 | | | | | NS
Lojander 1996, 1999^125,124^ 8681614, 10188139 | nd | 12 mo (PL) | CPAP + CM | 23 | Wechsler Verbal | 0 | | | | | NS | C
Lojander 1996, 1999^125,124^ 8681614, 10188139
Lojander 1996, 1999^125,124^ 8681614, 10188139 | | | CM | 21 | Wechsler Performance | 0 | | | | | NS
Lojander 1996, 1999^125,124^ 8681614, 10188139
Lojander 1996, 1999^125,124^ 8681614, 10188139 | | | | | Wechsler Memory | 0 | | | | | NS
Barnes 2004^140^ 15201136 | AHI 21 (12) ESS 10.7 (3.5) | 3 mo (XO) | CPAP Placebo | 80 | Beck Depression Inventory | 0 | | | | | NS | B
Engleman 1999^137^ 9927358 | AHI 10 (nd) | 4 wk (XO) | CPAP | 34 | SteerClear | 0 | | | | | NS | B
Engleman 1999^137^ 9927358 | | | | 34
Engleman 1999^137^ 9927358 | ESS 13 (3) | | Placebo | 34 | Trailmaking A and B | 0 | | | | | NS
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | Digit symbol | CPAP | 0.5 * | nd | | | 0.004
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | Block Design score | 0 | | | | | NS
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | Performance IQ score | 0 | | | | | NS
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | HADS anxiety score | 0 | | | | | NS
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | HADS depression score | CPAP | 0.41 † | | 0 | 21 | 0.003
Engleman 1999^137^ 9927358
Engleman 1999^137^ 9927358 | | | | | PASAT 2-s | CPAP | 0.36 ‡ | | | | 0.02
Barnes 2002^131^ 11897643 | AHI 13 (6) [>5] | 8 wk (XO) | CPAP | 28 | Word pair memory recall | 0 | | | | | NS | B
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | ESS 11.3 (5.0) | | Placebo | | WMS-R visual reproduction | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Trailmaking A (sec) | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Trailmaking B (sec) | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Digital symbol substitution test | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Controlled oral word association test | CPAP | +2.7 | 0.43, 4.97 § | | | 0.02
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Psychomotor vigilance task | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Stroop color association test | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | POMS | 0 | | | | | NS
Barnes 2002^131^ 11897643
Barnes 2002^131^ 11897643 | | | | | Mood-Beck depression inventory | 0 | | | | | NS
Engleman 1998^136^ 9708223 | AHI 43 (nd) | 4 wk (XO) | CPAP | 23 | SteerClear | 0 | | | | | NS | B
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | ESS 12.0 (nd) | | Placebo | | Trailmaking B | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | Digit symbol substitution | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | Block Design | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | Performance IQ decrement | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | HADS anxiety score | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | Rapid visual information processing | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | HADS depression score | 0 | | | | | NS
Engleman 1998^136^ 9708223
Engleman 1998^136^ 9708223 | | | | | PASAT 2-s | 0 | | | | | NS
Engleman 1994^133^ 7906330 | AHI 28 (7–129) | 1 mo (XO) | CPAP | 32 | IQ decrement score | CPAP | −3.2 | −6.3, −0.1 ** | NA | NA | 0.04 | C
Engleman 1994^133^ 7906330
Engleman 1994^133^ 7906330 | ESS nd | | Placebo | | Trailmaking B (sec) | CPAP | −9 | −16.5, −1.4 †† | NA | NA | 0.02
Engleman 1994^133^ 7906330
Engleman 1994^133^ 7906330 | | | | | PASAT | 0 | | | | | NS
Engleman 1994^133^ 7906330
Engleman 1994^133^ 7906330 | | | | | HADS anxiety score | CPAP | −1.2 | −2.2, −0.2 | 0 | 21 | 0.02
Engleman 1994^133^ 7906330
Engleman 1994^133^ 7906330 | | | | | HADS depression score | CPAP | −1.9 | −3.1, −0.7 ‡‡ | 0 | 21 | 0.002
Engleman 1997^135^ 9059469 | AHI 11 (4) | 4 wk (XO) | CPAP | 16 | IQ decrement score | 0 | | | | | NS | C
Engleman 1997^135^ 9059469
Engleman 1997^135^ 9059469 | ESS nd | | Placebo | | Trailmaking B (sec) | CPAP | −13.6 | −25.1, −2.1 | NA | NA | 0.02
Engleman 1997^135^ 9059469
Engleman 1997^135^ 9059469 | | | | | PASAT | 0 | | | | | NS
Engleman 1997^135^ 9059469
Engleman 1997^135^ 9059469 | | | | | Verbal fluency total words | 0 | | | | | NS
Engleman 1997^135^ 9059469
Engleman 1997^135^ 9059469 | | | | | HADS anxiety score | 0 | | | | | NS
Engleman 1997^135^ 9059469
Engleman 1997^135^ 9059469 | | | | | HADS depression score | CPAP | −1.6 | −3.0, −0.2 | 0 | 21 | 0.03

* Reported Effect size (final difference/standard deviation of difference)

† Reported Effect size (final difference/standard deviation of difference)

‡ Reported Effect size (final difference/standard deviation of difference)

§ Estimated from reported P value.

** Estimated from reported P value.

†† Estimated from reported P value.

‡‡ Estimated from reported P value.

Table 5.1.8a Blood pressure measurements (mm Hg) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [min] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI *,§ | P Btw | Dropout, % | Study Quality
Systolic Blood Pressure
Barbe 2010^130^ 20007932 | 43 (19) [>19] | 6.4 (2.4) | 12 mo (PL) | CPAP + conservative treatment | 178 | 141 (5) | 134.7 (nd) | −2.09 | −5.6, 1.4 | nd | 4 | B
Barbe 2010^130^ 20007932 | 43 (19) [>19] | 6.4 (2.4) | 12 mo (PL) | Conservative treatment | 181 | 141 (15) | 136.8 (nd) | | | | 4 | B
Diastolic Blood Pressure
Barbe 2010^130^ 20007932 | 43 (19) [>19] | 6.4 (2.4) | 12 mo (PL) | CPAP + conservative treatment | 178 | 85 (11) | 82.8 (nd) | 0.46 | −2.0, 2.9 | nd | 4 | B
Barbe 2010^130^ 20007932 | 43 (19) [>19] | 6.4 (2.4) | 12 mo (PL) | Conservative treatment | 181 | 86 (10) | 83.3 (nd) | | | | 4 | B
Daytime Systolic Blood Pressure
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | C-Flex | 12 | 122 (5) | 119 (9) | −1 | −8.2, 6.2 | NS | 0 | B
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | No treatment | 12 | 124 (11) | 122 (9) | | | | 0 | B
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | CPAP + conservative measures | 66 | 126.0 (17.0) | 122.0 (22.0) | −2 | −8.4, 4.4 | NS | 12 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | Conservative measures | 59 | 132.0 (17.0) | 130.0 (16.0) | | | | 12 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 126 (20.8) | 116 (17.3) | −16 | −34.4, 2.4 | NS | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 128 (24.2) | 134 (27.7) | | | | 0 | C
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | CPAP | 28 | 132.0 (11.0) | −0.7 (25.6) † | −2.1 | −11.2, 7.0 | 0.65 | 33 | C
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | Placebo | 28 | 132.0 (11.0) | 2.2 (9.8) ‡ | | | | 33 | C
Comondore 2009^132^ 18795367 | 28 (nd) [>15] | 6.8 (nd) | 4 wk (XO) | AutoCPAP | 13 | 139.3 (nd) | 131.9 (nd) | −3.6 | −18.5, 11.3 | 0.50 | 0 | C
Comondore 2009^132^ 18795367 | 28 (nd) [>15] | 6.8 (nd) | 4 wk (XO) | No treatment | 13 | 139.3 (nd) | 133.6 (nd) | | | | 0 | C
Engleman 1996^134^ 8843528 | 49 (32) [>5] | nd | 3 wk (XO) | CPAP | 13 | nd | 138.0 (14.4) | −0.1 | −10.8, 8.7 | nd | 19 | C
Engleman 1996^134^ 8843528 | 49 (32) [>5] | nd | 3 wk (XO) | Placebo | 13 | nd | 139.0 (10.8) | | | | 19 | C
Nightime Systolic Blood Pressure
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | C-Flex | 12 | 108.0 (9.0) | 105.0 (10.0) | −4 | −11.6, 3.6 | NS | 0 | B
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | No treatment | 12 | 109 (10.0) | 113.0 (9.0) | | | | 0 | B
Daytime Diastolic Blood Pressure
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | C-Flex | 12 | 79.0 (4.0) | 75.0 (7.0) | −1 | −4.6, 6.6 | NS | 0 | B
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | No treatment | 12 | 78.0 (9.0) | 75.0 (6.0) | | | | 0 | B
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | CPAP | 12 | 62.0 (13.9) | 59.0 (6.9) | −1 | −10.8, 8.8 | NS | 0 | C
Kaneko 2003^123^ 12660387 | 45 (5) [>20] | 5.7 (0.9) | 1 mo (PL) | Optimal drug treatment | 12 | 60.0 (13.9) | 58.0 (10.4) | | | | 0 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | CPAP + conservative measures | 66 | 81.0 (12.0) | 80.0 (10.0) | −1 | −4.9, 2.9 | NS | 12 | C
Monasterio 2001^127^ 11587974 | 21 (5) [>10] | 13.2 (4.3) | 6 mo (PL) | Conservative measures | 59 | 84.0 (11.0) | 84.0 (11v) | | | | 12 | C
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | CPAP | 28 | 84.0 (7.8) | −0.5 (25.6) ** | −2.6 | −11.7, −6.5 | 0.57 | 33 | C
Barnes 2002^131^ 11897643 | 13 (6) [>5] | 11.3 (5.0) | 8 wk (XO) | Placebo | 28 | | +2.1 (9.8) †† | | | | 33 | C
Comondore 2009^132^ 18795367 | 28 (nd) [>15] | 6.8 (nd) | 4 wk (XO) | AutoCPAP | 13 | 82.7 (nd) | 79.0 (nd) | −0.7 | −8.5, 7.1 | 0.84 | 0 | C
Comondore 2009^132^ 18795367 | 28 (nd) [>15] | 6.8 (nd) | 4 wk (XO) | No treatment | | 84.8 (nd) | 81.8 (nd) | | | | 0 | C
Engleman 1996^134^ 8843528 | 49 (32) [>5] | nd | 3 wk (XO) | CPAP | 13 | nd | 84.0 (3.0) | −2 | −4.3, 0.3 | nd | 19 | C
Engleman 1996^134^ 8843528 | 49 (32) [>5] | nd | 3 wk (XO) | Placebo | | nd | 86.0 (3.0) | | | | 19 | C
Nightime Diastolic Blood Pressure
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | C-Flex | 12 | 67.0 (8.0) | 63.0 (8.0) | −1 | −7.7, 5.7 | NS | 0 | B
Drager 2007^120^ 17556718 | 65 (22) [>30] | 13.0 (5.0) | 4 mo (PL) | No treatment | 12 | 69.0 (7.0) | 66.0 (10.0) | | | | 0 | B

* Estimated from reported data.

† Reported change.

‡ Reported change

§ Estimated from reported data.

** Reported change.

†† Reported change.

Table 5.1.8b HbA1C (%) in randomized controlled trials of CPAP vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Comondore 2009^132^ 18795367 | 28 (nd) [>15] | 6.8 (nd) | 4 wk (XO) | AutoCPAP | 13 | 5.91 (nd) | 5.94 (nd) | 0.04 | −0.27, 0.34 | NS | 0 | C
Comondore 2009^132^ 18795367 | 28 (nd) [>15] | 6.8 (nd) | 4 wk (XO) | No treatment | 13 | 5.85 (nd) | 5.85 (nd) | | | | 0 | C

Table 5.2.1 Characteristics of randomized controlled trials comparing CPAP with sham control

Study PMID | Interventions | CPAP Pressure^*,†^ (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Arias 2005^141^ 16009798 | CPAP | Auto (separate) | 52 | 100 | 30.5 | | Spain (nd)
Arias 2005^141^ 16009798 | Sham CPAP | Auto (separate) | 52 | 100 | 30.5 | | Spain (nd)
Barbe 2001^142^ 11388814 | CPAP | Manual (separate) | 53 | 91 | 29 | Non-sleepy | Spain (1999–2000) | N <30
Barbe 2001^142^ 11388814 | Sham CPAP | Manual (separate) | 53 | 91 | 29 | Non-sleepy | Spain (1999–2000) | N <30
Becker 2003^143^ 12515745 | CPAP | Manual (separate) | 53 | 91 | 33.4 | 67% with HTN | Germany (nd) | No power calculation, no allocation concealment, high dropout rate
Becker 2003^143^ 12515745 | Sham CPAP | Manual (separate) | 53 | 91 | 33.4 | 67% with HTN | Germany (nd) | No power calculation, no allocation concealment, high dropout rate
Campos-Rodriguez 2006^144^ 16778262 | CPAP | Manual (separate) | 57 | 60 | 34.8 | 30–70 yr with primary HTN and on treatment | Spain (nd) | Unclear randomization
Campos-Rodriguez 2006^144^ 16778262 | Sham CPAP | Manual (separate) | 57 | 60 | 34.8 | 30–70 yr with primary HTN and on treatment | Spain (nd) | Unclear randomization
Coughlin 2007^145^ 17251237 | CPAP | Auto (split) | 49 | 100 | 36.1 | Healthy obese males | UK (nd)
Coughlin 2007^145^ 17251237 | Sham CPAP | Auto (split) | 49 | 100 | 36.1 | Healthy obese males | UK (nd)
Cross 2008^146^ 18390635 | CPAP | Auto (separate) | 48 | 96 | 37 | 22% on aspirin, statins, or beta blockers | UK (nd)
Cross 2008^146^ 18390635 | Sham CPAP | Auto (separate) | 48 | 96 | 37 | 22% on aspirin, statins, or beta blockers | UK (nd)
Egea 2008^147^ 17904420 | CPAP | Manual (split) | 64 | 94 | 31.1 | Stable heart failure patients with sleep apnea | Spain (nd) | PSG results included 17% central sleep apnea subjects, but sleepiness and QoL measures only included OSA subjects
Egea 2008^147^ 17904420 | Sham CPAP | Manual (split) | 64 | 94 | 31.1 | Stable heart failure patients with sleep apnea | Spain (nd) | PSG results included 17% central sleep apnea subjects, but sleepiness and QoL measures only included OSA subjects
Haensel 2007^148^ 17503102 | CPAP | Manual (separate) | 49 | 80 | 33.4 | | US (nd) | relatively small samples, no power calculation
Haensel 2007^148^ 17503102 | Sham CPAP | Manual (separate) | 49 | 80 | 33.4 | | US (nd) | relatively small samples, no power calculation
Henke 2001^149^ 11282765 | CPAP | Manual (separate) | 50 | 56 | 42.6 | | US (nd) | No power calculation; one-way cross over
Henke 2001^149^ 11282765 | Sham CPAP | Manual (separate) | 50 | 56 | 42.6 | | US (nd) | No power calculation; one-way cross over
Hui 2006^150^ 16928705 | CPAP | Auto (separate) | 51 | 80 | 27.2 | | Hong Kong (nd) | Underpowered; Non-ITT analyses; likely selection bias; questionable patient blinding
Hui 2006^150^ 16928705 | Sham CPAP | Auto (separate) | 51 | 80 | 27.2 | | Hong Kong (nd) | Underpowered; Non-ITT analyses; likely selection bias; questionable patient blinding
Jenkinson 1999^151^ 10382693 Hack 2000^152^ 10679542 | CPAP | Auto (separate) | 49 | 100 | 35.1 | | UK (1997–98)
Jenkinson 1999^151^ 10382693 Hack 2000^152^ 10679542 | Sham CPAP | Auto (separate) | 49 | 100 | 35.1 | | UK (1997–98)
Lam 2010^169^ 19608589 | CPAP | Auto (separate) | 46 | 100 | 27.5 | | China (2002–2007)
Lam 2010^169^ 19608589 | Sham CPAP | Auto (separate) | 46 | 100 | 27.5 | | China (2002–2007)
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | CPAP | Manual (separate) | 48 | 75 | 31.3 | | US (nd)
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | Sham CPAP | Manual (separate) | 48 | 75 | 31.3 | | US (nd)
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | CPAP | Manual (separate) | 48 | 83 | 31.8 | | US (2002–04) | Poorly reported results, with much missing data, incomplete analyses
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | Sham CPAP | Manual (separate) | 48 | 83 | 31.8 | | US (2002–04) | Poorly reported results, with much missing data, incomplete analyses
Marshall 2005^159^ 15860720 | CPAP | Manual (separate) | 51 | 76 | 31.5 | | New Zealand (2001–03) | Allocation concealment: yes – assessors; no - patients
Marshall 2005^159^ 15860720 | Sham CPAP | Manual (separate) | 51 | 76 | 31.5 | | New Zealand (2001–03) | Allocation concealment: yes – assessors; no - patients
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | CPAP | Manual (separate) | 48 | 85 | 31.9 | | US (nd) | No power calculation
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | Sham CPAP | Manual (separate) | 48 | 85 | 31.9 | | US (nd) | No power calculation
Montserrat 2001^162^ 11520724 | CPAP | Manual (separate) | 54 | 91 | 32.0 | | Spain (nd) | Needed sample size 48 but had only 45
Montserrat 2001^162^ 11520724 | Sham CPAP | Manual (separate) | 54 | 91 | 32.0 | | Spain (nd) | Needed sample size 48 but had only 45
Norman 2006^163^ 16585412 | CPAP | Manual (separate) | 50 | 85 | 30.8 | | | No power calculation
Norman 2006^163^ 16585412 | Sham CPAP | Manual (separate) | 50 | 85 | 30.8 | | | No power calculation
Robinson 2006^164^ 16455835 | CPAP | Auto (split) | 54 | 89 | 33.2 | HTN with significant OSA, but without sufficient daytime hypersomnolence | UK (nd)
Robinson 2006^164^ 16455835 | Sham CPAP | Auto (split) | 54 | 89 | 33.2 | HTN with significant OSA, but without sufficient daytime hypersomnolence | UK (nd)
Siccolli 2008^165^ 19014075 | CPAP | Auto (separate) | 48 | 100 | 35.2 | | UK (nd)
Siccolli 2008^165^ 19014075 | Sham CPAP | Auto (separate) | 48 | 100 | 35.2 | | UK (nd)
Smith 2007^166^ 17470670 | CPAP | Auto (split) | 61 | 88 | 31 | CHF | UK (nd)
Smith 2007^166^ 17470670 | Sham CPAP | Auto (split) | 61 | 88 | 31 | CHF | UK (nd)
Spicuzza 2006^167^ 16963674 | CPAP | Manual (separate) | 56 | 80 | 32.1 | | Italy (nd)
Spicuzza 2006^167^ 16963674 | Sham CPAP | Manual (separate) | 56 | 80 | 32.1 | | Italy (nd)
West 2007^168^ 17557769 | CPAP | Auto (split) | 56 | 100 | 37.8 | Diabetes mellitus | UK (2004–05)
West 2007^168^ 17557769 | Sham CPAP | Auto (split) | 56 | 100 | 37.8 | Diabetes mellitus | UK (2004–05)
West 2009^170^ 19427263 | CPAP | Auto (separate) | 55 | 100 | 36.7 | Type 2 diabetes | UK (nd) | No power calculation; unclear how many patients were randomized
West 2009^170^ 19427263 | Sham CPAP | Auto (separate) | 55 | 100 | 36.7 | Type 2 diabetes | UK (nd) | No power calculation; unclear how many patients were randomized

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoPAP is the intervention). In parentheses: split (CPAP introduced in a split night study); separate (CPAP introduced on a separate full night than the diagnostic sleep study).

† Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoPAP is the intervention). In parentheses: split (CPAP introduced in a split night study); separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.2.2 AHI (events/hr) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥ 15] | 10.3 (4.9) | 1 wk (PL) | AutoCPAP | 30 | 33.4 (nd) | 0.6 (nd) | −24.6 | nd * | <0.001 | 0 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥ 15] | 10.3 (4.9) | 1 wk (PL) | Sham CPAP | 31 | 31.3 (nd) | 19.7 (nd) | | | | 0 | A
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 27 | 43.7 (22.9) | 10.8 (11.4) | −25.6 | −36.5, −14.6 † | <0.0001 ‡ | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 29 | 35.3 (16.7) | 28 (24.8) | | | | 18 | B
Haensel 2007^148^ 17503102 | 58 (30) [≥ 15] | nd | 2 wk (PL) | CPAP | 25 | 65.9 (28.6) | 3.5 (3.4) | −58.3 | −74.9, −41.7 § | <0.001 | 0 | B
Haensel 2007^148^ 17503102 | 58 (30) [≥ 15] | nd | 2 wk (PL) | Sham CPAP | 25 | 57.5 (32.1) | 53.4 (32.9) | | | | 0 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI 20] | nd | 1 wk (PL) | CPAP | 23 | 56.4 (24.1) | 3.3 (3.8) | −37.2 | −51.6, −22.7 ** | <0.001 | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI 20] | nd | 1 wk (PL) | Sham CPAP | 18 | 44.2 (25.3) | 28.3 (22.7) | | | | 14 | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | CPAP | 17 | 65.0 (34) | 2.56 (2.4) | −58.5 | −84.0, −33.0 †† | nd | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | Sham CPAP | 16 | 61.2 (41) | 57.3 (41) | | | | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 57 (32) [≥ 15] | 12.3 (6.7) | 2 wk (PL) | CPAP | 22 | 65.9 (28.6) | 3.0 (4.7) | −57.9 | −76.2, −39.6 ‡‡ | <0.001 | nd | C
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 57 (32) [≥ 15] | 12.3 (6.7) | 2 wk (PL) | Sham CPAP | 19 | 57.5 (32.1) | 52.5 (37.5) | | | | nd | C
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0(6.6) | 2 wk (PL) | CPAP | 18 | 66.1 (29.1) | 3.4 (3.0) | −58.9 | −79.2, −38.6^§§^ | <0.05 | nd | C
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0(6.6) | 2 wk (PL) | Sham CPAP | 15 | 53.9 (29.8) | 50.1 (32.1) | | | | nd | C
Becker 2003^143^ 12515745 | 65.0 (26.7) [≥5] | 14.1 (3.2) | 9 wk (PL) | CPAP | 16 | 62.5 (17.8) | 3.4 (3.1) | −27.5 | −43.4, −11.6 *** | 0.001 | 47 | C
Becker 2003^143^ 12515745 | 65.0 (26.7) [≥5] | 14.1 (3.2) | 9 wk (PL) | Sham CPAP | 16 | 65.0 (26.7) | 33.4 (29.2) | | | | 47 | C
Spicuzza 2006^167^ 16963674 | 59 (17) [>5] | nd | 1 mo (PL) | CPAP | 15 | 55.3 (11.9) | 2.1 (0.3) | −51.0 | −62.0, −40.0 ††† | <0.005 | nd | C
Spicuzza 2006^167^ 16963674 | 59 (17) [>5] | nd | 1 mo (PL) | Sham CPAP | 10 | 59.2 (17.3) | 57.0 (8.6) | | | | nd | C

* Only IQR were reported.

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data.

** Estimated from reported data.

†† Estimated from reported data.

‡‡ Estimated from reported data.

§§ Estimated from reported data.

*** Estimated from reported data

††† Estimated from reported data.

Table 5.2.3 ESS in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Drop-out % | Study Quality
West 2007^168^ 17557769 | nd | 14 (3.5) | 3 mo (PL) | AutoCPAP | 19 | 15 (3.5) | −6.6 (4.5) * | −4.0 | −7.0, −0.9 | 0.01 | 5 | A
West 2007^168^ 17557769 | nd | 14 (3.5) | 3 mo (PL) | Sham CPAP | 21 | 17 (3.5) | −2.6 (4.9) † | | | | 5 | A
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | CPAP | 34 | 14 (4.9) | nd | −3.1 | −4.5, −1.7 | <0.01 | 3 | A
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | Sham CPAP | 34 | 14 (4.9) | | | | | 3 | A
Robinson 2006^164^ 16455835 | nd | 5.3 (IRQ 3.0–7.0) | 1 mo (XO) | AutoCPAP | 32 | 5.3 (nd) | −1.4 (nd) ‡ | −1.1 | −2.0, −0.17^§^ | <0.02 | 9 | A
Robinson 2006^164^ 16455835 | nd | 5.3 (IRQ 3.0–7.0) | 1 mo (XO) | Sham CPAP | 32 | 5.3 (nd) | −0.3 (nd) ** | | | | 9 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥15] | 10.3 (4.9) | 1 wk (PL) | AutoCPAP | 30 | 10.3 (4.9) | 10.5 (5.2) | +0.7 | −0.76,2.06 †† | NS | 0 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥15] | 10.3 (4.9) | 1 wk (PL) | Sham CPAP | 31 | 10.8 (5.5) | 10.5 (5.6) | | | | 0 | A
Smith 2007^166^ 17470670 | 36 (23) [≥15] | 10 (5) | 6 wk (XO) | AutoCPAP | 23 | 10 (5) | 7 (4) | −1.0 | −1.9, 0 | 0.04 | 12 | A
Smith 2007^166^ 17470670 | 36 (23) [≥15] | 10 (5) | 6 wk (XO) | Sham CPAP | 23 | 10 (5) | 8 (5) | | | | 12 | A
Jenkinson 1999^151^ 10382693 Hack 2000^152^ 10679542 | nd | 17.0 (nd) | 4 wk (PL) | AutoCPAP | 52 | 15.5 (nd) | 7.0 (nd) | −7.0 | −10.5, −3.5^‡‡^ | <0.0001 | 6 | B
Jenkinson 1999^151^ 10382693 Hack 2000^152^ 10679542 | nd | 17.0 (nd) | 4 wk (PL) | Sham CPAP | 49 | 15.0 (nd) | 13.0 (nd) | | | | 6 | B
Siccolli 2008^165^ 19014075 | nd | 15.2 (4.0) | 4 wk (PL) | CPAP | 50 | 15.8 (4.0) | 6.8 (5.1) | −5.9 | −7.8, −3.95 | <0.0001 | 3 | B
Siccolli 2008^165^ 19014075 | nd | 15.2 (4.0) | 4 wk (PL) | Sham CPAP | 49 | 15.0 (4.0) | 11.9 (5.9) | | | | 3 | B
Campos-Rodriguez 2006^144^ 16778262 | 60 (22) [≥10] | 13.6 (3.6) | 4 wk (PL) | CPAP | 34 | 15.0 (3.9) | 11.2 (3.0) | −2.4 | −4.0, −0.81^§§^ | 0.003 | 6 | B
Campos-Rodriguez 2006^144^ 16778262 | 60 (22) [≥10] | 13.6 (3.6) | 4 wk (PL) | Sham CPAP | 34 | 13.6 (3.6) | 12.2 (2.2) | | | | 6 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | CPAP | 29 | 7 (2.2) | 8 (3.2) | +1.0 | −1.0, 3.0^***^ | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | Sham CPAP | 25 | 7 (2.0) | 8 (5.0) | | | | 2 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | CPAP | 23 | 10.2 (4.8) | 7.0 (4.8) | −0.04 | −2.94, 2.86 | NS | 18 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | Sham CPAP | 23 | 11.2 (5.5) | 8.1 (5.0) | | | | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 20 | 8.6 (3.6) | 5.0 (3.6) | −1.9 | −4.1, 0.3^†††^ | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 25 | 6.9 (4.0) | 5.2 (4.0) | | | | 18 | B
Montserrat 2001^162^ 11520721 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | CPAP | 23 | 16.1 (4.8) | 6.7 (3.4) | −7.2 | −10.1, −4.4^‡‡‡^ | <0.001 | 6 | B
Montserrat 2001^162^ 11520721 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | Sham CPAP | 22 | 16.9 (6.0) | 14 (5.5) | | | | 6 | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | CPAP | 22 | 11.6 (4.9) | 8.2 (4.4) | −1.7 | −5.2, 1.8^§§§^ | NS | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | Sham CPAP | 19 | 12.3 (6.7) | 10.6 (6.4) | | | | nd | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | CPAP | 29 | 12.5 (4.3) | 9.7 (3.8) | −2.4 | −4.2, −0.6 | 0.04 | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | Sham CPAP | 29 | 12.5 (4.3) | 12.0 (3.8) | | | | 6 | B
West 2009^170^ 19427263 | nd | 13.4 (2.6) | 3 mo (PL) | AutoCPAP | 16 | 13.4 (2.6) | −6.1 (4.4) **** | −3.3 | −6.5, −0.1^††††^ | 0.04 | nd | B
West 2009^170^ 19427263 | nd | 13.4 (2.6) | 3 mo (PL) | Sham CPAP | 20 | 13.3 (3.4) | −2.8 (5.1)^‡‡‡‡^ | | | | nd | B
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | CPAP | 16 | 14.4 (2.5) | 5.1 (3.8) | −4.1 | −6.8, −1.4^§§§§^ | 0.009 | 47 | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | Sham CPAP | 16 | 14.1 (3.2) | 8.9 (5.0) | | | | 47 | C

* Change from baseline (SD)

† Change from baseline (SD)

‡ Change from baseline (SD)

§ Estimated from reported P value

** Change from baseline (SD)

†† Estimated from reported data.

‡‡ Estimated from reported data.

§§ Estimated from reported data.

*** Estimated from reported data.

††† Estimated from reported data.

‡‡‡ Estimated from reported data.

§§§ Estimated from reported data.

**** Change from baseline (SD)

†††† Estimated from reported data

‡‡‡‡ Change from baseline (SD)

§§§§ Estimated from reported data

Table 5.2.4 Arousal index (events/hr) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout,% | Study Quality
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 1 wk (PL) | CPAP | 23 | 55.1 (24.4) | 1.4 (9.5) | −38.6 | −53.5, −23.7 * | 0.001 | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 1 wk (PL) | Sham CPAP | 18 | 48.6 (28.2) | 33.5 (23.2) | | | | 14 | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | CPAP | 22 | 41 (28.4) | 10.5 (1.0) | −27.2 | −45.9, −8.4^†^ | <0.001 | nd | C
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | Sham CPAP | 19 | 43.8 (32.6) | 40.5 (8.0) | | | | nd | C
Becker 2003^143^ 12515745 | 65 (27) [ ≥5] | 14.1 (3.2) | 9 wk (PL) | CPAP | 16 | 58.7 (21.9) | 24.1 (9.8) | −13.8 | −30.2, 2.6^‡^ | nd | 47 | C
Becker 2003^143^ 12515745 | 65 (27) [ ≥5] | 14.1 (3.2) | 9 wk (PL) | Sham CPAP | 16 | 62.0 (28.0) | 41.2 (27.2) | | | | 47 | C

* Estimated from reported data.

† Estimated from reported data.

‡ Estimated from reported data

Table 5.2.5 Sleep efficiency (%TST) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Haensel 2007^148^ 17503102 | 58 (30) [≥15] | nd | 2 wk (PL) | CPAP | 25 | 80.3 (2.3) | 87.5 (1.5) | 3.3 | 2.3, 4.3 * | NS | 0 | B
Haensel 2007^148^ 17503102 | 58 (30) [≥15] | nd | 2 wk (PL) | Sham CPAP | 25 | 82.0 (1.6) | 85.9 (1.6) | | | | 0 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI 20] | nd | 1 wk (PL) | CPAP | 23 | 83.7 (10.7) | 88.1 (8.6) | 2.9 | −4.1, 9.9 † | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI 20] | nd | 1 wk (PL) | Sham CPAP | 18 | 82.2 (11.8) | 83.7 (12.9) | | | | 14 | B

* Estimated from reported data.

† Estimated from reported data.

Table 5.2.6 Slow wave sleep (% TST) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 27 | 7.9 (8.3) | 7.2 (10.4) | 3.2 | −1.9, 8.3 * | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 29 | 9.7 (10.2) | 5.8 (9.7) | | | | 18 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 1 wk (PL) | CPAP | 23 | 7.4 (8.7) | 12.5 (10.6) | −1.6 | −8.7, 5.5 † | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 1 wk (PL) | Sham CPAP | 18 | 6.3 (8.6) | 13.0 (14.5) | | | | 14 | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | CPAP | 22 | 5.0 (6.9) | 7.1 (6.2) | 1.5 | −2.2, 5.2 ‡ | NS | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | Sham CPAP | 19 | 4.1 (5.1) | 4.7 (5.8) | | | | nd | B
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL | CPAP | 16 | 6.2 (7.2) | 15.2 (7.1) | 3.4 | −1.8, 8.6 § | NS | 47 | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL | Sham CPAP | 16 | 6.0 (8.4) | 11.6 (6.7) | | | | 47 | C

* Estimated from reported data.

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data

Table 5.2.7 REM sleep (% TST) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net Diff or diff * | 95% CI | P Btw | Dropout, % | Study Quality
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 27 | 15.7 (9.9) | 12.2 (6.2) | −2.8 | −6.9, 1.3 † | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 29 | 12.9 (7.0) | 12.2 (7.0) | | | | 18 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 1 wk (PL) | CPAP | 23 | 19.0 (7.9) | 26.2 (7.0) | 5.7 | 0.85, 10.6 ‡ | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 1 wk (PL) | Sham CPAP | 18 | 17.7 (8.0) | 19.2 (8.3) | | | | 14 | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | CPAP | 22 | 14.3 (6.9) | 22 (9.4) | 7.5 | 3.5, 11.5 § | <0.05 | nd | C
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | Sham CPAP | 19 | 15.3 (4.8) | 15.5 (4.4) | | | | nd | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | CPAP | 16 | 11.4 (6.8) | 22.3 (5.7) | 4.1 | −0.8, 9.0 ** | NS | 47% | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | Sham CPAP | 16 | 14.3 (6.3) | 21.1 (8.8) | | | | 47% | C

* In crossover studies, if only data on the final values and the difference in final values are reported (as opposed to changes from baseline and net change), these data are italicized.

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data.

** Estimated from reported data

Table 5.2.8 Maintenance of wakefulness test (min) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (SD) | Net diff | 95% CI | P Btw | Dropout, % | Study Quality
West 2007^168^ 17557769 | nd | 14 (3.5) | 3 mo (PL) | AutoCPAP | 19 | 22 (13) * | +10.6 (14) | +15.3 | 6.5, 24 | 0.001 | 5 | A
West 2007^168^ 17557769 | nd | 14 (3.5) | 3 mo (PL) | Sham | 21 | 32 (11) † | −4.7 (12) | | | | 5 | A
Jenkinson 1999^151^ 10382693 Hack 2000^152^ 0679542 | nd | 17.0 (nd) | 4 Wk (PL) | AutoCPAP | 52 | 23 (nd) | 32.9 (nd) | +6.8 | 2.0, 11.5 ‡ | 0.005 | 6 | B
Jenkinson 1999^151^ 10382693 Hack 2000^152^ 0679542 | nd | 17.0 (nd) | 4 Wk (PL) | Sham | 49 | 20 (nd) | 23.5 (nd) | | | | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | CPAP | 29 | 20.9 (2.5) | 23.1 (10.8) | +5.2 | −0.6, 11 | 0.09 | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | Sham | 29 | 20.9 (2.5) | 17.9 (10.8) | | | | 6 | B
West 2009^170^ 19427263 | nd | 13.4 (2.6) | 3 mo (PL) | AutoCPAP | 16 | 23.5 (12.7) | +10.4 (14.4) | +15.4 | −2.1, 52.1 | NS | nd | B
West 2009^170^ 19427263 | nd | 13.4 (2.6) | 3 mo (PL) | Sham CPAP | 20 | 33.9 (9.2) | −5.0 (12.0) | | | | nd | B

* Significantly different between group at baseline

† Significantly different between group at baseline

‡ Estimated from reported data.

Table 5.2.9 FOSQ in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff | 95% CI | P Btw | Dropout, % | Study Quality
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | CPAP | 29 | 102 (16) | 108 (11) | +4.0 | −3.3, 11.3 * | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | Sham CPAP | 25 | 107 (15) | 110 (10) | | | | 2 | B
Montserrat 2001^162^ 11520724 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | CPAP | 23 | 85 (22) | 109 (13) | +10.48 | −2.6, 23.6 † | NS | 6 | B
Montserrat 2001^162^ 11520724 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | Sham CPAP | 22 | 86 (28) | 101 (22) | | | | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | CPAP | 29 | 12.6 (1.6) | 13.6 (1.8) | −0.3 | −1.1, 0.5 | NS | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | Sham CPAP | 29 | 12.6 (1.6) | 13.3 (1.8) | | | | 6 | B

* Estimated from reported data.

† Estimated from reported data.

Table 5.2.10 Quality of life in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors * | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors * | Net Diff | 95 CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors * | Net Diff | 95 CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Smith 2007^166^ 17470670 | 36 (23) [≥15] | 10 (5) | 6 wk (XO) | AutoCPAP | 23 | SF-36 | 0 | | | | | NS | 12 | A
Smith 2007^166^ 17470670 | 36 (23) [≥15] | 10 (5) | 6 wk (XO) | | | | 0 | | | | | NS | 12 | A
Smith 2007^166^ 17470670 | 36 (23) [≥15] | 10 (5) | 6 wk (XO) | Sham | 23 | PCS | 0 | | | | | NS | 12 | A
Smith 2007^166^ 17470670
Smith 2007^166^ 17470670 | | | | | | SF-36 | 0 | | | | | NS
Smith 2007^166^ 17470670 | | | | | | MCS | 0 | | | | | NS
Siccolli 2008^165^ 1e9014075 | nd | 15.2 (4.0) | 4 wk (PL) | CPAP | 50 | SF-36 | CPAP | 8.2 | 0.4, 16.0 † | 0 | 100 | 0.01 | 3 | B
Siccolli 2008^165^ 1e9014075 | nd | 15.2 (4.0) | 4 wk (PL) | | | | CPAP | 8.2 | 0.4, 16.0 † | 0 | 100 | 0.01 | 3 | B
Siccolli 2008^165^ 1e9014075 | nd | 15.2 (4.0) | 4 wk (PL) | Sham CPAP | 49 | PCS | CPAP | 8.2 | 0.4, 16.0 † | 0 | 100 | 0.01 | 3 | B
Siccolli 2008^165^ 1e9014075
Siccolli 2008^165^ 1e9014075 | | | | | | SF-36 | CPAP | 10.8 | 2.8, 18.8 ‡ | 0 | 100 | 0.002
Siccolli 2008^165^ 1e9014075 | | | | | | MCS | CPAP | 10.8 | 2.8, 18.8 ‡ | 0 | 100 | 0.002
Siccolli 2008^165^ 1e9014075
Siccolli 2008^165^ 1e9014075 | | | | | | Calgary SAQLI total score | CPAP | 0.9 | 0.4, 1.4 § | 0 | 7 | 0.001
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 20 | SF-36 | 0 | | | | | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | | | | 0 | | | | | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 25 | PCS | 0 | | | | | NS | 18 | B
Egea 2008^147^ 17904420 | | | | | | | | | | | | | 18 | B
Egea 2008^147^ 17904420 | | | | | | SF-36 | 0 | | | | | NS | 18 | B
Egea 2008^147^ 17904420 | | | | | | MCS | 0 | | | | | NS | 18 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | CPAP | 29 | SF-36 | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | Sham CPAP | 25 | PCS | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | | | | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | | | | | | SF-36 | 0 | | | | | | 2 | B
Barbe 2001^142^ 11388814 | | | | | | MCS | 0 | | | | | | 2 | B
Montserrat 2001^162^ 11520724 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | CPAP | 23 | SF-36 | 0 | | | | | NS | 6 | B
Montserrat 2001^162^ 11520724 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | | | | 0 | | | | | NS | 6 | B
Montserrat 2001^162^ 11520724 | 54 (19) [>10] | 16.9 (5.6) | 6 wk (PL) | Sham CPAP | 22 | PCS | 0 | | | | | NS | 6 | B
Montserrat 2001^162^ 11520724 | | | | | | | | | | | | | 6 | B
Montserrat 2001^162^ 11520724 | | | | | | SF-36 | 0 | | | | | NS | 6 | B
Montserrat 2001^162^ 11520724 | | | | | | MCS | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | CPAP | 29 | SF-36 | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | | | | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | Sham CPAP | 29 | PCS | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | | | | | | | | | | | | | 6 | B
Marshall 2005^159^ 15860720 | | | | | | SF-36 | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | | | | | | MCS | 0 | | | | | NS | 6 | B

* The noted intervention statistically significantly favors the patient (net better score on test). 0 = no difference.

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data.

Table 5.2.11 Neuropsychological outcomes in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) | BaselineESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors *,† | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | BaselineESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors *,† | Net Diff | 95 CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | BaselineESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors *,† | Net Diff | 95 CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | CPAP | 29 | Trial Making A test | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | Trial Making A test | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | Sham CPAP | 25 | Trial Making A test | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | Trial Making B test | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | WAIS- Digital symbols | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | WAIS- block design | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | WAIS- digit span | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | WMS- mental control | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | WMS- verbal paired associated | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | PASAT 1 | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | PASAT 2 | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | PASAT 3 | 0 | | | | | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | | | | | | | | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | | | PASAT 4 | 0 | | | | | NS | 2 | B
Haensel 2007^148^ 17503102 | 58 (30) [≥15] | nd | 2 wk (PL) | CPAP | 25 | POMS total score | 0 | | | | | NS | 0 | B
Haensel 2007^148^ 17503102 | 58 (30) [≥15] | nd | 2 wk (PL) | | | POMS total score | 0 | | | | | NS | 0 | B
Haensel 2007^148^ 17503102 | 58 (30) [≥15] | nd | 2 wk (PL) | Sham CPAP | 25 | POMS total score | 0 | | | | | NS | 0 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | CPAP | 23 | POMS- TMD | 0 | | | | | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | | | POMS- TMD | 0 | | | | | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | Sham CPAP | 18 | POMS- TMD | 0 | | | | | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | | | | | | | | | | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | | | All Cognitive tests | 0 | | | | | NS | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | | | | | | | | | | 14 | B
Loredo 1999^153^ 10593774 Yu 1999^154^ 10504011 Bardwell 2001^155^ 11485111 Profant 2003^156^ 12571548 | 44 (25) [RDI≥20] | nd | 11 d (PL) | | | MOS | 0 | | | | | NS | 14 | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | CPAP | 22 | BSI GSI | 0 | | | | | NS | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | | | BSI GSI | 0 | | | | | NS | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | Sham CPAP | 19 | BSI GSI | 0 | | | | | NS | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | | | | | | | | | | nd | B
Loredo 2006^157^ 16676791 Bardwell 2001^155^ 11485111 | 58 (32) [≥15] | 12.3 (6.7) | 2 wk (PL) | | | BSI Depression | 0 | | | | | NS | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | CPAP | 17 | All neuropsychological tests except the one below | 0 | | | | | NS | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | | | All neuropsychological tests except the one below | 0 | | | | | NS | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | Sham CPAP | 14 | All neuropsychological tests except the one below | 0 | | | | | NS | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | | | | | | | | | | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | | | Digit Vigilance | CPAP | −15.3 | nd | | | 0.02 | nd | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | CPAP | 29 | Hospital Anxiety and Depression scale | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | | | Hospital Anxiety and Depression scale | 0 | | | | | NS | 6 | B
Marshall 2005^159^ 15860720 | 22 (nd) [nd] | 12.5 (4.3) | 3 wk (XO) | Sham CPAP | | Hospital Anxiety and Depression scale | 0 | | | | | NS | 6 | B
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | CPAP | 27 | Trial Making A test | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | Trial Making A test | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | Sham CPAP | 18 | Trial Making A test | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | | | | | | | | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | Trial Making B test | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | | | | | | | | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | WAIS- Digital symbols | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | | | | | | | | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | WAIS- complex figure | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | | | | | | | | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | WAIS- digit span | 0 | | | | | NS | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | | | | | | | | 0 | C
Henke 2001^149^ 11282765 | 68 (25) [>10] | 16.0 (4.8) | 2 wk (PL) | | | Hits on steer clear test | 0 | | | | | NS | 0 | C

* The noted intervention statistically significantly favors the patient (net better score on test). 0 = no difference.

† The noted intervention statistically significantly favors the patient (net better score on test). 0 = no difference.

Table 5.2.12 Blood pressure outcomes (mm Hg) in randomized controlled trials of CPAP vs. sham control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff | 95% CI | P Btw | Dropout, % | Study Quality
MAP
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | CPAP | 34 | nd | 103.1 (8.7) | −5.5 | minus;8.2, minus;2.8 | <0.01 | 3 | A
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | Sham | 34 | | 108.6 (9.9) | | | | 3 | A
Robinson 2006^164^ 16455835 | nd | 5.3 (IRQ 3.0–7.0) | 1 mo (XO) | AutoCPAP | 32 | 106 (14) | 105.6 (13.2) | +1.1 * | −2.9, +5.1 | NS | 9 | A
Robinson 2006^164^ 16455835 | nd | 5.3 (IRQ 3.0–7.0) | 1 mo (XO) | Sham | 32 | 109 (13) | 107.6 (13.6) | | | | 9 | A
Campos-Rodriguez 2006^144^ 16778262 | 60 (22) [≥10] | 13.6 (3.6) | 4 wk (PL) | CPAP | 34 | 100.8 (10.7) | 99.8 (10.1) | −0.8 | −3.1, 4.9 | NS | 6 | B
Campos-Rodriguez 2006^144^ 16778262 | 60 (22) [≥10] | 13.6 (3.6) | 4 wk (PL) | Sham CPAP | 34 | 98.9 (10.0) | 98.9 (11.2) | | | | 6 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | CPAP | 23 | 98.9 (10.1) | 96.9 (10.1) | −2.2 | −6.2, +1.9 | NS | 18 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | Sham CPAP | 23 | 98.1 (10.1) | 98.3 (11.5) | | | | 18 | B
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0 (6.6) | 2 wk (PL) | CPAP | 18 | Change (SD): −3.1 (5.5) | | −6.4 | −11.1, −1.7 † | <0.05 | nd | C
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0 (6.6) | 2 wk (PL) | Sham CPAP | 15 | Change (SD): +3.3 (7.2) | | | | | nd | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | CPAP | 16 | 103.6 (16.1) | 93.6 (11.3) | −11.3 | −20, −2.7 | 0.01 | 47 | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | Sham CPAP | 16 | 103.5 (12.1) | 104.8 (10.6) | | | | 47 | C
SBP
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | CPAP | 34 | nd | 135.7 (11.7) | −6.7 | −10, −1.7 | <0.01 | 3 | A
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | Sham | 34 | | 142.4 (14.0) | | | | 3 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥15] | 10.3 (4.9) | 1 wk (PL) | AutoCPAP | 30 | 131 (14.7) | 127 (15.9) | −0.94 | −5.2, 3.3 ‡ | NS | 0 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥15] | 10.3 (4.9) | 1 wk (PL) | Sham CPAP | 31 | 130 (16.5) | 127 (15.9) | | | | 0 | A
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | CPAP | 29 | 130 (10.8) | 127 (10.8) | −2 | −8.5, 4.5 § | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | Sham CPAP | 25 | 127 (10.0) | 124 (10.0) | | | | 2 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | CPAP | 23 | 129.1 (14.4) | 126.8 (14.4) | −2.5 | −8.2, +3.2 | NS | 18 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | Sham CPAP | 23 | 127.7 (14.4) | 128.0 (16.3) | | | | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 20 | 124.3 (18.8) | 124.3 (21.9) | +1.6 | −8.9, 12.1 ** | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 25 | 125.0 (13.5) | 123.4 (14) | | | | 18 | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | CPAP | 17 | 155.2 (18.6) | 145.1 (21.0) | −8.0 | −22.4, 6.4 †† | nd | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | Sham CPAP | 16 | 149.0 (23.2) | 146.9 (21.2) | | | | nd | B
Cross 2008^146^ 18390635 | 63.0 (26) [>15] | nd | 6 wk (XO) | AutoCPAP | 27 | 143.0 (17.1) | 141 (16.1) | −3.8 | −10.5, 2.9 ‡‡ | 0.07 | 13 | B
Cross 2008^146^ 18390635 | 63.0 (26) [>15] | nd | 6 wk (XO) | Sham CPAP | 27 | 143.0 (17.1) | 144.8 (19.2) | | | | 13 | B
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0 (6.6) | 2 wk (PL) | CPAP | 18 | Change (SD): −2.2 (5.5) | | −5.7 | −11.2, −0.2 §§ | <0.05 | nd | C
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0 (6.6) | 2 wk (PL) | Sham CPAP | 15 | Change (SD): +3.5 (9.7) | | | | | nd | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | CPAP | 16 | 140.1 (17.6) | 132.1 (15.7) | −10.3 | −20.6, 0.1 | 0.05 | 47 | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL) | Sham CPAP | 16 | 141.0 (13.8) | 143.2 (11.2) | | | | 47 | C
Arias 2005^141^ 16009798 | 44 (28) [≥10] | nd | 12 wk (XO) | AutoCPAP | 25 | 127 (50) | 127 (40) | 0 | −18, 18 *** | NS | 7 | C
| | | | Sham CPAP | 25 | 127 (50) | 127 (60)
DBP
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | CPAP | 34 | nd | 86.8 (8.7) | −4.9 | −8.0, −1.8 | <0.01 | 3 | A
Coughlin 2007^145^ 17251237 | 40 (14) [>15] | 14 (4.9) | 6 wk (XO) | Sham | 34 | | 91.7 (9.3) | | | | 3 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥15] | 10.3 (4.9) | 1 wk (PL) | AutoCPAP | 30 | 80 (10.8) | 76 (8.2) | −0.61 | −4.1, 2.9 ††† | NS | 0 | A
Lam 2010^169^ 19608589 | 39.7 (22.1) [≥15] | 10.3 (4.9) | 1 wk (PL) | Sham CPAP | 31 | 82 (11.6) | 79 (11.8) | | | | 0 | A
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | CPAP | 29 | 82(5.4) | 81 (5.4) | −1 | −5.4, 3.4 ‡‡‡ | NS | 2 | B
Barbe 2001^142^ 11388814 | 57 (15) [≥30] | 7.0 (2) | 6 wk (PL) | Sham CPAP | 25 | 80 (10.0) | 80 (10.0) | | | | 2 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | CPAP | 23 | 84.3 (10.1) | 82.3 (9.6) | −1.8 | −5.3, +1.8 | NS | 18 | B
Hui 2006^150^ 16928705 | 30 (16) [≥5] | 10.7 (3.3) | 3 mo (PL) | Sham CPAP | 23 | 83.6 (10.1) | 83.4 (9.1) | | | | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | CPAP | 20 | 75.6 (10.3) | 76.0 (12.5) | −0.8 | −8.9, 7.3 §§§ | NS | 18 | B
Egea 2008^147^ 17904420 | 35 (17) [>10] | 7.3 (4.5) | 3 mo (PL) | Sham CPAP | 25 | 75.8 (12) | 77.0 (18.5) | | | | 18 | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | CPAP | 17 | 84.2 (10.7 | 79.5 (13.2) | −4.0 | −12.5, 4.5 **** | nd | nd | B
Mills 2006^160^ 16357087 Lim 2007^161^ 17694727 | 61 (33) [>15] | nd | 2 wk (PL) | Sham CPAP | 16 | 83.6 (14.0) | 82.9 (12.4) | | | | nd | B
Cross 2008^146^ 18390635 | 63.0 (26) [>15] | nd | 6 wk (XO) | AutoCPAP | 27 | 80.4 (10.5) | 82.3 (9.9) | 0 | −3.5, 3.5 †††† | NS | 13 | B
Cross 2008^146^ 18390635 | 63.0 (26) [>15] | nd | 6 wk (XO) | Sham CPAP | 27 | 80.4 (10.5) | 82.3 (8.8) | | | | 13 | B
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0 (6.6) | 2 wk (PL) | CPAP | 18 | Change (SD): −2.6 (4.7) | | −5.2 | −9.3, −1.1 ‡‡‡‡ | <0.05 | nd | C
Norman 2006^163^ 16585412 | 54 (30) [>15] | 12.0 (6.6) | 2 wk (PL) | Sham CPAP | 15 | Change (SD): +2.6 (6.5) | | | | | nd | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL | CPAP | 16 | 86.4 (16.1) | 75.8 (11.6) | −11.2 | −19.5, −2.8 | 0.01 | 47 | C
Becker 2003^143^ 12515745 | 65 (27) [≥5] | 14.1 (3.2) | 9 wk (PL | Sham CPAP | 16 | 85.4 (12.3) | 85.9 (10.6) | | | | 47 | C
Arias 2005^141^ 16009798 | 44 (28) [≥10] | nd | 12 wk (XO) | AutoCPAP | 25 | 79 (25) | 78 (25) | 0 | −11, 11 §§§§ | NS | 7 | C
Arias 2005^141^ 16009798 | 44 (28) [≥10] | nd | 12 wk (XO) | Sham CPAP | 25 | 79 (25) | 78 (30) | | | | 7 | C

* Median

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data.

** Estimated from reported data.

†† Estimated from reported data.

‡‡ Estimated from reported data.

§§ Estimated from reported data.

*** Estimated from reported data.

††† Estimated from reported data.

‡‡‡ Estimated from reported data.

§§§ Estimated from reported data.

**** Estimated from reported data.

†††† Estimated from reported data.

‡‡‡‡ Estimated from reported data.

§§§§ Estimated from reported data.

Table 5.3.1 Randomized controlled trials of oral vs. nasal CPAP: study characteristics

Study PMID | Interventions | CPAP Pressure * (type) | Mean Age, yr | Male,% | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Anderson 2003^171^ 14572126 | oral CPAP | manual (both) | 46 | nd | 43 | high BMI | New Zealand (nd) | small sample
Anderson 2003^171^ 14572126 | nasal CPAP | manual (both) | 46 | nd | 43 | high BMI | New Zealand (nd) | small sample
Mortimore 1998^172^ 9741373 | oral CPAP | manual (separate?) | 52 | nd | 32 | - | UK (nd) | study inclusion criteria not stated
Mortimore 1998^172^ 9741373 | nasal CPAP | manual (separate?) | 52 | nd | 32 | - | UK (nd) | study inclusion criteria not stated
Khanna 2003^173^ 14592306 | oral CPAP | manual (separate) | 52 | 63 | 34.6 | - | US (2000–01) | incomplete reporting
Khanna 2003^173^ 14592306 | nasal CPAP | manual (separate) | 52 | 63 | 34.6 | - | US (2000–01) | incomplete reporting

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, eg if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.3.2 Compliance (mean hr/night) in randomized controlled trials of oral vs. nasal CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Change (final) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Anderson 2003^171^ 14572126 | 85 (36) [>20] | 17 (2.3) | 1 mo (XO) | oral CPAP | 21 | 3.5 | −0.3 | −1.1, 0.5 * | 0.50 | 16 | B
Anderson 2003^171^ 14572126 | 85 (36) [>20] | 17 (2.3) | 1 mo (XO) | | | | | | | 16 | B
Anderson 2003^171^ 14572126 | 85 (36) [>20] | 17 (2.3) | 1 mo (XO) | nasal CPAP | 21 | 3.8 | | | | 16 | B
Mortimore 1998^172^ 9741373 | 35 (23) [nd] | nd | 1 mo (XO) | oral CPAP | 20 | 4.3 | −1.0 | −1.8, −0.3 | 0.01 | 0 | C
Mortimore 1998^172^ 9741373 | 35 (23) [nd] | nd | 1 mo (XO) | | | | | | | 0 | C
Mortimore 1998^172^ 9741373 | 35 (23) [nd] | nd | 1 mo (XO) | nasal CPAP | 20 | 5.3 | | | | 0 | C
Khanna 2003^173^ 14592306 | 60 † (39) [>15] | 13.3 (3.6) | 1 mo (PL) | oral CPAP | 21 | 5.8 | 0 | −0.73, 0.73 ‡ | NS | 29 | C
Khanna 2003^173^ 14592306 | 60 † (39) [>15] | 13.3 (3.6) | 1 mo (PL) | | | | | | | 29 | C
Khanna 2003^173^ 14592306 | 60 † (39) [>15] | 13.3 (3.6) | 1 mo (PL) | nasal CPAP | 17 | 5.8 | | | | 29 | C
Khanna 2003^173^ 14592306 | 60 † (39) [>15] | 13.3 (3.6) | 2 mo (PL) | oral CPAP | 15 | 5.8 | 0.1 | −1.2, 1.4 § | NS | 29 | C
Khanna 2003^173^ 14592306 | 60 † (39) [>15] | 13.3 (3.6) | 2 mo (PL) | | | | | | | 29 | C
Khanna 2003^173^ 14592306 | 60 † (39) [>15] | 13.3 (3.6) | 2 mo (PL) | nasal CPAP | 12 | 5.7 | | | | 29 | C

* Estimated from reported P value

† RDI

‡ Estimated from reported data

§ Estimated from reported data

Table 5.3.3 ESS in randomized controlled trials of oral vs. nasal CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Anderson 2003^171^ 14572126 | 85 (36) [>20] | 17 (2.3) | 1 mo (XO) | oral CPAP | 21 | 17 (2.3) | −10.0 | 0.7 | −1.7, 3.1 | 0.20 | 16 | B
Anderson 2003^171^ 14572126 | 85 (36) [>20] | 17 (2.3) | 1 mo (XO) | nasal CPAP | 21 | 17 (2.3) | −11.0 | | | | 16 | B
Mortimore 1998^172^ 9741373 | 35 (23) [nd] | nd | 1 mo (XO) | oral CPAP | 20 | nd | 9.8 | 1.6 | 0.38, 2.82 * | <0.01 | 0 | C
Mortimore 1998^172^ 9741373 | 35 (23) [nd] | nd | 1 mo (XO) | nasal CPAP | 20 | nd | 8.2 | | | | 0 | C

* Estimated from reported P value

Table 5.4.1 Randomized controlled trials of autoCPAP vs. CPAP: study characteristics

Study PMID | Interventions | CPAP Pressure *,† (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Damjanovic 2009^174^ 19129293 | autoCPAP | auto/manual (separate) | 57 | 78 | 31.1 | - | Germany (nd)
Damjanovic 2009^174^ 19129293 | CPAP | auto/manual (separate) | 57 | 78 | 31.1 | - | Germany (nd)
Meurice 2007^177^ 17638595 | autoCPAP | auto/manual (separate) | 55 | nd | 30.8 | - | France (nd) | pt recruitment unclear
Meurice 2007^177^ 17638595 | CPAP | auto/manual (separate) | 55 | nd | 30.8 | - | France (nd) | pt recruitment unclear
Patruno 2007^180^ 17494789 | autoCPAP | manual (separate) | 48 | 81 | 36.5 | some with HTN | Italy (nd) | incomplete reporting
Patruno 2007^180^ 17494789 | CPAP | manual (separate) | 48 | 81 | 36.5 | some with HTN | Italy (nd) | incomplete reporting
Planes 2003^193^ 12683473 | autoCPAP | manual (separate) | 54 | 77 | 32.4 | - | France (1998–99) | pt recruitment unclear
Planes 2003^193^ 12683473 | CPAP | manual (separate) | 54 | 77 | 32.4 | - | France (1998–99) | pt recruitment unclear
Series 1997^191^ 9341056 | autoCPAP est./meas. | manual (separate) | 36–65 (range) | nd | 36.4 | - | Canada (1995–96) | potential selection bias
Series 1997^191^ 9341056 | CPAP | manual (separate) | 36–65 (range) | nd | 36.4 | - | Canada (1995–96) | potential selection bias
Fietze 2007^175^ 17337881 | autoCPAP | auto/manual (separate) | 54 | 95 | 30.9 | - | Germany (nd) | incomplete reporting; pt selection unclear
Fietze 2007^175^ 17337881 | CPAP | auto/manual (separate) | 54 | 95 | 30.9 | - | Germany (nd) | incomplete reporting; pt selection unclear
Resta 2004^188^ 15679008 | autoCPAP | manual (nd) | 33 | 90 | 36.7 | - | Italy (nd) | incomplete reporting
Resta 2004^188^ 15679008 | CPAP | manual (nd) | 33 | 90 | 36.7 | - | Italy (nd) | incomplete reporting
Vennelle 2010^194^ 20175411 | autoCPAP | auto/manual (separate) | 50 | 77 | 34.5 | - | UK | -
Vennelle 2010^194^ 20175411 | CPAP | auto/manual (separate) | 50 | 77 | 34.5 | - | UK | -
Hukins 2004^183^ 15683142 | autoCPAP | manual (nd) | 50 | 87 | 35.2 | - | Australia (nd) | -
Hukins 2004^183^ 15683142 | CPAP | manual (nd) | 50 | 87 | 35.2 | - | Australia (nd) | -
Randerath 2001^190^ 11254519 | autoCPAP | manual (separate) | 55 | 87 | 32.4 | - | Germany | -
Randerath 2001^190^ 11254519 | CPAP | manual (separate) | 55 | 87 | 32.4 | - | Germany | -
Massie 2003^186^ 12406840 | autoCPAP | manual (both) | 49 | 82 | 32 | - | Australia, UK, U.S. | incomplete reporting
Massie 2003^186^ 12406840 | CPAP | manual (both) | 49 | 82 | 32 | - | Australia, UK, U.S. | incomplete reporting
To 2008^181^ 18197915 | autoCPAP | auto/manual (separate?) | 46 | nd | 28.7 | severe OSA | China (nd) | -
To 2008^181^ 18197915 | CPAP | auto/manual (separate?) | 46 | nd | 28.7 | severe OSA | China (nd) | -
Nussbaumer 2006^179^ 16537862 | autoCPAP | manual (separate) | 49 | 90 | 31.1 | - | Switzerland (nd) | -
Nussbaumer 2006^179^ 16537862 | CPAP | manual (separate) | 49 | 90 | 31.1 | - | Switzerland (nd) | -
Senn 2003^189^ Switzerland 14525804 | autoCPAP (2 modes) | auto/manual (separate) | 53 | 79 | 33.3 | - | Switzerland (nd) | -
Senn 2003^189^ Switzerland 14525804 | CPAP | auto/manual (separate) | 53 | 79 | 33.3 | - | Switzerland (nd) | -
Nolan 2007^178^ 17326544 | autoCPAP | auto/manual (separate?) | 53 | 90 | 29.9 | - | Ireland (nd) | -
Nolan 2007^178^ 17326544 | CPAP | auto/manual (separate?) | 53 | 90 | 29.9 | - | Ireland (nd) | -
Noseda 2004^187^ 15249439 | autoCPAP | manual (separate) | 49 | 96 | 32.3 | high variability in pressure required during 2 wk autoCPAP run-in | Belgium (nd) | -
Noseda 2004^187^ 15249439 | CPAP | manual (separate) | 49 | 96 | 32.3 | high variability in pressure required during 2 wk autoCPAP run-in | Belgium (nd) | -
Hudgel 2000^182^ 10947032 | autoCPAP | auto/manual (both) | 46 | 54 | 42 | - | U.S. | incomplete reporting; 35% drop out
Hudgel 2000^182^ 10947032 | CPAP | auto/manual (both) | 46 | 54 | 42 | - | U.S. | incomplete reporting; 35% drop out
Marrone 2004^185^ 15165530 | autoCPAP | auto/manual (separate) | 53 | 95 | 32.9 | - | Italy | small sample & no power calc
Marrone 2004^185^ 15165530 | CPAP | auto/manual (separate) | 53 | 95 | 32.9 | - | Italy | small sample & no power calc
Galetke 2008^176^ 17148931 | autoCPAP | auto/manual (separate) | 56 | 80 | 29.3 | - | Germany (nd) | incomplete reporting; small sample & no power calc
Galetke 2008^176^ 17148931 | CPAP | auto/manual (separate) | 56 | 80 | 29.3 | - | Germany (nd) | incomplete reporting; small sample & no power calc
Hussain 2004^184^ 15072173 | autoCPAP | manual (separate) | 45 | 90 | 35.9 | - | Pakistan and Canada (nd) | pt recruitment method unclear; small sample & no power calc
Hussain 2004^184^ 15072173 | CPAP | manual (separate) | 45 | 90 | 35.9 | - | Pakistan and Canada (nd) | pt recruitment method unclear; small sample & no power calc
Teschler 2000^192^ 10885414 | autoCPAP | manual/auto (separate) | 52 | 100 | 33.8 | - | Germany (nd) | incomplete reporting; small sample; ?power calc
Teschler 2000^192^ 10885414 | CPAP | manual/auto (separate) | 52 | 100 | 33.8 | - | Germany (nd) | incomplete reporting; small sample; ?power calc

* Method for choosing CPAP Pressure: manual (during sleep study), auto (determined with AutoCPAP); Algorithm (by an algorithm); nd = no data reported; NA = not applicable (e.g., if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study), Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

† Method for choosing CPAP Pressure: manual (during sleep study), auto (determined with AutoCPAP); Algorithm (by an algorithm); nd = no data reported; NA = not applicable (e.g., if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study), Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.4.2 Compliance (mean hr/night) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | P Btw | Dropout, % | Study Quality
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | autoCPAP | 46 | 5.4 | 0 | −0.7, 0.7 | nd | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | CPAP | 46 | 5.4 | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | autoCPAP | 34 | 5.2 | 0.1 | −0.9, 1.1 | nd | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | CPAP | 44 | 5.1 | | | | 22 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | autoCPAP (AutoSet) | 15 | 6.0 | −0.1 | −0.786, 0.586 | nd | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | CPAP | 14 | 6.1 | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | autoCPAP (AutoSet) | 15 | 6.1 | −0.4 | −1.28, 0.48 | nd | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | 6.5 | | | | 15 | B
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | autoCPAP | 15 | 6.2 | 0.2 | −0.25, 0.65 | nd | 23 | C
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | CPAP | 16 | 6.0 | | | | 23 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | autoCPAP | 16 | 4.5 | −0.8 | nd | NS | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | CPAP | 14 | 5.3 | | | | 14 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP est. | 12 | nd * | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP meas. | 12 | nd † | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (PL) | autoCPAP | 20 | 5.0 | 0.8 | nd | NS | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (PL) | CPAP | 21 | 4.2 | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 5.2 | −0.1 | −1.12, 0.92 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 5.3 | | | | 0 | C
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | 6 wk (XO) | autoCPAP | 181 | 4.2 | 0.2 | 0.003, 0.397 | 0.047 | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | 6 wk (XO) | CPAP | 181 | 4.0 | | | | 9.5 | A
Hukins 2004^183^ 15683142 | 56 (nd) | 12.5 (nd) | 1–2 mo (XO) | autoCPAP | 46 | 5.05 | 0.19 | −0.062, 0.442 ‡ | 0.14 | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) | 12.5 (nd) | 1–2 mo (XO) | CPAP | 46 | 4.86 | | | | 16 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | autoCPAP | 52 (46?) | 5.26 | 0 | −0.44, 0.44 | nd | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) | 5.26 | | | | 12 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | autoCPAP | 44 | 5.1 | 0.58 | 0.18, 0.99 § | 0.005 | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | CPAP | 44 | 4.52 | | | | 4 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | autoCPAP | 41 | 4.3 | 0.5 | 0.02, 0.98 ** | 0.04 | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | CPAP | 41 | 3.8 | | | | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | autoCPAP | 41 | 4.4 | 0.7 | 0.17, 1.23 †† | 0.01 | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | CPAP | 41 | 3.7 | | | | 5 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | autoCPAP | 30 | 5.1 | 0.3 | −0.29, 0.89 | nd | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | CPAP | 30 | 4.8 | | | | 12 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | autoCPAP (Autoset T) | 29 | 5.5 | −0.1 | nd | NS | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | autoCPAP (AutoAdjust) | 29 | 5.5 | −0.1 | nd | NS | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | CPAP | 29 | 5.6 | | | | 7 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4.0) | 2 mo (XO) | autoCPAP | 29 | 4.9 | 0 | nd | 0.94 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4.0) | 2 mo (XO) | CPAP | 29 | 4.9 | | | | 15 | B
Noseda 2004^187^ 15249439 | 51 (25) [>20] | 10.7 (2.4) | 2 mo (XO) | autoCPAP | 24 | 5.3 | −0.2 | −0.89, 0.49 | nd | 11 | B
Noseda 2004^187^ 15249439 | 51 (25) [>20] | 10.7 (2.4) | 2 mo (XO) | CPAP | 24 | 5.5 | | | | 11 | B
Hudgel 2000^182^ 10947032 | 30 (25) [nd] | 16.0 (5.0) | 3 mo (XO) | autoCPAP | 14 | 6.0 | 0.5 | 0.02, 0.98 ‡‡ | <0.04 | 35 | C
Hudgel 2000^182^ 10947032 | 30 (25) [nd] | 16.0 (5.0) | 3 mo (XO) | CPAP | 19 | 5.5 | | | | 35 | C
Marrone 2004^185^ 15165530 | 68 (12) [30] | 16.3 (5.0) | 1 mo (XO) | autoCPAP | 22 | 4.9 | 0.5 | −0.26, 1.26 | nd | 0 | C
Marrone 2004^185^ 15165530 | 68 (12) [30] | 16.3 (5.0) | 1 mo (XO) | CPAP | 22 | 4.4 | | | | 0 | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | autoCPAP | 20 | 6.37 | −0.01 | −0.82, 0.8 | nd | 0? | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | CPAP | 20 | 6.38 | | | | 0? | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | autoCPAP | 10 | 4.3 | 0.6 | −0.84, 2.04 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 3.7 | | | | 0 | C
Teschler 2000^192^ 10885414 | 53 (26) [>20] | nd | 2 mo (XO) | autoCPAP | 10 | 6.3 | 0.2 | −0.7, 1.1 | nd | 0? | C
Teschler 2000^192^ 10885414 | 53 (26) [>20] | nd | 2 mo (XO) | CPAP | 10 | 6.1 | | | | 0? | C

* directions of changes were not reported in the study

† directions of changes were not reported in the study

‡ Estimated from reported P value

§ Estimated from reported P value

** Estimated from reported P value

†† Estimated from reported P value

‡‡ Estimated from reported P value

Table 5.4.3 AHI (events/hr) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI *,§ | P Btw | Dropout, % | Study Quality
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | autoCPAP | 46 | 41.8 (23.7) | −37.0 | 1.8 | −7.14, 10.74 | nd | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | | | | | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | CPAP | 46 | 45.5 (24.4) | −38.8 | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | autoCPAP | 34 | 41.8 (23.7)? | −38.2 | 1.9 | −6.86, 10.66 | nd | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | | | | | | | | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | CPAP | 44 | 45.5 (24.4)? | −40.1 | | | | 22 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | autoCPAP (AutoSet) | 15 | 53.4 (15.1) | −51.1 | 2.6 | −8.88, 14.08 | nd | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | 56.1 (21.4) | −53.7 | | | | 15 | B
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | autoCPAP | 15 | 47.3 (14.7) | −41.3 | 2.7 | −7.01,12.41 | nd | 23 | C
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | | | | | | | | 23 | C
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | CPAP | 16 | 46.0 (14.6) | −44.0 | | | | 23 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | autoCPAP | 16 | 57.5 (16.5) | −49.9 | 0.7 | −10.06, 11.46 | nd | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | | | | | | | | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | CPAP | 14 | 61.0 (17.4) | −50.6 | | | | 14 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP est. | 12 | 61.5 (27.9) | nd † | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | 50.1 (14.5) | nd | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP meas. | 12 | 46.8 (22.3) | nd ‡ | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | 50.1 (14.5) | nd | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (PL) | autoCPAP | 20 | 43.3 (30.2) | −38.9 | 0.5 | −1.19, 2.19 | nd | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (PL) | | | | | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (PL) | CPAP | 21 | 40.4 (26.1) | −36.5 | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 48.0 (14.3) | −39.7 | −2.8 | −12.96, 7.36 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | | | | | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 45.3 (10.7) | −36.9 | | | | 0 | C
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | autoCPAP | 52 (46?) | 35.1 (26) | −30.1 | 0.7 | −0.88, 2.28 | nd | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | | | | | | | | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) | 35.1 (26) | −30.8 | | | | 12 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | autoCPAP | 44 | nd | nd | −1.1 | −2.89, 0.69 | nd | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | | | | | | | | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | CPAP | 44 | nd | nd | | | | 4 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | autoCPAP | 30 | 41.1 (19.7) | −36.5 | −0.8 | −1.7, 3.3 ** | nd | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | | | | | | | | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | CPAP | 30 | 41.2 (19.7) | −35.7 | | | | 12 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | autoCPAP (Autoset T) | 29 | 45.8 (22.6) | −39.8 | 0.7 | −1.26, 2.66 | nd | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | | | | | | | | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | autoCPAP (AutoAdjust) | 29 | 45.8 (22.6) | −38.1 | 2.4 | −0.34, 5.14 | nd | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | | | | | | | | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | CPAP | 29 | 45.8 (22.6) | −40.5 | | | | 7 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4.0) | 2 mo (XO) | autoCPAP | 29 | 14.7 (8) | −12.0 | −0.8 | −1.89, 0.29 †† | 0.15 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4.0) | 2 mo (XO) | | | | | | | | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4.0) | 2 mo (XO) | CPAP | 29 | 14.7 (8) | −11.2 | | | | 15 | B
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | autoCPAP | 20 | 32.9 (19.1) | −27.3 | 1.0 | −0.45, 2.45 | nd | 0? | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | | | | | | | | 0? | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | CPAP | 20 | 32.9 (19.1) | −28.3 | | | | 0? | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | autoCPAP | 10 | 47.2 (35.6) | −34.1 | 3.5 | −1.02, 8.02 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | | | | | | | | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 47.2 (35.6) | −37.6 | | | | 0 | C
Teschler 2000^192^ 10885414 | 53 (26) [>20] | nd | 2 mo (XO) | autoCPAP | 10 | 52.9 (25.6) | −48.9 | 0.3 | −0.29, 0.89 | nd | 0? | C
Teschler 2000^192^ 10885414 | 53 (26) [>20] | nd | 2 mo (XO) | | | | | | | | 0? | C
Teschler 2000^192^ 10885414 | 53 (26) [>20] | nd | 2 mo (XO) | CPAP | 10 | 52.9 (25.6) | −49.2 | | | | 0? | C

* Estimated from reported data

† Directions of changes were not reported in the study

‡ Directions of changes were not reported in the study

§ Estimated from reported data

** Actual reported data

†† Estimated from reported P value

Table 5.4.4 ESS in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI * | P Btw | Dropout, % | Study Quality
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | autoCPAP | 46 | 8.5 (5.42) | −2.6 | −0.3 | −2.32, 1.72 | nd | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | | | | | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 3 mo (PL) | CPAP | 46 | 9.3 (4.75) | −2.3 | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | autoCPAP | 34 | 8.5 (5.42) ? | −2.6 | 0.1 | −1.92, 2.12 | nd | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | | | | | | | | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.2) | 9 mo (PL) | CPAP | 44 | 9.3 (4.75) ? | −2.7 | | | | 22 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | autoCPAP (AutoSet) | 15 | 12.9 (4.3) | −9.1 | −3.3 | −6.68, 0.08 | NS | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | CPAP | 14 | 10.6 (5.2) | −5.8 | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | autoCPAP (AutoSet) | 15 | 12.9 (4.3) | −7.7 | −3.0 | −6.44, 0.44 | NS | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | 10.6 (5.2) | −4.7 | | | | 15 | B
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | autoCPAP | 15 | 15.8 (3.5) | nd | nd | nd | NS | 23 | C
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | | | | | | | | 23 | C
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | CPAP | 16 | 14.1 (1.7) | nd | | | | 23 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | autoCPAP | 16 | 15.5 (4.7) | −8.0 | −0.9 | −3.72, 1.92 | nd | 14
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | | | | | | | | 14
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | CPAP | 14 | 14.7 (3.9) | −7.1 | | | | 14
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP est. | 12 | 17.0 (4.1) | −9.1 | −0.8 | −4.28, 2.69 | nd | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | 16.1 (4.5) | −8.3 | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP meas. | 12 | 13.5 (4.7) | −6.5 | 1.8 | −1.78, 5.38 | nd | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | 16.1 (4.5) | −8.3 | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [−10] | nd | 1.5 mo (PL) | autoCPAP | 20 | nd | nd | nd | nd | NS | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [−10] | nd | 1.5 mo (PL) | | | | | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [−10] | nd | 1.5 mo (PL) | CPAP | 21 | nd | nd | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 15.7 (5.1) | −10.5 | −2.6 | −5.84, 0.64 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | | | | | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 12.0 (3.2) | −7.9 | | | | 0 | C
Vennelle 2010^194^ 20175411 | 33 (18) [≥ 15] | 14 (3) | 6 wk (XO) | autoCPAP | 181 | 14 (3) | −4.5 | −0.5 | −0.95, −0.05 | 0.031 | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥ 15] | 14 (3) | 6 wk (XO) | | | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥ 15] | 14 (3) | 6 wk (XO) | CPAP | 181 | 14 (3) | −4 | | | | 9.5 | A
Hukins 2004^183^ 15683142 | 56 (nd) [≥ 5] | 12.5 (nd) | 1 – 2 mo (XO) | autoCPAP | 46 | 12.5 (nd) | −4.5 | −0.2 | nd | NS | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥ 5] | 12.5 (nd) | 1 – 2 mo (XO) | | | | | | | | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥ 5] | 12.5 (nd) | 1 – 2 mo (XO) | CPAP | 46 | 12.5 (nd) | −4.3 | | | | 16 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥ 10] | 11.1 (5.1) | 1.5 mo (XO) | autoCPAP | 52 (46?) | 11.1 (5.1) | −3.3 | −1 | −2.26, 0.26 | nd | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥ 10] | 11.1 (5.1) | 1.5 mo (XO) | | | | | | | | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥ 10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) | 11.1 (5.1) | −2.3 | | | | 12 | B
Massie 2003^186^ 12406840 | nd [≥ 15] | nd | 1.5 mo (XO) | autoCPAP | 44 | nd | nd | −1 | −2.06, 0.06 † | 0.065 | 4 | B
Massie 2003^186^ 12406840 | nd [≥ 15] | nd | 1.5 mo (XO) | | | | | | | | 4 | B
Massie 2003^186^ 12406840 | nd [≥ 15] | nd | 1.5 mo (XO) | CPAP | 44 | nd | nd | | | | 4 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | autoCPAP | 41 | 13.4 (5.76) | −4.9 | 0.3 | −1.46, 2.06 | nd | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | | | | | | | | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | CPAP | 41 | 13.4 (5.76) | −5.2 | | | | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | autoCPAP | 41 | 13.4 (5.76) | −4.9 | 0 | −1.76, 1.76 | nd | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | | | | | | | | 5 | B
To 2008^181^ 18197915 | 54 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | CPAP | 41 | 13.4 (5.76) | −4.9 | | | | 5 | B
Nussbaumer 2006^179^ 16537862 | 41 (207) [>10] | 12.7 (3.29) | 1 mo (XO) | autoCPAP | 30 | 12.7 (0.6) | −6.6 | 0 | −1.6, 1.1 | nd | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (207) [>10] | 12.7 (3.29) | 1 mo (XO) | | | | | | | | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (207) [>10] | 12.7 (3.29) | 1 mo (XO) | CPAP | 30 | 12.7 (0.6) | −6.6 | | | | 12 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.77) | 1 mo (XO) | autoCPAP (Autoset T) | 29 | 14.2 (3.77) | −5.2 | 0.8 | −0.49, 2.09 | nd | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.77) | 1 mo (XO) | | | | | | | | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.77) | 1 mo (XO) | autoCPAP (AutoAdjust) | 29 | 14.2 (3.77) | −6.2 | −0.2 | −1.68, 1.28 | nd | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.77) | 1 mo (XO) | | | | | | | | 7 | B
Senn 2003^189^ Switzerland 14525804 | 46 (23) [>10] | 14.2 (3.77) | 1 mo (XO) | CPAP | 29 | 14.2 (3.77) | −6.0 | | | | 7 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥ 5) | 12.3 (4.0) | 2 mo (XO) | autoCPAP | 29 | 12.3 (4.0) | −3.7 | 0.9 | −0.99, 2.79 ‡ | 0.35 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥ 5) | 12.3 (4.0) | 2 mo (XO) | | | | | | | | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥ 5) | 12.3 (4.0) | 2 mo (XO) | CPAP | 29 | 12.3 (4.0) | −4.6 | | | | 15 | B
Noseda 2004^187^ 15249439 | nd [>20] | 10.7 (2.4) | 2 mo (XO) | autoCPAP | 24 | 10.7 (2.4) | nd | −1 | −1.76, −0.24 § | <0.01 | 11 | B
Noseda 2004^187^ 15249439 | nd [>20] | 10.7 (2.4) | 2 mo (XO) | | | | | | | | 11 | B
Noseda 2004^187^ 15249439 | nd [>20] | 10.7 (2.4) | 2 mo (XO) | CPAP | 24 | 10.7 (2.4) | nd | | | | 11 | B
Hudgel 2000^182^ 10947032 | 30 (25) [nd] | 16.0 (5.0) | 3 mo (XO) | autoCPAP | 39 | 16.0 (5.0) | −7.0 | 1 | −0.96, 2.96 | nd | 35 | C
Hudgel 2000^182^ 10947032 | 30 (25) [nd] | 16.0 (5.0) | 3 mo (XO) | | | | | | | | 35 | C
Hudgel 2000^182^ 10947032 | 30 (25) [nd] | 16.0 (5.0) | 3 mo (XO) | CPAP | 39 | 16.0 (5.0) | −8.0 | | | | 35 | C
Marrone 2004^185^ 15165530 | 68 (12) [30] | 16.3 (5.0) | 1 mo (XO) | autoCPAP | 22 | 16.3 (5.0) | −12.4 | −1 | −2.4, 0.4 | nd | 0 | C
Marrone 2004^185^ 15165530 | 68 (12) [30] | 16.3 (5.0) | 1 mo (XO) | | | | | | | | 0 | C
Marrone 2004^185^ 15165530 | 68 (12) [30] | 16.3 (5.0) | 1 mo (XO) | CPAP | 22 | 16.3 (5.0) | −11.4 | | | | 0 | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | autoCPAP | 20 | 10.3 (5.7) | −5.4 | −1.7 | −3.76, 0.36 | nd | 0 | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | | | | | | | | 0 | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | CPAP | 20 | 10.3 (5.7) | −3.7 | | | | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | autoCPAP | 10 | 11.1 (6.4) | −3.1 | 1.4 | −2.2, 5.0 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | | | | | | | | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 11.1 (6.4) | −4.5 | | | | 0 | C

* Estimated from reported data

† Estimated from reported P value

‡ Estimated from reported P value

§ Estimated from reported P value

Table 5.4.5 Arousal index (events/hr) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI * | P Btw | Dropout, % | Study Quality
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.18) | 3 mo (PL) | autoCPAP | 46 | 30.6 (22.4) | −18.3 | −0.2 | −7.92, 7.52 | nd | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.18) | 3 mo (PL) | | | | | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.18) | 3 mo (PL) | CPAP | 46 | 34.5 (21.0) | −18.1 | | | | 8 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.18) | 3 mo (PL) | autoCPAP | 34 | 30.6 (22.4)? | −17.7 | 3.6 | −4.09, 11.29 | nd | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.18) | 3 mo (PL) | | | | | | | | 22 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥15] | 8.8 (5.18) | 3 mo (PL) | CPAP | 44 | 34.5 (21.0)? | −21.3 | | | | 22 | B
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | autoCPAP | 16 | 44.4 (19.1) | | 3.3 | −7.14, 12.74 | nd | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | | | | | | | | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | CPAP | 14 | 48.5 (14.2) | | | | | 14 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP est. | 12 | nd | nd † | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | nd | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP meas. | 12 | nd | nd^‡^ | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | nd | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 43.1 (11.9) | −35.7 | 0.1 | −8.29, 8.49 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | | | | | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 43.1 (9.1) | −35.8 | | | | 0 | C
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | autoCPAP | 52 (46?) | 34 (21.7) | −23.1 | −1.7 | −3.7, 0.3 | nd | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | | | | | | | | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) | 34 (21.7) | −21.4 | | | | 12 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥ 5) | 12.3 (4) | 2 mo (XO) | autoCPAP | 29 | 16.0 (14.0) | −14.0 | −3.0 | −5.7, −0.29 § | 0.03 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥ 5) | 12.3 (4) | 2 mo (XO) | | | | | | | | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥ 5) | 12.3 (4) | 2 mo (XO) | CPAP | 29 | 16.0 (14.0) | −11.0 | | | | 15 | B
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | autoCPAP | 20 | 17.6 (9.2) | −4.0 | 1.0 | −2.52, 4.52 | nd | 0? | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | | | | | | | | 0? | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | CPAP | 20 | 17.6 (9.2) | −5.0 | | | | 0? | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | autoCPAP | 10 | 17.3 (17.7) | −11.4 | 1.0 | −2.5, 4.5 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | | | | | | | | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 17.3 (17.7) | −12.4 | | | | 0 | C

* Estimated from reported data

† Directions of changes were not reported in the study

‡ Directions of changes were not reported in the study

§ Estimated from reported P value

Table 5.4.6 Minimum O_2_ saturation (%) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net Diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | AutoCPAP (AutoSet) | 15 | 82.1 (12.8) | 0.2 | −2.9 | −7.1, 7.5 | nd | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | 82.3 (9.9) | 0.5 | | | | 15 | B
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | AutoCPAP | 15 | 71.7 (10.6) | 16.4 | −4.4 | −11.8, 3.0 | nd | 23 | C
Patruno 2007^180^ 17494789 | 46 (14) [>20] | 15 (2.7) | 3 mo (PL) | CPAP | 16 | 70.0 (11.7) | 20.8 | | | | 23 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | AutoCPAP | 10 | 72.4 (10.5) | 15.9 | 0.9 | −7.4, 9.2 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 74.1 (10.8) | 15.0 | | | | 0 | C
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | AutoCPAP | 52 (46?) | 81 (8.0) | 7.0 | −1.0 | −2.1, 0.1 | nd | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) | 81 (8.0) | 8.0 | | | | 12 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | AutoCPAP | 29 | 79 (11.5) | 8.5 | 4.8 | −7.4, 17.0 † | 0.44 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | CPAP | 29 | 79 (11.5) | 3.7 | | | | 15 | B
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | AutoCPAP | 20 | 77.8 (8.4) | 8.7 | −1.8 | −3.8, 0.2 | nd | 0? | C
Galetke 2008^176^ 17148931 | 33 (19) [>10] | 10.3 (5.7) | 2 mo (XO) | CPAP | 20 | 77.8 (8.4) | 10.5 | | | | 0? | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | AutoCPAP | 10 | 67.8 (12.5) | 14.0 | −3.9 | −7.3, −0.5 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 67.8 (12.5) | 17.9 | | | | 0 | C

* Estimated from reported data

† Estimated from reported P value

Table 5.4.7 Sleep efficiency (%) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 86.9 (8) | −0.5 | −2.5 | −8.89, 3.89 * | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 84.2 (4.9) | 2 | | | | 0 | C
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (PL) | autoCPAP | 29 | 79 (9) | 4 | −1 | −4.34, 2.34 † | 0.39 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (PL) | CPAP | 29 | 79 (9) | 5 | | | | 15 | B

* Estimated from reported data

† Estimated from reported P value

Table 5.4.8 REM sleep (%) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | autoCPAP (AutoSet) | 15 | 18.9 (6.6) | −2.4 | −2.9 | −7.49, 1.69 | nd | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | 19.1 (5.9) | 0.5 | | | | 15 | B
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | autoCPAP | 16 | 12.4 (7.0) | 4.2 | 0.5 | −5.44, 6.44 | nd | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | | | | | | | | 14 | C
Planes 2003^193^ 12683473 | 59 (17) [≥30] | 15.1 (3.9) | 2 mo (PL) | CPAP | 14 | 13.7 (9.3) | 3.7 | | | | 14 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP est. | 12 | nd | nd * | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | nd | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP meas. | 12 | nd | nd † | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | nd | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 15.0 (8.1) | 6.7 | −2 | −10.31, 6.31 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | | | | | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 15.9 (4.2) | 8.7 | | | | 0 | C
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | autoCPAP | 52 (46?) ‡ | 11 (8) | 6.0 | 1 | −0.63, 2.63 | nd | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | | | | | | | | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) § | 11 (8) | 5.0 | | | | 12 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | autoCPAP | 29 | 17.6 (5.1) | −0.5 | −2.5 | −5.11, 0.11 ** | 0.06 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | | | | | | | | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | CPAP | 29 | 17.6 (5.1) | 2.0 | | | | 15 | B
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | autoCPAP | 10 | 15 (7.0) | 4.0 | −1 | −4.72, 2.72 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | | | | | | | | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 15 (7.0) | 5.0 | | | | 0 | C

* Directions of changes were not reported in the study

† Directions of changes were not reported in the study

‡ Unclear

§ Unclear

** Estimated from reported P value

Table 5.4.9 Stage 3 or 4 sleep (%) in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI * | P Btw | Dropout, % | Study Quality
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | autoCPAP (AutoSet) | 15 | 25.5 (14.7) | −4.4 | −5.2 | −13.51, 3.11 | nd | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | 17.1 (7) | 0.8 | | | | 15 | B
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP est. | 12 | nd | nd † | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | nd | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | autoCPAP meas. | 12 | nd | nd^‡^ | - | - | NS | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | | | | | | | | 0 | C
Series 1997^191^ 9341056 | 44 (20) [nd] | 15.5 (4.5) | 0.75 mo (PL) | CPAP | 12 | nd | nd | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | autoCPAP | 10 | 19.8 (10.9) | 14 | 7.3 | −2.35, 16.95 | nd | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | | | | | | | | 0 | C
Resta 2004^188^ 15679008 | 47 (11) [>30] | 13.9 (3.2) | 1 mo (PL) | CPAP | 10 | 22.8 (12.5) | 6.7 | | | | 0 | C
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | autoCPAP | 52 (46?) § | 14 (11) | 0 | −1 | −3.45, 1.45 | NS | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | | | | | | | | 12 | B
Randerath 2001^190^ 11254519 | 35 (26) [≥10] | 11.1 (5.1) | 1.5 mo (XO) | CPAP | 52 (46?) ** | 14 (11) | 1.0 | | | | 12 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | autoCPAP | 29 | 13.7 (7.8) | 1.3 | 0.3 | −3.29, 3.89 †† | 0.87 | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | | | | | | | | 15 | B
Nolan 2007^178^ 17326544 | 15 (8) [≥5) | 12.3 (4) | 2 mo (XO) | CPAP | 29 | 13.7 (7.8) | 1.0 | | | | 15 | B
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | autoCPAP | 10 | 14 (25) | −4.0 | −8 | −18.32, 2.32 | nd | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | | | | | | | | 0 | C
Hussain 2004^184^ 15072173 | 47 (36) [>15] | 11.1 (6.4) | 1 mo (XO) | CPAP | 10 | 14 (25) | 4.0 | | | | 0 | C

* Estimated from reported data

† directions of changes were not reported in the study

‡ directions of changes were not reported in the study

§ Unclear

** Unclear

†† Estimated from reported P value

Table 5.4.10 Quality of life and functional outcomes in randomized controlled trials of autoCPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If significant difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | 95% CI | Test range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | 6 wk (XO) | autoCPAP | 181 | SF-36-M | 0 | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | | | | | | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | | CPAP | 181 | SF-36-P | 0 | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | | | | | | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | | | | Vigilance (OSLER) | 0 | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | | | | | | | | | | | 9.5 | A
Vennelle 2010^194^ 20175411 | 33 (18) [≥15] | 14 (3) | | | | Vigilance (Psychomotor) | 0 | | | | | | 9.5 | A
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | autoCPAP (AutoSet) | 15 | SF-36-M | 0 | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | | | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | CPAP | 14 | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | | | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 3 mo (PL) | | | SF-36-P | 0 | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | | | | | | | | | | | | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | autoCPAP (AutoSet) | 15 | SF-36-M | 0 | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | CPAP | 14 | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | | | | | | | | 15 | B
Meurice 2007^177^ 17638595 | 55 (10) [nd] | 11.8 (4.9) | 6 mo (PL) | | | SF-36-P | 0 | | | | | | 15 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥5] | 12.5 (nd) | 2 mo (XO) | autoCPAP | 46 | SF-36-M | 0 | | | | | | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥5] | 12.5 (nd) | 2 mo (XO) | | | | | | | | | | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥5] | 12.5 (nd) | 2 mo (XO) | CPAP | 46 | | | | | | | | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥5] | 12.5 (nd) | 2 mo (XO) | | | | | | | | | | 16 | B
Hukins 2004^183^ 15683142 | 56 (nd) [≥5] | 12.5 (nd) | 2 mo (XO) | | | SF-36-P | 0 | | | | | | 16 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | autoCPAP | 44 | SF-36 - MH | autoCPAP | 5 | 0.16, 9.8 * | 0 | 100 | <0.05 | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | | | | | | | | | | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | CPAP | 44 | | | | | | | | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | | | | | | | | | | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | | | SF-36 - vitality | autoCPAP | 7 | 0.6, 13.4 † | 0 | 100 | <0.05 | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | | | | | | | | | | 4 | B
Massie 2003^186^ 12406840 | nd [≥15] | nd | 1.5 mo (XO) | | | SF-36 – remainder | 0 | | | | | | 4 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | autoCPAP | 41 | SAQLI | 0 | | | | | | 5 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | | | | | | | | | | 5 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | 1 mo (XO) | CPAP | 41 | | | | | | | | 5 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | | | | | | | | | | | 5 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | autoCPAP | 41 | SAQLI | 0 | | | | | | 5 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | | | | | | | | | | 5 | B
To 2008^181^ 18197915 | 54.3 (nd) [>30] | 13.4 (nd) | 2 mo (XO) | CPAP | 41 | | | | | | | | 5 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | autoCPAP | 30 | SF-36 all | 0 | | | | | | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | | | SF-36 all | 0 | | | | | | 12 | B
Nussbaumer 2006^179^ 16537862 | 41 (20) [>10] | 12.7 (3.3) | 1 mo (XO) | CPAP | 30 | SF-36 all | 0 | | | | | | 12 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | autoCPAP (Autoset T) | 29 | SF-36 all | 0 | | | | | | 7 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | | | | | | | | | | 7 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | autoCPAP (AutoAdjust) | 29 | | | | | | | | 7 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | | | | | | | | | | 7 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | CPAP | 29 | | | | | | | | 7 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | | | | | | | | | | 7 | B
Senn 2003^189^ 14525804 | 46 (23) [>10] | 14.2 (3.8) | 1 mo (XO) | | | Vigilance (OSLER) | 0 | | | | | | 7 | B
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (XO) | autoCPAP | 20 | SF-36 all | 0 | | | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (XO) | | | SF-36 all | 0 | | | | | | 0 | C
Fietze 2007^175^ 17337881 | 42 (26) [≥10] | nd | 1.5 mo (XO) | CPAP | 21 | SF-36 all | 0 | | | | | | 0 | C

* Estimated from reported P value

† Estimated from reported P value

Table 5.5.1 Characteristics of randomized controlled trials of bilevel CPAP vs. CPAP or autoCPAP

Study PMID | Interventions | CPAP Pressure * (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Piper 2008^197^ 18203817 | Bilevel CPAP | manual (nd) | 50 | 64 | 53 | morbidly obese | Australia (nd) | unclear % of central apnea
Piper 2008^197^ 18203817 | CPAP | manual (nd) | 50 | 64 | 53 | morbidly obese | Australia (nd) | unclear % of central apnea
Reeves-Hoche 1995^198^ 7842204 | Bilevel CPAP | manual (separate) | 47 | 73 | 39.4 | - | US (nd) | differential drop out
Reeves-Hoche 1995^198^ 7842204 | CPAP | manual (separate) | 47 | 73 | 39.4 | - | US (nd) | differential drop out
Gay 2003^195^ 14655921 | Bilevel CPAP | manual (split) | 44 | 81 | 35.2 | - | US (nd) | unclear conduct of randomization
Gay 2003^195^ 14655921 | CPAP | manual (split) | 44 | 81 | 35.2 | - | US (nd) | unclear conduct of randomization
Khayat 2008^196^ 18641111 | Bilevel CPAP | manual? (separate) | 53 | nd | 33.6 | AHA II or III | US (2005–07) | small sample; possible selection bias
Khayat 2008^196^ 18641111 | CPAP | manual? (separate) | 53 | nd | 33.6 | AHA II or III | US (2005–07) | small sample; possible selection bias
Randerath 2003^199^ 12942031 | Bilevel CPAP | manual (separate) | 57 | 85 | 33.5 | intolerance to CPAP | Germany (nd) | assumptions on missing pts unclear
Randerath 2003^199^ 12942031 | AutoCPAP | manual (separate) | 57 | 85 | 33.5 | intolerance to CPAP | Germany (nd) | assumptions on missing pts unclear

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.5.2 Compliance (mean hr/night) in randomized controlled trials of bilevel CPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Compliance (hr/night) | Difference | 95% CI | P Btw | Dropout, % | Study Quality
Piper 2008^197^ 18203817 | nd | 14.5 (IQR = 12–19) | 3 mo (PL) | Bilevel CPAP | 18 | 6.1 | 0.33 | −1.8, 1.2 | NS | 0 | B
Piper 2008^197^ 18203817 | nd | 14.5 (IQR = 12–19) | 3 mo (PL) | CPAP | 18 | 5.8 | | | | 0 | B
Reeves-Hoche 1995^198^ 7842204 | 52 (3) [≥10] | nd | 12 mo (PL) | Bilevel CPAP | 26 | 4.9 | −0.1 | −0.52, 0.32 * | NS | 25 | C
Reeves-Hoche 1995^198^ 7842204 | 52 (3) [≥10] | nd | 12 mo (PL) | CPAP | 36 | 5.0 | | | | 25 | C
Gay 2003^195^ 14655921 | 44 (24) [>10] | 12 (3.4) | 1 mo (PL) | Bilevel CPAP | 12 | 5.6 | 0 | nd | NS | 0 | C
Gay 2003^195^ 14655921 | 44 (24) [>10] | 12 (3.4) | 1 mo (PL) | CPAP | 15 | 5.6 | | | | 0 | C
Khayat 2008^196^ 18641111 | 32 (16) [>10] | 12.6 (6.3) | 3 mo (PL) | Bilevel CPAP | 13 | 4.5 | 0.9 | −1.6, 3.4 | NS | 4 | C
Khayat 2008^196^ 18641111 | 32 (16) [>10] | 12.6 (6.3) | 3 mo (PL) | CPAP | 11 | 3.6 | | | | 4 | C
Randerath 2003^199^ 12942031 | 49 (27) [≥ 10] | 12.1 (5.1) | 1.5 mo (XO) | Bilevel CPAP | 27 (?) | 94.4% days used | 4.8 | −3.14, 12.74 † | NS | 26 | C
Randerath 2003^199^ 12942031 | 49 (27) [≥ 10] | 12.1 (5.1) | 1.5 mo (XO) | AutoCPAP | 27 (?) | 89.6% days used | | | | 26 | C

* Estimated from reported data

† Estimated from reported data

Table 5.5.3 ESS in randomized controlled trials of bilevel CPAP vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or diff | 95% CI | P Btw | Dropout, % | Study Quality
Piper 2008^197^ 18203817 | nd | 14.5 (IQR = 12–19) | 3 mo (PL) | Bilevel CPAP | 18 | 14 (IQR 12–19) | −9.0 | −2.89 | −7.56, 1.78 | NS | 0 | B
Piper 2008^197^ 18203817 | nd | 14.5 (IQR = 12–19) | 3 mo (PL) | CPAP | 18 | 15 (IQR 8–17) | −6.0 | | | | 0 | B
Gay 2003^195^ 14655921 | 44 (24) [>10] | 12 (3.4) | 1 mo (PL) | Bilevel CPAP | 12 | 14.2 (3.4) | −6.4 | −0.9 | −3.88, 2.08 * | NS | 0 | C
Gay 2003^195^ 14655921 | 44 (24) [>10] | 12 (3.4) | 1 mo (PL) | CPAP | 15 | 13.5 (3.4) | −5.5 | | | | 0 | C
Khayat 2008^196^ 18641111 | 32 (16) [>10] | 12.6 (6.3) | 3 mo (PL) | Bilevel CPAP | 13 | 11.8 (SE 1.8) | −2.6 | 2.1 | −2.7, 6.9 | NS | 4 | C
Khayat 2008^196^ 18641111 | 32 (16) [>10] | 12.6 (6.3) | 3 mo (PL) | CPAP | 11 | 13.5 (SE 1.8) | −4.7 | | | | 4 | C
Randerath 2003^199^ 12942031 | 49 (27) [≥ 10] | 12.1 (5.1) | 1.5 mo (XO) | Bilevel CPAP | 27 (?) | 12.1 (5.1) | −3.7 | 1.2 | −0.63, 3.03 † | NS | 26 | C
Randerath 2003^199^ 12942031 | 49 (27) [≥ 10] | 12.1 (5.1) | 1.5 mo (XO) | AutoCPAP | 27 (?) | 12.1 (5.1) | −4.9 | | | | 26 | C

* Estimated from reported data

† Estimated from reported data

Table 5.5.4 Quality of life and functional outcomes in randomized controlled trials of bilevel CPAP vs. CPAP

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome measure | Favors | If significant difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome measure | Favors | Net difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome measure | Favors | Net difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Piper 2008^197^ 18203817 | nd | 14.5 (IQR = 12–19) | 3 mo (PL) | Bilevel CPAP | 18 | SF-36 | 0 | | | | | | 0 | B
Piper 2008^197^ 18203817 | nd | 14.5 (IQR = 12–19) | 3 mo (PL) | CPAP | 18 | Mental | 0 | | | | | | 0 | B
Piper 2008^197^ 18203817
Piper 2008^197^ 18203817 | | | | | | SF-36 | 0
Piper 2008^197^ 18203817 | | | | | | Physical
Piper 2008^197^ 18203817 | nd | 14.5 (IQR12–19) | 3 mo (PL) | Bilevel CPAP | 18 | mean of slowest 10% reaction | Bilevel CPAP | net diff of median 0.65 | | | | 0.03 | 0 | B
Piper 2008^197^ 18203817 | nd | 14.5 (IQR12–19) | 3 mo (PL) | CPAP | 18 | mean of slowest 10% reaction | Bilevel CPAP | net diff of median 0.65 | | | | 0.03 | 0 | B
Piper 2008^197^ 18203817
Piper 2008^197^ 18203817 | | | | | | Lapses | 0
Piper 2008^197^ 18203817
Piper 2008^197^ 18203817 | | | | | | Median (ms) | 0
Gay 2003^195^ 14655921 | 44 (24) | 12 | 1 mo (PL) | Bilevel CPAP | 12 | FOSQ | 0 | | | | | | 0 | C
Gay 2003^195^ 14655921 | 44 (24) | 12 | 1 mo (PL) | CPAP | 15 | FOSQ | 0 | | | | | | 0 | C
Khayat 2008^196^ 18641111 | 32 (16) | 12.6 (6.3) | 3 mo (PL) | Bilevel CPAP | 13 | MLHFQ | 0 | | | | | | 4 | C
Khayat 2008^196^ 18641111 | 32 (16) | 12.6 (6.3) | 3 mo (PL) | CPAP | 11 | MLHFQ | 0 | | | | | | 4 | C

Table 5.7.1 Characteristics of randomized controlled trials of C-Flex™ vs. CPAP

Study PMID | Interventions | CPAP Pressure * (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Pepin 2009^203^ 19567496 | C-Flex | auto/manual (separate) | 56 | 72 | 31 | | France (nd)
Pepin 2009^203^ 19567496 | CPAP | auto/manual (separate) | 56 | 72 | 31 | | France (nd)
Nilius 2006^202^ 17035433 | C-Flex | manual (separate) | 57 | 88 | 32.7 | | Germany (nd) | Recruitment unclear
Nilius 2006^202^ 17035433 | CPAP | manual (separate) | 57 | 88 | 32.7 | | Germany (nd) | Recruitment unclear
Dolan 2009^201^ 18551327 | C-Flex | nd (both) | 48 | 75 | 34.9 | | US; Germany (nd) | Incomplete reporting
Dolan 2009^201^ 18551327 | CPAP | nd (both) | 48 | 75 | 34.9 | | US; Germany (nd) | Incomplete reporting
Leidag 2008^204^ 19218664 | C-Flex | manual (separate) | 55 | 73 | 32 | | Germany | High drop out rate
Leidag 2008^204^ 19218664 | CPAP | manual (separate) | 55 | 73 | 32 | | Germany | High drop out rate

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.7.2 Compliance (mean hr/night) in randomized controlled trials of C-Flex™ vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Compliance (hr/night) | Difference | 95% CI * | P Btw | Dropout, % | Study Quality
Pepin 2009^203^ 19567496 | 44 (22) [≥15] | 11.6 (5.2) | 3 mo (PL) | C-Flex | 83 | 4.98 | 0.07 | −0.4, 0.6 | NS | 24 | B
Pepin 2009^203^ 19567496 | 44 (22) [≥15] | 11.6 (5.2) | 3 mo (PL) | CPAP | 82 | 4.91 | | | | 24 | B
Nilius 2006^202^ 17035433 | 53 (21) [>20) | 10.5 (nd) | 1.75 mo (PL) | C-Flex | 25 | 5.3 | 0.1 | −15.5, 15.7 † | 0.99 | 2 | B
Nilius 2006^202^ 17035433 | 53 (21) [>20) | 10.5 (nd) | 1.75 mo (PL) | CPAP | 26 | 5.2 | | | | 2 | B
Dolan 2009^201^ 18551327 | 52 (28) [≥10] | 14.9 (3.6) | 6 mo (PL) | C-Flex | 92 | 6.23 | 0.18 | −0.03, 0.39 | NS | 0? | C
Dolan 2009^201^ 18551327 | 52 (28) [≥10] | 14.9 (3.6) | 6 mo (PL) | CPAP | 92 | 6.05 | | | | 0? | C
Leidag 2008^204^ 19218664 | 35 (25) [≥5] | nd | 1.5 mo (XO) | C-Flex | 25 | 5.78 | −0.05 | −0.52, 0.42 | NS | 40 | C
Leidag 2008^204^ 19218664 | 35 (25) [≥5] | nd | 1.5 mo (XO) | CPAP | 23 | 5.83 | | | | 40 | C

* Estimated from reported data

† Estimated from reported P value

Table 5.7.3 ESS in randomized controlled trials of C-Flex™ vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff | 95% CI | P Btw | Dropout, % | Study Quality
Pepin 2009^203^ 19567496 | 44 (22) [≥15] | 11.6 (5.2) | 3 mo (PL) | C-Flex | 83 | 11.7 (5.1) | −3.9 | −0.5 | −2.1, 1.1 * | NS | 24 | B
Pepin 2009^203^ 19567496 | 44 (22) [≥15] | 11.6 (5.2) | 3 mo (PL) | CPAP | 82 | 11.4 (5.2) | −3.4 | | | | 24 | B
Nilius 2006^202^ 17035433 | 53 (21) [>20) | 10.5 (nd) | 1.75 mo (PL) | C-Flex | 25 | 10.9 (nd) | −5.1 | −1.0 | −10.1, 8.1 † | NS | 2 | B
Nilius 2006^202^ 17035433 | 53 (21) [>20) | 10.5 (nd) | 1.75 mo (PL) | CPAP | 26 | 10.2 (nd) | −4.1 | | | | 2 | B
Dolan 2009^201^ 18551327 | 52 (28) [≥10] | 14.9 (3.6) | 6 mo (PL) | C-Flex | 92 | nd | −6.6 | −0.2 | −0.7, 0.3 ‡ | NS | 0? | C
Dolan 2009^201^ 18551327 | 52 (28) [≥10] | 14.9 (3.6) | 6 mo (PL) | CPAP | 92 | nd | −6.4 | | | | 0? | C

* Estimated from reported data

† Estimated from reported P value

‡ Estimated from reported P value

Table 5.8.1 Randomized controlled trials comparing different aspects of humidification with CPAP or autoCPAP: study characteristics

Study PMID | Interventions | CPAP Pressure * (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Ryan 2009^205^ 19961025 | Heated humidity + CPAP | nd (nd) | 49 | 94 | 34.4 | - | Ireland (nd) | -
Ryan 2009^205^ 19961025 | CPAP | nd (nd) | 49 | 94 | 34.4 | - | Ireland (nd) | -
Neill 2003^208^ 12952257 | Heated humidity + CPAP | manual (both) | 49 | 89 | 34.8 | - | New Zealand (nd) | -
Neill 2003^208^ 12952257 | CPAP | manual (both) | 49 | 89 | 34.8 | - | New Zealand (nd) | -
Massie 1999^209^ 10453869 | Heated humidity + CPAP | manual (both) | 44 | 79 | 37.6 | - | New Zealand (nd) | Differential dropouts between arms; washout period used as control
Massie 1999^209^ 10453869 | Cold passover humidity + CPAP | manual (both) | 44 | 79 | 37.6 | - | New Zealand (nd) | Differential dropouts between arms; washout period used as control
Mador 2005^206^ 16236868 | Heated humidity + CPAP | manual (both) | 59 | 97 | 36 | - | US | Unclear analysis
Mador 2005^206^ 16236868 | CPAP + heated humidity as needed only | manual (both) | 59 | 97 | 36 | - | US | Unclear analysis
Salgado 2008^207^ 18982206 | Heated humidity + AutoCPAP | manual (nd) | 56 | 74 | nd | - | Portugal | Incomplete reporting
Salgado 2008^207^ 18982206 | AutoCPAP | manual (nd) | 56 | 74 | nd | - | Portugal | Incomplete reporting

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.8.2 Compliance (mean hr/night) in randomized controlled trials comparing different aspects of humidification with CPAP or autoCPAP

Study PMID | Baseline AHI (SD) [minimum] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Compliance (hr/night) | Difference | 95% CI | P Btw | Dropout, % | Study Quality
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12.7 (5) | 1 mo (PL) | Heated humidity + CPAP | 42 | 5.21 | 0 | nd | NS | 10 | B
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12.7 (5) | 1 mo (PL) | | | | | | | 10 | B
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12.7 (5) | 1 mo (PL) | CPAP | 39 | 5.21 | | | | 10 | B
Neill 2003^208^ 12952257 | 50 (26) [≥9] | 12.1 (5.1) | 0.75 mo (XO) | Heated humidity + CPAP | 37 | 5.7 | 0.4 | 0.05, 0.76 | 0.03 | 12 | B
Neill 2003^208^ 12952257 | 50 (26) [≥9] | 12.1 (5.1) | 0.75 mo (XO) | | | | | | | 12 | B
Neill 2003^208^ 12952257 | 50 (26) [≥9] | 12.1 (5.1) | 0.75 mo (XO) | CPAP | 37 | 5.3 | | | | 12 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.75 mo (XO) | Heated humidity + CPAP | 38 | 5.52 | 0.37 | nd | NS | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.75 mo (XO) | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.75 mo (XO) | Cold passover humidity + CPAP | 38 | 5.15 | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | Heated humidity + CPAP | 38 | 5.52 | 0.59 | 0.15, 1.03 * | 0.008 | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | CPAP | 38 | 4.93 | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | Cold passover humidity + CPAP | 38 | 5.15 | 0.22 | nd | NS | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | CPAP | 38 | 4.93 | | | | 19 | B
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 1 mo (PL) | Heated humidity + CPAP | 49 | 4.3 | 0 | nd | NS | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 1 mo (PL) | | | | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 1 mo (PL) | CPAP + heated humidity as needed only | 49 | 4.3 | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | | | | | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 12 mo | Heated humidity + CPAP | nd | 4.3 | −0.5 | nd | NS | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 12 mo | | | | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 12 mo | CPAP + heated humidity as needed only | nd | 4.8 | | | | 21 | C
Salgado 2008^207^ 18982206 | 28 (20) [nd] | 11.6 (6.3) | 1 mo (PL) | Heated humidity + AutoCPAP | 17 | 5.3 | 0.1 | nd | NS | 22 | C
Salgado 2008^207^ 18982206 | 28 (20) [nd] | 11.6 (6.3) | 1 mo (PL) | | | | | | | 22 | C
Salgado 2008^207^ 18982206 | 28 (20) [nd] | 11.6 (6.3) | 1 mo (PL) | AutoCPAP | 22 | 5.2 | | | | 22 | C

* Estimated from P value

Table 5.8.3 ESS in randomized controlled trials comparing different aspects of humidification with CPAP or autoCPAP

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff * | 95% CI | P Btw | Dropout, % | Study Quality
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12.7 (5) | 1 mo (PL) | Heated humidity + CPAP | 42 | 13 (6) | −5 | −2 | nd | NS | 10 | B
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12.7 (5) | 1 mo (PL) | | | | | | | | 10 | B
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12.7 (5) | 1 mo (PL) | CPAP | 39 | 12 (5) | −3 | | | | 10 | B
Neill 2003^208^ 12952257 | 50 (26) [≥9] | 12.1 (5.1) | 0.75 mo (XO) | Heated humidity + CPAP | 37 | 12.1 (5.1) | −8 | −0.4 | −1.28, 0.48 † | 0.37 | 12 | B
Neill 2003^208^ 12952257 | 50 (26) [≥9] | 12.1 (5.1) | 0.75 mo (XO) | | | | | | | | 12 | B
Neill 2003^208^ 12952257 | 50 (26) [≥9] | 12.1 (5.1) | 0.75 mo (XO) | CPAP | 37 | 12.1 (5.1) | −7.6 | | | | 12 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.75 mo (XO) | Heated humidity + CPAP | 38 | nd | 6.2 | −1 | nd | NS | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.75 mo (XO) | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.75 mo (XO) | Cold passover humidity + CPAP | 38 | nd | 7.2 | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | Heated humidity + CPAP | 38 | nd | 6.2 | −0.5 | nd | NS | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | CPAP | 38 | nd | 6.7 | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | Cold passover humidity + CPAP | 38 | nd | 7.2 | 0.5 | nd | NS | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | | | | | | | | 19 | B
Massie 1999^209^ 10453869 | 54 (38) [≥10] | nd | 0.5 mo (washout as control CPAP) | CPAP | 38 | nd | 6.7 | | | | 19 | B
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 1 mo (PL) | Heated humidity + CPAP | 49 | 12.9 (5.2) | −2.4 | 0.6 | nd | NS | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 1 mo (PL) | | | | | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 1 mo (PL) | CPAP + heated humidity as needed only | 49 | 14.1 (5.3) | −3 | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | | | | | | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 12 mo | Heated humidity + CPAP | nd | 12.9 (5.2) | −3.9 | 1.4 | nd | NS | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 12 mo | | | | | | | | 21 | C
Mador 2005^206^ 16236868 | 46 (30) [≥10] | 13.5 (5.3) | 12 mo | CPAP + heated humidity as needed only | nd | 14.1 (5.3) | −5.3 | | | | 21 | C
Salgado 2008^207^ 18982206 | 28 (20) [nd] | 11.6 (6.3) | 1 mo (PL) | Heated humidity + autoCPAP | 17 | 11.2 (5.8) | −4.3 | −0.9 | nd | NS | 22 | C
Salgado 2008^207^ 18982206 | 28 (20) [nd] | 11.6 (6.3) | 1 mo (PL) | | | | | | | | 22 | C
Salgado 2008^207^ 18982206 | 28 (20) [nd] | 11.6 (6.3) | 1 mo (PL) | autoCPAP | 22 | 11.9 (6.3) | −5.2 | | | | 22 | C

* In crossover studies, if only data on the final values and the difference in final values are reported (as opposed to changes from baseline and net change), these data are italicized.

† Estimated from reported P value

Table 5.9.1 Randomized controlled trials of mandibular devices vs. control: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Bloch 2000^210^ 10903249 | MAD-1 piece or MAD-2 piece | 51 | nd | 27.4 | | Switzerland | Patient not blinded, selection bias likely, compliance not accounted for, power not reported, no washout
Bloch 2000^210^ 10903249 | No treatment | 51 | nd | 27.4 | | Switzerland | Patient not blinded, selection bias likely, compliance not accounted for, power not reported, no washout
Barnes 2004^140^ 15201136 | Mandibular advancement splint | 47 | 80 | 31.1 | | Australia (nd)
Barnes 2004^140^ 15201136 | Placebo tablet | 47 | 80 | 31.1 | | Australia (nd)
Kato 2000^211^ 10767241 | Oral appliance 2 mm, oral appliance 4 mm, or oral appliance 6 mm | 49 | nd | 28.7 | | Japan (nd) | Interventions not adequately described
Kato 2000^211^ 10767241 | No oral appliance | 49 | nd | 28.7 | | Japan (nd) | Interventions not adequately described
Lam 2007^129^ 17121868 | Conservative management plus MAD | 47 | 79 | 27.3 | | Hong Kong (nd)
Lam 2007^129^ 17121868 | Conservative management | 47 | 79 | 27.3 | | Hong Kong (nd)
Petri 2008^212^ 18482111 | Mandibular advancement appliance | 50 | 81 | 31.1 | | Denmark (nd)
Petri 2008^212^ 18482111 | No treatment | 50 | 81 | 31.1 | | Denmark (nd)

Table 5.9.2 AHI (events/hr) in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-1 piece | 24 | 26.7 (3.3) | −18.8 | −14.7 | −20.0, −9.4 * | <0.05 | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | | | | | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 26.7 (3.3) | −4.1 | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-2 piece | 24 | 26.7 (3.3) | −18 | −13.9 | −19.2, −8.6 † | <0.05 | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | | | | | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 26.7 (3.3) | −4.1 | | | | 0 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 21.3 (1.3, SE) | −16.5 | −6.3 | −10.1, −2.5 ‡ | 0.001 | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | | | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 21.3 (1.3, SE) | −7.3 | | | | 14 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | MAD + conservative management | 34 | 20.9 (1.7, SE) | −10.3 | −11.5 | −17.0, −6.1 § | <0.001 | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | | | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | 19.3 (1.9, SE) | 1.2 | | | | 13 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | Mandibular advancement appliance | 27 | 39.1 (23.8) | −14.1 | −13.1 | −26.6, 0.4 ** | nd | 9 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | | | | | | | | 9 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | No treatment | 29 | 34.3 (26.3) | −0.9 | | | | 9 | B
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | Oral appliance 2 mm | 37 | 26.0, ODI | 17.3 †† | −8.7 | nd | <0.05 | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | | | | | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | No oral appliance | 37 | 26.0 | 26 | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | | | | | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | Oral appliance 4 mm | 37 | 26.0 | 14.7 | −11.3 | nd | <0.05 | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | | | | | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | No oral appliance | 37 | 26.0 | 26 | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | | | | | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | Oral appliance 6 mm | 37 | 26.0 | 10.8 | −15.2 | nd | <0.05 | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | | | | | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | No oral appliance | 37 | 26.0 | 26 | | | | 13 | C

* Estimated from reported data.

† Estimated from reported data.

‡ Estimated from reported P value.

§ Estimated from reported data.

** Estimated from reported data.

†† Median

Table 5.9.3 ESS in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-1 piece | 24 | 11.9 (0.8) | 9 median | −4.5 * | nd | <0.001 | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | | | | | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 11.9 (0.8) | 13.5 median | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-2 piece | 24 | 11.9 (0.8) | 9 median | −4.5 | nd | <0.001 | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | | | | | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 11.9 (0.8) | 13.5 median | | | | 0 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 10.7 (0.4) | −1.5 | −1 | −1.6, −0.4 † | 0.001 | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | | | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 10.7 (0.4) | −0.5 | | | | 14 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | MAD + conservative management | 34 | 12 (1) | −3 | −1 | −1.5, −0.5 ‡ | <0.05 | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | | | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | 12 (1) | −2 | | | | 13 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | Mandibular advancement appliance | 27 | 11.7 (4.3) | −3.3 | −2.6 | −3.3, 0.1 § | <0.05 | 9 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | | | | | | | | 9 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | No treatment | 29 | 10.7 (4.6) | −0.7 | | | | 9 | B

* Difference of medians

† Estimated from reported P value.

‡ Estimated from reported data.

§ Estimated from reported data.

Table 5.9.4a Minimum oxygen saturation (%) in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | Oral appliance 2 mm | 37 | 87.2 | (89.2) medians | 2.0 * | nd | <0.05 | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | No oral appliance | 37 | 87.2 | (87.2) | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | Oral appliance 4 mm | 37 | 87.2 | (89.5) | 2.3 | nd | <0.05 | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | No oral appliance | 37 | 87.2 | (87.2) | | | | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | Oral appliance 6 mm | 37 | 87.2 | (89.6) | 2.4 | nd | <0.05 | 13 | C
Kato 2000^211^ 10767241 | nd | nd | 8 nights (PL) | No oral appliance | 37 | 87.2 | (87.2) | | | | 13 | C
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | MAD + conservative management | 34 | 73.8 (1.9, SE) | 7.2 | 5.9 | 0.1, 11.7 † | NS | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | 76.1 (2.6) | 1.3 | | | | 13 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 86.7 (0.6) | 1.1 | 2.4 | 1.0, 3.8 ‡ | 0.001 | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 86.7 (0.6) | −1.3 | | | | 14 | B

* Differences between final median values.

† Estimated from reported data

‡ Estimated from reported P value.

Table 5.9.4b Arousal index (events/hr) in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-1 piece | 24 | 36 (4.3) | 26.5 | −14.5 | −22.6, −6.4 * | <0.05 | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | | | | | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 36 (4.3) | 41 | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-2 piece | 24 | 36 (4.3) | 30.9 | −10.1 | −17.9, −2.3 † | NS | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | | | | | | | | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 36 (4.3) | 41 | | | | 0 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 22.0 (1.2) | 1.8 | −1.4 | −3.6, 0.8 ‡ | NS | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | | | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 22.0 (1.2) | 3.2 | | | | 14 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | MAD + conservative management | 34 | 24.5 (2.2) | −2.9 | −8.2 | −14.8, −1.6 § | <0.05 | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | | | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | 23.5 (2.2) | 5.3 | | | | 13 | B

* Estimated from reported data.

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data.

Table 5.9.4c Sleep efficiency (%) in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-1 piece | 24 | 85 (2) | 3 | −1 | −4.9, 2.9 * | NS | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-2 piece | 24 | 85 (2) | 4 | 0 | −3.4, 3.4 † | NS | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 85 (2) | 4 | | | | 0 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 79.5 (1.1) | 2.5 | 1.3 | −0.6, 3.2 ‡ | NS | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 79.5 (1.1) | 1.2 | | | | 14 | B

* Estimated from reported data.

† Estimated from reported data.

‡ Estimated from reported data

Table 5.9.4d Slow wave sleep (%) in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-1 piece | 24 | nd | 18 | nd | nd | <0.05 | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-2 piece | 24 | nd | 16 | nd | nd | NS | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | nd | 12 | | | | 0 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 17.9 (1.2) | 2.8 | 0.6 | −0.6, 3.8 * | NS | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 17.9 (1.2) | 2.2 | | | | 14 | B

* Estimated from reported data

Table 5.9.4e REM sleep (%) in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-1 piece | 24 | 13 (1) | 2 | 1 | −1.0, 3.0 * | NS | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | MAD-2 piece | 24 | 13 (1) | 3 | 2 | 0.04, 4.0 † | NS | 0 | B
Bloch 2000^210^ 10903249 | 27 (16) [≥5] | 11.9 (3.9) | 1 wk (XO) | No treatment | 24 | 13 (1) | 1 | | | | 0 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | 18.8 (0.7) | 0.1 | 0.9 | −0.3, 2.1 ‡ | NS | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | 18.8 (0.7) | 1 | | | | 14 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | Mandibular advancement appliance | 27 | 18.4 (5.6) | 0.3 | −0.7 | −2.1, 2.4 § | nd | 9 | B
Petri 2008^212^ 18482111 | 34 (26) [>5] | 10.7 (4.6) | 4 wk (PL) | No treatment | 29 | 17.5 (6.2) | 1 | | | | 9 | B

* Estimated from reported data.

† Estimated from reported data.

‡ Estimated from reported data.

§ Estimated from reported data.

Table 5.9.5 Quality of life outcomes in randomized controlled trials of mandibular devices vs. control

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Diff | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Diff | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Mandibular advancement splint | 80 | Beck Depression Inventory | 0 | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | | | Beck Depression Inventory | 0 | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | Placebo tablet | 80 | Beck Depression Inventory | 0 | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | | | | | | | | | | 14 | B
Barnes 2004^140^ 15201136 | 21 (13) [nd] | 10.7 (4.1) | 3 mo (XO) | | | FOSQ social domain outcome | 0 | | | | | | 14 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management plus MAD | 34 | SAQLI- social interactions, treatment- related symptoms | 0 | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | | | SAQLI- social interactions, treatment- related symptoms | 0 | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | | | SAQLI- social interactions, treatment- related symptoms | 0 | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | | | | | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | SAQLI score * | Conservative management plus MAD | 0.7 | 0.6, 0.8 † | 1 | 7 | <0.001 | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | | | | | | | | 13 | B
Lam 2007^129^ 17121868 | 19 (11) [5–40] | 12 (5.7) | 10 wk (PL) | Conservative management | 33 | SF-36 All | 0 | | | | | | 13 | B

* Domain A-D, not including treatment-related symptoms

† Estimated from reported data

Table 5.10.1 Randomized controlled trials of mandibular advancement devices vs. inactive oral devices: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Major quality issues
Hans 1997^213^ 9155816 | MAD | 51 | 83 | 29 | -- | US (nd) | Blinding not reported; no power analysis; dropout rate 30%
Hans 1997^213^ 9155816 | Sham oral appliance | 51 | 83 | 29 | -- | US (nd) | Blinding not reported; no power analysis; dropout rate 30%
Johnston 2002^216^ 12143089 | MAD | 55 | 81 | 32 | -- | Ireland (nd)
Johnston 2002^216^ 12143089 | MAD Placebo | 55 | 81 | 32 | -- | Ireland (nd)
Mehta 2001^218^ 11371418 | MAD | 48 | 79 | 29 | -- | Australia (nd) | Blinding not reported
Mehta 2001^218^ 11371418 | Lower dental plate | 48 | 79 | 29 | -- | Australia (nd) | Blinding not reported
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^12204875 Gotsopoulos 2004^215^15453552 | MAD | 48 | 81 | 29 | -- | Australia (nd)
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^12204875 Gotsopoulos 2004^215^15453552 | Single upper plate | 48 | 81 | 29 | -- | Australia (nd)
Petri 2008^212^ 18482111 | MAD | 50 | 81 | 31 | -- | Denmark (nd)
Petri 2008^212^ 18482111 | Non- advancement MAD | 50 | 81 | 31 | -- | Denmark (nd)

Table 5.10.2 AHI (events/hr) in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Johnston 2002^216^ 12143089 | 31 (nd) [nd] | 30.7 (nd) | 4–6 wk (X0) | AHI | MAD | 20 | 31.9 (21.2) | −9.07 | −14.8 | −26.2, −3.4 | 0.011 | 5 | B
Johnston 2002^216^ 12143089 | 31 (nd) [nd] | 30.7 (nd) | 4–6 wk (X0) | AHI | MAD Placebo | 20 | 31.9 (21.18) | 5.75 | | | | 5 | B
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | AHI | MAD | 24 | 27 (17) | −13 | −16 | −24.1,−7.9 * | <0.0001 | 14 | B
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | AHI | Lower dental plate | 24 | 27 (17) | 3 | | | | 14 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5) | 4 wk (X0) | AHI | MAD | 73 | 26.9 (15.4) | −14.7 | −13.2 | −21.1, −5.3 † | <0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5) | 4 wk (X0) | AHI | Single upper plate | 73 | 26.9 (15.4) | −1.5 | | | | 0 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | AHI | MAD | 27 | 39.1 (23.8) | −14.1 | −13.1 | −26.0, 0.0 ‡ | <0.05 | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | AHI | Non- advancement MAD | 25 | 32.6 (22) | −0.9 | | | | 9 | B
Hans 1997^213^ 9155816 | RDI 36 (43) [RDI <30] | 12.5 (5.7) | 2 wk (X0) | RDI | MAD-A | 17 | 28.4 (21.1) | −14.5 | −24.8 | −41.9, −7.6 § | <0.0045 | 29 | C
Hans 1997^213^ 9155816 | RDI 36 (43) [RDI <30] | 12.5 (5.7) | 2 wk (X0) | RDI | Sham oral | 17 | 43.7 (46.8) | 10.3 | | | | 29 | C

* Estimated from reported P value

† Estimated from reported P value

‡ Estimated from reported P value

§ Estimated from reported P value

Table 5.10.3 ESS in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Johnston 2002^216^ 12143089 | 31 (nd) [nd] | 30.7 (nd) | 4–6 wk (X0) | MAD | 18 | 13.9 (6.39) | −2.29 | −0.94 | −3.32,1.43 | NS | 5 | B
Johnston 2002^216^ 12143089 | 31 (nd) [nd] | 30.7 (nd) | 4–6 wk (X0) | MAD Placebo | 18 | 13.9 (6.39) | −1.34 | | | | 5 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MAD | 73 | 10.9 (4.8) | −3.8 | −2 | −3.1, −0.8 * | <0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | Single upper plate | 73 | 10.9 (4.8) | −1.8 | | | | 0 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | MAD | 27 | 11.7 (4.3) | −3.3 | −2.1 † | −4.4,0.2 ‡ | nd | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | Non- advancement MAD | 25 | 10.8 (4.6) | −1.2 | | | | 9 | B
Hans 1997^213^ 9155816 | RDI 36 (43) [RDI <30] | 12.5 (5.7) | 2 wk (X0) | MAD-A | 17 | 12.1 (3.9) | −3.8 | −3.3 | −6.4,−0.2 § | NS | 29 | C
Hans 1997^213^ 9155816 | RDI 36 (43) [RDI <30] | 12.5 (5.7) | 2 wk (X0) | Sham oral | 17 | 13.0 (4.5) | −0.5 | | | | 29 | C

* Estimated from reported P value

† Estimated from reported P value

‡ Estimated from reported data

§ Estimated from reported P value. our estimates does not match reported NS

Table 5.10.4 Minimum oxygen saturation (%) in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Intervention | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | MAD | 24 | 85 (8) | 6 | 4 | 1.9, 6.0 * | <0.0001 | 14 | B
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | Lower dental plate | 24 | 85 (8) | 2 | | | | 14 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MAD | 73 | 85.7 (5.6) | 3 | 2.3 | 0.5, 4.0 † | <0.01 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | Single upper plate | 73 | 85.7 (5.6) | 0.7 | | | | 0 | B

* Estimated from reported P value

† Estimated from reported P value

Table 5.10.5 Arousal index (events/hr) in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | MAD | 24 | nd | 27 | −14 | −21.1, −6.6 * | <0.0001 | 14 | B
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | Lower dental plate | 24 | nd | 41 | | | | 14 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MAD | 73 | 35 (13.5) | −10 | −8.1 | −12.4, −3.2 † | <0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | Single upper plate | 73 | 35 (13.5) | −1.9 | | | | 0 | B

* Estimated from reported P value

† Estimated from reported P value

Table 5.10.6 Sleep efficiency (%) in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | MAD | 24 | nd | 85 | −2 | nd | nd | 14 | B
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | Lower dental plate | 24 | nd | 87 | | | | 14 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MAD | 73 | 80.6 (12) | 3 | 1.8 | −2.1, 5.6 * | nd | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | Single upper plate | 73 | 80.6 (12) | 1.2 | | | | 0 | B

* Estimated from reported data

Table 5.10.7 Changes in REM and slow wave sleep (%) in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net diff or Diff | 95% CI | P Btw | Dropout % | Study Quality
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | REM | MAD | 24 | nd | 21 | 5 | 1.5, 8.5 * | <0.005 | 14 | B
Mehta 2001^218^ 11371418 | 27 (17) [10–68] | nd | 1 wk (XO) | REM | Lower dental plate | 24 | nd | 16 | | | | 14 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | REM | MAD | 27 | 18.4 (5.6) | 0.3 | −0.4 | −3.7, 2.9 † | nd | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | REM | Non- advancement MAD | 25 | 16.8 (7.5) | 0.7 | | | | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | Stage 3 | MAD | 27 | 7 (5) | 2.1 | 2.9 | 0.1, 5.7 ‡ | nd | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | Stage 3 | Non- advancement MAD | 25 | 9.9 (5.1) | −0.8 | | | | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | Stage 4 | MAD | 27 | 10.2 (10.5) | 2.2 | −1.2 | −6.6, 4.2 § | nd | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | Stage 4 | Non- advancement MAD | 25 | 9.6 (10.3) | 3.4 | | | | 9 | B

* Estimated from reported P value

† Estimated from reported data

‡ Estimated from reported P value

§ Estimated from reported data

Table 5.10.8 Other outcomes (see 5th column) in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MSLT | MAD | 73 | nd | 10.3(0.5) | nd | nd | 0.01 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MSLT | Single upper plate | 73 | nd | 9.1(0.5) | | | | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | 24 hour systolic BP | MAD | 61 | 127.3 (1.3) * | −2.1 | −1.5 | −3.0, −0.0 † | 0.05 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | 24 hour systolic BP | Single upper plate | 61 | 127.3 (1.3) ‡ | −0.6 | | | | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | 24 hour diastolic BP | MAD | 61 | 77 (0.9) § | −1.3 | −1.6 | −2.5, −0.6 ** | 0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | 24 hour diastolic BP | Single upper plate | 61 | 77 (0.9) †† | 0.3 | | | | 0 | B

* Mean(SE)

† Estimated from reported P value

‡ Mean(SE)

§ Mean(SE)

** Estimated from reported P value

†† Mean(SE)

Table 5.10.9 Functional outcomes in randomized controlled trials of mandibular advancement devices vs. inactive oral devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net diff | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net diff | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | MAD | 27 | SF-36 Vitality * | MAD | 18.7 | nd | 0 | 100 | 0.001 | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | | | SF-36 Vitality * | MAD | 18.7 | nd | 0 | 100 | 0.001 | 9 | B
Petri 2008^212^ 18482111 | 35 (nd) [>5] | 11.0 (nd) | 4 wk (PL) | Nonadvancement MAD | 25 | SF-36 Vitality * | MAD | 18.7 | nd | 0 | 100 | 0.001 | 9 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | MAD | 73 | Neuro-psychological † (speed/vigilance- Choice reaction time) | MAD | −0.019 | nd | | | 0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | | | Neuro-psychological † (speed/vigilance- Choice reaction time) | MAD | −0.019 | nd | | | 0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | Single upper plate | 73 | Neuro-psychological † (speed/vigilance- Choice reaction time) | MAD | −0.019 | nd | | | 0.001 | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | | | | | | | | | | 0 | B
Naismith 2005^217^ 17564405 Gotsopoulos 2002^214^ 12204875 Gotsopoulos 2004^215^ 15453552 | 25 (13) [≥10] | 11.0 (5.0) | 4 wk (X0) | | | Beck Depression inventory (somatic items) ‡ | MAD | −0.6 | nd | | | <0.05 | 0 | B

* P value for all other domains Not Significant

† P value for other Neuropschological tests Not Significant.

‡ P value for other items on Beck Depression Inventory Not significant

Table 5.11.1 Randomized controlled trials of mandibular advancement devices vs. mandibular advancement devices: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Major quality issues
Campbell 2009^219^ 18989715 | MAD objective * | 47 | 86 | 28.0 | BMI<35 Kg/m^2^ | New Zealand (nd) | -
Campbell 2009^219^ 18989715 | MAD subjective † | 47 | 86 | 28.0 | BMI<35 Kg/m^2^ | New Zealand (nd) | -
Deane 2009^222^ 19480232 | MAD | 49 | 59 | 29.3 | | Australia (nd) | -
Deane 2009^222^ 19480232 | TSD | 49 | 59 | 29.3 | | Australia (nd) | -
Dort 2008^223^ 18461376 | Suction TRD | 48 | 69 | 29.4 | | Canada (nd) | -
Dort 2008^223^ 18461376 | Non suction TRD | 48 | 69 | 29.4 | | Canada (nd) | -
Vanderveken 2008^221^ 17673699 | MAD _cm_ ‡ | 47 | 84 | 28.0 | SDB, history of surgery § | Belgium (2003–04) | -
Vanderveken 2008^221^ 17673699 | MAD _tp_ ** | 47 | 84 | 28.0 | SDB, history of surgery § | Belgium (2003–04) | -
Walker Engstrom 2003^220^ 14569523 | 50% MAD †† | 46 | 100 | 30.2 | -- | Sweden 1998–2000) | -
Walker Engstrom 2003^220^ 14569523 | 75% MAD ‡‡ | 46 | 100 | 30.2 | -- | Sweden 1998–2000) | -

* “objective adjustment” at 3 weeks following PSG-based feedback

† self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

‡ Custom made mandibular advancement device

§ Some patients had refused CPAP treatment and others had a history of unsuccessful UPPP

** Pre- molded thermoplastic mandibular advancement device

†† 50% mandibular advancement (mean mandibular advancement 5.0 mm)

‡‡ 75% of mandibular advancement (mean mandibular advancement 7.2 mm)

Table 5.11.2 AHI (events/hr) in randomized controlled trials of mandibular advancement devices vs. mandibular advancement devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95 % CI | P Btw | Dropout, % | Study Quality
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | MAD objective * | 12 | 26.6 (12) | −14.9 | −3.8 | −11.4, 3.9 † | nd | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | MAD subjective ‡ | 16 | 25.4 (7.4) | −11.1 | | | | 6 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8.0 (5.0) | 4 mo (XO) | MAD _cm_ § | 23 | 14 (12) | −8 | −5 | −8.5, −1.5 ** | nd | 8 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8.0 (5.0) | 4 mo (XO) | MAD _tp_ †† | 23 | 14 (12) | −3 | | | | 8 | B
Walker Engstrom 2003^220^ 14569523 | 50 (4) [≥20] | 11.5 (3.1) | 6 mo (PL) | 50% MAD ‡‡ | 37 | 47.0 (5.1) | −29.6 | 5.2 | 2.7,7.6 §§ | NS | 8 | B
Walker Engstrom 2003^220^ 14569523 | 50 (4) [≥20] | 11.5 (3.1) | 6 mo (PL) | 75% MAD *** | 40 | 50.4 (4.7) | −34.8 | | | | 8 | B

* objective adjustment at 3 weeks following PSG-based feedback

† Estimated from reported data

‡ self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

§ Custom made mandibular advancement device

** Estimated from reported data

†† Pre- molded thermoplastic mandibular advancement device

‡‡ 50% mandibular advancement (mean mandibular advancement 5.0 mm)

§§ Estimated from reported data; our estimates do not match with reported NS

*** 75% of mandibular advancement (mean mandibular advancement 7.2 mm)

Table 5.11.3 AHI (events/hr) in randomized controlled trials of mandibular advancement devices vs. mandibular advancement devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | n Event | N Total | Outcome Metric | Result * | 95% CI | P Btw | Dropout, % | Study Quality
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | AHI<5 | MAD objective † | 3.9 | 12 | % | 33.0 vs. 12.5 | nd | NS | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | AHI<5 | MAD subjective ‡ | 1.9 | 16 | | | | | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | Improvement percentage § | MAD objective ** | 5.0 | 12 | % | 42.0 vs. 56.2 | nd | NS | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | Improvement percentage § | MAD subjective †† | 8.9 | 16 | | | | | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | Failure percentage ‡‡ | MAD objective §§ | 3.0 | 12 | % | 25.0 vs. 31.2 | nd | NS | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | Failure percentage ‡‡ | MAD subjective *** | 4.9 | 16 | | | | | 6 | B

* Top row intervention vs. bottom row intervention.

† objective adjustment at 3 weeks following PSG-based feedback

‡ self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

§ >50% reduction in AHI but still >5/hr

** objective adjustment at 3 weeks following PSG-based feedback

†† self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

‡‡ AHI decreased by <50%

§§ objective adjustment at 3 weeks following PSG-based feedback

*** self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

Table 5.11.4 ESS in randomized controlled trials of mandibular advancement devices vs. mandibular advancement devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | MAD objective * | 12 | 11.0(5.3) | −1.5 | 2.3 | −1.4, 6.0 † | nd | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6 wk (PL) | MAD subjective ‡ | 16 | 11.6(4.7) | −3.8 | | | | 6 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8 (5) | 4mo (XO) | MAD _cm_ § | 23 | 7(5) | −2 | 0 | −1.6, 1.6 ** | nd | 8 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8 (5) | 4mo (XO) | MAD _tp_ †† | 23 | 7(5) | −2 | | | | 8 | B
Walker Engstrom 2003^220^ 14569523 | 50 (4) [≥20] | 11.5 (3.1) | 6 mo(PL) | 50% MAD ‡‡ | 37 | 11.7(3.1) | −3.1 | 0.9 | −0.4, 2.2 | nd | 8 | B
Walker Engstrom 2003^220^ 14569523 | 50 (4) [≥20] | 11.5 (3.1) | 6 mo(PL) | 75% MAD §§ | 40 | 11.5(3.1) | −4 | | | | 8 | B

* objective adjustment at 3 weeks following PSG-based feedback

† Estimated from reported data

‡ self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

§ Custom made mandibular advancement device

** Estimated from reported data

†† Pre- molded thermoplastic mandibular advancement device

‡‡ 50% mandibular advancement (mean mandibular advancement 5.0 mm)

§§ 75% of mandibular advancement (mean mandibular advancement 7.2 mm)

Table 5.11.5 Other outcomes reported in randomized controlled trials of mandibular advancement devices vs. mandibular advancement devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6wk (PL) | Arousal index | MAD objective * | 12 | 33.6(10) | −9.4 | 0.5 | −7.3,8.3 † | nd | 6 | B
Campbell 2009^219^ 18989715 | 25 (7) [10–40] | 11.6 (4.7) | 6wk (PL) | Arousal index | MAD subjective ‡ | 16 | 32.1(13.3) | −9.9 | | | | 6 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8 (5) | 4 mo (XO) | Minimum oxygen saturation | MAD _cm_ § | 23 | 83 (7) | −1 | 0 | −3.2,3.2 ** | nd | 8 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8 (5) | 4 mo (XO) | Minimum oxygen saturation | MAD _tp_ †† | 23 | 83 (7) | −1 | | | | 8 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8 (5) | 4 mo (XO) | Sleep efficiency | MAD _cm_ ‡‡ | 23 | 78(11) | 2 | −1 | −5.7,3.7 §§ | nd | 8 | B
Vanderveken 2008^221^ 17673699 | 13 (11) [<40] | 8 (5) | 4 mo (XO) | Sleep efficiency | MAD _tp_ *** | 23 | 78(11) | 3 | | | | 8 | B

* objective adjustment at 3 weeks following PSG-based feedback

† Estimated from reported data

‡ self-adjustment of mandibular advancement device during the entire study duration (6 weeks)

§ Custom made mandibular advancement device

** Estimated from reported data

†† Pre- molded thermoplastic mandibular advancement device

‡‡ Custom made mandibular advancement device

§§ Estimated from reported data

*** Pre- molded thermoplastic mandibular advancement device

Table 5.11.6 Outcomes randomized controlled trials of mandibular advancement devices vs. tongue-retaining devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | AHI | MAD | 22 | 27 (17) | −15 | −1 | −9.7, 7.7 * | nd | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | AHI | TSD | 22 | 27 (17) | −14 | | | | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | Minimum O_2_ sat | MAD | 22 | 84 (7) | 3 | −1 | −4.7, 2.7 † | nd | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | Minimum O_2_ sat | TSD | 22 | 84 (7) | 4 | | | | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | Arousal index | MAD | 22 | 33 (16) | −12 | 0 | nd | nd | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | Arousal index | TSD | 22 | 33 (16) | −12 | | | | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | Sleep efficiency | MAD | 22 | 80 (11) | −2 | −1 | −8.7, 6.7 ‡ | nd | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | Sleep efficiency | TSD | 22 | 80 (11) | −1 | | | | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | REM | MAD | 22 | nd | 18 | 1 | nd | NS | 19 | B
Deane 2009^222^ 19480232 | 27.0(nd) [>10] | nd | 1 wk (XO) | REM | TSD | 22 | nd | 17 | | | | 19 | B

† Estimated from reported data

* Estimated from reported data

‡ Estimated from reported data

Table 5.11.7 Outcomes randomized controlled trials of tongue-retaining devices vs. tongue-retaining devices

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Dort 2008^223^ 18461376 | nd [RDI 5–30] | 12.4 (nd) | 1 wk (XO) | SQALI | Suction TRD | 32 | 3.9 (1.2) | 0.3 | 0.28 | −0.93,0.31 | NS | nd | C
Dort 2008^223^ 18461376 | nd [RDI 5–30] | 12.4 (nd) | 1 wk (XO) | SQALI | Non suction TRD | 32 | 3.9 (1.2) | 0 | | | | nd | C
Dort 2008^223^ 18461376 | nd [RDI 5–30] | 12.4 (nd) | 1 wk (XO) | AHI | Suction TRD | 32 | 15.5(17.6) | −6.6 | −4.9 | −8.9,−0.85 | 0.019 | nd | C
Dort 2008^223^ 18461376 | nd [RDI 5–30] | 12.4 (nd) | 1 wk (XO) | AHI | Non suction TRD | 32 | 15.5(17.6) | −2.0 | | | | nd | C
Dort 2008^223^ 18461376 | nd [RDI 5–30] | 12.4 (nd) | 1 wk (XO) | ESS | Suction TRD | 32 | 12.4(4.5) | −1.5 | 0.65 | −0.47, 1.8 | NS | nd | C
Dort 2008^223^ 18461376 | nd [RDI 5–30] | 12.4 (nd) | 1 wk (XO) | ESS | Non suction TRD | 32 | 12.4(4.5) | −21 | | | | nd | C

Table 5.12.1 Randomized controlled trials of mandibular advancement devices vs. CPAP: study characteristics

Study PMID | Interventions | CPAP Pressure * (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Major quality issues
Barnes 2004^140^ 15201136 | MAD (Medical Dental Sleep Appliance) | nd (nd) | 47 | 80 | 31.1 | Excluded diabetes | Australia (nd)
Barnes 2004^140^ 15201136 | CPAP | nd (nd) | 47 | 80 | 31.1 | Excluded diabetes | Australia (nd)
Clark 1996^224^ 8769497 | MAD, custom | nd (separate) | 47 | 100 | 28.1 | -- | Israel (1991–92) | Failed crossover design
Clark 1996^224^ 8769497 | CPAP | nd (separate) | 47 | 100 | 28.1 | -- | Israel (1991–92) | Failed crossover design
Engleman 2002^225^ 12231497 | MAD, custom | nd (split) | 46 | 75 | nd | -- | UK (nd)
Engleman 2002^225^ 12231497 | CPAP | nd (split) | 46 | 75 | nd | -- | UK (nd)
Ferguson 1996^226^ 8625679 | MAD (Snore- Guard) | nd (separate) | 46 | 88 | 30.4 | -- | Canada (1991–94)
Ferguson 1996^226^ 8625679 | CPAP | nd (separate) | 46 | 88 | 30.4 | -- | Canada (1991–94)
Gagnadoux 2009^227^ 19324954 | MAD (AMC) | manual (split) | 50 | 61 | 26.7 | -- | France (nd)
Gagnadoux 2009^227^ 19324954 | CPAP | manual (split) | 50 | 61 | 26.7 | -- | France (nd)
Hoekema 2007^231^ 17081222 Hoekema 2008^230^ 18719218 | MAD (Thornton Adjustable Positioner) | nd (separate) | 49 | 89 | 33.3 | -- | Netherlands (2002–05)
Hoekema 2007^231^ 17081222 Hoekema 2008^230^ 18719218 | CPAP | nd (separate) | 49 | 89 | 33.3 | -- | Netherlands (2002–05)
Lam 2007^129^ 17121868 | MAD, custom | nd (nd) | 45 | 78 | 27.5 | Excluded previous surgery | Hong Kong (nd)
Lam 2007^129^ 17121868 | CPAP | nd (nd) | 45 | 78 | 27.5 | Excluded previous surgery | Hong Kong (nd)
Randerath 2002^228^ 12171833 | MAD (Hinz IST) | manual (nd) | 57 | 80 | 31.2 | -- | Germany (1999)
Randerath 2002^228^ 12171833 | CPAP | manual (nd) | 57 | 80 | 31.2 | -- | Germany (1999)
Skinner 2004^232^ 14718430 | Cervicomandibular support collar | auto (nd) | 49 | 80 | 34.1 | -- | New Zealand (nd) | Study stopped with ½ sample size due to lack of objective benefit
Skinner 2004^232^ 14718430 | AutoCPAP | auto (nd) | 49 | 80 | 34.1 | -- | New Zealand (nd) | Study stopped with ½ sample size due to lack of objective benefit
Tan 2002^229^ 12143088 | MAD, custom | manual (nd) | 51 | 83 | 31.9 | Excluded recent CVD | UK (nd)
Tan 2002^229^ 12143088 | CPAP | manual (nd) | 51 | 83 | 31.9 | Excluded recent CVD | UK (nd)

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, eg if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 5.12.2 Treatment response in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome (subgroup) | Interventions | n Event | N Total | Metric | Result * | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | Effective Treatment † (Total) | MAD | 39 | 51 | RD | −6.2% | −22, 9.4 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | Effective Treatment † (Total) | CPAP | 43 | 52 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI≤30) | MAD | 21 | 25 | RD | +4.0% | −18, 25 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI≤30) | CPAP | 20 | 25 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI>30) | MAD | 18 | 26 | RD | −1.6% | −37, 6.8 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI>30) | CPAP | 23 | 27 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | AHI<5 (Total) | MAD | 29 | 51 | RD | −20.0% | −37, −1.9 | 0.02 ‡ | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | AHI<5 (Total) | CPAP | 40 | 52 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI≤30) | MAD | 21 | 25 | RD | +4.0% | −18, 25 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI≤30) | CPAP | 20 | 25 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI>30) | MAD | 8 | 26 | RD | −43.3% | −62, −17 | <0.001 § | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI>30) | CPAP | 20 | 27 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | AHI<10 ** (Total) | MAD | 31 | 44 | RD | −4.5% | −23, 14 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | AHI<10 ** (Total) | CPAP | 33 | 44 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI≤30) | MAD | 16 | 18 | RD | +18.3% | −8.7, 43 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI≤30) | CPAP | 12 | 17 | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI>30) | MAD | 15 | 26 | RD | −20.1% | −42, 4.9 | NS | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR 60–88 d] (PL) | (AHI>30) | CPAP | 21 | 27 | | | | | 4 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | Complete Response †† | MAD | 12 | 28 | RD ‡‡ | −28.6% | −53, −3.8 | 0.02 §§ | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | Complete Response †† | CPAP | 20 | 28 | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | Partial *** or Complete Response | MAD | 26 | 28 | RD ††† | −3.6% | −15, 8.2 | NS ‡‡‡ | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | Partial *** or Complete Response | CPAP | 27 | 28 | | | | | 0 | B

* Top row intervention vs. bottom row intervention.

† AHI<5 or >50% reduction to an AHI<20 without symptoms

‡ Estimated from confidence interval

§ Estimated from confidence interval

** Excluding 15 participants who had AHI<10 at baseline.

†† ≥50% reduction in AHI to <5

‡‡ Calculated from reported data

§§ Calculated from reported data

*** ≥50% reduction in AHI to ≥5

††† Calculated from reported data

‡‡‡ Calculated from reported data

Table 5.12.3 AHI (events/hr) in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | 39.4 (30.8) | 2.2 (0, 9.5) † | -- | -- | 0.006 ‡ | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | 40.3 (27.6) | 0 (0, 3.0) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 21.3 (11.6) | 14.0 (9.8) | 9.2 | 7.3, 11.1 § | <0.05 | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 21.3 (11.6) | 4.8 (4.5) | | | | 23 | B
Lam 2007^129^ 17121868 | 24 (6) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | 20.9 (9.9) | 10.6 (9.9) | 10.7 | 6.1, 15.4 ** | <0.001 | 0 | B
Lam 2007^129^ 17121868 | 24 (6) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | 23.8 (11.1) | 2.8 (6.4) | | | | 0 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | MAD | 19 | 19.7 (13.8) | 9.7 (7.3) | 4.0 | −3.7, 11.7 †† | nd | 24 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | CPAP | 20 | 17.6 (13.2) | 3.6 (1.7) | | | | 24 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | MAD | 28 | 34.2 (13.0) | 6 (nd) | 4 | 1.6, 6.4 ‡‡ | 0.001 | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | 34.2 (13.0) | 2 (nd) | | | | 0 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | MAD | 24 | 22.2 (9.6) | 8.0 (10.9) | 4.9 | 1.0, 8.8 §§ | NS | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | CPAP | 24 | 22.2 (9.6) | 3.1 (2.8) | | | | 12 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | MAD | 20 | 17.5 (7.7) | 13.8 (11.1) | 10.6 | 2.5, 18.7 *** | 0.01 | 0 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | CPAP | 20 | 17.5 (7.7) | 3.2 (2.9) | | | | 0 | B
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | MAD | 21 | 33.86 (14.30) | 19.94 (12.75) | 8.8 | 4.0, 13.6 ††† | nd | 4 | C
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | CPAP | 21 | 33.86 (14.30) | 11.15 (3.93) | | | | 4 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 29.4 (13.4) | 26.9 (17.2) | 16.9 | 6.8, 27.0 ‡‡‡ | 0.001 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 29.4 (13.4) | 9.9 (8.0) | | | | 0 | C

* Baseline/Final

† Median (IQR)

‡ Statistical analysis of final values. By Mann-Whitney test. Skewed distribution.

§ Estimated from reported SE’s.

** Estimated from reported SE’s.

†† Estimated from reported SD’s.

‡‡ Estimated from reported P value.

§§ Estimated from reported SD’s. Our estimate does not match with reported significance.

*** Estimated from reported P value.

††† Estimated from reported SD’s.

‡‡‡ Estimated from reported P value.

Table 5.12.4 ESS in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | 12.9 (5.6) | 6.9 (5.5) | 2.3 | 0.2, 4.4 † | 0.53 ‡ | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | 14.2 (5.6) | 5.9 (4.8) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 10.7 (3.6) | 9.2 (3.6) | 0 | −0.8, 0.8 § | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 10.7 (3.6) | 9.2 (3.6) | | | | 23 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | 12 (6) | 9 (6) | 2 | −1, 5 ** | <0.05 | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | 12 (6) | 7 (6) | | | | 0 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | 13 (4) | 12 (5) | 6 | 4.2, 7.8 †† | <0.001 | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | 15 (3) | 8 (5) | | | | 6 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | MAD | 28 | 10.6 (4.5) | 7.7 (4.0) | −0.5 | −2.0, 1.0 ‡‡ | <0.05 | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | 10.6 (4.5) | 8.2 (3.9) | | | | 0 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | MAD | 24 | 13.4 (4.6) | 9.0 (5.1) | 0.9 | −1.0, 2.8 §§ | NS | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | CPAP | 24 | 13.4 (4.6) | 8.1 (4.1) | | | | 12 | B
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 13.2 (4.9) | 9.4 (5.5) | −1.9 | −4.9, 1.1 *** | 0.22 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 13.2 (4.9) | 11.3 (4.6) | | | | 0 | C

* Baseline/Final

† Estimated from reported SD’s.

‡ Statistical analysis of comparison of final values.

§ Estimated from reported SD’s.

** Estimated from reported SE’s Our estimate does not match with reported significance.

†† Estimated from reported SD’s.

‡‡ Estimated from reported SD’s.

§§ Estimated from reported SD’s.

*** Estimated from reported P value.

Table 5.12.5a AI (events/hr) in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 22.0 (10.7) | 23.8 (10.7) | 5.5 | 3.4, 7.6 * | <0.05 | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 22.0 (10.7) | 18.3 (8.0) | | | | 23 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | 24.5 (12.8) | 21.6 (14.6) | 2.4 | −3.4, 8.2 † | NS | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | 21.6 (9.9) | 16.3 (10.5) | | | | 0 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | MAD | 24 | 19.3 (9.6) | 11.6 (5.6) | 1.8 | −0.7, 4.3 ‡ | NS | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | CPAP | 24 | 19.3 (9.6) | 9.8 (6.6) | | | | 12 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | MAD | 20 | 21.8 (9.9) | 17.0 (5.1) | 2.9 | 0.7, 5.1 § | NS | 0 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | CPAP | 20 | 21.8 (9.9) | 14.1 (5.1) | | | | 0 | B
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 27.7 (9.0) | 31.7 (22.8) | 15.2 | −1.4, 31.7 ** | 0.072 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 27.7 (9.0) | 16.5 (5.9) | | | | 0 | C

* Estimated from reported SE’s.

† Estimated from reported SE’s.

‡ Estimated from reported SD’s.

§ Estimated from reported SD’s. Our estimate does not match with reported significance.

** Estimated from reported P value.

Table 5.12.5b Minimum oxygen saturation (%) in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | 78.0 (8.5) | 87.7 (6.3) | −2.1 | −5.3, 1.1 | NS † | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | 77.9 (9.9) | 89.7 (5.8) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 86.7 (5.4) | 87.8 (3.6) | −4.1 | −4.9, −3.4 ‡ | <0.05 | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 86.7 (5.4) | 91.9 (2.7) | | | | 23 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | 73.8 (11.1) | 81.0 (9.3) | −5.0 | −11.0, 1.0 § | NS | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | 75.0 (8.2) | 87.2 (16.9) | | | | 0 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | MAD | 19 | 83.0 (7.4) | 83.8 (7.3) | −5.3 | −9.3, −1.3 ** | nd | 24 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | CPAP | 20 | 82.6 (6.0) | 88.7 (2.5) | | | | 24 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | MAD | 20 | 54.5 (25.9) | 85.3 (3.1) | −3.7 | −5.1, −2.3 †† | <0.05 | 0 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | CPAP | 20 | 54.5 (25.9) | 89.0 (3.4) | | | | 0 | B
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | MAD | 21 | 84.3 (6.77) | 90.2 (4.36) | −0.9 | −3.3, 1.5 ‡‡ | nd | 4 | C
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | CPAP | 21 | 84.3 (6.77) | 91.1 (6.40) | | | | 4 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 84.3 (4.4) | 81.0 (12.0) | −9.8 | −20.6, 1.0 §§ | 0.076 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 84.3 (4.4) | 90.8 (3.0) | | | | 0 | C

* Baseline/Final

† Statistical analysis of comparison of final values.

‡ Estimated from reported SE’s.

§ Estimated from reported SE’s.

** Estimated from reported SD’s.

†† Estimated from reported SD’s.

‡‡ Estimated from reported SD’s.

§§ Estimated from reported P value.

Table 5.12.5c Sleep efficiency (%TST) in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | 88.3 (9.7) | 86.1 (8.1) | −2.9 | −7.4, 1.6 † | NS ‡ | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | 85.5 (15.5) | 86.2 (10.0) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 79.5 (9.8) | 82.0 (8.9) | −0.1 | −1.9, 1.7 § | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 79.5 (9.8) | 82.1 (7.2) | | | | 23 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | MAD | 19 | 88.0 (5.4) | 86.5 (10.6) | −1.8 | −7.1, 3.5 ** | nd | 24 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | CPAP | 20 | 87.8 (7.7) | 88.1 (7.3) | | | | 24 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | MAD | 24 | 81.6 (10.4) | 83.2 (8.1) | −4 | −7.2, 0.8 †† | NS | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | CPAP | 24 | 81.6 (10.4) | 87.2 (8.1) | | | | 12 | B
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | MAD | 21 | 87.1 (10.7) | 89.9 (5.5) | 0.4 | −2.4, 3.2 ‡‡ | NS | 4 | C
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | CPAP | 21 | 87.1 (10.7) | 89.5 (7.3) | | | | 4 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 81.9 (7.9) | 78.6 (11.8) | 0.2 | −7.1, 7.5 §§ | 0.97 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 81.9 (7.9) | 78.4 (11.6) | | | | 0 | C

* Baseline/Final

† Estimated from reported SD’s.

‡ Statistical analysis of comparison of final values.

§ Estimated from reported SE’s.

** Estimated from reported SD’s.

†† Estimated from reported SD’s.

‡‡ Estimated from reported SD’s.

§§ Estimated from reported SD’s.

Table 5.12.5d Slow wave sleep (% TST) in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | 13.7 (9.0) | 20.4 (7.7) | −2.1 | −5.8, 1.6 † | NS ‡ | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | 13.0 (11.5) | 21.8 (8.0) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 17.9 (10.7) | 20.1 (9.8) | −0.6 | −2.8, 1.6 § | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 17.9 (10.7) | 20.7 (9.8) | | | | 23 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | MAD | 20 | 14.2 (10.6) | 14.1 (10.8) | −2.1 | −6.5, 2.3 ** | NS | 0 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | CPAP | 20 | 14.2 (10.6) | 16.2 (9.1) | | | | 0 | B
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | MAD | 21 | 12.4 (7.8) | 13.4 (8.0) | −1.8 | −4.9, 1.2 †† | nd | 4 | C
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | CPAP | 21 | 12.4 (7.8) | 15.2 (5.6) | | | | 4 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 20.4 (8.2) | 20.1 (13.4) | −3.9 | −11.2, 3.4 ‡‡ | 0.30 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 20.4 (8.2) | 24.0 (8.9) | | | | 0 | C

* Baseline/Final

† Estimated from reported SD’s.

‡ Statistical analysis of comparison of final values.

§ Estimated from reported SE’s.

** Estimated from reported SD’s.

†† Estimated from reported SD’s.

‡‡ Estimated from reported SD’s.

Table 5.12.5e REM sleep (% TST) in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | 21.0 (7.8) | 26.5 (6.7) | 0.6 | −2.2, 3.4 † | NS ‡ | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | 19.2 (7.4) | 24.1 (5.7) | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | 18.8 (6.3) | 19.8 (5.4) | 0.9 | −0.2, 2.0 § | NS | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | 18.8 (6.3) | 18.9 (4.5) | | | | 23 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | MAD | 19 | 14.3 (6.5) | 20.0 (12.3) | 6.1 | 0.3, 11.9 ** | nd | 24 | B
Ferguson 1996^226^ 8625679 | 25 (9) [15–50] | nd | 4 mo (XO) | CPAP | 20 | 16.5 (8.2) | 16.1 (6.1) | | | | 24 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | MAD | 24 | 12.7 (5.8) | 13.8 (5.6) | −4.7 | −7.0, −2.4 †† | NS | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | CPAP | 24 | 12.7 (5.8) | 18.5 (6.1) | | | | 12 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | MAD | 20 | 15.1 (5.9) | 14.8 (7.3) | −0.5 | −3.6, 2.6 ‡‡ | NS | 0 | B
Randerath 2002^228^ 12171833 | 18 (8) [5–30] | nd | 6 wk (XO) | CPAP | 20 | 15.1 (5.9) | 15.3 (6.8) | | | | 0 | B
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | MAD | 21 | 5.9 (5.8) | 20.9 (7.5) | 0.2 | −2.9, 3.3 §§ | NS | 4 | C
Clark 1996^224^ 8769497 | 34 (14) [≥10] | nd | 2 wk (XO) | CPAP | 21 | 5.9 (5.8) | 20.7 (6.7) | | | | 4 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 20.4 (4.6) | 19.7 (5.1) | −0.7 | −5.0, 3.6 *** | 0.82 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 20.4 (4.6) | 20.4 (8.0) | | | | 0 | C

* Baseline/Final

† Estimated from reported SD’s.

‡ Statistical analysis of comparison of final values.

§ Estimated from reported SE’s.

** Estimated from reported SD’s.

†† Estimated from reported SD’s. Our estimate does not match with reported significance.

‡‡ Estimated from reported SD’s.

§§ Estimated from reported SD’s.

*** Estimated from reported SD’s.

Table 5.12.6 Wakefulness tests in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Test | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | MWT (min) | nd | 22 (12) | −2 | −7.3, 2.7 * | 0.46 | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | MWT (min) | nd | 24 (12) | | | | 6 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | MAD | 28 | OSLER (sec) | 2094 (674) | 2312 (322) | 12 | −122, 146 † | NS | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | OSLER (sec) | 2094 (674) | 2300 (391) | | | | 0 | B

* Estimated from reported P value.

† Estimated from reported SD’s.

Table 5.12.7a FOSQ in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Final (SD) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/49 * | 13.7 (3.1) | 16.6 (2.8) | 0.1 | −1.1, 1.3 | NS † | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/50 | 13.9 (3.7) | 16.7 (3.1) | | | | 4 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | 12 (2) | 13 (3) | −3 | −4.8, −1.2 ‡ | 0.001 | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | 10 (3) | 14 (2) | | | | 6 | B
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | 12.2 (3.1) | 12.7 (3.1) | −0.1 | −1.2, 1.0 § | 0.85 | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | 12.2 (3.1) | 12.8 (2.7) | | | | 0 | C

* Baseline/Final

† Statistical analysis of comparison of final values.

‡ Estimated from reported P value.

§ Estimated from reported P value.

Table 5.12.7b Quality of life in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | Estimated 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | Estimated 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | MAD | 51/47 * | SF-36 (all 8 components) | 0 | | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | | | | | | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | Hospital Anxiety Scale | 0 | | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | | | | | | | | 4 | B
Hoekema 2008^230^ 18719218 | 40 (28) [≥5] | 14.2 (5.6) | 78 d [IQR = 60–88 d] (PL) | CPAP | 52/47 | Hospital Depression Scale | 0 | | | | | | 4 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | MAD | 80 | SF-36 (mean score) | 0 | | | | | | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | | 80 | | | | | | | | 23 | B
Barnes 2004^140^ 15201136 | 21 (12) [nd] | 10.7 (3.6) | 3 mo (XO) | CPAP | 80 | Beck Depression Index | 0 | | | | | | 23 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | SF-36 Bodily Pain | CPAP | −16 | −17, −14 | 0 | 100 | <0.05 | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | | | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | SF-36 (other components) | 0 | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | | | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | MAD | 34 | SAQLI (A,B,C,D) † | 0 | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | | | | | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | SAQLI A-D ‡ | CPAP | −0.3 | −0.4, −0.2 | 1 | 7 | <0.05 | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | | | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | SAQLI E § | MAD | −0.8 | −0.9, −0.7 | 7 | 1 | <0.05 | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | | | | | | | | 0 | B
Lam 2007^129^ 17121868 | 24 (5.8) [5–40] | 12 (6) | 10 wk (PL) | CPAP | 34 | SAQLI A-E ** | 0 | | | | | | 0 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | SF-36 Health transition | CPAP | 0.52 | nd | Effect size (SD units) | | 0.001 | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | | | | | Effect size (SD units) | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | SF-36 PCS | CPAP | 0.35 | nd | Effect size (SD units) | | 0.02 | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | | | | | Effect size (SD units) | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | SF-36 MCS | CPAP | 0.34 | nd | Effect size (SD units) | | 0.008 | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | | 48 | | | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | Hospital Anxiety Score | 0 | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | | | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | Hospital Depression Score | 0 | | | | | | 6 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | MAD | 28 | Nottingham Health Profile (6 components) | 0 | | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | | 28 | Nottingham Health Profile (6 components) | 0 | | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | Nottingham Health Profile (6 components) | 0 | | | | | | 0 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | MAD | 24 | General Health †† | 0 | | | | | | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | | 24 | General Health †† | 0 | | | | | | 12 | B
Tan 2002^229^ 12143088 | 22 (10) [<50] | 13.4 (4.6) | 2 mo (XO) | CPAP | 24 | General Health †† | 0 | | | | | | 12 | B
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | SF-36 PCS | 0 | | | | | | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | CMS collar | 10 | SF-36 MCS | 0 | | | | | | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | | 10 | | | | | | | | 0 | C
Skinner 2004^232^ 14718430 | 29 (13) [10–60] | 13.2 (4.9) | 1 mo (XO) | AutoCPAP | 10 | SQ | 0 | | | | | | 0 | C

* Baseline/Final

† A: Daily functioning; B: Social interactions; C: Emotional; D: Symptoms

‡ Summary score for components A-D.

§ E: Treatment-related symptoms

** Summary score for components A-E.

†† Flemons WW, Whitelaw WA, Brant R, Remmers JE. 1994. Likelihood ratios for a sleep apnea clinical prediction rule. Am J Resp Crit Care Med. 150: 1279–1285

Table 5.12.8 Cognitive function tests in randomized controlled trials of mandibular advancement devices vs. CPAP

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors * | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors * | Net Difference | Estimated 95% CI | Test Range | | PS Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors * | Net Difference | Estimated 95% CI | “Worst” | “Best” | PS Btw | Dropout, % | Study Quality
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | Performance IQ | 0 | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | | | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | MAD | 48 | Trailmaking B | 0 | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | | 48 | | | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | SteerClear | 0 | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | | | | | | | | 6 | B
Engleman 2002^225^ 12231497 | 31 (26) [≥5] | 14 (4) | 8 wk (XO) | CPAP | 48 | PASAT 2s | 0 | | | | | | 6 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | MAD | 28 | OSLER Errors | 0 | | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | | 28 | | | | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | Trailmaking A | 0 | | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | | | | | | | | 0 | B
Gagnadoux 2009^227^ 19324954 | 34 (13) [10–60] | 10.6 (4.5) | 2 mo (XO) | CPAP | 28 | Trailmaking B | 0 | | | | | | 0 | B

* The noted intervention statistically significantly favors the patient (net better score on test). 0 = no difference.

Table 5.16.1 Randomized controlled trials of positional therapy vs. CPAP: study characteristics

Study PMID | Interventions | CPAP Pressure * (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Jokic 1999^235^ 10084491 | Positional treatment | Manual (Split) | 51 | nd | 30 | nd | Canada (nd) | No washout
Jokic 1999^235^ 10084491 | CPAP | Manual (Split) | 51 | nd | 30 | nd | Canada (nd) | No washout
Skinner 2004^233^ 15611894 | SHEP † | Auto (Split) | 54 | 85 | 34 | nd | New Zealand | Patient not blinded, multicenter not accounted for in analysis, no power analysis reported
Skinner 2004^233^ 15611894 | CPAP | Auto (Split) | 54 | 85 | 34 | nd | New Zealand | Patient not blinded, multicenter not accounted for in analysis, no power analysis reported
Skinner 2008^234^ 18713092 | TASB ‡ | Auto (Separate) | 56 | nd | 30.7 | Positional OSA | New Zealand | Patient not blinded
Skinner 2008^234^ 18713092 | CPAP | Auto (Separate) | 56 | nd | 30.7 | Positional OSA | New Zealand | Patient not blinded

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, eg if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

† Shoulder-head elevation pillow

‡ Thoracic anti-supine band

Table 5.16.2a AHI (events/hr) in randomized controlled trials of positional therapy vs. CPAP

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Difference | 95% CI | P Btw | Dropout, % | Study Quality
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Positional therapy | 13 | 17.9 (nd) | −8.4 | 6.1 | 2, 10.2 | 0.007 | 7 | B
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | CPAP | 13 | 17.9 (nd) | −14.5 | | | | 7 | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | SHEP | 14 | 27 (12) | −6 | 16 | 4.2, 27.8 * | 0.008 | 7 | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | nCPAP | 13 | 27 (12) | −22 | | | | 7 | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | TASB | 20 | 22.7 | −10.7 | 7.1 | 1.1, 13.1 † | 0.02 | 0 | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | nCPAP | 20 | 22.7 | −17.8 | | | | 0 | B

* Estimated from reported P value

† Estimated from reported P value

Table 5.16.2b AHI ≤10 events/hr in randomized controlled trials of positional therapy

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | n Event | N Total | Outcome Metric | Result * | 95% CI | P Btw | Dropout, % | Study Quality
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | TASB | 13 | 18 | RR | 0.81 | 0.58, 1.13 | 0.004 † | 0 | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | CPAP | 16 | 18 | | | | | 0 | B

* T op row intervention vs. bottom row intervention. Estimated based on reported data.

† Per article, by Wilcoxin sign-rank test.

Table 5.16.3 ESS in randomized controlled trials of positional therapy vs. CPAP

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Difference | 95% CI | P Btw | Dropout, % | Study Quality
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Positional therapy | 13 | 13.4 (nd) | 9.5 | 1.5 * | −2.9, 0.8 | 0.2 | 7 | B
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | CPAP | 13 | 13.4 (nd) | 8.75 | | | | 7 | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | SHEP | 14 | 10.2 (5.0) | −1.7 | 0.7 | −2.8, 4.2 † | 0.69 | 7 | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | nCPAP | 14 | 9.5 (4.0) | −2.4 | | | | 7 | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | TASB | 20 | 13.6 | 50.5 | 1.2 | | NS | 0 | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | nCPAP | 20 | 13.6 | 50.5 | | | | 0 | B

* median

† Estimated from reported P value.

Table 5.16.4 Other sleep study and related outcomes in randomized controlled trials of positional therapy vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Arousal index (events/hr) | Positional therapy | 13 | 24.5 (nd) | −5.0 | 4.5 | (−0.7, 9.4) | 0.08 | 7 | B
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Arousal index (events/hr) | CPAP | 13 | 24.5 (nd) | −9.5 | | | | 7 | B
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Sleep efficiency (%) | Positional therapy | 13 | nd | 82 | −4 | nd | 0.51 | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Sleep efficiency (%) | CPAP | 13 | nd | 84 | | | | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Slow wave sleep (%) | Positional therapy | 13 | nd | 20 | −2 | nd | 0.31 | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | Slow wave sleep (%) | CPAP | 13 | nd | 22 | | | | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | REM (%) | Positional therapy | 13 | nd | 24 | −2 | nd | 0.71 | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | REM (%) | CPAP | 13 | nd | 26 | | | | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | MWT (min) | Positional therapy | 13 | nd | 31.2 | −1.7 | (−1.9, 5.3) | 0.32 | 7 | C *
Jokic 1999^235^ 10084491 | 18 (nd) [4–33] | 13.4 (nd) | 2 wk (XO) | MWT (min) | CPAP | 13 | nd | 32.9 | | | | 7 | C *

* No baseline data

Table 5.16.5 Quality of life in randomized controlled trials of positional therapy vs CPAP

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Jokic 1999 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | Positional Therapy | 13 | General Health Questionnaire | 0 | | | | | | 7% | B
Jokic 1999 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | General Health Questionnaire | 0 | | | | | | 7% | B
Jokic 1999 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | CPAP | 13 | General Health Questionnaire | 0 | | | | | | 7% | B
| | | | | | | | | | | | | 7% | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | SHEP | 14 | SF-36 physical | 0 | | | | | | 7% | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | | | SF-36 physical | 0 | | | | | | 7% | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | | | SF-36 physical | 0 | | | | | | 7% | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | | | | | | | | | | 7% | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | TASB | 14 | SF-36 mental | 0 | | | | | | 7% | B
| | | | | | | | | | | | | 7% | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | SHEP | 20 | SF-36 physical | 0 | | | | | | 7% | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | | | SF-36 physical | 0 | | | | | | 7% | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | | | SF-36 physical | 0 | | | | | | 7% | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | | | | | | | | | | 7% | B
Skinner 2008^234^ 18713092 | 23 (12) [6–51] | 13.6 (50.5) | 1 mo (XO) | TASB | 20 | SF-36 mental | 0 | | | | | | 7% | B

Table 5.16.6 FOSQ in randomized controlled trials of positional therapy vs. CPAP

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Difference | 95% CI | P Btw | Dropout, % | Study Quality
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | SHEP * | 14 | 12.1 (1.9) | 1.1 | −0.3 | nd | 0.93 | 7 | B
Skinner 2004^233^ 15611894 | 27 (12) [13–50] | 11.9 (4.6) | 1 mo (XO) | CPAP | 14 | 12.1 (1.9) | 1.4 | | | | 7 | B

* Shoulder-head elevation pillow

Table 5.16.7 Neurocognitive tests in randomized controlled trials of positional therapy vs. CPAP

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | Positional Therapy | 13 | Wechsler Memory Scale | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Wechsler Memory Scale | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | CPAP | 13 | Wechsler Memory Scale | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | | | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Purdue Pegboard | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | | | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Trail-Making test | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Symbol Digit Modalities | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Consonant Trigram | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Concentration Endurance Test | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Nottingham Health Profile Energy | CPAP | −1 | | 0 | 3 | 0.04 | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | | | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Nottingham Health Profile Others | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | | | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Hospital Anxiety Scale | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | Hospital Depression Scale | 0 | | | | | | 7 | B
Jokic 1999^235^ 10084491 | 17.9 (nd) [4.4–32.8] | 13.4 | 2 wk (XO) | | | UWIST adjective checklist | 0 | | | | | | 7 | B

Table 5.17.1 Randomized controlled trials of weight loss: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Foster 2009^236^ 19786682 | Intensive lifestyle intervention | 61 | 42 | 36.7 | Diabetics | US (nd) | Unclear if outcome data included all initial participants, and if so, unclear how data were imputed.
Foster 2009^236^ 19786682 | Diabetes support and education | 61 | 42 | 36.7 | Diabetics | US (nd) | Unclear if outcome data included all initial participants, and if so, unclear how data were imputed.
Johansson 2009^237^ 19959590 | Low energy diet | 50 | 100 | 34.8 | No | Sweden (2009)
Johansson 2009^237^ 19959590 | Usual diet | 50 | 100 | 34.8 | No | Sweden (2009)
Tuomilehto 2009^238^ 19011153 | VLCD with lifestyle changes | 51 | 74 | 31.4 | Obese | Finland (2004–06)
Tuomilehto 2009^238^ 19011153 | General counseling | 51 | 74 | 31.4 | Obese | Finland (2004–06)

Table 5.17.2 Patients with OSA cure in 1 year in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | n Event | N Total | Outcome metric | Result^*^ | 95% CI † | P Btw | Dropout, % | Study Quality
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | VLCD with lifestyle changes | 22 | 35 | OR (adjusted) ‡ | 4.17 | (1.41, 12.34) | 0.011 | 11 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | General counseling | 13 | 37 | | | | | 11 | B

* Top row intervention vs. bottom row intervention.

† Estimated from reported P value

‡ Adjusted OR for age, sex, BMI and baseline AHI.

Table 5.17.3 AHI (events/hr) in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Low energy diet | 30 | 37 (17) | −25 | −23 | −30, −15 | <0.001 | 3 | A
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Usual diet | 33 | 37 (14) | −2 | | | | 3 | A
Foster 2009^236^ 19786682 | 24 (15) [nd] | nd | 1 yr (PL) | Intensive lifestyle intervention | 125 | 22.9 (18.0) | −5.4 | −9.7 | −13.6, −5.7 | <0.001 | 17 | B
Foster 2009^236^ 19786682 | 24 (15) [nd] | nd | 1 yr (PL) | Diabetes support and education | 139 | 23.5 (15.0) | 4.2 | | | | 17 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | VLCD with lifestyle changes | 40 | 11 (3.6) | −4 | −4.3 | −7.6, −1.0 | 0.011 | 11 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | General counseling | 41 | 9 (2.7) | 0.3 | | | | 11 | B

* Estimated from reported data.

Table 5.17.4 ESS in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Low energy diet | 30 | 9 (5) | −3 | −4 | −6, −2 | <0.001 | 3 | A
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Usual diet | 33 | 7 (5) | 1 | | | | 3 | A
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | VLCD with lifestyle changes | 40 | 10.1 (5) | −3.1 | −1 | −2.7, 0.7 † | 0.25 | 11% | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | General counseling | 41 | 9.9 (4.8) | −2.1 | | | | 11% | B

† Estimated from reported data.

Table 5.17.5 Minimum oxygen saturation (%) in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Low energy diet | 30 | 82 (6) | 5 | 5 | 2, 7 | 0.002 | 3 | A
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Usual diet | 33 | 82 (5) | 0 | | | | 3 | A

Table 5.17.6 Blood pressure (mm Hg) in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI ^*^ | P Btw | Dropout, % | Study Quality
Systolic blood pressure
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | VLCD with lifestyle changes | 40 | 131.2 (10.2) | −1.7 | −0.6 | −8.4, 7.2 | 0.88 | 11 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | General counseling | 41 | 130.0 (12.8) | −1.9 | | | | 11 | B
Diastolic blood pressure
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | VLCD with lifestyle changes | 40 | 81.8 (8.9) | −1.9 | −1.5 | −7.4, 4.4 | 0.62 | 11 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | General counseling | 41 | 80.7 (7.8) | −0.4 | | | | 11 | B

Table 5.17.7 Hemoglobin A1c (%) in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI † | P Btw | Dropout, % | Study Quality
Foster 2009^236^ 19786682 | 24 (15) [nd] | nd | 1 yr (PL) | Intensive lifestyle intervention | 125 | 7.1 (0.9) | −0.7 | −0.5 | −0.8, −0.2 | <0.001 | 17 | B
Foster 2009^236^ 19786682 | 24 (15) [nd] | nd | 1 yr (PL) | Diabetes support and education | 139 | 7.3 (1.1) | −0.2 | | | | 17 | B

* Estimated from reported data.

† Estimated from reported data.

Table 5.17.8 Weight change (kg) in randomized controlled trials of weight loss

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI * | P Btw | Dropout, % | Study Quality
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Low energy diet | 30 | 113.4 (14.8) | −18.7 | −19.8 | −21.4, −18.2 | nd | 3 | A
Johansson 2009^237^ 19959590 | 37 (14) [≥15] | 7.0 (5.0) | 9 wk (PL) | Usual diet | 33 | 111.7 (13.7) | 1.1 | | | | 3 | A
Foster 2009^236^ 19786682 | 24 (15) [nd] | nd | 1 yr (PL) | Intensive lifestyle intervention | 125 | 102.9 (19.6) | −10.8 | −10.2 | −12.1, −8.3 | <0.001 | 17 | B
Foster 2009^236^ 19786682 | 24 (15) [nd] | nd | 1 yr (PL) | Diabetes support and education | 139 | 102.0 (17.1) | −0.6 | | | | 17 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | VLCD with lifestyle changes | 40 | 101.2 (11.9) | −10.7 | −8.3 | −11.1, −5.5 | <0.001 | 11 | B
Tuomilehto 2009^238^ 19011153 | 9 (3) [>5] | 9.9 (4.8) | 1 yr (PL) | General counseling | 41 | 92.3 (11.3) | −2.4 | | | | 11 | B

* Estimated from reported data.

Table 5.18.1 Randomized controlled trials of oropharyngeal exercises: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, 2 kg/m | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Guimaraes 2009^240^ 19234106 | Oropharyngeal exercise | 48 | 73 | 31.0 | - | Brazil (nd)
Guimaraes 2009^240^ 19234106 | Sham therapy | 48 | 73 | 31.0 | - | Brazil (nd)
Randerath 2004^241^ 15124719 | Tongue training | 53 | 66 | 28.9 | - | Germany (2002)
Randerath 2004^241^ 15124719 | Sham training | 53 | 66 | 28.9 | - | Germany (2002)
Puhan 2005^239^ 16377643 | Didgeridoo | 49 | 84 | 25.8 | - | Switzerland (2004–05)
Puhan 2005^239^ 16377643 | No intervention | 49 | 84 | 25.8 | - | Switzerland (2004–05)

Table 5.18.2 AHI (events/hr) in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | Didgeridoo | 14 | 22.3 (5.0) | −10.7 | −6.2 | −12.3, −0.1 | 0.05 | 0 | A
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | No treatment | 11 | 19.9 (4.7) | −4.5 | | | | 0 | A
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Oropharyngeal exercise | 16 | 22.4 (5.4) | −8.7 | −12.2 | −19, −5 * | <0.001 | 10 | B
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Sham therapy | 15 | 22.4 (5.4) | 3.5 | | | | 10 | B
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Tongue training | 33 | 24.7 (8.6) | 0.6 | 0.4 | −5.6, 6.4 † | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Sham training | 24 | 27.7 (6.3) | 0.2 | | | | 8 | A

* Estimated from reported P value

† Estimated from reported data

Table 5.18.3 ESS in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | Didgeridoo | 14 | 11.8 (3.5) | −4.4 | −2.8 | −5.7, −0.3 | 0.04 | 0 | A
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | No treatment | 11 | 11.1 (6.4) | −1.4 | | | | 0 | A
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Oropharyngeal exercise | 16 | 14 (5) | −6 | −4 | −8, −0.02 * | <0.05 | 10 | B
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Sham therapy | 15 | 14 (7) | −2 | | | | 10 | B
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Tongue training | 33 | 10.2 (4.9) | −1.5 | −0.2 | −2.6, 2.4 † | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Sham training | 24 | 10.5 (5.1) | −1.3 | | | | 8 | A

* Estimated from reported P value

† Estimated from reported data

Table 5.18.4 Minimum oxygen saturation (%) in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Oropharyngeal exercise | 16 | 83 (6) | 85 (7) | 4 | 0.2, 7.8 * | NS | 10 | B
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Sham therapy | 15 | 82 (4) | 80 (4) | | | | 10 | B
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Tongue training | 33 | 81.7 (6.8) | −0.3 | 1.1 | −2.4, 4.6 † | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Sham training | 24 | 82.3 (5.8) | −1.4 | | | | 8 | A

* Estimated from reported data

† Estimated from reported data

Table 5.18.5 Sleep efficiency (%) in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Oropharyngeal exercise | 16 | 87 (8) | −1 | −2 | −8.8, 4.8 * | 0.58 | 10 | B
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Sham therapy | 15 | 86 (10) | 1 | | | | 10 | B

* Estimated from reported data.

Table 5.18.6 Other sleep study outcomes in randomized controlled trials of positional therapy vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Slow wave sleep | Tongue training | 33 | 19.1 (13.6) | 6.8 | 11 | −1.3, 21.5 * | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Slow wave sleep | Sham training | 24 | 23.5 (9.8) | −4.2 | | | | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | REM sleep | Tongue training | 33 | 11 (4.7) | 1.1 | −0.3 | −3.0, 2.2 † | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | REM sleep | Sham training | 24 | 12.9 (5.2) | 1.4 | | | | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Arousal index | Tongue training | 33 | 23.7 (9.5) | −0.7 | −1.9 | −6.9, 3.5 ‡ | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Arousal index | Sham training | 24 | 23 (9.8) | 1.2 | | | | 8 | A

* Estimated from reported data

† Estimated from reported data

‡ Estimated from reported data

Note: There is no Table 5.18.7.

Table 5.18.8 FOSQ in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Tongue training | 33 | 84.8 (32.5) | 4.2 | 1.6 | −20.4, 13.6 ^*^ | NS | 8 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Sham training | 24 | 74.2 (36.9) | 2.6 | | | | 8 | A

Table 5.18.9 Quality of life outcomes in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | Didgeridoo | 14 | PQoSI | 0 | | | | | | 0 | A
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | | | PQoSI | 0 | | | | | | 0 | A
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | No treatment | 11 | PQoSI | 0 | | | | | | 0 | A
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | | | | | | | | | | 0 | A
Puhan 2005^239^ 16377643 | 20 (5) [≥15] | 11.5 (nd) | 4 mo (PL) | | | SF-36- all domains | 0 | | | | | | 0 | A
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Oropharyngeal exercise | 16 | Pittsburgh Quality of Sleep Index | Oropharyngeal exercise | −3.4 | nd | 21 | 0 | <0.01 | 10 | B
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | | | Pittsburgh Quality of Sleep Index | Oropharyngeal exercise | −3.4 | nd | 21 | 0 | <0.01 | 10 | B
Guimaraes 2009^240^ 19234106 | 22 (5) [≥15] | 14 (7) | 3 mo (PL) | Sham therapy | 15 | Pittsburgh Quality of Sleep Index | Oropharyngeal exercise | −3.4 | nd | 21 | 0 | <0.01 | 10 | B

Table 5.18.10 Neurocognitive tests in randomized controlled trials of oropharyngeal exercises

Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Tongue training | 33 | Attention Test | 0 | | | | | | 0 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | | | Attention Test | 0 | | | | | | 0 | A
Randerath 2004^241^ 15124719 | 28 (6) [10–40] | 9.4 (4.7) | 8 wk (PL) | Sham training | 24 | Attention Test | 0 | | | | | | 0 | A

* Estimated from reported data

Table 5.19.1 Randomized controlled trials of palatal implants vs. control: study characteristics

Study PMID | Interventions | Mean Age ( yr) | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Friedman 2008^242^ 18241718 | Palatal implants | 39 (9) | 53 | 28.7 (2.3) | - | US (2005–06) | -
Friedman 2008^242^ 18241718 | Placebo | 39 (9) | 53 | 28.7 (2.3) | - | US (2005–06) | -
Steward 2008^243^ 18922335 | Soft palate implants | 49 (nd) | 79 | 27.6 (nd) | - | US (nd) | -
Steward 2008^243^ 18922335 | Sham implants | 49 (nd) | 79 | 27.6 (nd) | - | US (nd) | -

Table 5.19.2a AHI (events/hr) in randomized controlled trials of palatal implant vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Palatal implants | 29 | 23.8 (5.5) | −7.1 | −8.8 | 5.3, 12.2 | <0.0001 | 11 | A
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Placebo | 26 | 20.1 (4.0) | +0.9 | | | | 11 | A
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Soft palate implants | 47 | 17.2 (nd) | 2.9 | −6 | 0.9, −13 | NS | 1 | B
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Sham implants | 50 | 16.7(nd) | 8.9 | | | | 1 | B

Table 5.19.2b Fifty percent reduction in AHI to ≤ 20 events/hr in randomized controlled trials of palatal implant vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | n Event | N Total | Outcome Metric | Result * | 95% CI | P Btw | Dropout, % | Study Quality
Steward 2008^243^ 18922335 | 16 (nd) [10–40] | 10.6(nd) | 3 mo (PL) | Soft palate implants | 13 | 50 | RR | 2.60 | 1.00, 6.75 | 0.04 † | 1 | B
Steward 2008^243^ 18922335 | 16 (nd) [10–40] | 10.6(nd) | 3 mo (PL) | Sham implants | 5 | 50 | | | | | 1 | B

* Top row intervention vs. bottom row intervention.

† Per article, by chi-squared test.

Table 5.19.3 ESS in randomized controlled trials of palatal implant vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Palatal implants | 31 | 12.7(2.7) | −2.4 | −1.9 | 1.0, 2.9 | 0.0002 | 11 | A
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Placebo | 31 | 11.7(2.7) | −0.5 | | | | 11 | A
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Soft palate implants | 47 | 10.6(nd) | −1.8 | −0.3 | −1.8, 1.1 | NS | 1 | B
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Sham implants | 49 | 10.7(nd) | −1.5 | | | | 1 | B

Table 5.19.4 Minimum oxygen saturation in randomized controlled trials of palatal implant vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Palatal implants | 28 | 88.3 (3.0) | −1.3 | −0.6 | −2.2, 1.0 | NS | 11 | A
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Placebo | 23 | 89.6 (2.5) | −0.7 | | | | 11 | A
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Soft palate implants | 46 | nd | 0.1 | −2.9 | −0.8, −5.0 | 0.007 | 1 | B
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Sham implants | 48 | nd | 3 | | | | 1 | B

Table 5.19.5 REM sleep in randomized controlled trials of palatal implant vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Palatal implants | 29 | 16.1 (3.3) | −0.8 | −2 | −4.0, 0.01 | NS | 11 | A
Friedman 2008^242^ 18241718 | 20 (4) [5–40] | 11.7 (2.7) | 3 mo (PL) | Placebo | 26 | 12.9 (3.7) | 1.2 | | | | 11 | A

Table 5.19.6 FOSQ total in randomized controlled trials of palatal implant vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Soft palate implants | 49 | 15.5(nd) | 1.4 | 0.83 | 0.0,1.6 | NS | 1 | B
Steward 2008^243^ 18922335 | 17 (nd) [10–40] | 10.6 (nd) | 3 mo (PL) | Sham implants | 49 | 16.1(nd) | 0.6 | | | | 1 | B

Table 5.20.1 Studies of surgery vs. control: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (Enrollment years) | Major quality issues
Back 2009^244^ 19504550 | RFA (Soft palate) | 30–65 (range) | 100 | 25.6 (median) | BMI ≤35 kg/m^2^ | Finland (nd)
Back 2009^244^ 19504550 | Sham surgery | 30–65 (range) | 100 | 25.6 (median) | BMI ≤35 kg/m^2^ | Finland (nd)
Ferguson 2003^245^ 12502473 | LAUP | 44 | 78 | 31.6 | - | Canada (nd)
Ferguson 2003^245^ 12502473 | No treatment | 44 | 78 | 31.6 | - | Canada (nd)
Guilleminault 2008^248^ 19014072 | Surgery combo * | 32 | 40 | 23.9 | - | US (2002–03) | First phase †
Guilleminault 2008^248^ 19014072 | Cognitive behavioral therapy for insomnia | 32 | 40 | 23.9 | - | US (2002–03) | First phase †
Koutsourelakis 2008^246^ 17898015 | Surgery ‡ | 37 | 59 | 29.9 | Deviated nasal septum | Greece (nd)
Koutsourelakis 2008^246^ 17898015 | Sham surgery | 37 | 59 | 29.9 | Deviated nasal septum | Greece (nd)
Li 2009^249^ 19793414 | Nasal surgery | 38 | 95 | 26.2 | Nasal obstruction | Taiwan (nd) | Not randomized; no data on followup duration
Li 2009^249^ 19793414 | Conservative treatment | 38 | 95 | 26.2 | Nasal obstruction | Taiwan (nd) | Not randomized; no data on followup duration
Lojander 1996^124^ 8681614 Lojander 1999^125^ 10188139 | UPPP | 47 | 97 | 31.0 | BMI ≤40kg/m^2^ | Finland (1987–92)
Lojander 1996^124^ 8681614 Lojander 1999^125^ 10188139 | Conservative treatment | 47 | 97 | 31.0 | BMI ≤40kg/m^2^ | Finland (1987–92)
Woodson 2003^247^ 12825037 | RFA (tongue & palate) | 46 | 70 | 28.5 | - | US (nd)
Woodson 2003^247^ 12825037 | Sham RFA | 46 | 70 | 28.5 | - | US (nd)
Woodson 2003^247^ 12825037 | RFA (nd where) | 46 | 70 | 28.5 | - | US (nd)

* combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty and RFA of the inferior nasal turbinates

† Paper was presented as a crossover study between behavioral therapy and surgery. Only the first phase (prior to crossover) evaluated here.

‡ Submucous resection of the deviated septum and bilateral resection of inferior turbinates

Table 5.20.2 AHI or oxygen desaturation index (events/hr) in randomized controlled trials of surgery vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcomes | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Back 2009^244^ 19504550 | 12 (5–8)^*^ [5–15] | 8.0 (3.0–16.0)^†^ | 4 mo (PL) | AHI | RFA | 17 | 11 (5–15)^‡^ | 2 | 3 | −9.1, 15.1^§^ | NS | 0 | A
Back 2009^244^ 19504550 | 12 (5–8)^*^ [5–15] | 8.0 (3.0–16.0)^†^ | 4 mo (PL) | AHI | Sham surgery | 15 | 12.0 (5.0–8.0)^**^ | −1 | | | | 0 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40]^††^ | 11.6(3.5) | 2 mo (PL) | AHI | RFA | 24 | 21.3 (11.1) | −4.5 | −2.7 | −9.9,4.5 | NS | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40]^††^ | 11.6(3.5) | 2 mo (PL) | AHI | Sham RFA | 28 | 15.4 (7.8) | −1.8 | | | | 13 | A
Koutsourelakis 2008^246^ 17898015 | 31 (14) [≥5] | 13.7 (4.4) | 4 mo (PL) | AHI | Surgery^‡‡^ | 27 | 31.5 (16.7) | 0 | −1.5 | −10.3, 7.3^§§^ | nd | 3 | A
Koutsourelakis 2008^246^ 17898015 | 31 (14) [≥5] | 13.7 (4.4) | 4 mo (PL) | AHI | Sham surgery | 22 | 30.6 (13.8) | 1.5 | | | | 3 | A
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to15 mo (PL) | AHI | LAUP | 21 | 18.6 (4.3) | −3.9 | −10.5 | −20.5, −0.4^***^ | nd | 1 | B
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to15 mo (PL) | AHI | No treatment | 23 | 16.1 (4.0) | 6.6 | | | | 1 | B
Lojander, 1996^124^ 8681614 | nd | (nd) | 12 mo (PL) | ODI4^†††^ | UPPP | 16 | 45 | −31 | −20 | nd | NS | 3 | C
Lojander, 1996^124^ 8681614 | nd | (nd) | 12 mo (PL) | ODI4^†††^ | Conservative treatment | 10 | 34 | −11 | | | | 3 | C
Lojander, 1996^124^ 8681614 | nd | (nd) | 12 mo (PL) | ODI10^‡‡‡^ | UPPP | 16 | 17 | −14 | −6 | nd | NS | 3 | C
Lojander, 1996^124^ 8681614 | nd | (nd) | 12 mo (PL) | ODI10^‡‡‡^ | Conservative treatment | 10 | 14 | −8 | | | | 3 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | AHI | Surgery combo^§§§^ | 15 | 9.7 (5.7) | −5.2 | −6.2 | −9.3, −3.1^****^ | <0.0001 | 33 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | AHI | Cognitive behavioral therapy | 15 | 9.7 (5.7) | 1 | | | | 33 | C
Li 2009^249^ 19793414 | 26 (27) [≥5] | 10.2 (5.2) | nd (PL) | AHI | Nasal surgery | 44 | 36.4 (29.1) | 1.1 | 2.6 | −11.0, 16.2^††††^ | NS | 0 | C
Li 2009^249^ 19793414 | 26 (27) [≥5] | 10.2 (5.2) | nd (PL) | AHI | Conservative treatment | 22 | 25.9 (27.0) | −1.5 | | | | 0 | C

* Median (range)

† Median (range)

‡ Median (range)

§ Estimated from reported P value

** Median (range)

†† Two parts of methods section disagree with each other

‡‡ Patients had submucous resection of the deviated septum and bilateral resection of inferior turbinates

§§ Estimated from reported data

*** Estimated from reported data

††† no. of desaturation of ≥4% per hr in bed

‡‡‡ no. of desaturation of ≥10% per hr in bed

§§§ combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty and RFA of the inferior nasal turbinates

**** Estimated from reported P value

†††† Estimated from reported data

Table 5.20.3 ESS in randomized controlled trials of surgery vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Back 2009^244^ 19504550 | 12 (5–8) * [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | RFA | 17 | 10 (3–21)^‡^ | −3 | 0 | nd | NS | 0 | A
Back 2009^244^ 19504550 | 12 (5–8) * [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | sham surgery | 15 | 8.0 (3.0– 16.0) § | −3 | | | | 0 | A
Koutsourelakis 2008^246^ 17898015 | 31 (14) [≥5] | 13.7 (4.4) | 4 mo (PL) | Surgery ** | 27 | 13.4 (2.9) | −1.7 | −0.5 | −2.5, 1.5 †† | nd | 3 | A
Koutsourelakis 2008^246^ 17898015 | 31 (14) [≥5] | 13.7 (4.4) | 4 mo (PL) | Sham surgery | 22 | 13.7 (4.4) | −1.2 | | | | 3 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ‡‡ | 11.6(3.5) | 2 mo (PL) | RFA | 26 | 11.9 (4.6) | −2.1 | −1.2 | −3.1, 0.8 | NS | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ‡‡ | 11.6(3.5) | 2 mo (PL) | Sham RFA | 28 | 11.6 (3.5) | −1.0 | | | | 13 | A
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to 15 mo (PL) | LAUP | 21 | 10.7 (3.7) | 1.4 | −2.2 | −5.8, 1.4 §§ | nd | 1 | B
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to 15 mo (PL) | No treatment | 23 | 10.0 (5.2) | −0.8 | | | | 1 | B
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | Surgery combo *** | 15 | 6.6 (1.2) | −1.8 | −1.2 | −1.8, −0.5 ††† | 0.005 | 33 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | Cognitive behavioral therapy | 15 | 6.6 (1.2) | −0.6 | | | | 33 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | Nasal surgery | 44 | 10.6 (3.9) | −3.0 | −3.6 | −6.1, −1.1 ‡‡‡ | 0.02 | 0 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | Conservative treatment | 22 | 10.2 (5.2) | 0.6 | | | | 0 | C

* Median(range)

† Median(range)

‡ Median(range)

§ Median(range)

** Patients had submucous resection of the deviated septum and bilateral resection of inferior turbinates

†† Estimated from reported data

‡‡ two parts of methods section disagree with each other

§§ Estimated from reported data

*** combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty and RFA of the inferior nasal turbinates

††† Estimated from reported P value

‡‡‡ Estimated from reported data

Table 5.20.4 Minimum oxygen saturation (%) in randomized controlled trials of surgery vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Back 2009^244^ 19504550 | 12 (5–8)^*^ [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | RFA | 17 | 82.0 (68.0–88.0) ‡ | 0 | 0 | nd | NS | 0 | A
Back 2009^244^ 19504550 | 12 (5–8)^*^ [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | sham surgery | 15 | 83.0 (69.0–88.0) § | 0 | | | | 0 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ** | 11.6(3.5) | 2 mo (PL) | RFA | 24 | 86.3 (7.6) | −0.6 | −1.2 | −3.8, 1.4 | NS | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ** | 11.6(3.5) | 2 mo (PL) | Sham RFA | 28 | 88.3 (3.9) | 0.6 | | | | 13 | A
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | Surgery combo †† | 15 | 91.3 (1.9) | 4.7 | 4.4 | 2.1,6.6 ‡‡ | <0.0001 | 33 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | Cognitive behavioral therapy | 15 | 91.3 (1.9) | 0.3 | | | | 33 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | Nasal surgery | 44 | 78.3 (11.6) | 0.8 | 0.3 | 2.1,6.6 §§ | NS | 0 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | Conservative treatment | 22 | 82.7 (8.5) | 0.5 | | | | 0 | C

* Median(range)

† Median(range)

‡ Median(range)

§ Median(range)

** Two parts of methods section disagree with each other

†† combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty and RFA of the inferior nasal turbinates

‡‡ Estimated from reported P value

§§ Estimated from reported data

Table 5.20.5 Sleep stage changes (%) in randomized controlled trials of surgery vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | REM | Surgery combo * | 15 | 13.1(1.8) | 3.7 | 3.1 | 1.5, 4.6 † | <0.0001 | 33 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | REM | Cognitive behavioral therapy | 15 | 13.1(1.8) | 0.6 | | | | 33 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | Stage 3 and 4 | Surgery combo ‡ | 15 | 11.5(1.5) | 4.5 | 3.5 | 1.7, 5.3 § | <0.0001 | 33 | C
Guilleminault 2008^248^ 19014072 | 10 (6) [nd] | 6.6 (1.2) | 3 mo (XO first phase) | Stage 3 and 4 | Cognitive behavioral therapy | 15 | 11.5(1.5) | 1 | | | | 33 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | REM | Nasal surgery | 44 | 13.7 (5.7) | 0.9 | −0.1 | −3.9, 1.9 ** | NS | 0 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | REM | Conservative treatment | 22 | 13.9 (4.6) | 1.0 | | | | 0 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | Stage 3 and 4 | Nasal surgery | 44 | 6.3 (7.0) | −0.2 | −1.0 | −3.0, 2.8 †† | NS | 0 | C
Li 2009^249^ 19793414 | 26 (27) [≥ 5] | 10.2 (5.2) | nd (PL) | Stage 3 and 4 | Conservative treatment | 22 | 2.4 (3.8) | 0.8 | | | | 0 | C

* combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty and RFA of the inferior nasal turbinates

† Estimated from reported P value

‡ combinations of pharyngoplasty, tonsillectomy, adenoidectomy, genioglossal advancement septoplasty and RFA of the inferior nasal turbinates

§ Estimated from reported P value

** Estimated from reported data

†† Estimated from reported data

Table 5.20.6 FOSQ in randomized controlled trials of surgery vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6(3.5) | 2 mo (PL) | RFA | 24 | 16.5(2.0) | 1.2 | 0.9 | −0.1, 1.9 | 0.04 | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6(3.5) | 2 mo (PL) | Sham RFA | 27 | 16.8(2.1) | 0.4 | | | | 13 | A

* Two parts of methods section disagree with each other

Table 5.20.7 Functional Outcomes in randomized controlled trials of surgery vs. control

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Back 2009^244^ 19504550 | 12 (5–8) * [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | RFA | 17 | SF-36 (all domains) | 0 | | | | | | 0 | A
Back 2009^244^ 19504550 | 12 (5–8) * [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | | | SF-36 (all domains) | 0 | | | | | | 0 | A
Back 2009^244^ 19504550 | 12 (5–8) * [5–15] | 8.0 (3.0–16.0) † | 4 mo (PL) | sham surgery | 15 | SF-36 (all domains) | 0 | | | | | | 0 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ‡ | 11.6(3.5) | 2 mo (PL) | RFA | 24 | SF-36 (all domains) | 0 | | | | | | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ‡ | 11.6(3.5) | 2 mo (PL) | | | SF-36 (all domains) | 0 | | | | | | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] ‡ | 11.6(3.5) | 2 mo (PL) | Sham RFA | 27 | SF-36 (all domains) | 0 | | | | | | 13 | A
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to 15 mo (PL) | LAUP | 21 | SAQLI | 0 | | | | | | 1 | B
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to 15 mo (PL) | | | SAQLI | 0 | | | | | | 1 | B
Ferguson 2003^245^ 12502473 | 16 (4) [10–25] | 10.0 (5.2) | 8 to 15 mo (PL) | No treatment | 23 | SAQLI | 0 | | | | | | 1 | B
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | UPPP | 10 | Wechsler verbal | 0 | | | | | | 3 | C
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | | | Wechsler verbal | 0 | | | | | | 3 | C
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | Conservative treatment | 10 | Wechsler verbal | 0 | | | | | | 3 | C
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | | | | | | | | | | 3 | C
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | | | Wechsler performance | 0 | | | | | | 3 | C
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | | | | | | | | | | 3 | C
Lojander, 1999^125^ 10188139 | nd | (nd) | 12 mo (PL) | | | Wechsler memory | 0 | | | | | | 3 | C

* Median (range)

† Median (range)

‡ Two parts of methods section disagree with each other

Table 5.21.1 Studies of surgery vs. CPAP: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Major quality issues
Anand 1991^255^ 1945423 | UPPP | 53 (nd) | 60 | nd | -- | US (1983–90) | No eligibility criteria. Retrospective.
Anand 1991^255^ 1945423 | CPAP | 53 (nd) | 60 | nd | -- | US (1983–90) | No eligibility criteria. Retrospective.
Ceylan 2009^254^ 19770425 | TCRFVTR | 46 (nd) | 89 | 28.8 | -- | Turkey (2003–06) | Small sample size. Prospective nonrandomized.
Ceylan 2009^254^ 19770425 | CPAP | 46 (nd) | 89 | 28.8 | -- | Turkey (2003–06) | Small sample size. Prospective nonrandomized.
Conradt 1998^251^ 9785277 | MMO | 42 (10) | 100 | 26.7 | Craniofacial abnormalities | Germany (1993–96) | No eligibility criteria. Prospective nonrandomized.
Conradt 1998^251^ 9785277 | CPAP | 42 (10) | 100 | 26.7 | Craniofacial abnormalities | Germany (1993–96) | No eligibility criteria. Prospective nonrandomized.
Katsantonis 1988^256^ 327 8184 | UPP | 49 (19–78) * | 81 | nd | -- | US (1982–86) | No eligibility criteria. Retrospective.
Katsantonis 1988^256^ 327 8184 | Orthognathic device | 49 (19–78) * | 81 | nd | -- | US (1982–86) | No eligibility criteria. Retrospective.
Katsantonis 1988^256^ 327 8184 | Tracheostomy | 49 (19–78) * | 81 | nd | -- | US (1982–86) | No eligibility criteria. Retrospective.
Katsantonis 1988^256^ 327 8184 | Medication(TCA) | 49 (19–78) * | 81 | nd | -- | US (1982–86) | No eligibility criteria. Retrospective.
Katsantonis 1988^256^ 327 8184 | Tongue retaining device | 49 (19–78) * | 81 | nd | -- | US (1982–86) | No eligibility criteria. Retrospective.
Katsantonis 1988^256^ 327 8184 | CPAP | 49 (19–78) * | 81 | nd | -- | US (1982–86) | No eligibility criteria. Retrospective.
Keenan 1994^257^ 8275724 | UPPP | 52 (12) | 79 | 36.0 | -- | Canada (1984–90) | Significant difference between followup durations. Retrospective.
Keenan 1994^257^ 8275724 | CPAP | 52 (12) | 79 | 36.0 | -- | Canada (1984–90) | Significant difference between followup durations. Retrospective.
Lin 2006^258^ 16735919 | Extended UPP | 48 (nd) | nd | 27.2 | -- | Taiwan (2000–01) | Significant differences in baseline characteristics. Retrospective.
Lin 2006^258^ 16735919 | CPAP | 48 (nd) | nd | 27.2 | -- | Taiwan (2000–01) | Significant differences in baseline characteristics. Retrospective.
Robinson 2009^259^ 19643262 | Stepwise surgery | 56 (nd) | 88 | 31.6 | | Australia (2003–04) | Incomplete results. Retrospective.
Robinson 2009^259^ 19643262 | CPAP | 56 (nd) | 88 | 31.6 | | Australia (2003–04) | Incomplete results. Retrospective.
Vicini 2010^250^ 19944893 | MMA | 48 (10) | 86 | 30.2 | AHI >30 events/hr | Italy (nd) | No exclusion criteria
Vicini 2010^250^ 19944893 | CPAP | 48 (10) | 86 | 30.2 | AHI >30 events/hr | Italy (nd) | No exclusion criteria
Weaver 2004^260^ 15195049 | UPPP | 57 (nd) | 98 | nd | -- | US (1997–2001) | No details on OSA severity. Retrospective.
Weaver 2004^260^ 15195049 | CPAP | 57 (nd) | 98 | nd | -- | US (1997–2001) | No details on OSA severity. Retrospective.
Woodson 2001^252^ 11593163 | TCRFVTR | 48 (9) | 77 | 31.2 | BMI <35 kg/m^2^, Anesthesia risk group ASA class I, II, or III | US (nd) | No eligibility criteria. Prospective nonrandomized.
Woodson 2001^252^ 11593163 | CPAP | 48 (9) | 77 | 31.2 | BMI <35 kg/m^2^, Anesthesia risk group ASA class I, II, or III | US (nd) | No eligibility criteria. Prospective nonrandomized.
Woodson 2003^247^ 12825037 | RFA (tongue & palate) | 53 (nd) | 60 | nd | -- | US (nd)
Woodson 2003^247^ 12825037 | CPAP | 53 (nd) | 60 | nd | -- | US (nd)
Zorick 1990^253^ 2086548 | UPPP | 46 (nd) | 89 | 28.8 | -- | US (nd) | Dropout rate >20%. No eligibility criteria. Prospective nonrandomized
Zorick 1990^253^ 2086548 | CPAP | 46 (nd) | 89 | 28.8 | -- | US (nd) | Dropout rate >20%. No eligibility criteria. Prospective nonrandomized

* Range

Table 5.21.2 Categorical outcomes in studies of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | n Event | N Total | Outcome Metric | Result * | 95% CI | P Btw | Dropout, % | Study Quality
Weaver 2004^260^ 15195049 | nd [nd] | nd | 6 y (NRCS, retrospective) | Mortality | UPPP | nd | 2072 | HR | 1.31 | 1.03, 1.67 | 0.03 | NA | C
Weaver 2004^260^ 15195049 | nd [nd] | nd | 6 y (NRCS, retrospective) | Mortality | CPAP | nd | 20826 | | | | | NA | C
Katsantonis 1988^256^ 327 8184 | 70 UPPP 80 CPAP [nd] | nd | 18 mo (retrospective) | 50% improvement in AHI and 85% improvement in severity index | UPPP | 37 | 98 | % | 38 vs. 100 | nd | nd | NA | C
Katsantonis 1988^256^ 327 8184 | 70 UPPP 80 CPAP [nd] | nd | 18 mo (retrospective) | 50% improvement in AHI and 85% improvement in severity index | CPAP | 53 | 53 | | | | | NA | C
Keenan 1994^257^ 8275724 | nd [≥ 5] | nd | 28 to 43 mo (NRCS, retrospective) | Survival | UPPP | 6 | 149 | % | 4 vs. 2 | nd | NS | NA | C
Keenan 1994^257^ 8275724 | nd [≥ 5] | nd | 28 to 43 mo (NRCS, retrospective) | Survival | CPAP | 3 | 126 | | | | | NA | C
Anand 1991^255^ 1945423 | (nd) [nd] | nd | 16 d to 87mo (NRCS, retrospective) | Increased MSLT score ≥ 3 min | UPPP | 13 | 43 | % | 30 vs. 41 | nd | nd | NA | C
Anand 1991^255^ 1945423 | (nd) [nd] | nd | 16 d to 87mo (NRCS, retrospective) | Increased MSLT score ≥ 3 min | CPAP | 12 | 29 | | | | | NA | C

* Top row intervention vs. bottom row intervention.

Table 5.21.3 Survival in studies of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Keenan 1994^257^ 8275724 | nd [≥ 5] | nd | 28 to 43 mo (NRCS, retrospective) | Age adjusted 5 y probability of survival | UPPP | 149 | nd | 0.94 (0.02) * | −0.01 | nd | NS | NA | C
Keenan 1994^257^ 8275724 | nd [≥ 5] | nd | 28 to 43 mo (NRCS, retrospective) | Age adjusted 5 y probability of survival | CPAP | 126 | nd | 0.95 (0.03) † | | | | NA | C
Weaver 2004^260^ 15195049 | nd [nd] | nd | 4 y (NRCS, retrospective) | Survival (years) | UPPP | 2072 | nd | 2.81 | 0.06 | 0.0, 0.1 ‡ | 0.03 | NA | C
Weaver 2004^260^ 15195049 | nd [nd] | nd | 4 y (NRCS, retrospective) | Survival (years) | CPAP | 20, 826 | nd | 2.75 | | | | NA | C

* Mean (SE)

† Mean (SE)

‡ Estimated from reported P value

Table 5.21.4 AHI or RDI in studies of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Ceylan 2009^254^ 19770425 | 28 (6) [5–40] | 11.1 (3.1) | 12 mo (NRCS, prospective) | AHI | TCRFTVR | 26 | 29.6 (7.8) | −13.5 | −0.7 | −4.8, 3.4 * | NS | 0 | C
Ceylan 2009^254^ 19770425 | 28 (6) [5–40] | 11.1 (3.1) | 12 mo (NRCS, prospective) | AHI | CPAP | 21 | 28.5 (6.9) | −12.8 | | | | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) [nd] | nd | 3 mo (NRCS, prospective) | RDI | MMA | 24 | 59.4 (24.1) | −53.8 | 0.3 | −11.7, 12.3 † | NS | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) [nd] | nd | 3 mo (NRCS, prospective) | RDI | CPAP | 24 | 59.4 (24.1) | −54.1 | | | | 0 | C
Katsantonis 1988^256^ 327 8184 | 70 UPPP 80 CPAP [nd] | nd | 18 mo (retrospective) | AHI | UPPP | 98 | ~70 (nd) | −20 | 35 | nd | nd | NA | C
Katsantonis 1988^256^ 327 8184 | 70 UPPP 80 CPAP [nd] | nd | 18 mo (retrospective) | AHI | CPAP | 53 | ~80 (nd) | −55 | | | | NA | C
Lin 2006^258^ 16735919 | RDI 65 (24) vs. 44 (30) [nd] | 14.1 (4.4) vs. 11.8 (5.5) | 6 mo (NRCS, retrospective) | RDI | Extended UPP | 55 | 43.6 (29.7) | −31.5 | 31.1 | 12.5, 49.6 | <0.001 | NA | C
Lin 2006^258^ 16735919 | RDI 65 (24) vs. 44 (30) [nd] | 14.1 (4.4) vs. 11.8 (5.5) | 6 mo (NRCS, retrospective) | RDI | CPAP | 54 | 65.3 (24.7) | −62.6 | | | | NA | C
Vicini 2010^250^ 19944893 | 50 (12) [>30] | 11.2 (1.6) | 12 mo (PL RCT) | AHI | MMA | 25 | 56.8 (16.5) | −48.7 | −4.7 | −11.9, 2.5 | NS | 12% CPAP | C
Vicini 2010^250^ 19944893 | 50 (12) [>30] | 11.2 (1.6) | 12 mo (PL RCT) | AHI | CPAP | 25 | 50.3 (12.4) | −44 | | | | 12% CPAP | C

* Estimated from reported P value

† Estimated from reported data

Table 5.21.5 ESS in studies of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | RFA | 26 | 11.9 (4.6) | −2.1 | −0.2 | −2.4, 2.8 | NS | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | CPAP | 25 | 12.6 (5.0) | −2.3 | | | | 13 | A
Ceylan 2009^254^ 19770425 | 28 (6) [5–40 | 11.1 (3.1) | 12 mo (NRCS prospective) | TCRFTVR † | 26 | 10.8 (3.2) | −2.6 | +0.1 | −0.7, 0.9 ‡ | NS | 0 | C
Ceylan 2009^254^ 19770425 | 28 (6) [5–40 | 11.1 (3.1) | 12 mo (NRCS prospective) | CPAP | 21 | 11.1 (3.1) | −2.7 | | | | 0 | C
Lin 2006^258^ 16735919 | RDI 65 (24) vs. 44 (30) [nd] | 14.1 (4.4) vs. 11.8 (5.5) | 6 mo (NRCS, retrospective) | Extended UPP | 55 | 11.1 (3.72) | −3.78 | +1.09 | nd | NS | NA | C
Lin 2006^258^ 16735919 | RDI 65 (24) vs. 44 (30) [nd] | 14.1 (4.4) vs. 11.8 (5.5) | 6 mo (NRCS, retrospective) | CPAP | 54 | 14.1 (4.43) | −4.87 | | | | NA | C
Robinson 2009^259^ 19643262 | RDI 45 (nd) [>15] | 10.5 (8.75) § | 20–46 mo (NRCS, retrospective) | Surgery, stepwise approach | 77 | 9 (7) ** | −5 | 1.5 | −8.7, 11.7 †† | NS ‡‡ | NA | C
Robinson 2009^259^ 19643262 | RDI 45 (nd) [>15] | 10.5 (8.75) § | 20–46 mo (NRCS, retrospective) | CPAP | 89 | 10.5 (8.75) §§ | −6.5 | | | | NA | C
Vicini 2010^250^ 19944893 | 50 (12) [>30] | 11.2 (1.6) | 12 mo (PL RCT) | MMA | 25 | 11.6 (2.8) | −3.9 | 1.4 | −0.74, 3.5 | NS | 12% CPAP | C
Vicini 2010^250^ 19944893 | 50 (12) [>30] | 11.2 (1.6) | 12 mo (PL RCT) | CPAP | 25 | 11.2 (2.6) | −5.3 | | | | 12% CPAP | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | TCRFTVR *** | 50 | 11.1 (nd) | −3.7 | 0.7 | nd | nd | 15 | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | CPAP | 74 | 11.8 (nd) | −4.4 | | | | 15 | C

* two parts of methods section disagree with each other

† temperature controlled RF tissue volume reduction and septoplasty ± nasal valve suspension (somnoplasty)

‡ Estimated from reported P value

§ Median (IQR)

** Median (IQR)

†† Estimated from reported P value

‡‡ adjusted for age, RDI, Epworth, length of followup

§§ Median (IQR)

*** temperature controlled radiofrequency tissue volume reduction of the soft palate

Table 5.21.6 Other continuous outcomes in studies of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | FOSQ | RFA | 26 | 16.5 (2.0) | 1.2 | −0.29 | −1.35, 0.77 | NS | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | FOSQ | CPAP | 25 | 16.0 (2.6) | 1.5 | | | | 13 | A
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | Sleep efficiency | MMA | 24 | 80.2 (9.91) | 4 | −1 | −6.2, 4.2 † | NS | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | Sleep efficiency | CPAP | 24 | 80.2 (9.91) | 5 | | | | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | Arousal index | MMA | 24 | 54.3 (20.0) | −34.6 | 0.4 | −10.3, 11.1 | NS | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | Arousal index | CPAP | 24 | 54.3 (20.0) | −35 | | | | 0 | C
Ceylan 2009^254^ 19770425 | 28 (6) [5–40 | 11.1 (3.1) | 12 mo (NRCS, prospective) | Minimum O_2_ saturation | TCRFTVR | 26 | 86.8 (8.9) | 7.8 | 2.7 | −4.7, 10.2 ‡ | NS | 0 | C
Ceylan 2009^254^ 19770425 | 28 (6) [5–40 | 11.1 (3.1) | 12 mo (NRCS, prospective) | Minimum O_2_ saturation | CPAP | 21 | 88.4 (8.5) | 5.1 | | | | 0 | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | FOSQ | TCRFTVR | 18 | 72.3 (13.8) | 7.8 | −4.4 | −10.2, 1.4 § | NS | 15 | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | FOSQ | CPAP | 74 | 69.9 (19.7) | 12.2 | | | | 15 | C
Zorick 1990^253^ 2086548 | nd [nd] | nd | 6 wk (NRCS, prospective) | MSLT | UPPP | 46 | 4.1 (0.9) | 1.4 | −4.5 | −8.9, −0.02 ** | <0.05 | nd | C
Zorick 1990^253^ 2086548 | nd [nd] | nd | 6 wk (NRCS, prospective) | MSLT | CPAP | 46 | 4.4 (1.1) | 5.9 | | | | nd | C

* Two parts of methods section disagree with each other

† Estimated from reported data

‡ Estimated from reported P value

§ Estimated from reported P value

** Estimated from reported data

Table 5.21.7 Sleep stage in randomized controlled trials of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (Final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | REM | MMA | 24 | 19.6 (7.38) | 1.7 | 0.1 | −3.7, 3.9 * | NS | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | REM | CPAP | 24 | 19.6 (7.38) | 1.6 | | | | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | Stage 3 and 4 | MMA | 24 | 8.0 (6.08) | 6.4 | −3.8 | −8.9,1.3 † | NS | 0 | C
Conradt 1998^251^ 9785277 | RDI 59 (24) | nd | 3 mo (NRCS, prospective) | Stage 3 and 4 | CPAP | 24 | 8.0 (6.08) | 10.2 | | | | 0 | C
Zorick 1990^253^ 2086548 | nd [nd] | nd | 6 wk (NRCS, prospective) | REM | UPPP | 46 | 10 (5) | 3 | −8 | −15.9, −0.03 ‡ | <0.05 | nd | C
Zorick 1990^253^ 2086548 | nd [nd] | nd | 6 wk (NRCS, prospective) | REM | CPAP | 46 | 10 (6) | 11 | | | | nd | C
Zorick 1990^253^ 2086548 | nd [nd] | nd | 6 wk (NRCS, prospective) | Stage 3 and 4 | UPPP | 46 | 4.0 (6) | 1 | -−7 | −13.9, −0.03 § | <0.05 | nd | C
Zorick 1990^253^ 2086548 | nd [nd] | nd | 6 wk (NRCS, prospective) | Stage 3 and 4 | CPAP | 46 | 1.0 (3) | 8 | | | | nd | C

* Estimated from reported data

† Estimated from reported data

‡ Estiated from reported data

§ Estimated from reported data

Table 5.21.8 Quality of life outcomes in randomized controlled trials of surgery vs. CPAP

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | If Significant Difference | | | | | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | Test Range | | P Btw | Dropout, % | Study Quality
Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Outcome | Favors | Net Difference | 95% CI | “Worst” | “Best” | P Btw | Dropout, % | Study Quality
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | RFA (tongue & palate) | 24 | SF-36 (PCS, MCS) | 0 | | | | | | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | | | SF-36 (PCS, MCS) | 0 | | | | | | 13 | A
Woodson 2003^247^ 12825037 | 15 (7) [10–30 or 5–40] * | 11.6 (3.5) | 2 mo (PL RCT) | CPAP | 24 | SF-36 (PCS, MCS) | 0 | | | | | | 13 | A
Lin 2006^258^ 16735919 | RDI 65 (24) [nd] | 14.1 (4.4) | 6 mo (NRCS, retrospective) | Extended UPP | 55 | SF-36 (all domains) | 0 | | | | | | NA | C
Lin 2006^258^ 16735919 | RDI 65 (24) [nd] | 14.1 (4.4) | 6 mo (NRCS, retrospective) | | | SF-36 (all domains) | 0 | | | | | | NA | C
Lin 2006^258^ 16735919 | RDI 65 (24) [nd] | 14.1 (4.4) | 6 mo (NRCS, retrospective) | CPAP | 54 | SF-36 (all domains) | 0 | | | | | | NA | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | TCRFVTR | nd | SF-36 (all domains) | 0 | | | | | | NA | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | | | SF-36 (all domains) | 0 | | | | | | NA | C
Woodson 2001^252^ 11593163 | 40 (21) [15–60] | 11.8 (nd) | 8–12 wk (NRCS, prospective) | nCPAP | nd | SF-36 (all domains) | 0 | | | | | | NA | C

* Two parts of methods section disagree with each other

Table 5.23.1 Randomized controlled trials of drug interventions: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Carley 2007^264^ 17310863 | Mirtazapine 4.5 or 15 mg | 41 | 58 | 37.8 | Most pts with HTN excluded | US (nd) | -
Carley 2007^264^ 17310863 | Placebo | 41 | 58 | 37.8 | Most pts with HTN excluded | US (nd) | -
Clarenbach 2008^269^ 18710420 | Xylometazoline | 49 | 87 | 30.7 | nd | Switzerland (2004–05) | -
Clarenbach 2008^269^ 18710420 | Placebo | 49 | 87 | 30.7 | nd | Switzerland (2004–05) | -
Kiely 2004^265^ 14694248 | Fluticasone | 47 | nd | 29.8 | Snorers | Ireland (nd) | -
Kiely 2004^265^ 14694248 | placebo | 47 | nd | 29.8 | Snorers | Ireland (nd) | -
Kraiczi 1999^266^ 9989366 | Paroxetine | 53 | 100 | 28.7 | No | Sweden (nd) | -
Kraiczi 1999^266^ 9989366 | Placebo | 53 | 100 | 28.7 | No | Sweden (nd) | -
Suurna 2008^268^ 18656731 | Pantoprazole | 51 | 42 | 31 | All patients have GERD | US (2004–06) | -
Suurna 2008^268^ 18656731 | Placebo | 51 | 42 | 31 | All patients have GERD | US (2004–06) | -
Ryan 2009^205^ 19961025 | Steroid + CPAP | 48 | 94 | 34 | nd | Ireland (nd) | -
Ryan 2009^205^ 19961025 | Dry CPAP | 48 | 94 | 34 | nd | Ireland (nd) | -
Whyte 1988^267^ 3067313 | Acetazolamide or Protriptyline | nd | 80 | nd | nd | UK (nd) | No information on exclusion criteria
Whyte 1988^267^ 3067313 | Placebo | nd | 80 | nd | nd | UK (nd) | No information on exclusion criteria

Table 5.23.2 AHI (events/hr) in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 4.5 mg | 12 | nd | 13.5 | −8.8 | −14.8, −2.8^*^ | 0.004 | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | | | | | | | | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 15 mg | 12 | nd | 11.4 | −10.9 | −18.3, −3.5^†^ | 0.004 | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | | | | | | | | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Placebo | 12 | nd | 22.3 | | | | 0 | B
Clarenbach 2008^269^ 18710420 | 33 (25) [>10] | 11.8 (4.5) | 1 wk (XO) | Xylometazoline | 12 | 32.6 (24.5) | 29.3 (32.5) | −2.9 | −21.4, 15.6 ‡ | NS | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (25) [>10] | 11.8 (4.5) | 1 wk (XO) | | | | | | | | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (25) [>10] | 11.8 (4.5) | 1 wk (XO) | Placebo | 12 | 32.6 (24.5) | 32.2 (32.8) | | | | 0 | A
Kiely 2004^265^ 14694248 | 26 § (27) ** | 12 (nd) | 4 wk (XO) | Fluticasone | 13 | 26.5 (26.9) †† | 23.3 | −6.5 ‡‡ | −29.5, 1.8 | <0.05 | 0 | B
Kiely 2004^265^ 14694248 | 26 § (27) ** | 12 (nd) | 4 wk (XO) | | | | | | | | 0 | B
Kiely 2004^265^ 14694248 | 26 § (27) ** | 12 (nd) | 4 wk (XO) | Placebo | 13 | 26.5 (26.9) | 30.3 | | | | 0 | B
Kiely 2004^265^ 14694248 | 26 § (27) ** | 12 (nd) | 4 wk (XO) | Fluticasone | 18 §§ | nd | 17 | −5.6 *** | −22.6, −0.7 | 0.01 | 0 | B
Kiely 2004^265^ 14694248 | 26 § (27) ** | 12 (nd) | 4 wk (XO) | | | | | | | | 0 | B
Kiely 2004^265^ 14694248 | 26 § (27) ** | 12 (nd) | 4 wk (XO) | Placebo | 13 ††† | nd | 24.3 | | | | 0 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Paroxetine | 17 | nd | 30.2 | −6.1 | −17.9, 0.6 | 0.021 | 15 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | | | | | | | | 15 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Placebo | 17 | nd | 36.3 | | | | 15 | B
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Acetazolamide | 10 | nd | 26 | −24 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | | | | | | | | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Protriptyline | 10 | nd | 46 | −4 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | | | | | | | | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Placebo | 10 | nd | 50 | | | | 0 | C

* Estimated from reported P value

† Estimated from reported P value

‡ Estimated from reported data

§ Median

** Quartile range

†† Median (quartile range)

‡‡ Median

§§ Using definition of AHI ≥ 5 instead of AHI ≥ 10

*** Median

††† Using definition of AHI ≥ 5 instead of AHI ≥ 10

Table 5.23.3 ESS in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Xylometazoline | 12 | nd | 10.5 (3.8) | −1.3 | −3.6, 1.0 * | NS | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Placebo | 12 | nd | 11.8 (4.4) | | | | 0 | A
Suurna 2008^268^ 18656731 | 10 (8) [≤30] | 14 (3.5) | 2 wk (XO) | Pantoprazole | 57 | 14 (3.5) | −1.8 | −0.5 | −0.98, −0.02 † | 0.04 | 16 | B
Suurna 2008^268^ 18656731 | 10 (8) [≤30] | 14 (3.5) | 2 wk (XO) | Placebo | 57 | 14 (3.5) | −1.3 | | | | 16 | B
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12 (5) | 4 wk (PL) | Steroid + CPAP | 42 | 13 (6) | −4 | −1 | −4.0, 2.0 ‡ | nd | 9 | B
Ryan 2009^205^ 19961025 | 36 (22) [≥10] | 12 (5) | 4 wk (PL) | Dry CPAP | 39 | 12 (5) | −3 | | | | 9 | B

* Estimated from reported data.

† Estimated from reported P value.

‡ Estimated from reported data.

Table 5.24.4 Arousal index (events/hr) in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 4.5 mg | 12 | nd | 41.9 | 0.8 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 15 mg | 12 | nd | 28.1 | −13.0 | −24, −2 * | 0.02 | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Placebo | 12 | nd | 41.1 | | | | 0 | B
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Xylometazoline | 12 | nd | 54 | −2 | nd | NS | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Placebo | 12 | nd | 56 | | | | 0 | A
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Acetazolamide | 10 | nd | 16 | −10 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Protriptyline | 10 | nd | 21 | −5 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Placebo | 10 | nd | 26 | | | | 0 | C

* Estimated from reported P value

Table 5.24.5 Sleep efficiency (%) in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 4.5 mg | 12 | nd | 87.7 | 4.8 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 15 mg | 12 | nd | 90.1 | 8.2 | nd | 0.05 | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Placebo | 12 | nd | 82.9 | | | | 0 | B
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Xylometazoline | 12 | nd | 86 (12) | −2 | nd | NS | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Placebo | 12 | nd | 88 (6) | | | | 0 | A
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Paroxetine | 17 | nd | 77.2 | −2.9 | −10.6,4.3 | 0.411 | 15 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Placebo | 17 | nd | 80.3 | | | | 15 | B
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Acetazolamide | 10 | nd | 82 * | 12 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Protriptyline | 10 | nd | 78 † | 8 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Placebo | 10 | nd | 70 ‡ | | | | 0 | C

* Estimated from Figure 4 in paper

† Estimated from Figure 4 in paper

‡ Estimated from Figure 4 in paper

Table 5.23.6 Slow wave sleep (%) in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 4.5 mg | 12 | nd | 7.5 | 2.4 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 15 mg | 12 | nd | 7.2 | 2.1 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Placebo | 12 | nd | 5.1 | | | | 0 | B
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Xylometazoline | 12 | nd | 9 (8) | −2 | nd | NS | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Placebo | 12 | nd | 7 (6) | | | | 0 | A
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Paroxetine | 17 | nd | 12.2 | −0.6 | −6.4, 4.7 | 0.411 | 15 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Placebo | 17 | nd | 12.8 | | | | 15 | B
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Acetazolamide | 10 | nd | 14 * | −1 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Protriptyline | 10 | nd | 15 † | 0 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Placebo | 10 | nd | 15 ‡ | | | | 0 | C

* Estimated from Figure 4 in paper

† Estimated from Figure 4 in paper

‡ Estimated from Figure 4 in paper

Table 5.23.7 REM sleep (%) in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [Eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 4.5 mg | 12 | nd | 15.6 | −6.6 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | | | | | | | | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 15 mg | 12 | nd | 16.6 | −5.6 | nd | 0.04 | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | | | | | | | | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Placebo | 12 | nd | 22.2 | | | | 0 | B
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Xylometazoline | 12 | nd | 10 (5) | −1 | nd | NS | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | | | | | | | | 0 | A
Clarenbach 2008^269^ 18710420 | 33 (24) [>10] | 11.8 (4.5) | 1 wk (XO) | Placebo | 12 | nd | 11 (5) | | | | 0 | A
Kiely 2004^265^ 14694248 | 26.5 * (26.9) † | 12 (nd) | 4 wk (XO) | Fluticasone | 13 | nd | 10.9 | 0.4 ‡ | nd | NS | 0 | B
Kiely 2004^265^ 14694248 | 26.5 * (26.9) † | 12 (nd) | 4 wk (XO) | | | | | | | | 0 | B
Kiely 2004^265^ 14694248 | 26.5 * (26.9) † | 12 (nd) | 4 wk (XO) | Placebo | 13 | nd | 10.5 | | | | 0 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Paroxetine | 17 | nd | 9.7 | nd | −7.4, 1.4 | 0.191 | 15 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | | | | | | | | 15 | B
Kraiczi 1999^266^ 9989366 | nd | nd | 6 wk (XO) | Placebo | 17 | nd | 12.9 | | | | 15 | B
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Acetazolamide | 10 | nd | 23 | 4 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Protriptyline | 10 | nd | 18 | −1 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Placebo | 10 | nd | 19 | | | | 0 | C

* Median

† Quartile range

‡ Median

Table 5.23.8 Minimum oxygen saturation (%) in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 4.5 mg | 12 | nd | 81.1 | −0.6 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Mirtazapine 15 mg | 12 | nd | 80.8 | −0.9 | nd | NS | 0 | B
Carley 2007^264^ 17310863 | 23 (17) [nd] | nd | 7 d (XO) | Placebo | 12 | nd | 81.7 | | | | 0 | B
Kiely 2004^265^ 14694248 | 26.5 ^*^ (26.9) ^†^ | 12 (nd) | 4 wk (XO) | Fluticasone | 13 | nd | 2.1 | −0.1 | nd | NS | 0 | B
Kiely 2004^265^ 14694248 | 26.5 ^*^ (26.9) ^†^ | 12 (nd) | 4 wk (XO) | Placebo | 13 | nd | 2.2 | | | | 0 | B
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Acetazolamide | 10 | nd | 72 | 2 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Protriptyline | 10 | nd | 77 | 7 | nd | nd | 0 | C
Whyte 1988^267^ 3067313 | nd [>15] | nd | 2 wk (XO) | Placebo | 10 | nd | 70 | | | | 0 | C

Table 5.23.9 FOSQ in randomized controlled trials of drug interventions

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Suurna 2008^268^ 18656731 | 10 (8) [≤30] | 14 (3.5) | 2 wk (XO) | Pantoprazole | 57 | nd | −8.1 | −2.6 | −5.3, 0.1 ‡ | 0.06 | 16 | B
Suurna 2008^268^ 18656731 | 10 (8) [≤30] | 14 (3.5) | 2 wk (XO) | Placebo | 57 | nd | −5.5 | | | | 16 | B

* Median

† Quartile range

‡ Estimated from reported P value.

Table 5.24.1 Randomized controlled trials of atrial overdrive pacing: study characteristics

Study PMID | Interventions | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Other quality issues
Melzer 2006^270^ 17040007 | AOP 75 bpm | 69 | 84% | 29.5 | nd | Germany, Switzerland (nd) | Dropout >20%, patient not blinded.
Melzer 2006^270^ 17040007 | AOP 45 bpm | 69 | 84% | 29.5 | nd | Germany, Switzerland (nd) | Dropout >20%, patient not blinded.
Simantirakis 2005^271^ 16354893 | AOP | 60 | 75% | nd | Bradyarrhythmia (pacer) | Greece | No description of how pressure was titrated.
Simantirakis 2005^271^ 16354893 | CPAP | 60 | 75% | nd | Bradyarrhythmia (pacer) | Greece | No description of how pressure was titrated.

Table 5.24.2 AHI (events/hr) in randomized controlled trials of atrial overdrive pacing

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Melzer 2006^270^ 17040007 | 27 * (nd) [>15] | 9.0 (3.9) | 1 wk (XO) | AOP 75 bpm | 19 | nd | 23.0 | −3.8 | −14.6, 7.0 † | 0.49 | 5 | A
Melzer 2006^270^ 17040007 | 27 * (nd) [>15] | 9.0 (3.9) | 1 wk (XO) | AOP 45 bpm | 19 | nd | 26.8 | | | | 5 | A
Simantirakis 2005^271^ 16354893 | 49 (19) [nd] | 15.7 (nd) | 1 mo (XO) | AOP | 16 | 49.0 (19) | 0.2 | 46.5 | −9.8, 27.8 ‡ | nd | 0 | B
Simantirakis 2005^271^ 16354893 | 49 (19) [nd] | 15.7 (nd) | 1 mo (XO) | CPAP | 16 | 49.0 (19) | −46.3 | | | | 0 | B

* Estimated from control value

† Estimated from reported P value.

‡ Estimated from reported data.

Table 5.24.3 ESS in randomized Controlled trials of atrial overdrive pacing

Study PMID | Baseline AHI (SD) [range] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Simantirakis 2005^271^ 16354893 | 49.0 (nd) | 15.7 (nd) | 1 mo (XO) | AOP | 16 | 15.7 (nd) | 0.1 | 10.3 | nd | nd | 0% | B
Simantirakis 2005^271^ 16354893 | 49.0 (nd) | 15.7 (nd) | 1 mo (XO) | CPAP | 16 | 15.7 (nd) | −10.2 | | | | 0% | B

Table 5.24.4 REM and Slow Wave Sleep (%) in randomized controlled trials of atrial overdrive pacing

Study PMID | Baseline AHI (SD) [eligibility] | Baseline ESS (SD) | Duration (design) | Outcome | Interventions | No. Analyzed | Baseline (SD) | Change (final) | Net Diff or Diff | 95% CI | P Btw | Dropout, % | Study Quality
Melzer 2006^270^ 17040007 | nd | 9.0 (3.9) | 1 wk (XO) | REM (%) | AOP 75 bpm | 19 | nd | 0 | 0 | nd | 0.93 | 5% | A
Melzer 2006^270^ 17040007 | nd | 9.0 (3.9) | 1 wk (XO) | REM (%) | AOP 45 bpm | 19 | nd | 0 | | | | 5% | A
Melzer 2006^270^ 17040007 | nd | 9.0 (3.9) | 1 wk (XO) | Slow wave sleep (%) | AOP 75 bpm | 19 | nd | 14 | −3.8 | −46.0, 38.4 * | 0.86 | 5% | A
Melzer 2006^270^ 17040007 | nd | 9.0 (3.9) | 1 wk (XO) | Slow wave sleep (%) | AOP 45 bpm | 19 | nd | 13 | | | | 5% | A

* Estimated from reported P value.

Table 5.25.1 Positive airway pressure devices, reported major adverse events * †

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Robinson, 2009^259^ 19643262 | CPAP | 2–4 mo | 73 | Claustrophobia | 1 | 1.4%
Hukins, 2004^183^ 15683142 | CPAP | 2 mo | 55 | Pressure intolerance | 5 | 9.2%
Hukins, 2004^183^ 15683142 | AutoCPAP | 2 mo | 55 | Pressure intolerance | 2 | 3.6%
Salgado, 2008^207^ 18982206 | AutoCPAP, humidified | 4 wk | 17 | Epistaxis | 0 | 0
Salgado, 2008^207^ 18982206 | AutoCPAP, nonhumidified | 4 wk | 22 | Epistaxis | 2 | 9.1%
Khanna, 2003^173^ 14592306 | Nasal CPAP | 1 mo | 17 | Excessive nasal dryness | 2 | 12%
Khanna, 2003^173^ 14592306 | Nasal CPAP | 1 mo | 17 | Epistaxis | 2 | 12%
Khanna, 2003^173^ 14592306 | Nasal CPAP | 2 mo | 15 | Excessive pressure | 2 | 13%
Khanna, 2003^173^ 14592306 | Nasal CPAP | 2 mo | 13 | Severe claustrophobia | 3 | 23%
Khanna, 2003^173^ 14592306 | Oral CPAP | 1 mo | 21 | Excessive oral dryness | 11 | 52%
Khanna, 2003^173^ 14592306 | Oral CPAP | 1 mo | 21 | Severe gum pain | 3 | 14%
Khanna, 2003^173^ 14592306 | Oral CPAP | 1 mo | 21 | Excessive pressure | 4 | 19%
Nussbaumer, 2006^179^ 16537862 | AutoCPAP | 1 mo | 34 | Claustrophobia | 1 | 2.9%
Anderson, 2003^171^ 14572126 | Nasal CPAP | 1 mo | 21 | Claustrophobia | 1 | 4.8%
Anderson, 2003^171^ 14572126 | Oral CPAP | 1 mo | 21 | Dry mouthr/throat (major problem) | 3 | 14%
Anderson, 2003^171^ 14572126 | Oral CPAP | 1 mo | 21 | Excess salivation (major problem) | 1 | 4.8%
Anderson, 2003^171^ 14572126 | Oral CPAP | 1 mo | 21 | Sore gums/lips (major problem) | 2 | 9.5%

* Reporting of no events excluded (unless N≥100), except Salgado 2008 because the direct comparison between humidified and nonhumidified CPAP was reported.

† Other adverse events (or side effects or harms) reported by studies included: skin irritation, nasal irritation or obstruction, dry nose or mouth, excess salivation, minor or moderate sore gums or lips, minor aerophagia, abdominal distension, minor chest wall discomfort, pressure discomfort, and transient or minor epistaxis.

Table 5.25.2 Mandibular advancement devices, reported major adverse events *,†

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Engleman, 2002^225^ 12231497 | Custom-made (80% maximal comfortable mandibular protrusion, 2–4 mm interdental clearance) | 8 wk | 48 | Dental crown damaged | 3 | 6.3%
Walker- Engstrom 2002^262^ 11888954 | Custom-made (50% maximal mandibular advancement, 5 mm vertical opening) | 4 yr | 45 | Tooth malocclusion and TMJ pain | 1 | 2.2%
Walker- Engstrom 2002^262^ 11888954 | Custom-made (50% maximal mandibular advancement, 5 mm vertical opening) | 4 yr | 45 | Aphthous ulcer due to acrylic polymer allergy | 1 | 2.2%
Petri, 2008^212^ 18482111 | Custom-made (maximal comfortable mandibular advancement, 5 mm vertical opening) | 4 wk | 31 | Teeth loosening | 1 | 3.2%
Petri, 2008^212^ 18482111 | Custom-made (maximal comfortable mandibular advancement, 5 mm vertical opening) | 4 wk | 31 | TMJ pain | 1 | 3.2%
Ferguson 1996^226^ 8625679 | Snore-Guard (mandible 3 mm posterior to maximal acceptable advance, 7 mm opening) | 4 mo | 25 | Moderate to severe jaw discomfort | 1 | 4.0%
Johnston, 2002^216^ 12143089 | Custom-made (75% maximal comfortable mandibular protrusion, 4 mm interincisal clearance) | 4–6 wk | 19 | Persistent daytime TMJ discomfort | 1 | 5.2%

* Reporting of no events excluded (unless N≥100).

† Other adverse events (or side effects or harms) reported by studies included: pressure sensation in the mouth, transient morning mouth and TMJ discomfort or sounds, minor sore teeth or jaw, transient mild mucosal erosions, minor excessive salivation, tooth grinding, and sleep disruption.

Table 5.25.3 Surgical intervention (UPPP primarily), reported major adverse events *,†,§,**

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Death | 7 | 0.2%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Reintubation | 17 | 0.5%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Emergency tracheotomy | 7 | 0.2%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Ventilation >48 hr | 6 | 0.2%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Pneumonia | 11 | 0.4%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Cardiovascular complication | 8 | 0.3%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Hemorrhage | 9 | 0.3%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Deep vein thrombosis | 0 | 0%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Kidney failure | 0 | 0%
Kezirian, 2004^277^ 15091217 | UPPP ± tonsil, nasal, turbinate surgery | 30 days | 3130 | Total serious complications (including death) | 51 | 1.6%
Lundkvist 2009^278^ 19863325 | UPPP (with tonsillectomy) | 1 yr | 158 | Bleeding from tonsillectomy, profuse | 2 | 1.3%
Lundkvist 2009^278^ 19863325 | UPPP (with tonsillectomy) | 1 yr | 158 | Laryngeal edema, substantial | 2 | 1.3%
Lundkvist 2009^278^ 19863325 | UPPP (with tonsillectomy) | 1 yr | 158 | Long-term sequelae from complications | 0 | 0%
Lundkvist 2009^278^ 19863325 | UPPP (with tonsillectomy) | 1 yr | 158 | Death | 0 | 0%
Esclamado 1989^279^ 2530406 | UPPP ± tonsil, nasal surgery, tracheostomy | 24 hr | 135 | Reintubation (long-term sequelae = 0/135) | 7 | 5.2%
Esclamado 1989^279^ 2530406 | UPPP ± tonsil, nasal surgery, tracheostomy | 24 hr | 135 | Death | 1 | 0.7%
Esclamado 1989^279^ 2530406 | UPPP ± tonsil, nasal surgery, tracheostomy | 24 hr | 135 | Pulmonary edema | 1 | 0.7%
Esclamado 1989^279^ 2530406 | UPPP ± tonsil, nasal surgery, tracheostomy | 24 hr | 135 | Hemorrhage, requiring surgical intervention | 3 | 2.2%
Friedman, 2004^280^ 15091218 | UPPP | Perioperative | 134 | Airway complication | 0 | 0%
Friedman, 2004^280^ 15091218 | UPPP | Perioperative | 134 | Abscess requiring surgical intervention | 0 | 0%
Friedman, 2004^280^ 15091218 | UPPP | Perioperative | 134 | Rehospitalization | 0 | 0%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 126 | Oropharyngeal hemorrhage | 7 | 5.5%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 126 | Voice change (rhinolalia) | 2 | 0.6%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 126 | Nasopharyngeal reflux | 0 | 0%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 126 | Pharyngeal infection | 0 | 0%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 132 ‡ | Pneumonia | 2 | 1.5%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 132 ‡ | Death | 2 | 1.5%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 132 ‡ | Emergency tracheotomy | 2 | 1.5%
Harmon 1989^281^ 2916139 | UPPP ± nasal, adenoid, tracheostomy | 3 mo | 132 ‡ | Intubation difficulty and/or pulmonary edema or respiratory arrest | 6 | 4.5%
Haavisto 1994^282^ 7923849 | UPPP | Postoperative | 101 | Hemorrhage requiring surgical intervention | 5 | 5.0%
Haavisto 1994^282^ 7923849 | UPPP | Postoperative | 101 | Tracheostomy | 4 | 4.0%
Haavisto 1994^282^ 7923849 | UPPP | Postoperative | 101 | Asystole, post-extubation | 1 | 1.0%
Haavisto 1994^282^ 7923849 | UPPP | Postoperative | 101 | Infection | 0 | 0%
Haavisto 1994^282^ 7923849 | UPPP | Postoperative | 101 | Arrhythmia | 0 | 0%
Haavisto 1994^282^ 7923849 | UPPP | 1 yr | 91 | Nasopharyngeal regurgitation | 22 | 24%
Haavisto 1994^282^ 7923849 | UPPP | 1 yr | 91 | Difficulty swallowing | 9 | 10%
Haavisto 1994^282^ 7923849 | UPPP | 1 yr | 91 | Difficulty with speech or change in voice quality | 14 | 15%
Haavisto 1994^282^ 7923849 | UPPP | 1 yr | 91 | Loss of taste | 2 | 2.2%
Haavisto 1994^282^ 7923849 | UPPP | 1 yr | 91 | Breathing difficulty | 5 | 5.5%
Haavisto 1994^282^ 7923849 | UPPP | 1 yr | 91 | Hemorrhage | 1 | 1.1%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Velopharyngeal incompetence >1 mo | 8 | 12%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Voice change, long term | 1 | 1.5%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Choanal stenosis, unilateral | 1 | 1.5%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Bleeding, requiring surgical intervention | 1 | 1.5%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Reintubation | 1 | 1.5%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Death | 1 | 1.5%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Nasal synechiae | 2 | 3.0%
Anand 1991^255^ 1945423 | UPPP ± nose, turbinate, tonsil, epiglottis surgery, tracheostomy | 16 d – 7.25 yr | 66 | Tracheal stenosis | 1 | 1.5%
Walker- Engstrom 2002^262^ 11888954 | UPPP | 4 yr | 40 | Nasopharyngeal regurgitation of fluids (pronounced) | 3 | 8%
Walker- Engstrom 2002^262^ 11888954 | UPPP | 4 yr | 40 | Difficulty swallowing (pronounced) | 4 | 10%
Ferguson, 2003^245^ 12502473 | LAUP | nd | 21 | Swallowing difficulty, persistent, moderate | 1 | 4.8%
Ferguson, 2003^245^ 12502473 | LAUP | nd | 21 | Bleeding, requiring medical attention | 1 | 4.8%
Lojander, 1996^124^ 8681614 | UPPP ± osteotomy | 12 mo | 18 | Tracheotomy × 1 mo | 1 | 5.6%
Lojander, 1996^124^ 8681614 | UPPP ± osteotomy | 12 mo | 18 | Infection, requiring surgical intervention | 2 | 11%
Lojander, 1996^124^ 8681614 | UPPP ± osteotomy | 12 mo | 18 | Velopharyngeal incompetence | 2 | 11%

* Reporting of no events excluded (unless N≥100).

† Other adverse events (or side effects or harms) reported by studies included: unplanned medications, mild transient pain and swallowing difficulty, postoperative (minor) hematomas or ulcerations, mild bleeding, mild and transient tongue deviation, transient swelling sensation, pharyngeal dryness, nasal regurgitation (transient), increased mucus secretion, gagging, cough, infection (self-limited), antibiotic-related diarrhea, burning sensation, anosmia, temporary vocal quality change, and difficulty singing, playing saxophone, etc.

‡ Including patients who received tracheostomy, tonsillectomy, and/or septoplasty without UPPP.

§ Reporting of no events excluded (unless N≥100).

** Other adverse events (or side effects or harms) reported by studies included: unplanned medications, mild transient pain and swallowing difficulty, postoperative (minor) hematomas or ulcerations, mild bleeding, mild and transient tongue deviation, transient swelling sensation, pharyngeal dryness, nasal regurgitation (transient), increased mucus secretion, gagging, cough, infection (self-limited), antibiotic-related diarrhea, burning sensation, anosmia, temporary vocal quality change, and difficulty singing, playing saxophone, etc.

Table 5.25.4 Radiofrequency ablation, reported major adverse events *,†

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Stuck 2003 ‡,283 12797590 | RFVTR, tongue base or soft palate or turbinates or combination ± other oropharyngeal, nasal, hyoid surgery | 3–8 days | 497 | Tongue base ulceration, requiring surgical intervention | 3 | 0.6%
Stuck 2003 ‡,283 12797590 | RFVTR, tongue base or soft palate or turbinates or combination ± other oropharyngeal, nasal, hyoid surgery | 3–8 days | 497 | Soft palate mucosa ulceration, requiring surgical intervention | 1 | 0.2%
Stuck 2003 ‡,283 12797590 | RFVTR, tongue base or soft palate or turbinates or combination ± other oropharyngeal, nasal, hyoid surgery | 3–8 days | 497 | Dysphagia requiring hospitalization | 4 | 0.8%
Stuck 2003 ‡,283 12797590 | RFVTR, tongue base or soft palate or turbinates or combination ± other oropharyngeal, nasal, hyoid surgery | 3–8 days | 497 | Hypoglossal nerve palsy, temporary | 1 | 0.2%
Stuck 2003 ‡,283 12797590 | RFVTR, tongue base or soft palate or turbinates or combination ± other oropharyngeal, nasal, hyoid surgery | 3–8 days | 497 | Tongue base abscess, requiring surgical intervention | 1 | 0.2%
Stuck 2003 ‡,283 12797590 | RFVTR, tongue base or soft palate or turbinates or combination ± other oropharyngeal, nasal, hyoid surgery | >8 days | 422 | Long-term complications | 0 | 0%
Woodson, 2001^252^ 11593163 | RFVTR, tongue base | 6 wk | 73 | Severe, suppurative tongue base infection (2 required surgical intervention, 2 drained spontaneously) | 4 | 5.5%
Woodson, 2001^252^ 11593163 | RFVTR, tongue base | 6 wk | 73 | Tongue abscess | 1 | 1.4%
Woodson, 2001^252^ 11593163 | RFVTR, tongue base | 6 wk | 73 | Infection or cellulitis | 7 | 9.6%

* Reporting of no events excluded (unless N≥100).

† Other adverse events (or side effects or harms) reported by studies included: unplanned medications, mild transient pain and swallowing difficulty, postoperative (minor) hematomas or ulcerations, mild and transient tongue deviation, transient swelling sensation, and asymptomatic fibrotic narrowing.

‡ Complication rate decreased over time, 1999–2002.

Table 5.25.5 Combination or various surgeries, reported major adverse events *,†

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Riley, 1993^284^ 8441535 | UPPP + MO/GAHM ‡ | Postoperative | 233 | Bleeding requiring anesthesia | 3 | 1.3%
Riley, 1993^284^ 8441535 | UPPP + MO/GAHM ‡ | 9 mo | 233 | Long-term speech or swallowing problem | 0 | 0%
Riley, 1997^285^ 9419093 | UPPP + GA + HS § UPPP ± GA ± HS ± MMO | 3–7 days | 182 ** | Bleeding (not described) | 4 | 1.9%
Riley, 1997^285^ 9419093 | UPPP + GA + HS § UPPP ± GA ± HS ± MMO | 3–7 days | 182 ** | New onset atrial fibrillation | 4 | 1.9%
Riley, 1997^285^ 9419093 | UPPP + GA + HS § UPPP ± GA ± HS ± MMO | 3–7 days | 182 ** | New unstable angina | 1 | 0.5%
Riley, 1997^285^ 9419093 | UPPP + GA + HS § UPPP ± GA ± HS ± MMO | 3–7 days | 182 ** | Death | 0 | 0%
Friedman, 2004^280^ 15091218 | UPPP + Tongue RFA | Perioperative | 143 | Hypoglossal nerve paralysis | 1 | 0.7%
Friedman, 2004^280^ 15091218 | UPPP + Tongue RFA | Perioperative | 143 | Nerve paralysis (transient) | 2 | 1.4%
Friedman, 2004^280^ 15091218 | UPPP + Tongue RFA | Perioperative | 143 | Airway complication | 0 | 0%
Friedman, 2004^280^ 15091218 | UPPP + Tongue RFA | Perioperative | 143 | Abscess requiring surgical intervention | 0 | 0%
Friedman, 2004^280^ 15091218 | UPPP + Tongue RFA | Perioperative | 143 | Rehospitalization | 0 | 0%
Friedman, 2007^286^ 17713449 | 3-level: Tongue RF, Pillar implants, partial uvulectomy, nasal, turbinate surgery | nd | 122 | Major complication | 0 | 0%
Friedman, 2007^286^ 17713449 | 3-level: Tongue RF, Pillar implants, partial uvulectomy, nasal, turbinate surgery | nd | 122 | Nasal septum perforation, tongue mucosal ulceration, & hypoglossal nerve weakness <1 month | 1 | 0.8%
Friedman, 2007^286^ 17713449 | 3-level: Tongue RF, Pillar implants, partial uvulectomy, nasal, turbinate surgery | nd | 122 | Turbinate bone exposure | 2 | 1.6%
Friedman, 2007^286^ 17713449 | 3-level: Tongue RF, Pillar implants, partial uvulectomy, nasal, turbinate surgery | nd | 122 | Pillar extrusion requiring removal and replacement | 5 | 4.1%
Benazzo, 2008^287^ 18568505 | HS + nasal, turbinate, palate surgery | 6 mo | 109 | “Major complication” | 0 | 0%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Paresthesia | 11 | 17%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Dysphagia | 7 | 11%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Voice change | 2 | 3.1%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Taste alteration | 1 | 1.6%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Wound dehiscence | 1 | 1.6%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Infection | 2 | 3.1%
Robinson, 2009^259^ 19643262 | Stepwise UPPP, GA, TAP, HS, Tongue RFA | nd | 64 | Palatal fistula (transient) | 1 | 1.6%

* Reporting of no events excluded (unless N≥100).

† Other adverse events (or side effects or harms) reported by studies included: aspiration, neck seroma, transient dysphagia, transient tongue base ulceration, suture removal for foreign body reaction, and transient facial anesthesia.

‡ Small number with only UPPP or only MO/GAHM.

§ Mostly

** 210 procedures in 182 patients

Table 5.25.6 Surgical implant, reported major adverse events *

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Steward, 2008^243^ 18922335 | Pillar implant | 1 wk | 50 | Infection | 1 | 2%
Steward, 2008^243^ 18922335 | Pillar implant | 1 wk | 50 | Extrusion | 2 | 4%

* Reporting of no events excluded (unless N≥100). Other reported adverse events included sore throat and foreign body sensation.

Table 5.25.7 Bariatric surgery, reported major adverse events *

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Grunstein, 2007^272^ 17580591 | Vertical banded gastroplasty (72%) Gastric banding (20%) Gastric bypass (8%) | Perioperative | 1592 | Perioperative mortality | ~3 | 0.21%
Grunstein, 2007^272^ 17580591 | Vertical banded gastroplasty (72%) Gastric banding (20%) Gastric bypass (8%) | Perioperative | 1592 | Bleeding, embolus and/or thrombosis, wound complications, deep infections, pulmonary, and other complications | ~207 | 13.0%

* Reporting of no events excluded (unless N≥100).

Table 5.25.8 Weight loss diet, reported major adverse events *

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Johansson, 2009^237^ 19959590 | Liquid, very low energy diet | 9 wk | 30 | Elevated alanine aminotransferase concentration (transient) | 2 | 6.7%
Johansson, 2009^237^ 19959590 | Liquid, very low energy diet | 9 wk | 30 | Gout (transient) | 1 | 3.3%

* Reporting of no events excluded (unless N≥100). Other reported adverse events included dizziness, dry lips, and constipation.

Table 5.25.9 Drugs, reported major adverse events *

Study PMID | Intervention details | Followup duration | No. Analyzed | Adverse event | n | %
Bradshaw, 2006^288^ 17099012 | Zolpidem | 4 wk | 72 | Sleep walking | 1 | 1.4%
Kraiczi, 1999^266^ 9989366 | Paroxetine † | 6 wk | 20 | Ejaculation disturbance | 3 | 15%
Kraiczi, 1999^266^ 9989366 | Paroxetine † | 6 wk | 20 | Decreased libido | 2 | 10%
Kraiczi, 1999^266^ 9989366 | Paroxetine † | 6 wk | 20 | Headache | 1 | 5%
Kraiczi, 1999^266^ 9989366 | Paroxetine † | 6 wk | 20 | Constipation | 1 | 5%
Whyte, 1988^267^ 3067313 | Protriptyline | 2 wk | 10 | Severe dry mouth requiring discontinuation | 2 | 20%
Whyte, 1988^267^ 3067313 | Protriptyline | 2 wk | 10 | Visual upset | 1 | 10%
Whyte, 1988^267^ 3067313 | Protriptyline | 2 wk | 10 | Urinary symptoms | 1 | 10%
Whyte, 1988^267^ 3067313 | Protriptyline | 2 wk | 10 | Altered sexual potency & testicular discomfort | 1 | 10%
Whyte, 1988^267^ 3067313 | Acetazolamide | 2 wk | 10 | Paresthesia, intolerable | 1 | 10%
Whyte, 1988^267^ 3067313 | Acetazolamide | 2 wk | 10 | Paresthesia, any | 8 | 80%

* Reporting of no events excluded (unless N≥100).

† Other reported adverse events included, fatigue, mouth dryness, somnolence, and dizziness (with both paroxetine and placebo); and sweating, nervousness, infectious pneumonia and Lyme disease (during paroxetine treatment).

Table 6.1a Predictors of compliance with CPAP: study characteristics

Study PMID | Design Country (study years) | eligibility | N | Factor | Value | Treatment | CPAP Pressure^A^ (type) | Ancillary care | (Lack of) Compliance definition
McArdle 1999^289^ 10194153 | Prosp Scotland, UK (1986–97) | Starting CPAP | 1103 | Male | 86% | CPAP various | Manual (separate) | 2 weeks with nurse specialist^B^ | <2 hr/night × 1 mo or voluntarily discontinued
McArdle 1999^289^ 10194153 | Prosp Scotland, UK (1986–97) | Starting CPAP | 1103 | Age | 50 C yr | CPAP various | Manual (separate) | 2 weeks with nurse specialist^B^ | <2 hr/night × 1 mo or voluntarily discontinued
McArdle 1999^289^ 10194153 | Prosp Scotland, UK (1986–97) | Starting CPAP | 1103 | BMI | 30 C | CPAP various | Manual (separate) | 2 weeks with nurse specialist^B^ | <2 hr/night × 1 mo or voluntarily discontinued
McArdle 1999^289^ 10194153 | Prosp Scotland, UK (1986–97) | Starting CPAP | 1103 | AHI | 50 (18–53) D | CPAP various | Manual (separate) | 2 weeks with nurse specialist^B^ | <2 hr/night × 1 mo or voluntarily discontinued
Krieger 1996^290^ 9122571 | Prosp France (1984–95) | Starting CPAP | 608 | Male | nd | CPAP | nd (separate) | Questionnaire: If use <3 hr/night then f/up | <1 hr/night
Krieger 1996^290^ 9122571 | Prosp France (1984–95) | Starting CPAP | 608 | Age | 54 yr | CPAP | nd (separate) | Questionnaire: If use <3 hr/night then f/up | <1 hr/night
Krieger 1996^290^ 9122571 | Prosp France (1984–95) | Starting CPAP | 608 | BMI | 31.9 | CPAP | nd (separate) | Questionnaire: If use <3 hr/night then f/up | <1 hr/night
Krieger 1996^290^ 9122571 | Prosp France (1984–95) | Starting CPAP | 608 | AHI | 70 | CPAP | nd (separate) | Questionnaire: If use <3 hr/night then f/up | <1 hr/night
Pepin 2009^203^ 19567496 | Prosp (RCT) France (nd) | Starting CPAP | 218 | Male | 72% | C-Flex vs. CPAP | Auto (separate) | nd | “Objective compliance” not defined (measured by CPAP)
Pepin 2009^203^ 19567496 | Prosp (RCT) France (nd) | Starting CPAP | 218 | Age | 56 yr | C-Flex vs. CPAP | Auto (separate) | nd | “Objective compliance” not defined (measured by CPAP)
Pepin 2009^203^ 19567496 | Prosp (RCT) France (nd) | Starting CPAP | 218 | BMI | 31 | C-Flex vs. CPAP | Auto (separate) | nd | “Objective compliance” not defined (measured by CPAP)
Pepin 2009^203^ 19567496 | Prosp (RCT) France (nd) | Starting CPAP | 218 | AHI | 44 | C-Flex vs. CPAP | Auto (separate) | nd | “Objective compliance” not defined (measured by CPAP)
Wild 2004^291^ 15358707 | Prosp Scotland, UK (nd) | Starting CPAP | 119 | Male | 79% | CPAP | nd (separate) | Pretitration training Support × 2 wk | Adherence = >3 hr/night
Wild 2004^291^ 15358707 | Prosp Scotland, UK (nd) | Starting CPAP | 119 | Age | 51 yr | CPAP | nd (separate) | Pretitration training Support × 2 wk | Adherence = >3 hr/night
Wild 2004^291^ 15358707 | Prosp Scotland, UK (nd) | Starting CPAP | 119 | BMI | 33 | CPAP | nd (separate) | Pretitration training Support × 2 wk | Adherence = >3 hr/night
Wild 2004^291^ 15358707 | Prosp Scotland, UK (nd) | Starting CPAP | 119 | AHI | 45 | CPAP | nd (separate) | Pretitration training Support × 2 wk | Adherence = >3 hr/night
Hui 2001^292^ 11451834 | Prosp Hong Kong (1997–98) | Starting CPAP | 112 | Male | 90% | AutoCPAP | Auto (separate) | Initial education, brochure & training session | hr/night (continuous)
Hui 2001^292^ 11451834 | Prosp Hong Kong (1997–98) | Starting CPAP | 112 | Age | 46 yr | AutoCPAP | Auto (separate) | Initial education, brochure & training session | hr/night (continuous)
Hui 2001^292^ 11451834 | Prosp Hong Kong (1997–98) | Starting CPAP | 112 | BMI | 29.3 | AutoCPAP | Auto (separate) | Initial education, brochure & training session | hr/night (continuous)
Hui 2001^292^ 11451834 | Prosp Hong Kong (1997–98) | Starting CPAP | 112 | AHI | 48 | AutoCPAP | Auto (separate) | Initial education, brochure & training session | hr/night (continuous)

A Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, eg if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

B 2 weeks contact with nurse specialist. At reviews, if objective CPAP use <2 h, confronted with usage data to encourage increase use. If still <2 h at 1 month f/up visit, CPAP machine reclaimed.

C Median

D Median (interquartile range)

Table 6.1b Predictors of compliance with CPAP, multivariable analyses

Study PMID | Outcome | Overall outcome rate | Follow- up | Predictor | Baseline predictor | HR/OR | 95% CI | P | Quality
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | ESS ≤10 B | 40% | 1.92 | 1.41–2.61 | <0.001 | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | AHI <15 C | nd | 2.48 | 1.79–3.46 | <0.001 | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | Nonsnorer | 2% | 2.76 | 1.29–5.95 | 0.009 | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | CPAP use at 3 mo <2 hr | nd | 13.8 | 8.86–21.5 | <0.001 | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | AHI <30 | ~50% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | Arousal Index <32 | ~50% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | No witnessed apneas | 17% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | No somnolence | 19% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | No driving problem | 64% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | Coexisting COPD | 10% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | Pressure <8 cm H2O | ~50% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | Female | 14% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | Age ≥50 y | ~50% | | | NS | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | | | | | | A
McArdle A 1999^289^ 10194153 | Discontinue CPAP | 16% 32% | (12 mo) (4 yr) 22 mo, mean | BMI ≤30 | ~50% | | | NS | A
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | AHI ≤15 | 5% | nd | | <0.05 | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | | | | | | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | Age (continuous E) | 50 | nd | | <0.05 | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | | | | | | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | MSLT (continuous E) | 16.5 min | | | NS | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | | | | | | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | ESS (continuous E) | 8.8 | | | NS | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | | | | | | C
Krieger D 1996^290^ 9122571 | CPAP withdrawn | 14% | 3.2 yr | Respiratory symptoms (nd) | | | | NS | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | Mean SaO2, per % | 93% | 1.22 | 1.03–1.45 | 0.02 | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | | | | | | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | GrenobleSAQOL Sleepiness H, per scale unit | ~15 | 1.13 | 1.04–1.24 | <0.01 | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | | | | | | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | Age, per 10 y | 56 y | 0.9 | 0.54–1.34 | NS | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | | | | | | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | GrenobleSAQOL Treatment, efficacy J per unit (3 mo) | nd | 1.16 | 1.02–1.32 | 0.02 | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | | | | | | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | Noise (3 mo, not defined) | nd | 0.74 | 0.98–1.02 K | nd | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | | | | | | C
Pepin F 2009^203^ 19567496 | “Objective compliance” G | 5 hr/night | 3 mo | Feel exhalation resistance (3 mo) | nd | 1.02 | 1.00–1.04 | 0.1 L | C
Wild M 2004^291^ 15358707 | Adherence G | nd | 3 mo | AHI (continuous E) | 45 | 1.02 | nd | 0.02 | B
Wild M 2004^291^ 15358707 | Adherence G | nd | 3 mo | CPAP Pressure (continuous E) | 9 cm H _2_ O | 0.82 | nd | 0.05 | B
Wild M 2004^291^ 15358707 | Adherence G | nd | 3 mo | BMI (continuous E) | 33 | 1.09 | nd | 0.02 | B
Wild M 2004^291^ 15358707 | Adherence G | nd | 3 mo | ESS (continuous E) | 13 | 1.09 | nd | 0.04 | B
Hui N 2001^292^ 11451834 | hr/night use | 5.4 hr/night | 1 mo | AHI (continuous E) | 48 | nd | nd | 0.006 | C
Hui N 2001^292^ 11451834 | hr/night use | 5.4 hr/night | 1 mo | Snoring | | nd | nd | NS | C
Hui N 2001^292^ 11451834 | hr/night use | | | | | | | | C
Hui N 2001^292^ 11451834 | hr/night use | 5.4 hr/night | 3 mo | AHI (continuous E) | 48 | nd | nd | 0.004 | C
Hui N 2001^292^ 11451834 | hr/night use | 5.4 hr/night | 3 mo | Snoring | | nd | nd | NS | C

Predictors measured after baseline are italicized.

A Occupation, referral source, collar size, alcohol consumption, smoking status, diagnostic test type, and CPAP titration method were not associated with discontinuing CPAP by univariable analysis.

B Also reported that lower ESS (analyzed as a continuous variable) predicted less compliance across the range of ESS.

C Also reported that lower AHI (analyzed as a continuous variable) predicted less compliance across the range of AHI.

D No data on which tested variables were not associated with CPAP withdrawal by univariable analysis.

E Implied.

F No data on which tested variables were not associated with “objective compliance” by univariable analysis.

G Note that in contrast to most other studies, the outcome is compliance/adherence, not lack of compliance.

H Grenoble Sleep Apnea Quality of Life. 25 point scale (implied), with higher scores indicating worse conditions.

J This outcome is not defined or included in the list of domains in Grenoble Sleep Apnea Quality of Life. Higher scores indicate worse conditions.

K These illogical OR and confidence interval were what was reported. The reported beta and standard error of the beta did not match any of these values.

L Although this P value does not match with the reported beta, standard error of the beta, OR, or 95% CI, it is what was reported.

M Also analyzed with psychological variables (Multidimensional locus of control scale). Results for AHI, CPAP Pressure, BMI, and ESS were similar. Higher health value scale (measure of how much patient values his/her health) was associated with increased compliance (OR=1.40, P=0.02). Other psychological tests were not significantly associated. Age, alcohol intake, current cigarette use, marital status, and minimum O2 saturation were not associated with adherence by univariable analysis.

N Frequent awakenings, witnessed apneas, and other symptoms were not associated with adherence at 1 or 3 months by univariable analyses.

Table 6.2a Mandibular advancement device as predictors of compliance: Study characteristics

Study PMID | Design Country (study years) | eligibility | N | Factor | Value | Treatment | Description | Ancillary Care | (Lack of) Compliance Definition
Izci 2005^293^ 15733510 | Retro Scotland, UK (nd) | MAD after PSG | 144 | Male | 79% | Individually fitted mandibular repositioning splint | ~80 maximal comfortable mandibular protrusion 2–4 mm interdental clearance | Standard education Adjusted until workable | Compliance hr/night and/or nights/wk (unclear)
Izci 2005^293^ 15733510 | Retro Scotland, UK (nd) | MAD after PSG | 144 | Age | 51 yr | Individually fitted mandibular repositioning splint | ~80 maximal comfortable mandibular protrusion 2–4 mm interdental clearance | Standard education Adjusted until workable | Compliance hr/night and/or nights/wk (unclear)
Izci 2005^293^ 15733510 | Retro Scotland, UK (nd) | MAD after PSG | 144 | BMI | nd | Individually fitted mandibular repositioning splint | ~80 maximal comfortable mandibular protrusion 2–4 mm interdental clearance | Standard education Adjusted until workable | Compliance hr/night and/or nights/wk (unclear)
Izci 2005^293^ 15733510 | Retro Scotland, UK (nd) | MAD after PSG | 144 | AHI | 23 | Individually fitted mandibular repositioning splint | ~80 maximal comfortable mandibular protrusion 2–4 mm interdental clearance | Standard education Adjusted until workable | Compliance hr/night and/or nights/wk (unclear)

Table 6.2b Pre-treatment predictors of compliance with mandibular advancement device, univariable analysis^*^

Study PMID | Outcome | Overall Outcome Rate | Follow- up | Predictor | Quality
Izci, 2005^293^ 15733510 | Compliance | nd | 31 mo | Not associated with compliance on univariable analysis (nd): Age, Sex, Occupation, “Marital situation”, Snoring, Refreshment after sleep, Daytime somnolence, Driving problems, ESS, AHI, CPAP failure or refusal | C

* No studies performed multivariable analyses.

Table 7.1 Randomized controlled trials of interventions to improve compliance with CPAP use: study characteristics

Study PMID | Interventions | CPAP Pressure *,† (type) | Mean Age, yr | Male, % | Mean BMI, kg/m^2^ | Other Patient Characteristics | Country (enrollment years) | Major quality issues
Extra Support or Education
Chervin 1997^294^ 9231954 | Telephone calls | nd (nd) | 52 | 64 | nd | Either new to CPAP (31%) or continuous CPAP users (69%) | US (1995) | Different follow-up durations between comparative groups.
Chervin 1997^294^ 9231954 | Literature | nd (nd) | 52 | 64 | nd | Either new to CPAP (31%) or continuous CPAP users (69%) | US (1995) | Different follow-up durations between comparative groups.
Chervin 1997^294^ 9231954 | Standard care | nd (nd) | 52 | 64 | nd | Either new to CPAP (31%) or continuous CPAP users (69%) | US (1995) | Different follow-up durations between comparative groups.
Damjanovic 2009^174^ 19129293 | Intensive support | Auto and manual (separate) | 57 | 78 | 31 | Newly diagnosed OSA | Germany (nd) | Large dropout rate. Assumed non-compliance for dropout patients.
Damjanovic 2009^174^ 19129293 | Standard support | Auto and manual (separate) | 57 | 78 | 31 | Newly diagnosed OSA | Germany (nd) | Large dropout rate. Assumed non-compliance for dropout patients.
Fletcher, 1991^296^ 2024846 | Telephone reinforcement about OSA and CPAP use | Manual (separate) | 52 | 100 | Mean IBW = 158% | New CPAP users | US (nd) | Inconsistent reporting; primarily relying on self-reported readings for CPAP use
Fletcher, 1991^296^ 2024846 | Usual care | Manual (separate) | 52 | 100 | Mean IBW = 158% | New CPAP users | US (nd) | Inconsistent reporting; primarily relying on self-reported readings for CPAP use
Hoy 1999^297^ 10194151 | Intensive educational programs and nursing support | Manual (separate) | 58 | 98 | 33 | New CPAP users | UK (nd)
Hoy 1999^297^ 10194151 | Usual care | Manual (separate) | 58 | 98 | 33 | New CPAP users | UK (nd)
Hui 2000^298^ 10807830 | Augmented education and support | Auto (separate) | 45 | 90 | 30 | Newly diagnosed OSA | Hong Kong (nd) | More missing data on objective CPAP use in the intervention group than the control group due to technical problems.
Hui 2000^298^ 10807830 | Basic education and support | Auto (separate) | 45 | 90 | 30 | Newly diagnosed OSA | Hong Kong (nd) | More missing data on objective CPAP use in the intervention group than the control group due to technical problems.
Wiese 2005^299^ 15716221 | Educational videotape | nd (nd) | 48 | 53 | 38 | Newly diagnosed OSA | US (nd) | More dropouts in the control group than intervention group. Assumed non-compliance for dropout patients.
Wiese 2005^299^ 15716221 | No intervention | nd (nd) | 48 | 53 | 38 | Newly diagnosed OSA | US (nd) | More dropouts in the control group than intervention group. Assumed non-compliance for dropout patients.
Lewis 2006^300^ 16564210 | Extra early support | Auto (separate?) | 51 | 86 | 36 | New CPAP users | UK (nd) | More dropouts in the control group than intervention group.
Lewis 2006^300^ 16564210 | Usual care | Auto (separate?) | 51 | 86 | 36 | New CPAP users | UK (nd) | More dropouts in the control group than intervention group.
Meurice 2007^301^ 17157557 | RP+RH | Manual (separate) | 58 | nd | 33 | New CPAP users | France (nd) | Potential center effects were not controlled fro in the analyses.
Meurice 2007^301^ 17157557 | RP+SH | Manual (separate) | 58 | nd | 33 | New CPAP users | France (nd) | Potential center effects were not controlled fro in the analyses.
Meurice 2007^301^ 17157557 | SP+RH | Manual (separate) | 58 | nd | 33 | New CPAP users | France (nd) | Potential center effects were not controlled fro in the analyses.
Meurice 2007^301^ 17157557 | SP+SH | Manual (separate) | 58 | nd | 33 | New CPAP users | France (nd) | Potential center effects were not controlled fro in the analyses.
Smith 2009^303^ 18829212 | Habit-promoting experimental audio intervention: CPAP everyday | Auto (nd) | 63 | 58 | 82% >30 | Newly diagnosed OSA and new CPAP users | US (nd) | Assumed non-compliance for dropout patients.
Smith 2009^303^ 18829212 | Placebo control audio- based intervention | Auto (nd) | 63 | 58 | 82% >30 | Newly diagnosed OSA and new CPAP users | US (nd) | Assumed non-compliance for dropout patients.
Telehealth or telemonitoring care
DeMolles 2004^295^ 15258478 | Telephone-linked communications for CPAP | nd (nd) | 46 | nd | 38 | New CPAP users | US (nd) | How CPAP use data were collected was not described. “Usual care” was not described.
DeMolles 2004^295^ 15258478 | Usual care | nd (nd) | 46 | nd | 38 | New CPAP users | US (nd) | How CPAP use data were collected was not described. “Usual care” was not described.
Stepnowsky 2007^304^ 17513285 | Wireless telemonitoring clinical care | Auto (nd) | 59 | 98 | 32 | Newly diagnosed OSA and new CPAP users | US (2004–06) | Small sample size
Stepnowsky 2007^304^ 17513285 | Usual care | Auto (nd) | 59 | 98 | 32 | Newly diagnosed OSA and new CPAP users | US (2004–06) | Small sample size
Taylor 2006^305^ 16565867 | Telemedicine support | nd (nd) | 45 | 69 | nd | New CPAP users | US (2002–03) | Patients who had difficulties to use telemedicine support were excluded from the analyses.
Taylor 2006^305^ 16565867 | Usual care | nd (nd) | 45 | 69 | nd | New CPAP users | US (2002–03) | Patients who had difficulties to use telemedicine support were excluded from the analyses.
Behavioral interventions
Richards 2007^302^ 17552379 | Cognitive behavioral therapy | Manual (nd) | 56 | 86 | 30 | nd | Australia (2005)
Richards 2007^302^ 17552379 | Usual care | Manual (nd) | 56 | 86 | 30 | nd | Australia (2005)
Miscellaneous interventions
Bradshaw 2006^288^ 17099012 | Oral hypnotic agent (zolpidem), 10 mg | nd (both) | 38 | 100 | 32 | New CPAP users | US (2001–03) | Patients in the standard care had more severe OSA based on AHI; not blinded.
Bradshaw 2006^288^ 17099012 | Placebo pill | nd (both) | 38 | 100 | 32 | New CPAP users | US (2001–03) | Patients in the standard care had more severe OSA based on AHI; not blinded.
Bradshaw 2006^288^ 17099012 | Standard care (no zolpidem or placebo pill) | nd (both) | 38 | 100 | 32 | New CPAP users | US (2001–03) | Patients in the standard care had more severe OSA based on AHI; not blinded.
Massie 2003^306^ 12684301 | Nasal pillows | Manual (both) | 49 | 82 | 36 | New CPAP users | US (nd)
Massie 2003^306^ 12684301 | Nasal mask | Manual (both) | 49 | 82 | 36 | New CPAP users | US (nd)
Different care models
Antic 2009^307^ 19136368 | Simplified nurse-led model of care | Auto and manual (separate) | 50 | 74 | 35 | nd | Australia (2004–06) | Different CPAP titrations between groups by study design
Antic 2009^307^ 19136368 | Usual care | manual (nd) | 50 | 74 | 35 | nd | Australia (2004–06) | Different CPAP titrations between groups by study design
Holmdahl 2009^308^ 19179111 | Simplified nurse-led model of care | Manual (nd) | 58 | 85 | 35 | CPAP-treated patients with OSAS in a stable condition | Sweden (nd) | More patients dropped out in the control group. How CPAP use data were collected was not reported.
Holmdahl 2009^308^ 19179111 | Usual care | Manual (nd) | 58 | 85 | 35 | CPAP-treated patients with OSAS in a stable condition | Sweden (nd) | More patients dropped out in the control group. How CPAP use data were collected was not reported.
Palmer 2004^309^ 14725828 | A home visit from a specialist nurse | nd (nd) | 55 | 86 | nd | The mean duration of CPAP therapy = 2.99 yr | UK (2001) | Baseline patient characteristics were unclear. Dropout and unusable CPAP use data were excluded form the analyses.
Palmer 2004^309^ 14725828 | A visit to a consultant led clinic | nd (nd) | 55 | 86 | nd | The mean duration of CPAP therapy = 2.99 yr | UK (2001) | Baseline patient characteristics were unclear. Dropout and unusable CPAP use data were excluded form the analyses.

* Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

† Method for choosing CPAP Pressure: Manual (during sleep study); Auto (determined with AutoCPAP); Algorithm (by an algorithm); nd (no data reported); NA (not applicable, e.g. if AutoCPAP is the intervention). In parentheses: Split (CPAP introduced in a split night study); Separate (CPAP introduced on a separate full night than the diagnostic sleep study).

Table 7.2 Compliance (hr/night) in randomized controlled trials of interventions to improve CPAP use

Study PMID | Baseline AHI (SD) [minimum] | Baseline ESS (SD) | Duration (design) | Interventions | No. Analyzed | Final | SD | Diff | 95% CI | P Btw | Dropout, % | Study Quality
Extra Support or Education
Hoy 1999^297^ 10194151 | 58 (33) [>15] | 13 (6) | 6 mo (PL) | Intensive support | 40 | 5.4 | 1.9 | +1.6 | 0.62, 2.58 * | 0.003 | 0 | A
Hoy 1999^297^ 10194151 | 58 (33) [>15] | 13 (6) | 6 mo (PL) | | | | | | | 0.003 | 0 | A
Hoy 1999^297^ 10194151 | 58 (33) [>15] | 13 (6) | 6 mo (PL) | Usual care | 40 | 3.8 | 2.5 | | | 0.003 | 0 | A
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | RP+RH | 27 | 5.6 | 2.4 | +0.9 | −0.38, 2.18 † | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | | | | | | | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | RP+SH | 30 | 4.7 | 2.2 | 0 | −1.20, 1.20 ‡ | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | | | | | | | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | SP+RH | 28 | 5.1 | 2.5 | +0.4 | −0.90, 1.70 § | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | | | | | | | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 3 mo (PL) | SP+SH | 27 | 4.7 | 2.4 | | | NS | 16 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | | | | | | | | | | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | RP+RH | 23 | 5.8 | 2.8 | +0.3 | −1.16, 1.76 | NS | 19 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | | | | | | | NS | 19 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | RP+SH | 22 | 6.3 | 2.2 | +0.8 | −0.49, 2.09 | NS | 19 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | | | | | | | NS | 19 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | SP+RH | 21 | 5.7 | 2.2 | +0.2 | −1.09, 1.49 | NS | 19 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | | | | | | | NS | 19 | B
Meurice 2007^301^ 17157557 | 58 (24) [>30] | 11.3 (5.4) | 12 mo (PL) | SP+SH | 25 | 5.5 | 2.4 | | | NS | 19 | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | 3 mo (PL) | Intensive support | 50 | 5.5 | 1.4 | +0.1 | −0.61, 0.81 ** | NS | 0 †† | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | 3 mo (PL) | | | | | | | NS | 0 †† | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | 3 mo (PL) | Standard support | 50 | 5.4 | 2.1 | | | NS | 0 †† | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | | | | | | | | | 0 †† | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | 9 mo (PL) | Intensive support | 50 | 5.7 | 1.4 | +1.1 | 0.22, 1.98 ‡‡ | <0.05 | 0 †† | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | 9 mo (PL) | | | | | | | <0.05 | 0 †† | B
Damjanovic 2009^174^ 19129293 | 44 (25) [≥ 15] | 8.8 (5.2) | 9 mo (PL) | Standard support | 50 | 4.6 | 2.8 | | | <0.05 | 0 †† | B
Hui 2000^298^ 10807830 | 48 (24) [≥ 10] | 12.5 (5.1) | 3 mo (PL) | Augmented support | 45 | 5.3 | 0.3 | 0 | −0.7, 0.7 §§ | NS | 10 | B
Hui 2000^298^ 10807830 | 48 (24) [≥ 10] | 12.5 (5.1) | 3 mo (PL) | | | | | | | NS | 10 | B
Hui 2000^298^ 10807830 | 48 (24) [≥ 10] | 12.5 (5.1) | 3 mo (PL) | Basic support | 52 | 5.3 | 0.2 | | | NS | 10 | B
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | 1 mo (PL) | Extra early support | 36 | 5.2 | nd | −0.2 | nd | nd | 6 | C
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | 1 mo (PL) | | | | | | | nd | 6 | C
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | 1 mo (PL) | Usual care | 32 | 5.4 | nd | | | nd | 6 | C
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | | | | | | | | | | C
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | 12 mo (PL) | Extra early support | 30 | 4.6 | nd | −0.5 | nd | nd | 17 | C
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | 12 mo (PL) | | | | | | | nd | 17 | C
Lewis 2006^300^ 16564210 | 42 (27) [nd] | 15.7 (4.3) | 12 mo (PL) | Usual care | 30 | 5.1 | nd | | | nd | 17 | C
Chervin 1997^294^ 9231954 | 49 (39) [nd] | 10.9 (5.1) | 1–2.5 mo (PL) | Telephone calls | 12 | 5.7 | 2.3 | +1.3 | −1.45, 4.05^***^ | 0.02 | 18 | C
Chervin 1997^294^ 9231954 | 49 (39) [nd] | 10.9 (5.1) | 1–2.5 mo (PL) | | | | | | | 0.02 | 18 | C
Chervin 1997^294^ 9231954 | 49 (39) [nd] | 10.9 (5.1) | 1–2.5 mo (PL) | Literature | 14 | 7.1 | 1.8 | +2.7 | 0.35, 5.05 ††† | 0.02 | 18 | C
Chervin 1997^294^ 9231954 | 49 (39) [nd] | 10.9 (5.1) | 1–2.5 mo (PL) | | | | | | | 0.02 | 18 | C
Chervin 1997^294^ 9231954 | 49 (39) [nd] | 10.9 (5.1) | 1–2.5 mo (PL) | Standard care | 7 | 4.4 | 3.4 | | | 0.02 | 18 | C
Fletcher, 1991^296^ 2024846 | 49 (26) [nd] | nd | 3 mo (XO) | Telephone reinforcement | 10 | 5.95 | 2.7 | −0.05 | −1.76, 1.66 ‡‡‡ | NS | 0 | C
Fletcher, 1991^296^ 2024846 | 49 (26) [nd] | nd | 3 mo (XO) | | | | | | | NS | 0 | C
Fletcher, 1991^296^ 2024846 | 49 (26) [nd] | nd | 3 mo (XO) | Usual care | 10 | 6.0 | 2.8 | | | NS | 0 | C
Telehealth or telemonitoring care
Stepnowsky 2007^304^ 17513285 | 41 (16) [≥ 15] | 12.6 (5.5) | 2 mo (PL) | Wireless telemonitoring | 20 | 4.1 | 1.8 | +1.3 | −0.05, 2.5 §§§ | 0.07 | 12 | B
Stepnowsky 2007^304^ 17513285 | 41 (16) [≥ 15] | 12.6 (5.5) | 2 mo (PL) | | | | | | | 0.07 | 12 | B
Stepnowsky 2007^304^ 17513285 | 41 (16) [≥ 15] | 12.6 (5.5) | 2 mo (PL) | Usual care | 20 | 2.8 | 2.2 | | | 0.07 | 12 | B
Taylor 2006^305^ 16565867 | 41% severe OSA [>4] | 14 (4) | 30 d (PL) | Telemedicine support | 47 | 4.3 | 2.2 | +0.07 | −0.77, 0.91 **** | NS | 16 | C
Taylor 2006^305^ 16565867 | 41% severe OSA [>4] | 14 (4) | 30 d (PL) | | | | | | | NS | 16 | C
Taylor 2006^305^ 16565867 | 41% severe OSA [>4] | 14 (4) | 30 d (PL) | Usual care | 49 | 4.2 | 2.1 | | | NS | 16 | C
DeMolles 2004^295^ 15258478 | 42 (38) [nd] | nd | 2 mo (PL) | Telephone-linked CPAP communication | 15 | 4.4 | 3.0 | +1.5 | −0.53, 3.53 †††† | 0.08 | 0 | C
DeMolles 2004^295^ 15258478 | 42 (38) [nd] | nd | 2 mo (PL) | | | | | | | 0.08 | 0 | C
DeMolles 2004^295^ 15258478 | 42 (38) [nd] | nd | 2 mo (PL) | Usual care | 15 | 2.9 | 2.4 | | | 0.08 | 0 | C
Behavioral interventions
Richards 2007^302^ 17552379 | 26 (22) [>5] | 10.5 (5.3) | 28 days (PL) | Cognitive behavioral therapy | 48 | 5.4 | 2.6 | +2.8 | 1.8, 3.9 ‡‡‡‡ | <0.0001 | 4 | A
Richards 2007^302^ 17552379 | 26 (22) [>5] | 10.5 (5.3) | 28 days (PL) | | | | | | | | 4 | A
Richards 2007^302^ 17552379 | 26 (22) [>5] | 10.5 (5.3) | 28 days (PL) | Usual care | 48 | 2.5 | 2.7 | | | | 4 | A
Miscellaneous interventions
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 1– 14 (PL) | Zolpidem 10 mg | 24 | 11.1 | 3.7 | +1.6 §§§§ | −0.83, 4.03 ***** | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 1– 14 (PL) | | | | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 1– 14 (PL) | Placebo pill | 24 | 9.5 | 4.6 | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 1– 14 (PL) | | | | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 1– 14 (PL) | Standard care ††††† | 24 | 12.1 | 3.2 | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | | | | | | | | | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 15– 28 (PL) | Zolpidem 10 mg | 24 | 9.5 | 4.6 | +1.2 ‡‡‡‡‡ | −1.65, 4.05 §§§§§ | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 15– 28 (PL) | | | | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 15– 28 (PL) | Placebo pill | 24 | 8.3 | 5.2 | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 15– 28 (PL) | | | | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (28) [≥ 5] | 15.4 (3.5) | Days 15– 28 (PL) | Standard care ****** | 24 | 10.8 | 3.9 | | | NS | 0 | B
Massie 2003^306^ 12684301 | 47 (35) [≥ 15] | 12.8 (4.9) | 3 wk (XO) | Nasal pillows | 39 | 5.6 | 1.3 | +0.2 | −3.8, 4.2†††††† | NS | 7 | B
Massie 2003^306^ 12684301 | 47 (35) [≥ 15] | 12.8 (4.9) | 3 wk (XO) | | | | | | | NS | 7 | B
Massie 2003^306^ 12684301 | 47 (35) [≥ 15] | 12.8 (4.9) | 3 wk (XO) | Nasal mask | 39 | 5.4 | 1.6 | | | NS | 7 | B
Different care models
Antic 2009^307^ 19136368 | 68 (27) | 13 (3.9) | 3 mo | Simplified nurse-led model of care | 94 | 4.1 | 2.7 | −0.45 | −1.26, 0.36 | NS | 10 | B
Antic 2009^307^ 19136368 | 68 (27) | 13 (3.9) | 3 mo | | | | | | | NS | 10 | B
Antic 2009^307^ 19136368 | 68 (27) | 13 (3.9) | 3 mo | Usual care | 83 | 4.6 | 2.7 | | | NS | 10 | B
Palmer 2004^309^ 14725828 | nd [nd] | 8.5 (5.5) | 12 mo | One home visit by special nurse | 63 | 5.9 | 2.7 | +0.21 | −0.40, 0.82 ‡‡‡‡‡‡ | NS | 28 | C
Palmer 2004^309^ 14725828 | nd [nd] | 8.5 (5.5) | 12 mo | | | | | | | NS | 28 | C
Palmer 2004^309^ 14725828 | nd [nd] | 8.5 (5.5) | 12 mo | One consultant clinic visit | 63 | 5.6 | 2.5 | | | NS | 28 | C

* Estimated from reported SE’s

† Estimated from reported SD’s

‡ Estimated from reported SD’s

§ Estimated from reported SD’s

** Estimated from reported SE’s

†† Compliance parameters were set to zero when patients did not appear for their follow-up visit (8% and 22% dropout at 3 and 9 mo, respectively)

‡‡ Estimated from reported SE’s

§§ Estimated from reported SE’s

*** Estimated from reported SD’s

††† Estimated from reported SD’s

‡‡‡ Estimated from reported SD’s

§§§ Estimated from reported SD’s

**** Estimated from reported SD’s

†††† Estimated from reported SD’s

‡‡‡‡ Estimated from reported SD’s

§§§§ Compared to placebo

***** Estimated from reported SD’s

††††† Patients in the standard care had more severe OSA based on AHI [mean = 54.8 (28 SD), P=0.012 compared to other groups]

‡‡‡‡‡ Compared to placebo

§§§§§ Estimated from reported SD’s

****** Patients in the standard care had more severe OSA based on AHI [mean = 54.8 (28 SD), P=0.012 compared to other groups]

†††††† Estimated from reported SD’s

‡‡‡‡‡‡ Estimated from reported changes (SD) from baseline

Table 7.3 Non-compliance outcome in randomized controlled trials of interventions to improve CPAP use

Study PMID | Baseline AHI (SD) [minimum] | Baseline ESS (SD) | Duration (design) | Definition of non- compliance | Interventions | n Event | N Total | Outcome metric | Result *,†† | 95% CI †,‡‡ | P Btw | Dropout, % | Study Quality
Extra Support or Education
Hui 2000^298^ 10807830 | 48 (24) [≥ 10] | 12.5 (5.1) | 3 mo (PL) | Mean CPAP use ≤ 4 hr and ≤ 70% of nights | Augmented support | 16 | 54 | RD | −0.04 | −0.13, 0.21 | NS | 10 | B
Hui 2000^298^ 10807830 | 48 (24) [≥ 10] | 12.5 (5.1) | 3 mo (PL) | Mean CPAP use ≤ 4 hr and ≤ 70% of nights | Basic support | 14 | 54 | RD | | | NS | 10 | B
Smith 2009^303^ 18829212 | 50 (nd) [≥ 20] | nd | 1 mo (PL) | CPAP use <4 hr/night and less than 80% use rate | Habit-promoting experimental audio intervention | 6 | 55 | RD | −0.34 | −0.52, −0.17 | <0.01 | 0 ‡ | B
Smith 2009^303^ 18829212 | 50 (nd) [≥ 20] | nd | 1 mo (PL) | CPAP use <4 hr/night and less than 80% use rate | Placebo control audio- intervention | 19 | 42 | | | | <0.01 | 0 ‡ | B
Smith 2009^303^ 18829212 | 50 (nd) [≥ 20] | nd | 6 mo (PL) | CPAP use <4 hr/night and less than 80% use rate | Habit- promoting experimental audio intervention | 14 | 55 | RD | −0.03 | −0.21, 0.15 | NS | 0 ‡ | B
Smith 2009^303^ 18829212 | 50 (nd) [≥ 20] | nd | 6 mo (PL) | CPAP use <4 hr/night and less than 80% use rate | Placebo | 12 | 42 | | | | NS | 0 ‡ | B
Wiese 2005^299^ 15716221 | 9 (nd) [>4] | 13 (6) | 1 mo (PL) | Not return to clinic at 4 weeks | Educational videotape | 14 | 51 | RD | −0.24 | −0.42, −0.05 | 0.02 | 39 § | C
Wiese 2005^299^ 15716221 | 9 (nd) [>4] | 13 (6) | 1 mo (PL) | Not return to clinic at 4 weeks | No intervention | 25 | 49 | | | | 0.02 | 39 § | C
Behavioral interventions
Richards 2007^302^ 17552379 | 26 (22) [>5] | 10.5 (5.3) | 28 d (PL) | CPAP use <4 hr/night at 28 days | Cognitive behavioral therapy | 9 | 48 | Adjusted OR ** | 0.14 | 0.05, 0.36 | <0.0001 | 4 | A
Richards 2007^302^ 17552379 | 26 (22) [>5] | 10.5 (5.3) | 28 d (PL) | CPAP use <4 hr/night at 28 days | Usual care | 33 | 48 | | | | <0.0001 | 4 | A
Miscellaneous interventions
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Mean CPAP use ≤ 4 hr | Zolpidem 10 mg | 7 | 24 | RD | −0.17 §§ | −0.44, 0.10 | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Mean CPAP use ≤ 4 hr | Placebo pill | 11 | 24 | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Mean CPAP use ≤ 4 hr | Standard care *** | 7 | 24 | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Receiving CPAP ≤ 70% of nights | Zolpidem 10 mg | 8 | 24 | RD | −0.13 ††† | −0.40, 0.15 | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Receiving CPAP ≤ 70% of nights | Placebo pill | 11 | 24 | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Receiving CPAP ≤ 70% of nights | Standard care ‡‡‡ | 4 | 24 | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Mean CPAP use ≤ 4 hr and ≤ 70% of nights | Zolpidem 10 mg | 10 | 24 | RD | −0.08 §§§ | −0.36, 0.20 | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Mean CPAP use ≤ 4 hr and ≤ 70% of nights | Placebo pill | 12 | 24 | | | | NS | 0 | B
Bradshaw 2006^288^ 17099012 | 43 (27) [≥ 5] | 15.4 (3.5) | 4 wk (PL) | Mean CPAP use ≤ 4 hr and ≤ 70% of nights | Standard care **** | 9 | 24 | | | | NS | 0 | B
Different care models
Holmdahl 2009^308^ 19179111 | nd [>15] | nd | 2 yr (PL) | <6 hr CPAP use per night | Simplified nurse-led model of care | 23 | 95 | RD | −0.02 | −0.14, 0.11 | NS | 16 | C
Holmdahl 2009^308^ 19179111 | nd [>15] | nd | 2 yr (PL) | <6 hr CPAP use per night | Usual care | 23 | 89 | | | | NS | 16 | C
Holmdahl 2009^308^ 19179111 | nd [>15] | nd | 2 yr (PL) | <4 hr CPAP use per night | Simplified nurse-led model of care | 5 | 95 | RD | −0.02 | −0.08, 0.05 | NS | 16 | C
Holmdahl 2009^308^ 19179111 | nd [>15] | nd | 2 yr (PL) | <4 hr CPAP use per night | Usual care | 6 | 89 | | | | NS | 16 | C

* Top row intervention vs. bottom row intervention.

† Estimated from the reported number of events and total number of patients, unless otherwise noted.

‡ ITT analysis: all dropouts due to lost to contact were also counted as non-adherent patients

§ Lost-to follow-up rate were used as measure of non-compliance

** Adjusted for sex

†† Top row intervention vs. bottom row intervention.

‡‡ Estimated from the reported number of events and total number of patients, unless otherwise noted.

§§ Compared to placebo pill

*** Patients in the standard care had more severe OSA based on AHI [mean = 54.8 (28 SD), P=0.012 compared to other groups]

††† Compared to placebo pill

‡‡‡ Patients in the standard care had more severe OSA based on AHI [mean = 54.8 (28 SD), P=0.012 compared to other groups]

§§§ Compared to placebo pill

**** Patients in the standard care had more severe OSA based on AHI [mean = 54.8 (28 SD), P=0.012 compared to other groups]

## Abbreviations and Acronyms Used in Tables

Abbreviation/Acronym: Definition
AHI: apnea-hypopnea index in events/hour of sleep
AOP: atrial overdrive pacing
ASA: American Society of Anesthesiologists
AUC: area under the curve
Auto: automated scoring
autoCPAP: autotitrating positive airway pressure
BDI: Beck Depression Inventory
Block Design: Block Design and Digit Symbol Substitution
BMI: body mass index
bpm: beats per minute
Calgary: Calgary Sleep Apnea Quality of Life Index
C-flex™: splinted airway pressure
CHF: congestive heart failure
CI: confidence interval
CM: conservative management (sleep hygiene and weight control)
CMS collar: cervicomandibular support collar
COPD: chronic obstructive pulmonary disease
CPAP: continuous positive airway pressure
CT: conservative treatment
CVD: cardiovascular disease
DBP: diastolic blood pressure
Diff: difference
DM: diabetes mellitus (Type 2 Diabetes)
ED: emergency department
ESS: Epworth Sleepiness Scale (no units)
FOSQ: Functional Outcomes of Sleep Questionnaire
GA: geniotubercle advancement
GAHM: genioglossus advancement with hyoid myotomy/suspension
GERD: gastroesophageal reflux disease
GHQ-28: general health questionnaire
GrenobleSAQOL: Grenoble Sleep Apnea Quality of Life test
HADS: Hospital Anxiety and Depression Scale
HR: hazard ratio
HS: hyoid suspension (hyothyroidopexy)
HTN: hypertension
IQR: interquartile range
ISI: Insomnia Severity Index
LAUP: laser-assisted uvulopalatoplasty
LOA: limits of agreement
MAD: mandibular advancement device
MCS: Mental Component Summary (SF-36)
MLHFQ: Minnesota Living with Heart Failure questionnaire
MMO: maxillomandibular advancement osteotomy
MMSE: Mini Mental Status Examination
MSLT: Multiple Sleep Latency Test
nd: no data
NHP: Nottingham Health Profile
O2 desat: oxygen desaturation
OR: odds ratio
OSA: obstructive sleep apnea
OSLER: Oxford sleep resistance
P Btw: P value of difference between two interventions
PASAT: Paced Auditory Serial Addition Test
PCS: Physical Component Summary (SF-36)
PL: parallel design
PMID: Pubmed identifier (also known as unique identifier)
PSG: polysomnography; STOP
QLSESQ: Quality of Life Enjoyment and Satisfaction Questionnaire
RCT: randomized controlled trial
ROC: Receiver operating characteristics
RDI: respiratory disturbance index
Resp dz: respiratory disease
RFA: radiofrequency ablation
RFVTR: radiofrequency volumetric tissue reduction
RH: reinforced education by the homecare team
ROC: receiver-operator characteristic curve
RP: reinforced education by the prescriber
RR: relative risk
SACS: sleep apnea clinical score
SAHS: sleep apnea-hypopnea syndrome-related symptoms questionnaire
SAQLI: Sleep Apnea Quality of Life Index
SBP: systolic blood pressure
SD: standard deviation
SDB: sleep disordered breathing
SF-36: Short Form (36) Health Survey
SH: standard education by the homecare network
SHEP: shoulder head elevation pillow
SHHS: Sleep Heart Health Study
SP: standard education by the prescriber
SQ: Scottish National Sleep Laboratory symptom questionnaire
STOP: Snoring, tiredness during daytime, observed apnea, and high blood pressure
STOP-Bang: STOP with BMI, age, neck circumference, and gender variables
TAP: transpalatal advancement pharyngoplasty
TASB: thoracic anti-supine band
TC: total cholesterol
TCA: tricyclic antidepressants
TCRFTVR: temperature controlled radiofrequency tissue volume reduction of the soft palate
Tg: triglycerides
TMJ: temporomandibular joint
TSD: tongue stabilizing device
Tx: treatment
UMACL: University of Wales mood adjective list energetic arousal score
UPP: uvulopalatoplasty
UPPP: uvulopalatopharyngoplasty
VLCD: very low calorie diet
WAIS: Wechsler Adult Intelligence Scale
WHR: waist-hip ratio
WMS: Wechsler Memory Scale
WSCS: Wisconsin Sleep Cohort Study
XO: crossover design