# Appendix C Data Extraction Form

Diagnostic Test Data Extraction Form Key Questions 1–3

Treatments Data Extraction Form Key Questions 5 & 7

Treatments Data Extraction Form Surgical Cohort Studies (Key Question 5)

Prediction Data Extraction Form Key Questions 4 & 6