# Appendix B Excluded Studies

Studies are listed in alphabetical order by author. The reason for rejection for each study is indicated after the study.

Aboussouan LS, Golish JA, Wood BG, Mehta AC, Wood DE, Dinner DS. (1995). Dynamic pharyngoscopy in predicting outcome of uvulopalatopharyngoplasty for moderate and severe obstructive sleep apnea. Chest.
Acebo C, Watson RK, Bakos L, Thoman EB. (1991). Sleep and apnea in the elderly: reliability and validity of 24-hour recordings in the home. Sleep.
Akkina NC, Kumar S, Fulambaker A, Cohen M, Farooki B, Copur AS. (2007). Role of empiric treatment with autotitrating-cpap in patients suspected of having obstructive sleep apnea. Chest.
Al-Jawder S, Bahammam A. (2008). Acceptance of C-FLEX therapy in patients with obstructive sleep apnea who refused auto-continuous positive airway pressure. Saudi Medical Journal.
Aloia MS, Di DL, Ilniczky N, Perlis ML, Greenblatt DW, Giles DE. (2001). Improving compliance with nasal CPAP and vigilance in older adults with OAHS. Sleep & Breathing.
Aloia MS, Stanchina M, Arnedt JT, Malhotra A, Millman RP. (2005). Treatment adherence and outcomes in flexible vs standard continuous positive airway pressure therapy. Chest.
Alonso-Fernandez A, Garcia-Rio F, Arias MA, et al. (2009). Effects of CPAP on oxidative stress and nitrate efficiency in sleep apnoea: a randomised trial. Thorax.
Alonso-Fernandez A, Garcia-Rio F, Arias MA, et al. (2006). Obstructive sleep apnoea-hypoapnoea syndrome reversibly depresses cardiac response to exercise. European Heart Journal.
Altman JS, Halpert RD, Mickelson SA, Senior BA. (1999). Effect of uvulopalatopharyngoplasty and genial and hyoid advancement on swallowing in patients with obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
Alvarez D, Hornero R, Abasolo D, del CF, Zamarron C. (2006). Nonlinear characteristics of blood oxygen saturation from nocturnal oximetry for obstructive sleep apnoea detection. Physiological Measurement.
Alvarez D, Hornero R, Garcia M, del CF, Zamarron C. (2007). Improving diagnostic ability of blood oxygen saturation from overnight pulse oximetry in obstructive sleep apnea detection by means of central tendency measure. Artificial Intelligence in Medicine.
Amfilochiou A, Tsara V, Kolilekas L, et al. (2009). Determinants of continuous positive airway pressure compliance in a group of Greek patients with obstructive sleep apnea. European Journal of Internal Medicine.
Ancoli-Israel S, Mason W, Coy TV, Stepnowsky C, Clausen JL, Dimsdale J. (1997). Evaluation of sleep disordered breathing with unattended recording: the Nightwatch System. Journal of Medical Engineering & Technology.
Ancoli-Israel S, Palmer BW, Cooke JR, et al. (2008). Cognitive effects of treating obstructive sleep apnea in Alzheimer’s disease: a randomized controlled study. Journal of the American Geriatrics Society.
Anttalainen U, Saaresranta T, Kalleinen N, Aittokallio J, Vahlberg T, Polo O. (2007). CPAP adherence and partial upper airway obstruction during sleep. Sleep & Breathing.
Argekar P, Griffin V, Litaker D, Rahman M. (2007). Sleep apnea in hemodialysis patients: risk factors and effect on survival. Hemodialysis International.
Arias MA, Garcia-Rio F, Alonso-Fernandez A, et al. (2008). CPAP decreases plasma levels of soluble tumour necrosis factor-alpha receptor 1 in obstructive sleep apnoea. European Respiratory Journal.
Arias MA, Garcia-Rio F, Alonso-Fernandez A, Martinez I, Villamor J. (2006). Pulmonary hypertension in obstructive sleep apnoea: effects of continuous positive airway pressure: a randomized, controlled cross-over study. European Heart Journal.
Atef A, Mosleh M, Hesham M, Fathi A, Hassan M, Fawzy M. (2005). Radiofrequency vs laser in the management of mild to moderate obstructive sleep apnoea: does the number of treatment sessions matter?. Journal of Laryngology & Otology.
Ayalon L, Ancoli-Israel S, Stepnowsky C, et al. (2006). Adherence to continuous positive airway pressure treatment in patients with Alzheimer’s disease and obstructive sleep apnea. American Journal of Geriatric Psychiatry.
Ayappa I, Norman RG, Suryadevara M, Rapoport DM. (2004). Comparison of limited monitoring using a nasal-cannula flow signal to full polysomnography in sleep-disordered breathing. Sleep.
Ayas NT, Pittman S, MacDonald M, White DP. (2003). Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Medicine.
Bachour A, Virkkala JT, Maasilta PK. (2007). AutoCPAP initiation at home: optimal trial duration and cost-effectiveness. Sleep Medicine.
Back L, Palomaki M, Piilonen A, Ylikoski J. (2001). Sleep-disordered breathing: radiofrequency thermal ablation is a promising new treatment possibility. Laryngoscope.
Back LJ, Liukko T, Rantanen I, et al. (2009). Hypertonic saline injections to enhance the radiofrequency thermal ablation effect in the treatment of base of tongue in obstructive sleep apnoea patients: a pilot study. Acta Oto-Laryngologica.
Bagnato MC, Nery LE, Moura SM, Bittencourt LR, Tufik S. (2000). Comparison of AutoSet and polysomnography for the detection of apnea-hypopnea events. Brazilian Journal of Medical & Biological Research.
Baisch A, Maurer JT, Hormann K. (2006). The effect of hyoid suspension in a multilevel surgery concept for obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Baldwin CM, Griffith KA, Nieto FJ, O’Connor GT, Walsleben JA, Redline S. (2001). The association of sleep-disordered breathing and sleep symptoms with quality of life in the Sleep Heart Health Study. Sleep.
Ballester E, Solans M, Vila X, et al. (2000). Evaluation of a portable respiratory recording device for detecting apnoeas and hypopnoeas in subjects from a general population. European Respiratory Journal.
Ballon JS, Feifel D. (2006). A systematic review of modafinil: Potential clinical uses and mechanisms of action. Journal of Clinical Psychiatry.
Baltzan MA, Elkholi O, Wolkove N. (2009). Evidence of interrelated side effects with reduced compliance in patients treated with nasal continuous positive airway pressure. Sleep Medicine.
Baltzan MA, Verschelden P, Al-Jahdali H, Olha AE, Kimoff RJ. (2000). Accuracy of oximetry with thermistor (OxiFlow) for diagnosis of obstructive sleep apnea and hypopnea. Sleep.
Bao X, Nelesen RA, Loredo JS, Dimsdale JE, Ziegler MG. (2002). Blood pressure variability in obstructive sleep apnea: role of sympathetic nervous activity and effect of continuous positive airway pressure. Blood Pressure Monitoring.
Bar A, Pillar G, Dvir I, Sheffy J, Schnall RP, Lavie P. (2003). Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies. Chest.
Barakate M, Havas T. (2008). Lingual tonsillectomy: a review of 5 years experience and evolution of surgical technique. Otolaryngology - Head & Neck Surgery.
Bassiouny A, El SA, Abd El-Tawab M, Atef A. (2007). Bipolar radiofrequency treatment for snoring with mild to moderate sleep apnea: a comparative study between the radiofrequency assisted uvulopalatoplasty technique and the channeling technique. European Archives of Oto-Rhino-Laryngology.
Behbehani K, Yen FC, Lucas EA, Burk JR. (1998). A sleep laboratory evaluation of an automatic positive airway pressure system for treatment of obstructive sleep apnea. Sleep.
Bennett LS, Davies RJ, Stradling JR. (1998). Oral appliances for the management of snoring and obstructive sleep apnoea. Thorax.
Berger G, Finkelstein Y, Stein G, Ophir D. (2001). Laser-assisted uvulopalatoplasty for snoring: medium- to long-term subjective and objective analysis. Archives of Otolaryngology -- Head & Neck Surgery.
Berger G, Stein G, Ophir D, Finkelstein Y. (2003). Is there a better way to do laser-assisted uvulopalatoplasty?. Archives of Otolaryngology -- Head & Neck Surgery.
Berry RB, Hill G, Thompson L, McLaurin V. (2008). Portable monitoring and autotitration versus polysomnography for the diagnosis and treatment of sleep apnea. Sleep.
Bertolazi AN, Fagondes SC, Hoff LS, Pedro VD, Menna Barreto SS, Johns MW. (2009). Portuguese-language version of the Epworth sleepiness scale: validation for use in Brazil. Jornal Brasileiro De Pneumologia: Publicacao Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia.
Bettega G, Pepin JL, Veale D, Deschaux C, Raphael B, Levy P. (2000). Obstructive sleep apnea syndrome. fifty-one consecutive patients treated by maxillofacial surgery. American Journal of Respiratory & Critical Care Medicine.
Bittencourt LR, Lucchesi LM, Rueda AD, et al. (2008). Placebo and modafinil effect on sleepiness in obstructive sleep apnea. Progress in Neuro-Psychopharmacology & Biological Psychiatry.
Black JE, Hirshkowitz M. (2005). Modafinil for treatment of residual excessive sleepiness in nasal continuous positive airway pressure-treated obstructive sleep apnea/hypopnea syndrome. Sleep.
Blanco J, Zamarron C, Abeleira Pazos MT, Lamela C, Suarez QD. (2005). Prospective evaluation of an oral appliance in the treatment of obstructive sleep apnea syndrome. Sleep & Breathing.
Blumen MB, Coquille F, Rocchicioli C, Mellot F, Chabolle F. (2006). Radiofrequency tongue reduction through a cervical approach: a pilot study. Laryngoscope.
Blumen MB, Dahan S, Fleury B, Hausser-Hauw C, Chabolle F. (2002). Radiofrequency ablation for the treatment of mild to moderate obstructive sleep apnea. Laryngoscope.
Boland LL, Shahar E, Iber C, et al. (2002). Measures of cognitive function in persons with varying degrees of sleep-disordered breathing: the Sleep Heart Health Study. Journal of Sleep Research.
Bolitschek J, Rieder A, Broinger G, Rosenberger A, Kunze M, Aigner K. (2001). N-CPAP rejecters--a specific group of noncompliant patients with obstructive sleep apnea syndrome. Wiener Klinische Wochenschrift.
Bonsignore G, Marrone O, Macaluso C, Salvaggio A, Stallone A, Bellia V. (1990). Validation of oximetry as a screening test for obstructive sleep apnoea syndrome. European Respiratory Journal - Supplement.
Boot H, Poublon RM, Van WR, et al. (1997). Uvulopalatopharyngoplasty for the obstructive sleep apnoea syndrome: value of polysomnography, Mueller manoeuvre and cephalometry in predicting surgical outcome. Clinical Otolaryngology & Allied Sciences.
Boot H, Van WR, Poublon RM, Bogaard JM, Schmitz PI, Van der Meche FG. (2000). Long-term results of uvulopalatopharyngoplasty for obstructive sleep apnea syndrome. Laryngoscope.
Borgel J, Sanner BM, Bittlinsky A, et al. (2006). Obstructive sleep apnoea and its therapy influence high-density lipoprotein cholesterol serum levels. European Respiratory Journal.
Borgel J, Sanner BM, Keskin F, et al. (2004). Obstructive sleep apnea and blood pressure. Interaction between the blood pressure-lowering effects of positive airway pressure therapy and antihypertensive drugs. American Journal of Hypertension.
Boudewyns A, De CW, Willemen M, Wagemans M, De BW, Van de Heyning PH. (1997). Influence of uvulopalatopharyngoplasty on alpha-EEG arousals in nonapnoeic snorers. European Respiratory Journal.
Bowden MT, Kezirian EJ, Utley D, Goode RL. (2005). Outcomes of hyoid suspension for the treatment of obstructive sleep apnea. Archives of Otolaryngology -- Head & Neck Surgery.
Bradley PA, Mortimore IL, Douglas NJ. (1995). Comparison of polysomnography with ResCare Autoset in the diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax.
Brin YS, Reuveni H, Greenberg S, Tal A, Tarasiuk A. (2005). Determinants affecting initiation of continuous positive airway pressure treatment. Israel Medical Association Journal: Imaj.
Brostrom A, Stromberg A, Martensson J, Ulander M, Harder L, Svanborg E. (2007). Association of Type D personality to perceived side effects and adherence in CPAP-treated patients with OSAS. Journal of Sleep Research.
Brown DJ, Kerr P, Kryger M. (2001). Radiofrequency tissue reduction of the palate in patients with moderate sleep-disordered breathing. Journal of Otolaryngology.
Brownell LG, Perez-Padilla R, West P, Kryger MH. (1983). The role of protriptyline in obstructive sleep apnea. Bulletin europeen de physiopathologie respiratoire.
Brownell LG, West P, Sweatman P, Acres JC, Kryger MH. (1982). Protriptyline in obstructive sleep apnea: a double-blind trial. New England Journal of Medicine.
Bruckert E, Duchene E, Bonnefont-Rousselot D, et al. (2010). Proof of concept study: does fenofibrate have a role in sleep apnoea syndrome?. Current Medical Research & Opinion.
Buchner NJ, Sanner BM, Borgel J, Rump LC. (2007). Continuous positive airway pressure treatment of mild to moderate obstructive sleep apnea reduces cardiovascular risk. American Journal of Respiratory & Critical Care Medicine.
Budhiraja R, Parthasarathy S, Drake CL, et al. (2007). Early CPAP use identifies subsequent adherence to CPAP therapy. Sleep.
Busaba NY. (2002). Same-stage nasal and palatopharyngeal surgery for obstructive sleep apnea: is it safe?. Otolaryngology - Head & Neck Surgery.
Cahali MB. (2003). Lateral pharyngoplasty: a new treatment for obstructive sleep apnea hypopnea syndrome. Laryngoscope.
Cahali MB, Formigoni GG, Gebrim EM, Miziara ID. (2004). Lateral pharyngoplasty versus uvulopalatopharyngoplasty: a clinical, polysomnographic and computed tomography measurement comparison. Sleep.
Caldarelli DD, Cartwright R, Lilie JK. (1986). Severity of sleep apnea as a predictor of successful treatment by palatopharyngoplasty. Laryngoscope.
Caldarelli DD, Cartwright RD, Lilie JK. (1985). Obstructive sleep apnea: variations in surgical management. Laryngoscope.
Calleja JM, Esnaola S, Rubio R, Duran J. (2002). Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. European Respiratory Journal.
Canisius S, Kesper K, Jerrentrup L, et al. (2009). C-Flex technology: effects on breathing parameters and inspiratory flow limitation. Respiration.
Carmona BC, Capote GF, Botebol BG, Garcia LP, Sanchez AA, Castillo GJ. (2000). Assessment of excessive day-time sleepiness in professional drivers with suspected obstructive sleep apnea syndrome. Archivos de bronconeumologia.
Carrasco O, Montserrat JM, Lloberes P, et al. (1996). Visual and different automatic scoring profiles of respiratory variables in the diagnosis of sleep apnoea-hypopnoea syndrome. European Respiratory Journal.
Carratu P, Karageorgiou G, Bonfitto P, et al. (2007). Long-term evaluation of mental fatigue by Maastricht Questionnaire in patients with OSAS treated with CPAP. Monaldi Archives for Chest Disease.
Casale M, Rinaldi V, Bressi F, et al. (2008). A suitable test for identifying high risk adult patients of moderate-severe obstructive sleep apnea syndrome. European Review for Medical & Pharmacological Sciences.
Chabolle F, Wagner I, Blumen MB, Sequert C, Fleury B, De DT. (1999). Tongue base reduction with hyoepiglottoplasty: a treatment for severe obstructive sleep apnea. Laryngoscope.
Chasens ER, Pack AI, Maislin G, Dinges DF, Weaver TE. (2005). Claustrophobia and adherence to CPAP treatment. Western Journal of Nursing Research.
Chiner E, Signes-Costa J, Arriero JM, Marco J, Fuentes I, Sergado A. (1999). Nocturnal oximetry for the diagnosis of the sleep apnoea hypopnoea syndrome: a method to reduce the number of polysomnographies. Thorax.
Chisholm E, Kotecha B. (2007). Oropharyngeal surgery for obstructive sleep apnoea in CPAP failures. European Archives of Oto-Rhino-Laryngology.
Choi JH, Kim EJ, Choi J, et al. (2009). The effect of adenotonsillectomy on changes of position during sleep in pediatric obstructive sleep apnea syndrome. American Journal of Rhinology & Allergy.
Choi S, Bennett LS, Mullins R, Davies RJ, Stradling JR. (2000). Which derivative from overnight oximetry best predicts symptomatic response to nasal continuous positive airway pressure in patients with obstructive sleep apnoea. Respiratory Medicine.
Choi S, Mullins R, Crosby JH, Davies RJO, Stradling JR. (2001). Is (re)titration of nasal continuous positive airway pressure for obstructive sleep apnoea necessary. Sleep Medicine.
Chong MS, Ayalon L, Marler M, et al. (2006). Continuous positive airway pressure reduces subjective daytime sleepiness in patients with mild to moderate Alzheimer’s disease with sleep disordered breathing. Journal of the American Geriatrics Society.
Cillo JE, Finn R, Dasheiff RM. (2006). Combined open rhinoplasty with spreader grafts and laser-assisted uvuloplasty for sleep-disordered breathing: long-term subjective outcomes. Journal of Oral & Maxillofacial Surgery.
Cincik H, Cekin E, Cetin B, Gungor A, Poyrazoglu E. (2006). Comparison of uvulopalatopharyngoplasty, laser-assisted uvulopalatoplasty and cautery-assisted uvulopalatoplasty in the treatment of primary snoring. Orl; Journal of Oto-Rhino-Laryngology & its Related Specialties.
Cistulli PA, Palmisano RG, Poole MD. (1998). Treatment of obstructive sleep apnea syndrome by rapid maxillary expansion. Sleep.
Clark GT, Arand D, Chung E, Tong D. (1993). Effect of anterior mandibular positioning on obstructive sleep apnea. American Review of Respiratory Disease.
Coleman JA. (1998). Laser-assisted uvulopalatoplasty: long-term results with a treatment for snoring. Ear, Nose, & Throat Journal.
Collen J, Lettieri C, Kelly W, Roop S. (2009). Clinical and polysomnographic predictors of short-term continuous positive airway pressure compliance. Chest.
Collop NA. (2010). Home sleep testing: it is not about the test. Chest.
Conradt R, Hochban W, Brandenburg U, Heitmann J, Peter JH. (1997). Long-term follow-up after surgical treatment of obstructive sleep apnoea by maxillomandibular advancement. European Respiratory Journal.
Conway W, Fujita S, Zorick F, et al. (1985). Uvulopalatopharyngoplasty. One-year followup. Chest.
Craig S, Pepperell JC, Kohler M, Crosthwaite N, Davies RJ, Stradling JR. (2009). Continuous positive airway pressure treatment for obstructive sleep apnoea reduces resting heart rate but does not affect dysrhythmias: a randomised controlled trial. Journal of Sleep Research.
Croft CB, Golding-Wood DG. (1990). Uses and complications of uvulopalatopharyngoplasty. Journal of Laryngology & Otology.
Cross MD, Vennelle M, Engleman HM, et al. (2006). Comparison of CPAP titration at home or the sleep laboratory in the sleep apnea hypopnea syndrome. Sleep.
Dattilo DJ, Drooger SA. (2004). Outcome assessment of patients undergoing maxillofacial procedures for the treatment of sleep apnea: comparison of subjective and objective results. Journal of Oral & Maxillofacial Surgery.
Davis JA, Fine ED, Maniglia AJ. (1993). Uvulopalatopharyngoplasty for obstructive sleep apnea in adults: clinical correlation with polysomnographic results. Ear, Nose, & Throat Journal.
de Almeida FR, Lowe AA, Tsuiki S, et al. (2005). Long-term compliance and side effects of oral appliances used for the treatment of snoring and obstructive sleep apnea syndrome. Journal of Clinical Sleep Medicine.
Defaye P, Pepin JL, Poezevara Y, et al. (2004). Automatic recognition of abnormal respiratory events during sleep by a pacemaker transthoracic impedance sensor. Journal of Cardiovascular Electrophysiology.
del Campo F, Hornero R, Zamarron C, Abasolo DE, Alvarez D. (2006). Oxygen saturation regularity analysis in the diagnosis of obstructive sleep apnea. Artificial Intelligence in Medicine.
Delides A, Viskos A. (2010). Fractal quantitative endoscopic evaluation of the upper airway in patients with obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
den Herder C, Kox D, van Tinteren H, de Vries N. (2006). Bipolar radiofrequency induced thermotherapy of the tongue base: Its complications, acceptance and effectiveness under local anesthesia. European Archives of Oto-Rhino-Laryngology.
den Herder C, van Tinteren H, de Vries N. (2005). Hyoidthyroidpexia: a surgical treatment for sleep apnea syndrome. Laryngoscope.
Dickson RI, Mintz DR. (1996). One-stage laser-assisted uvulopalatoplasty. Journal of Otolaryngology.
Dimsdale JE, Loredo JS, Profant J. (2000). Effect of continuous positive airway pressure on blood pressure : a placebo trial. Hypertension.
Ding J, Nieto FJ, Beauchamp NJ, et al. (2004). Sleep-disordered breathing and white matter disease in the brainstem in older adults. Sleep.
Dinges DF, Weaver TE. (2003). Effects of modafinil on sustained attention performance and quality of life in OSA patients with residual sleepiness while being treated with nCPAP. Sleep Medicine.
Dingli K, Coleman EL, Vennelle M, et al. (2003). Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. European Respiratory Journal.
Djupesland G, Schrader H, Lyberg T, Refsum H, Lilleas F, Godtlibsen OB. (1992). Palatopharyngoglossoplasty in the treatment of patients with obstructive sleep apnea syndrome. Acta Oto-Laryngologica Supplement.
Dort LC, Hussein J. (2004). Snoring and obstructive sleep apnea: compliance with oral appliance therapy. Journal of Otolaryngology.
d’Ortho MP, Grillier-Lanoir V, Levy P, et al. (2000). Constant vs. automatic continuous positive airway pressure therapy: home evaluation. Chest.
Douglas NJ, Thomas S, Jan MA. (1992). Clinical value of polysomnography. Lancet.
Drigo R, Fontana M, Coin A, Ferraresso A, Enzo E, Zambotto FM. (2006). APAP titration in patients with mild to moderate OSAS and periodic limb movement syndrome. Monaldi Archives for Chest Disease.
Dunlevy TM, Karakla DW. (1998). Uvulopalatopharyngoplasty: the Naval Medical Center, Portsmouth, experience. American Journal of Otolaryngology.
Elasfour A, Miyazaki S, Itasaka Y, Yamakawa K, Ishikawa K, Togawa K. (1998). Evaluation of uvulopalatopharyngoplasty in treatment of obstructive sleep apnea syndrome. Acta Oto-Laryngologica Supplement.
Elbaz M, Roue GM, Lofaso F, Quera Salva MA. (2002). Utility of actigraphy in the diagnosis of obstructive sleep apnea. Sleep.
Elshaug AG, Moss JR, Southcott AM, Hiller JE. (2007). An analysis of the evidence-practice continuum: is surgery for obstructive sleep apnoea contraindicated. Journal of Evaluation in Clinical Practice.
el-Solh AA, Mador MJ, Ten-Brock E, Shucard DW, Abul-Khoudoud M, Grant BJ. (1999). Validity of neural network in sleep apnea. Sleep.
Emsellem HA, Corson WA, Rappaport BA, Hackett S, Smith LG, Hausfeld JN. (1990). Verification of sleep apnea using a portable sleep apnea screening device. Southern Medical Journal.
Engelke WG, Mendoza M, Repetto G. (2006). Preliminary radiographic observations of the tongue-repositioning manoeuvre. European Journal of Orthodontics.
Engleman HM, Asgari-Jirhandeh N, McLeod AL, Ramsay CF, Deary IJ, Douglas NJ. (1996). Self-reported use of CPAP and benefits of CPAP therapy: a patient survey. Chest.
Engleman HM, Cheshire KE, Deary IJ, Douglas NJ. (1993). Daytime sleepiness, cognitive performance and mood after continuous positive airway pressure for the sleep apnoea/hypopnoea syndrome. Thorax.
Epstein LJ, Dorlac GR. (1998). Cost-effectiveness analysis of nocturnal oximetry as a method of screening for sleep apnea-hypopnea syndrome. Chest.
Esnaola S, Duran J, Infante-Rivard C, Rubio R, Fernandez A. (1996). Diagnostic accuracy of a portable recording device (MESAM IV) in suspected obstructive sleep apnoea. European Respiratory Journal.
Eun YG, Kim SW, Kwon KH, Byun JY, Lee KH. (2008). Single-session radiofrequency tongue base reduction combined with uvulopalatopharyngoplasty for obstructive sleep apnea syndrome. European Archives of Oto-Rhino-Laryngology.
Eun YG, Kwon KH, Shin SY, Lee KH, Byun JY, Kim SW. (2009). Multilevel surgery in patients with rapid eye movement-related obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Eveloff SE, Rosenberg CL, Carlisle CC, Millman RP. (1994). Efficacy of a Herbst mandibular advancement device in obstructive sleep apnea. American Journal of Respiratory & Critical Care Medicine.
Faber CE, Hilberg O, Grymer L. (2002). Flextube reflectometry for level diagnosis in patients with obstructive sleep apnoea and snoring. Rhinology.
Farney RJ, Walker LE, Jensen RL, Walker JM. (1986). Ear oximetry to detect apnea and differentiate rapid eye movement (REM) and non-REM (NREM) sleep. Screening for the sleep apnea syndrome. Chest.
Ferguson KA, Ono T, Lowe AA, al-Majed S, Love LL, Fleetham JA. (1997). A short-term controlled trial of an adjustable oral appliance for the treatment of mild to moderate obstructive sleep apnoea. Thorax.
Ferland A, Poirier P, Series F. (2009). Sibutramine versus continuous positive airway pressure in obese obstructive sleep apnoea patients. European Respiratory Journal.
Fernandez-Julian E, Munoz N, Achiques MT, Garcia-Perez MA, Orts M, Marco J. (2009). Randomized study comparing two tongue base surgeries for moderate to severe obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
Fibbi A, Ameli F, Brocchetti F, Mignosi S, Cabano ME, Semino L. (2009). Tongue base suspension and radiofrequency volume reduction: a comparison between 2 techniques for the treatment of sleep-disordered breathing. American Journal of Otolaryngology.
Ficker JH, Clarenbach CF, Neukirchner C, et al. (2003). Auto-CPAP therapy based on the forced oscillation technique. Biomedizinische Technik.
Ficker JH, Fuchs FS, Wiest GH, Asshoff G, Schmelzer AH, Hahn EG. (2000). An auto-continuous positive airway pressure device controlled exclusively by the forced oscillation technique. European Respiratory Journal.
Ficker JH, Wiest GH, Lehnert G, Wiest B, Hahn EG. (1998). Evaluation of an auto-CPAP device for treatment of obstructive sleep apnoea. Thorax.
Ficker JH, Wiest GH, Wilpert J, Fuchs FS, Hahn EG. (2001). Evaluation of a portable recording device (Somnocheck) for use in patients with suspected obstructive sleep apnoea. Respiration.
Fietze I, Glos M, Rottig J, Witt C. (2002). Automated analysis of data is inferior to visual analysis of ambulatory sleep apnea monitoring. Respiration.
Fietze I, Quispe-Bravo S, Hansch T, Rottig J, Baumann G, Witt C. (1997). Arousals and sleep stages in patients with obstructive sleep apnoea syndrome: Changes under nCPAP treatment. Journal of Sleep Research.
Findley L, Smith C, Hooper J, Dineen M, Suratt PM. (2000). Treatment with nasal CPAP decreases automobile accidents in patients with sleep apnea. American Journal of Respiratory & Critical Care Medicine.
Finkelstein Y, Shapiro-Feinberg M, Stein G, Ophir D. (1997). Uvulopalatopharyngoplasty vs laser-assisted uvulopalatoplasty. Anatomical considerations. Archives of Otolaryngology -- Head & Neck Surgery.
Finkelstein Y, Stein G, Ophir D, Berger R, Berger G. (2002). Laser-assisted uvulopalatoplasty for the management of obstructive sleep apnea: myths and facts. Archives of Otolaryngology -- Head & Neck Surgery.
Fischer Y, Khan M, Mann WJ. (2003). Multilevel temperature-controlled radiofrequency therapy of soft palate, base of tongue, and tonsils in adults with obstructive sleep apnea. Laryngoscope.
Fitzpatrick MF, Alloway CE, Wakeford TM, MacLean AW, Munt PW, Day AG. (2003). Can patients with obstructive sleep apnea titrate their own continuous positive airway pressure?. American Journal of Respiratory & Critical Care Medicine.
Flemons WW, Whitelaw WA, Brant R, Remmers JE. (1994). Likelihood ratios for a sleep apnea clinical prediction rule. American Journal of Respiratory & Critical Care Medicine.
Fleury B, Rakotonanahary D, Hausser-Hauw C, Lebeau B, Guilleminault C. (1996). A laboratory validation study of the diagnostic mode of the Autoset system for sleep-related respiratory disorders. Sleep.
Foltan R, Hoffmannova J, Pretl M, Donev F, Vlk M. (2007). Genioglossus advancement and hyoid myotomy in treating obstructive sleep apnoea syndrome - A follow-up study. Journal of Cranio-Maxillo-Facial Surgery.
Fong SY, Ho CK, Wing YK. (2005). Comparing MSLT and ESS in the measurement of excessive daytime sleepiness in obstructive sleep apnoea syndrome. Journal of Psychosomatic Research.
Fransson AM, Isacsson G, Leissner LC, Nasman AB, Alton MK. (2001). Treatment of snoring and obstructive sleep apnea with a mandibular protruding device: an open-label study. Sleep & Breathing.
Freedman RR, Roehrs TA. (2007). Sleep disturbance in menopause. Menopause.
Friedman M, Duggal P, Joseph NJ. (2007). Revision uvulopalatoplasty by Z-palatoplasty. Otolaryngology - Head & Neck Surgery.
Friedman M, Ibrahim H, Bass L. (2002). Clinical staging for sleep-disordered breathing. Otolaryngology - Head & Neck Surgery.
Friedman M, Ibrahim H, Joseph NJ. (2004). Staging of obstructive sleep apnea/hypopnea syndrome: a guide to appropriate treatment. Laryngoscope.
Friedman M, Ibrahim H, Lowenthal S, Ramakrishnan V, Joseph NJ. (2004). Uvulopalatoplasty (UP2): a modified technique for selected patients. Laryngoscope.
Friedman M, Ibrahim HZ, Vidyasagar R, Pomeranz J, Joseph NJ. (2004). Z-palatoplasty (ZPP): a technique for patients without tonsils. Otolaryngology - Head & Neck Surgery.
Friedman M, Schalch P, Joseph NJ. (2006). Palatal stiffening after failed uvulopalatopharyngoplasty with the Pillar Implant System. Laryngoscope.
Friedman M, Soans R, Gurpinar B, Lin HC, Joseph N. (2008). Evaluation of submucosal minimally invasive lingual excision technique for treatment of obstructive sleep apnea/hypopnea syndrome. Otolaryngology - Head & Neck Surgery.
Friedman M, Soans R, Joseph N, Kakodkar S, Friedman J. (2009). The effect of multilevel upper airway surgery on continuous positive airway pressure therapy in obstructive sleep apnea/hypopnea syndrome. Laryngoscope.
Friedman M, Tanyeri H, La RM, et al. (1999). Clinical predictors of obstructive sleep apnea. Laryngoscope.
Friedman M, Vidyasagar R, Bliznikas D, Joseph N. (2005). Does severity of obstructive sleep apnea/hypopnea syndrome predict uvulopalatopharyngoplasty outcome. Laryngoscope.
Friedman M, Vidyasagar R, Bliznikas D, Joseph NJ. (2006). Patient selection and efficacy of pillar implant technique for treatment of snoring and obstructive sleep apnea/hypopnea syndrome. Otolaryngology - Head & Neck Surgery.
Fry JM, DiPhillipo MA, Curran K, Goldberg R, Baran AS. (1998). Full polysomnography in the home. Sleep.
Fujita S, Conway W, Zorick F, Roth T. (1981). Surgical correction of anatomic azbnormalities in obstructive sleep apnea syndrome: uvulopalatopharyngoplasty. Otolaryngology - Head & Neck Surgery.
Fujita S, Conway WA, Zorick FJ, et al. (1985). Evaluation of the effectiveness of uvulopalatopharyngoplasty. Laryngoscope.
Fujita S, Woodson BT, Clark JL, Wittig R. (1991). Laser midline glossectomy as a treatment for obstructive sleep apnea. Laryngoscope.
Furuta H, Kaneda R, Kosaka K, Arai H, Sano J, Koshino Y. (1999). Epworth Sleepiness Scale and sleep studies in patients with obstructive sleep apnea syndrome. Psychiatry & Clinical Neurosciences.
Gagnadoux F, Pelletier-Fleury N, Philippe C, Rakotonanahary D, Fleury B. (2002). Home unattended vs hospital telemonitored polysomnography in suspected obstructive sleep apnea syndrome: a randomized crossover trial. Chest.
Galetke W, Randerath WJ, Stieglitz S, et al. (2009). Comparison of manual titration and automatic titration based on forced oscillation technique, flow and snoring in obstructive sleep apnea. Sleep Medicine.
Gali B, Whalen FX, Schroeder DR, Gay PC, Plevak DJ. (2009). Identification of patients at risk for postoperative respiratory complications using a preoperative obstructive sleep apnea screening tool and postanesthesia care assessment. Anesthesiology.
Garza CA, Pellikka PA, Somers VK, et al. (2010). Structural and functional changes in left and right ventricles after major weight loss following bariatric surgery for morbid obesity. American Journal of Cardiology.
Gauthier L, Laberge L, Beaudry M, Laforte M, Rompre PH, Lavigne GJ. (2009). Efficacy of two mandibular advancement appliances in the management of snoring and mild-moderate sleep apnea: a cross-over randomized study. Sleep Medicine.
Ghazal A, Sorichter S, Jonas I, Rose EC. (2009). A randomized prospective long-term study of two oral appliances for sleep apnoea treatment. Journal of Sleep Research.
Gilman MP, Floras JS, Usui K, Kaneko Y, Leung RS, Bradley TD. (2008). Continuous positive airway pressure increases heart rate variability in heart failure patients with obstructive sleep apnoea. Clinical Science.
Gislason T, Lindholm CE, Almqvist M, et al. (1988). Uvulopalatopharyngoplasty in the sleep apnea syndrome. Predictors of results. Archives of Otolaryngology -- Head & Neck Surgery.
Gislason T, Tammivaara R. (1992). Airway obstruction, obesity and CO2 ventilatory responsiveness in the sleep apnea syndrome. Upsala Journal of Medical Sciences.
Goessler UR, Hein G, Verse T, Stuck BA, Hormann K, Maurer JT. (2007). Soft palate implants as a minimally invasive treatment for mild to moderate obstructive sleep apnea. Acta Oto-Laryngologica.
Goh YH, Lim KA. (2003). Modified maxillomandibular advancement for the treatment of obstructive sleep apnea: a preliminary report. Laryngoscope.
Goh YH, Mark I, Fee WE. (2007). Quality of life 17 to 20 years after uvulopalatopharyngoplasty. Laryngoscope.
Golpe R, Jimenez A, Carpizo R. (2002). Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest.
Golpe R, Jimenez A, Carpizo R, Cifrian JM. (1999). Utility of home oximetry as a screening test for patients with moderate to severe symptoms of obstructive sleep apnea. Sleep.
Grontved AM, Karup P. (2000). Complaints and satisfaction after uvulopalatopharyngoplasty. Acta Oto-Laryngologica Supplement.
Gugger M. (1997). Comparison of ResMed AutoSet (version 3.03) with polysomnography in the diagnosis of the sleep apnoea/hypopnoea syndrome. European Respiratory Journal.
Gugger M, Mathis J, Bassetti C. (1995). Accuracy of an intelligent CPAP machine with in-built diagnostic abilities in detecting apnoeas: a comparison with polysomnography. Thorax.
Guilleminault C, Hayes B. (1983). Naloxone, theophylline, bromocriptine, and obstructive sleep apnea. Negative results. Bulletin europeen de physiopathologie respiratoire.
Guilleminault C, Hayes B, Smith L, Simmons FB. (1983). Palatopharyngoplasty and obstructive sleep apnea syndrome. Bulletin europeen de physiopathologie respiratoire.
Gyulay S, Gould D, Sawyer B, Pond D, Mant A, Saunders N. (1987). Evaluation of a microprocessor-based portable home monitoring system to measure breathing during sleep. Sleep.
Gyulay S, Olson LG, Hensley MJ, King MT, Allen KM, Saunders NA. (1993). A comparison of clinical assessment and home oximetry in the diagnosis of obstructive sleep apnea. American Review of Respiratory Disease.
Hagert B, Wahren LK, Wikblad K, Odkvist L. (1999). Patients’ and cohabitants’ reports on snoring and daytime sleepiness, 1–8 years after surgical treatment of snoring. Orl; Journal of Oto-Rhino-Laryngology & its Related Specialties.
Han F, Song W, Li J, Zhang L, Dong X, He Q. (2006). Influence of UPPP surgery on tolerance to subsequent continuous positive airway pressure in patients with OSAHS. Sleep & Breathing.
Hanada T, Furuta S, Tateyama T, Uchizono A, Seki D, Ohyama M. (1996). Laser-assisted uvulopalatoplasty with Nd:YAG laser for sleep disorders. Laryngoscope.
Haraldsson PO, Bredbacka S. (1996). Laser-uvulopalatoplasty (LUPP) under local anesthesia: effective, safe and comfortable. Orl; Journal of Oto-Rhino-Laryngology & its Related Specialties.
Haraldsson PO, Carenfelt C, Knutsson E, Persson HE, Rinder J. (1992). Preliminary report: validity of symptom analysis and daytime polysomnography in diagnosis of sleep apnea. Sleep.
Haraldsson PO, Carenfelt C, Lysdahl M, Tornros J. (1995). Long-term effect of uvulopalatopharyngoplasty on driving performance. Archives of Otolaryngology -- Head & Neck Surgery.
Hattori C, Nishimura T, Kawakatsu K, Hayakawa M, Suzuki K. (2003). Comparison of surgery and nasal continuous positive airway pressure treatment for obstructive sleep apnea syndrome. Acta Oto-Laryngologica Supplement.
Hayakawa M, Nishimura T, Suzuki K, et al. (2003). Comparison of the state of sleep in patients with sleep-disordered breathing before and after surgical treatment. Acta Oto-Laryngologica Supplement.
He J, Kryger MH, Zorick FJ, Conway W, Roth T. (1988). Mortality and apnea index in obstructive sleep apnea. Experience in 385 male patients. Chest.
Hedner J, Kraiczi H, Peker Y, Murphy P. (2003). Reduction of sleep-disordered breathing after physostigmine. American Journal of Respiratory & Critical Care Medicine.
Hedner J, Pillar G, Pittman SD, Zou D, Grote L, White DP. (2004). A novel adaptive wrist actigraphy algorithm for sleep-wake assessment in sleep apnea patients. Sleep.
Hendler BH, Costello BJ, Silverstein K, Yen D, Goldberg A. (2001). A protocol for uvulopalatopharyngoplasty, mortised genioplasty, and maxillomandibular advancement in patients with obstructive sleep apnea: an analysis of 40 cases. Journal of Oral & Maxillofacial Surgery.
Herer B, Roche N, Carton M, Roig C, Poujol V, Huchon G. (1999). Value of clinical, functional, and oximetric data for the prediction of obstructive sleep apnea in obese patients. Chest.
Herford AS, Finn R. (2000). Single-stage CO2 laser assisted uvuloplasty for treatment of snoring and mild obstructive sleep apnoea. Journal of Cranio-Maxillo-Facial Surgery.
Hermida RC, Zamarron C, Ayala DE, Calvo C. (2004). Effect of continuous positive airway pressure on ambulatory blood pressure in patients with obstructive sleep apnoea. Blood Pressure Monitoring.
Hertegonne KB, Rombaut B, Houtmeyers P, Van MG, Pevernagie DA. (2008). Titration efficacy of two auto-adjustable continuous positive airway pressure devices using different flow limitation-based algorithms. Respiration.
Hertegonne KB, Volna J, Portier S, De PR, Van MG, Pevernagie DA. (2008). Titration procedures for nasal CPAP: automatic CPAP or prediction formula. Sleep Medicine.
Hessel NS, de VN. (2003). Results of uvulopalatopharyngoplasty after diagnostic workup with polysomnography and sleep endoscopy: a report of 136 snoring patients. European Archives of Oto-Rhino-Laryngology.
Hessel NS, Vries N. (2004). Increase of the apnoea-hypopnoea index after uvulopalatopharyngoplasty: analysis of failure. Clinical Otolaryngology & Allied Sciences.
Hester TO, Phillips B, Archer SM. (1995). Surgery for obstructive sleep apnea: effects on sleep, breathing, and oxygenation. Southern Medical Journal.
Hira HS. (1998). Obstructive sleep apnea syndrome: evaluation of subcritical continuous positive airway pressure. Journal of the Association of Physicians of India.
Hirshkowitz M, Black JE, Wesnes K, Niebler G, Arora S, Roth T. (2007). Adjunct armodafinil improves wakefulness and memory in obstructive sleep apnea/hypopnea syndrome. Respiratory Medicine.
Hla KM, Young T, Finn L, Peppard PE, Szklo-Coxe M, Stubbs M. (2008). Longitudinal association of sleep-disordered breathing and nondipping of nocturnal blood pressure in the Wisconsin Sleep Cohort Study. Sleep.
Hochban W, Brandenburg U, Peter JH. (1994). Surgical treatment of obstructive sleep apnea by maxillomandibular advancement. Sleep.
Hochban W, Conradt R, Brandenburg U, Heitmann J, Peter JH. Surgical maxillofacial treatment of obstructive sleep apnea. Plastic & Reconstructive Surgery.
Hoekema A. (2006). Efficacy and comorbidity of oral appliances in the treatment of obstructive sleep apnea-hypopnea: a systematic review and preliminary results of a randomized trial. Sleep & Breathing.
Hoekema A, Stegenga B, Bakker M, et al. (2007). Simulated driving in obstructive sleep apnoea-hypopnoea; effects of oral appliances and continuous positive airway pressure. Sleep & Breathing.
Hoekema A, Voors AA, Wijkstra PJ, et al. (2008). Effects of oral appliances and CPAP on the left ventricle and natriuretic peptides. International Journal of Cardiology.
Hofer SO, Dhar BK, Robinson PH, Goorhuis-Brouwer SM, Nicolai JP. A 10-year review of perioperative complications in pharyngeal flap surgery. Plastic & Reconstructive Surgery.
Hoffstein V, Szalai JP. (1993). Predictive value of clinical features in diagnosing obstructive sleep apnea. Sleep.
Hoffstein V, Viner S, Mateika S, Conway J. (1992). Treatment of obstructive sleep apnea with nasal continuous positive airway pressure. Patient compliance, perception of benefits, and side effects. American Review of Respiratory Disease.
Hollandt JH, Mahlerwein M. (2003). Nasal breathing and continuous positive airway pressure (CPAP) in patients with obstructive sleep apnea (OSA). Sleep & Breathing.
Hsiao HR, Wang PC, Cheng WN, et al. (2009). Survey of short-term patient satisfaction after surgery for obstructive sleep apnea. Chang Gung Medical Journal.
Hsu CY, Vennelle M, Li HY, Engleman HM, Dennis MS, Douglas NJ. (2006). Sleep-disordered breathing after stroke: a randomised controlled trial of continuous positive airway pressure. Journal of Neurology, Neurosurgery & Psychiatry.
Huang TW, Cheng PW. (2008). Microdebrider-assisted extended uvulopalatoplasty: an effective and safe technique for selected patients with obstructive sleep apnea syndrome. Archives of Otolaryngology -- Head & Neck Surgery.
Hultcrantz E, Johansson K, Bengtson H. (1999). The effect of uvulopalatopharyngoplasty without tonsillectomy using local anaesthesia: a prospective long-term follow-up. Journal of Laryngology & Otology.
Iber C, Redline S, Kaplan Gilpin AM, et al. (2004). Polysomnography performed in the unattended home versus the attended laboratory setting--Sleep Heart Health Study methodology. Sleep.
Ibrahim LH, Jacono FJ, Patel SR, et al. (2010). Heritability of abnormalities in cardiopulmonary coupling in sleep apnea: use of an electrocardiogram-based technique. Sleep.
Insalaco G, Romano S, Marrone O, Salvaggio A, Bonsignore G. (2005). A new method of negative expiratory pressure test analysis detecting upper airway flow limitation to reveal obstructive sleep apnea. Chest.
Ip MS, Lam B, Ng MM, Lam WK, Tsang KW, Lam KS. (2002). Obstructive sleep apnea is independently associated with insulin resistance. American Journal of Respiratory & Critical Care Medicine.
Issa FG, Morrison D, Hadjuk E, Iyer A, Feroah T, Remmers JE. (1993). Digital monitoring of sleep-disordered breathing using snoring sound and arterial oxygen saturation. American Review of Respiratory Disease.
Itasaka Y, Miyazaki S, Tanaka T, Ishikawa K. (2001). Uvulopalatopharyngoplasty for obstructive sleep-related breathing disorders: one-year follow up. Psychiatry & Clinical Neurosciences.
Jacobowitz O. (2006). Palatal and tongue base surgery for surgical treatment of obstructive sleep apnea: a prospective study. Otolaryngology - Head & Neck Surgery.
Janson C, Gislason T, Bengtsson H, et al. (1997). Long-term follow-up of patients with obstructive sleep apnea treated with uvulopalatopharyngoplasty. Archives of Otolaryngology -- Head & Neck Surgery.
Jenkinson C, Davies RJ, Mullins R, Stradling JR. (2001). Long-term benefits in self-reported health status of nasal continuous positive airway pressure therapy for obstructive sleep apnoea. Qjm.
Jobin V, Mayer P, Bellemare F. (2007). Predictive value of automated oxygen saturation analysis for the diagnosis and treatment of obstructive sleep apnoea in a home-based setting. Thorax.
Johal A. (2006). Health-related quality of life in patients with sleep-disordered breathing: effect of mandibular advancement appliances. Journal of Prosthetic Dentistry.
Kamami YV. (1994). Outpatient treatment of sleep apnea syndrome with CO2 laser: laser-assisted UPPP. Journal of Otolaryngology.
Kao YH, Shnayder Y, Lee KC. (2003). The efficacy of anatomically based multilevel surgery for obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Karason K, Lindroos AK, Stenlof K, Sjostrom L. (2000). Relief of cardiorespiratory symptoms and increased physical activity after surgically induced weight loss: results from the Swedish Obese Subjects study. Archives of Internal Medicine.
Katz I, Zamel N, Slutsky AS, Rebuck AS, Hoffstein V. (1990). An evaluation of flow-volume curves as a screening test for obstructive sleep apnea. Chest.
Kawakatsu K, Nishimura T. (2003). Long-term surgical follow-up of sleep apnea syndrome. Acta Oto-Laryngologica Supplement.
Keenan SP, Anderson B, Wiggs B, Ryan CF, Fleetham JA. (1993). The predictive accuracy of home oximetry in patients with suspected obstructive sleep apnea. Sleep.
Kern RC, Kutler DI, Reid KJ, Conley DB, Herzon GD, Zee P. (2003). Laser-assisted uvulopalatoplasty and tonsillectomy for the management of obstructive sleep apnea syndrome. Laryngoscope.
Khan A, Ramar K, Maddirala S, Friedman O, Pallanch JF, Olson EJ. (2009). Uvulopalatopharyngoplasty in the management of obstructive sleep apnea: the mayo clinic experience. Mayo Clinic Proceedings.
Khan W, Gleason R, Strome M, Regestein Q. (1995). Clinical features as diagnostic guides in obstructive sleep apnea. Comprehensive Psychiatry.
Khayat RN, Abraham WT, Patt B, Pu M, Jarjoura D. (2009). In-hospital treatment of obstructive sleep apnea during decompensation of heart failure. Chest.
Kiely JL, Delahunty C, Matthews S, McNicholas WT. (1996). Comparison of a limited computerized diagnostic system (ResCare Autoset) with polysomnography in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal.
Kiely JL, Murphy M, McNicholas WT. (1999). Subjective efficacy of nasal CPAP therapy in obstructive sleep apnoea syndrome: a prospective controlled study. European Respiratory Journal.
Kim JA, Lee JJ, Jung HH. (2005). Predictive factors of immediate postoperative complications after uvulopalatopharyngoplasty. Laryngoscope.
Kim ST, Choi JH, Jeon HG, Cha HE, Kim DY, Chung YS. (2004). Polysomnographic effects of nasal surgery for snoring and obstructive sleep apnea. Acta Oto-Laryngologica.
Kingshott RN, Douglas NJ. (2000). The effect of in-laboratory polysomnography on sleep and objective daytime sleepiness. Sleep.
Kingshott RN, Vennelle M, Coleman EL, Engleman HM, Mackay TW, Douglas NJ. (2001). Randomized, double-blind, placebo-controlled crossover trial of modafinil in the treatment of residual excessive daytime sleepiness in the sleep apnea/hypopnea syndrome. American Journal of Respiratory & Critical Care Medicine.
Kita H, Ohi M, Chin K, et al. (1998). Effects of nasal continuous positive airway pressure therapy on respiratory parameters of upper airway patency in patients with obstructive sleep apnea syndrome. Chest.
Kohler M, Pepperell JC, Casadei B, et al. (2008). CPAP and measures of cardiovascular risk in males with OSAS. European Respiratory Journal.
Konermann M, Sanner BM, Vyleta M, et al. (1998). Use of conventional and self-adjusting nasal continuous positive airway pressure for treatment of severe obstructive sleep apnea syndrome: a comparative study. Chest.
Koziej M, Cieslicki JK, Gorzelak K, Sliwinski P, Zielinski J. (1994). Hand-scoring of MESAM 4 recordings is more accurate than automatic analysis in screening for obstructive sleep apnoea. European Respiratory Journal.
Krahn AD, Yee R, Erickson MK, et al. (2006). Physiologic pacing in patients with obstructive sleep apnea: a prospective, randomized crossover trial. Journal of the American College of Cardiology.
Krakow B, Melendrez D, Ferreira E, et al. (2001). Prevalence of insomnia symptoms in patients with sleep-disordered breathing. Chest.
Krekmanov L, Andersson L, Ringqvist M, et al. (1998). Anterior-inferior mandibular osteotomy in treatment of obstructive sleep apnea syndrome. International Journal of Adult Orthodontics & Orthognathic Surgery.
Krieger J. (1992). Long-term compliance with nasal continuous positive airway pressure (CPAP) in obstructive sleep apnea patients and nonapneic snorers. Sleep.
Krieger J, Meslier N, Lebrun T, et al. (1997). Accidents in obstructive sleep apnea patients treated with nasal continuous positive airway pressure: a prospective study. The Working Group ANTADIR, Paris and CRESGE, Lille, France. Association Nationale de Traitement a Domicile des Insuffisants Respiratoires. Chest.
Krystal AD, Harsh JR, Yang RR, Rippon GA, Lankford DA. (2010). A double-blind, placebo-controlled study of armodafinil for excessive sleepiness in patients with treated obstructive sleep apnea and comorbid depression. Journal of Clinical Psychiatry.
Kuhnel TS, Schurr C, Wagner B, Geisler P. (2005). Morphological changes of the posterior airway space after tongue base suspension. Laryngoscope.
Kushida CA, Nichols DA, Quan SF, et al. (2006). The Apnea Positive Pressure Long-term Efficacy Study (APPLES): rationale, design, methods, and procedures. Journal of Clinical Sleep Medicine.
Langin T, Pepin JL, Pendlebury S, et al. (1998). Upper airway changes in snorers and mild sleep apnea sufferers after uvulopalatopharyngoplasty (UPPP). Chest.
Larsson H, Carlsson-Nordlander B, Svanborg E. (1991). Long-time follow-up after UPPP for obstructive sleep apnea syndrome. Results of sleep apnea recordings and subjective evaluation 6 months and 2 years after surgery. Acta Oto-Laryngologica.
Larsson LH, Carlsson-Nordlander B, Svanborg E. (1994). Four-year follow-up after uvulopalatopharyngoplasty in 50 unselected patients with obstructive sleep apnea syndrome. Laryngoscope.
Lauretano AM, Khosla RK, Richardson G, et al. (1997). Efficacy of laser-assisted uvulopalatoplasty. Lasers in Surgery & Medicine.
Lavie P, Lavie L. (2009). Unexpected survival advantage in elderly people with moderate sleep apnoea. Journal of Sleep Research.
Lawton HM, Battagel JM, Kotecha B. (2005). A comparison of the Twin Block and Herbst mandibular advancement splints in the treatment of patients with obstructive sleep apnoea: a prospective study. European Journal of Orthodontics.
Lee CH, Shin HW, Han DH, et al. (2009). The implication of sleep position in the evaluation of surgical outcomes in obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Lee NR, Givens CD, Wilson J, Robins RB. (1999). Staged surgical treatment of obstructive sleep apnea syndrome: a review of 35 patients. Journal of Oral & Maxillofacial Surgery.
Leng PH, Mosharraf-Hossain AK, Chan YH, Tan WC. (2006). The clinical predictors of hypertension and sleepiness in an Asian population with sleep-disordered breathing. Annals of the Academy of Medicine, Singapore.
Levy P, Pepin JL, Deschaux-Blanc C, Paramelle B, Brambilla C. (1996). Accuracy of oximetry for detection of respiratory disturbances in sleep apnea syndrome. Chest.
Lewis MR, Ducic Y. (2003). Genioglossus muscle advancement with the genioglossus bone advancement technique for base of tongue obstruction. Journal of Otolaryngology.
Li HY, Chen NH, Lee LA, Shu YH, Fang TJ, Wang PC. (2004). Use of morphological indicators to predict outcomes of palatopharyngeal surgery in patients with obstructive sleep apnea. Orl; Journal of Oto-Rhino-Laryngology & its Related Specialties.
Li HY, Chen NH, Shu YH, Wang PC. (2004). Changes in quality of life and respiratory disturbance after extended uvulopalatal flap surgery in patients with obstructive sleep apnea. Archives of Otolaryngology -- Head & Neck Surgery.
Li HY, Huang YS, Chen NH, Fang TJ, Liu CY, Wang PC. (2004). Mood improvement after surgery for obstructive sleep apnea. Laryngoscope.
Li HY, Lee LA. (2009). Relocation pharyngoplasty for obstructive sleep apnea. Laryngoscope.
Li HY, Li KK, Chen NH, Wang CJ, Liao YF, Wang PC. (2005). Three-dimensional computed tomography and polysomnography findings after extended uvulopalatal flap surgery for obstructive sleep apnea. American Journal of Otolaryngology.
Li HY, Li KK, Chen NH, Wang PC. (2003). Modified uvulopalatopharyngoplasty: The extended uvulopalatal flap. American Journal of Otolaryngology.
Li HY, Lin Y, Chen NH, Lee LA, Fang TJ, Wang PC. (2008). Improvement in quality of life after nasal surgery alone for patients with obstructive sleep apnea and nasal obstruction. Archives of Otolaryngology -- Head & Neck Surgery.
Li HY, Wang PC, Hsu CY, Chen NH, Lee LA, Fang TJ. (2004). Same-stage palatopharyngeal and hypopharyngeal surgery for severe obstructive sleep apnea. Acta Oto-Laryngologica.
Li HY, Wang PC, Hsu CY, Lee SW, Chen NH, Liu SA. (2005). Combined nasal-palatopharyngeal surgery for obstructive sleep apnea: simultaneous or staged?. Acta Oto-Laryngologica.
Li HY, Wang PC, Lee LA, Chen NH, Fang TJ. (2006). Prediction of uvulopalatopharyngoplasty outcome: anatomy-based staging system versus severity-based staging system. Sleep.
Li KK, Guilleminault C, Riley RW, Powell NB. (2002). Obstructive sleep apnea and maxillomandibular advancement: an assessment of airway changes using radiographic and nasopharyngoscopic examinations. Journal of Oral & Maxillofacial Surgery.
Li KK, Powell NB, Riley RW, Guilleminault C. (2002). Temperature-controlled radiofrequency tongue base reduction for sleep-disordered breathing: Long-term outcomes. Otolaryngology - Head & Neck Surgery.
Li KK, Powell NB, Riley RW, Zonato A, Gervacio L, Guilleminault C. (2000). Morbidly obese patients with severe obstructive sleep apnea: is airway reconstructive surgery a viable treatment option. Laryngoscope.
Li KK, Riley RW, Powell NB, Gervacio L, Troell RJ, Guilleminault C. (2000). Obstructive sleep apnea surgery: patient perspective and polysomnographic results. Otolaryngology - Head & Neck Surgery.
Li KK, Riley RW, Powell NB, Guilleminault C. (2000). Maxillomandibular advancement for persistent obstructive sleep apnea after phase I surgery in patients without maxillomandibular deficiency. Laryngoscope.
Li KK, Riley RW, Powell NB, Troell RJ. (2001). Obstructive sleep apnea surgery: genioglossus advancement revisited. Journal of Oral & Maxillofacial Surgery.
Liesching TN, Carlisle C, Marte A, Bonitati A, Millman RP. (2004). Evaluation of the accuracy of SNAP technology sleep sonography in detecting obstructive sleep apnea in adults compared to standard polysomnography. Chest.
Lin CC, Chang KC, Lee KS. (2002). Effects of treatment by laser-assisted uvuloplasty on sleep energy expenditure in obstructive sleep apnea patients. Metabolism: Clinical & Experimental.
Lin CC, Chang KC, Lee KS, Wu KM, Chou CS, Lin CK. (2005). Effect of treatment by laser-assisted uvulopalatoplasty on cardiopulmonary exercise test in obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
Lin CC, Lee KS, Chang KC, Wu KM, Chou CS. (2006). Effect of laser-assisted uvulopalatoplasty on oral airway resistance during wakefulness in obstructive sleep apnea syndrome. European Archives of Oto-Rhino-Laryngology.
Lin CC, Lee KS, Wang YP, et al. (2007). Effect of uvulopalatopharyngoplasty on work of breathing during wakefulness in obstructive sleep apnea syndrome. Annals of Otology, Rhinology & Laryngology.
Lin CL, Yeh C, Yen CW, Hsu WH, Hang LW. (2009). Comparison of the indices of oxyhemoglobin saturation by pulse oximetry in obstructive sleep apnea hypopnea syndrome. Chest.
Liu SA, Li HY, Tsai WC, Chang KM. (2005). Associated factors to predict outcomes of uvulopharyngopalatoplasty plus genioglossal advancement for obstructive sleep apnea. Laryngoscope.
Lloberes P, Marti S, Sampol G, et al. (2004). Predictive factors of quality-of-life improvement and continuous positive airway pressure use in patients with sleep apnea-hypopnea syndrome: study at 1 year. Chest.
Lloberes P, Montserrat JM, Ascaso A, et al. (1996). Comparison of partially attended night time respiratory recordings and full polysomnography in patients with suspected sleep apnoea/hypopnoea syndrome. Thorax.
Lloberes P, Sampol G, Levy G, et al. (2001). Influence of setting on unattended respiratory monitoring in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal.
Lu SJ, Chang SY, Shiao GM. (1995). Comparison between short-term and long-term post-operative evaluation of sleep apnoea after uvulopalatopharyngoplasty. Journal of Laryngology & Otology.
Ludwig A. (2008). Results of electromyostimulation therapy in obstructive sleep apnea. Artificial Organs.
Lye KW, Waite PD, Meara D, Wang D. (2008). Quality of life evaluation of maxillomandibular advancement surgery for treatment of obstructive sleep apnea. Journal of Oral & Maxillofacial Surgery.
Lysdahl M, Haraldsson PO. (2002). Uvulopalatopharyngoplasty versus laser uvulopalatoplasty: prospective long-term follow-up of self-reported symptoms. Acta Oto-Laryngologica.
Macaluso RA, Reams C, Gibson WS, Vrabec DP, Matragrano A. (1989). Uvulopalatopharyngoplasty: postoperative management and evaluation of results. Annals of Otology, Rhinology & Laryngology.
Magalang UJ, Dmochowski J, Veeramachaneni S, et al. (2003). Prediction of the apnea-hypopnea index from overnight pulse oximetry. Chest.
Magnan A, Philip-Joet F, Rey M, Reynaud M, Porri F, Arnaud A. (1993). End-tidal CO2 analysis in sleep apnea syndrome. Conditions for use. Chest.
Maisel RH, Antonelli PJ, Iber C, et al. (1992). Uvulopalatopharyngoplasty for obstructive sleep apnea: a community’s experience. Laryngoscope.
Maislin G, Pack AI, Kribbs NB, et al. (1995). A survey screen for prediction of apnea. Sleep.
Malbois M, Giusti V, Suter M, Pellaton C, Vodoz JF, Heinzer R. (2010). Oximetry alone versus portable polygraphy for sleep apnea screening before bariatric surgery. Obesity Surgery.
Malow BA, Foldvary-Schaefer N, Vaughn BV, et al. (2008). Treating obstructive sleep apnea in adults with epilepsy: a randomized pilot trial. Neurology.
Man GC, Kang BV. (1995). Validation of a portable sleep apnea monitoring device. Chest.
Marcos JV, Hornero R, Alvarez D, del CF, Lopez M. (2007). Applying neural network classifiers in the diagnosis of the obstructive sleep apnea syndrome from nocturnal pulse oximetric recordings.
Marcos JV, Hornero R, Alvarez D, Nabney IT, del CF, Zamarron C. (2010). The classification of oximetry signals using Bayesian neural networks to assist in the detection of obstructive sleep apnoea syndrome. Physiological Measurement.
Marklund M. (2006). Predictors of long-term orthodontic side effects from mandibular advancement devices in patients with snoring and obstructive sleep apnea. American Journal of Orthodontics & Dentofacial Orthopedics.
Marklund M, Franklin KA. (2007). Long-term effects of mandibular repositioning appliances on symptoms of sleep apnoea. Journal of Sleep Research.
Marklund M, Stenlund H, Franklin KA. (2004). Mandibular advancement devices in 630 men and women with obstructive sleep apnea and snoring: tolerability and predictors of treatment success. Chest.
Marrone O, Salvaggio A, Insalaco G, Bonsignore MR, Bonsignore G. (2001). Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Archives for Chest Disease.
Marshall NS, Neill AM, Campbell AJ. (2008). Randomised trial of compliance with flexible (C-Flex) and standard continuous positive airway pressure for severe obstructive sleep apnea. Sleep & Breathing.
Masdeu MJ, Ayappa I, Hwang D, Mooney AM, Rapoport DM. (2010). Impact of clinical assessment on use of data from unattended limited monitoring as opposed to full-in lab PSG in sleep disordered breathing. Journal of Clinical Sleep Medicine.
Martinho FL, Tangerina RP, Moura SM, Gregorio LC, Tufik S, Bittencourt LR. (2008). Systematic head and neck physical examination as a predictor of obstructive sleep apnea in class III obese patients. Brazilian Journal of Medical & Biological Research.
Mayer P, Meurice JC, Philip-Joet F, et al. (1998). Simultaneous laboratory-based comparison of ResMed Autoset with polysomnography in the diagnosis of sleep apnoea/hypopnoea syndrome. European Respiratory Journal.
McArdle N, Kingshott R, Engleman HM, Mackay TW, Douglas NJ. (2001). Partners of patients with sleep apnoea/hypopnoea syndrome: effect of CPAP treatment on sleep quality and quality of life. Thorax.
McArdle N, Singh B, Murphy M, et al. (2010). Continuous positive airway pressure titration for obstructive sleep apnoea: automatic versus manual titration. Thorax.
McFadyen TA, Espie CA, McArdle N, Douglas NJ, Engleman HM. (2001). Controlled, prospective trial of psychosocial function before and after continuous positive airway pressure therapy. European Respiratory Journal.
McGuirt WF, Johnson JT, Sanders MH. (1995). Previous tonsillectomy as prognostic indicator for success of uvulopalatopharyngoplasty. Laryngoscope.
McLean HA, Urton AM, Driver HS, et al. (2005). Effect of treating severe nasal obstruction on the severity of obstructive sleep apnoea. European Respiratory Journal.
Mehra R, Principe-Rodriguez K, Kirchner HL, Strohl KP. (2006). Sleep apnea in acute coronary syndrome: high prevalence but low impact on 6-month outcome. Sleep Medicine.
Mendez MO, Bianchi AM, Matteucci M, Cerutti S, Penzel T. (2009). Sleep apnea screening by autoregressive models from a single ECG lead. IEEE Transactions on Biomedical Engineering.
Mendez MO, Corthout J, Van HS, et al. (2010). Automatic screening of obstructive sleep apnea from the ECG based on empirical mode decomposition and wavelet analysis. Physiological Measurement.
Meston N, Davies RJ, Mullins R, Jenkinson C, Wass JA, Stradling JR. (2003). Endocrine effects of nasal continuous positive airway pressure in male patients with obstructive sleep apnoea. Journal of Internal Medicine.
Meurice JC, Marc I, Series F. (1996). Efficacy of auto-CPAP in the treatment of obstructive sleep apnea/hypopnea syndrome. American Journal of Respiratory & Critical Care Medicine.
Michaelson PG, Allan P, Chaney J, Mair EA. (2006). Validations of a portable home sleep study with twelve-lead polysomnography: comparisons and insights into a variable gold standard. Annals of Otology, Rhinology & Laryngology.
Mickelson SA, Rosenthal L. (1997). Midline glossectomy and epiglottidectomy for obstructive sleep apnea syndrome. Laryngoscope.
Mickelson SA, Ahuja A. (1999). Short-term objective and long-term subjective results of laser-assisted uvulopalatoplasty for obstructive sleep apnea. Laryngoscope.
Miles PG, Nimkarn Y. (1995). Maxillomandibular advancement surgery in patients with obstructive sleep apnea: mandibular morphology and stability. International Journal of Adult Orthodontics & Orthognathic Surgery.
Miljeteig H, Tvinnereim M. (1992). Uvulopalatopharyngoglossoplasty (UPPGP) in the treatment of the obstructive sleep apnea syndrome. Acta Oto-Laryngologica Supplement.
Milleron O, Pilliere R, Foucher A, et al. (2004). Benefits of obstructive sleep apnoea treatment in coronary artery disease: a long-term follow-up study. European Heart Journal.
Millman RP, Carlisle CC, Rosenberg C, Kahn D, McRae R, Kramer NR. (2000). Simple predictors of uvulopalatopharyngoplasty outcome in the treatment of obstructive sleep apnea. Chest.
Millman RP, Kipp GJ, Beadles SC, Braman SS. (1988). A home monitoring system for nasal CPAP. Chest.
Millman RP, Rosenberg CL, Carlisle CC, Kramer NR, Kahn DM, Bonitati AE. (1998). The efficacy of oral appliances in the treatment of persistent sleep apnea after uvulopalatopharyngoplasty. Chest.
Miyamoto T, Miyamoto M, Iwanami M, et al. (2009). The REM sleep behavior disorder screening questionnaire: validation study of a Japanese version. Sleep Medicine.
Miyata S, Noda A, Nakata S, et al. (2007). Daytime polysomnography for early diagnosis and treatment of patients with suspected sleep-disordered breathing. Sleep & Breathing.
Miyazaki S, Tanaka T, Itasaka Y, Ishikawa K. (2001). A trial study of RhinoSleep for the diagnosis of sleep apnea. Psychiatry & Clinical Neurosciences.
Mizuma H, Sonnenschein W, Meier-Ewert K. (1996). Diagnostic use of daytime polysomnography versus nocturnal polysomnography in sleep apnea syndrome. Psychiatry & Clinical Neurosciences.
Mooe T, Franklin KA, Holmstrom K, Rabben T, Wiklund U. (2001). Sleep-disordered breathing and coronary artery disease: long-term prognosis. American Journal of Respiratory & Critical Care Medicine.
Moraes W, Poyares D, Sukys-Claudino L, Guilleminault C, Tufik S. (2008). Donepezil improves obstructive sleep apnea in Alzheimer disease: a double-blind, placebo-controlled study. Chest.
Morales Divo C, Selivanova O, Mewes T, Gosepath J, Lippold R, Mann WJ. (2009). Polysomnography and ApneaGraph in patients with sleep-related breathing disorders. Orl; Journal of Oto-Rhino-Laryngology & its Related Specialties.
Morinaga M, Nakata S, Yasuma F, et al. (2009). Pharyngeal morphology: a determinant of successful nasal surgery for sleep apnea. Laryngoscope.
Morris LG, Kleinberger A, Lee KC, Liberatore LA, Burschtin O. (2008). Rapid risk stratification for obstructive sleep apnea, based on snoring severity and body mass index. Otolaryngology - Head & Neck Surgery.
Morrish E, Shneerson JM, Smith IE. (2008). Why does gender influence survival in obstructive sleep apnoea. Respiratory Medicine.
Mueller A, Fietze I, Voelker R, et al. (2006). Screening for sleep-related breathing disorders by transthoracic impedance recording integrated into a Holter ECG system. Journal of Sleep Research.
Mulgrew AT, Fox N, Ayas NT, Ryan CF. (2007). Diagnosis and initial management of obstructive sleep apnea without polysomnography: a randomized validation study. Annals of Internal Medicine.
Mulgrew AT, Lawati NA, Ayas NT, et al. (2010). Residual sleep apnea on polysomnography after 3 months of CPAP therapy: clinical implications, predictors and patterns. Sleep Medicine.
Munoz R, Duran-Cantolla J, Martinez-Vila E, et al. (2006). Severe sleep apnea and risk of ischemic stroke in the elderly. Stroke.
Myatt HM, Croft CB, Kotecha BT, Ruddock J, Mackay IS, Simonds AK. (1999). A three-centre prospective pilot study to elucidate the effect of uvulopalatopharyngoplasty on patients with mild obstructive sleep apnoea due to velopharyngeal obstruction. Clinical Otolaryngology & Allied Sciences.
Nader NZ, Steinel JA, Auckley DH. (2006). Newly identified obstructive sleep apnea in hospitalized patients: analysis of an evaluation and treatment strategy. Journal of Clinical Sleep Medicine.
Nakano H, Hayashi M, Ohshima E, Nishikata N, Shinohara T. (2004). Validation of a new system of tracheal sound analysis for the diagnosis of sleep apnea-hypopnea syndrome. Sleep.
Nakano H, Ikeda T, Hayashi M, et al. (2004). Effect of body mass index on overnight oximetry for the diagnosis of sleep apnea. Respiratory Medicine.
Nakata S, Miyazaki S, Ohki M, et al. (2007). Reduced nasal resistance after simple tonsillectomy in patients with obstructive sleep apnea. American Journal of Rhinology.
Nakata S, Noda A, Yagi H, et al. (2005). Nasal resistance for determinant factor of nasal surgery in CPAP failure patients with obstructive sleep apnea syndrome. Rhinology.
Nakata S, Noda A, Yanagi E, Suzuki K, Yamamoto H, Nakashima T. (2006). Tonsil size and body mass index are important factors for efficacy of simple tonsillectomy in obstructive sleep apnoea syndrome. Clinical Otolaryngology.
Nakata S, Noda A, Yasuma F, et al. (2008). Effects of nasal surgery on sleep quality in obstructive sleep apnea syndrome with nasal obstruction. American Journal of Rhinology.
Nelson LM. (2001). Combined temperature-controlled radiofrequency tongue reduction and UPPP in apnea surgery. Ear, Nose, & Throat Journal.
Neruntarat C. (2003). Genioglossus advancement and hyoid myotomy under local anesthesia. Otolaryngology - Head & Neck Surgery.
Neruntarat C. (2003). Genioglossus advancement and hyoid myotomy: short-term and long-term results. Journal of Laryngology & Otology.
Neruntarat C. (2003). Hyoid myotomy with suspension under local anesthesia for obstructive sleep apnea syndrome. European Archives of Oto-Rhino-Laryngology.
Neruntarat C, Chantapant S. (2009). Radiofrequency surgery for the treatment of obstructive sleep apnea: short-term and long-term results. Otolaryngology - Head & Neck Surgery.
Nilius G, Domanski U, Franke KJ, Ruhle KH. (2008). Impact of a controlled heated breathing tube humidifier on sleep quality during CPAP therapy in a cool sleeping environment. European Respiratory Journal.
Nimkarn Y, Miles PG, Waite PD. (1995). Maxillomandibular advancement surgery in obstructive sleep apnea syndrome patients: long-term surgical stability. Journal of Oral & Maxillofacial Surgery.
Nino-Murcia G, McCann CC, Bliwise DL, Guilleminault C, Dement WC. (1989). Compliance and side effects in sleep apnea patients treated with nasal continuous positive airway pressure. Western Journal of Medicine.
Nordgard S, Hein G, Stene BK, Skjostad KW, Maurer JT. (2007). One-year results: palatal implants for the treatment of obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Nordgard S, Stene BK, Skjostad KW. (2006). Soft palate implants for the treatment of mild to moderate obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Noseda A, Jann E, Hoffmann G, Linkowski P, Kerkhofs M. (2000). Compliance with nasal continuous positive airway pressure assessed with a pressure monitor: pattern of use and influence of sleep habits. Respiratory Medicine.
Noseda A, Nouvelle M, Lanquart JR, et al. (2002). High leg motor activity in sleep apnea hypopnea patients: efficacy of clonazepam combined with nasal CPAP on polysomnographic variables. Respiratory Medicine.
Noseda A, Andre S, Potmans V, Kentos M, de MV, Hoffmann G. (2009). CPAP with algorithm-based versus titrated pressure: A randomized study. Sleep Medicine.
Ohayon MM, Guilleminault C, Zulley J, Palombini L, Raab H. (1999). Validation of the sleep-EVAL system against clinical assessments of sleep disorders and polysomnographic data. Sleep.
Okabayashi K, Kasahara E, Uchiyama H, et al. (2007). Obstructive sleep apnea-hypopnea syndrome patients with overweight and hypertension in a Japanese workplace. Journal of Occupational Health.
Olson LG, Ambrogetti A, Gyulay SG. (1999). Prediction of sleep-disordered breathing by unattended overnight oximetry. Journal of Sleep Research.
Omur M, Ozturan D, Elez F, Unver C, Derman S. (2005). Tongue base suspension combined with UPPP in severe OSA patients. Otolaryngology - Head & Neck Surgery.
Orr WC, Eiken T, Pegram V, Jones R, Rundell OH. (1994). A laboratory validation study of a portable system for remote recording of sleep-related respiratory disorders. Chest.
Osman EZ, Osborne J, Hill PD, Lee BW. (1999). The Epworth Sleepiness Scale: can it be used for sleep apnoea screening among snorers?. Clinical Otolaryngology & Allied Sciences.
Osnes T, Rollheim J, Hartmann E. (2002). Effect of UPPP with respect to site of pharyngeal obstruction in sleep apnoea: follow-up at 18 months by overnight recording of airway pressure and flow. Clinical Otolaryngology & Allied Sciences.
Overland B, Bruskeland G, Akre H, Skatvedt O. (2005). Evaluation of a portable recording device (Reggie) with actimeter and nasopharyngeal/esophagus catheter incorporated. Respiration.
Ozegowski S, Wilczynska E, Piorunek T, Szymanowska K, Paluszkiewicz L. (2007). Usefulness of ambulatory ECG in the diagnosis of sleep-related breathing disorders. Kardiologia Polska.
Pack AI, Black JE, Schwartz JR, Matheson JK. (2001). Modafinil as adjunct therapy for daytime sleepiness in obstructive sleep apnea. American Journal of Respiratory & Critical Care Medicine.
Pang KP. (2005). One-stage nasal and multi-level pharyngeal surgery for obstructive sleep apnoea: safety and efficacy. Journal of Laryngology & Otology.
Pang KP, Dillard TA, Blanchard AR, Gourin CG, Podolsky R, Terris DJ. (2006). A comparison of polysomnography and the SleepStrip in the diagnosis of OSA. Otolaryngology - Head & Neck Surgery.
Pang KP, Terris DJ. (2007). Modified cautery-assisted palatal stiffening operation: new method for treating snoring and mild obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Pang KP, Woodson BT. (2007). Expansion sphincter pharyngoplasty: a new technique for the treatment of obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Parra O, Garcia-Esclasans N, Montserrat JM, et al. (1997). Should patients with sleep apnoea/hypopnoea syndrome be diagnosed and managed on the basis of home sleep studies. European Respiratory Journal.
Partinen M, Guilleminault C. (1990). Daytime sleepiness and vascular morbidity at seven-year follow-up in obstructive sleep apnea patients. Chest.
Penzel T, Fricke R, Jerrentrup A, Peter JH, Vogelmeier C. (2002). Peripheral arterial tonometry for the diagnosis of obstructive sleep apnea. Biomedizinische Technik.
Penzel T, Kesper K, Pinnow I, Becker HF, Vogelmeier C. (2004). Peripheral arterial tonometry, oximetry and actigraphy for ambulatory recording of sleep apnea. Physiological Measurement.
Pepin JL, Viot-Blanc V, Escourrou P, et al. (2009). Prevalence of residual excessive sleepiness in CPAP-treated sleep apnoea patients: the French multicentre study. European Respiratory Journal.
Peppard PE, Szklo-Coxe M, Hla KM, Young T. (2006). Longitudinal association of sleep-related breathing disorder and depression. Archives of Internal Medicine.
Pepperell JC, Ramdassingh-Dow S, Crosthwaite N, et al. (2002). Ambulatory blood pressure after therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised parallel trial. Lancet.
Perez de Llano LA, Golpe R, Piquer MO, et al. (2008). Clinical heterogeneity among patients with obesity hypoventilation syndrome: therapeutic implications. Respiration.
Permut I, az-Abad M, Chatila W, et al. (2010). Comparison of positional therapy to CPAP in patients with positional obstructive sleep apnea. Journal of Clinical Sleep Medicine.
Persson HE, Svanborg E. (1996). Sleep deprivation worsens obstructive sleep apnea. Comparison between diurnal and nocturnal polysomnography. Chest.
Petri N, Suadicani P, Wildschiodtz G, Bjorn-Jorgensen J. (1994). Predictive value of Muller maneuver, cephalometry and clinical features for the outcome of uvulopalatopharyngoplasty. Evaluation of predictive factors using discriminant analysis in 30 sleep apnea patients. Acta Oto-Laryngologica.
Phillips BA, Schmitt FA, Berry DT, Lamb DG, Amin M, Cook YR. (1990). Treatment of obstructive sleep apnea. A preliminary report comparing nasal CPAP to nasal oxygen in patients with mild OSA. Chest.
Piccirillo JF, Gates GA, White DL, Schectman KB. (1998). Obstructive sleep apnea treatment outcomes pilot study. Otolaryngology - Head & Neck Surgery.
Pieters T, Collard P, Aubert G, Dury M, Delguste P, Rodenstein DO. (1996). Acceptance and long-term compliance with nCPAP in patients with obstructive sleep apnoea syndrome. European Respiratory Journal.
Pillar G, Bar A, Betito M, et al. (2003). An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Medicine.
Pillar G, Bar A, Shlitner A, Schnall R, Shefy J, Lavie P. (2002). Autonomic arousal index: an automated detection based on peripheral arterial tonometry. Sleep.
Piper AJ, Laks L, Sullivan CE. Effectiveness of short-term NIPPV in the management of patients with severe OSA and REM hypoventilation. Sleep.
Pitsis AJ, Darendeliler MA, Gotsopoulos H, Petocz P, Cistulli PA. (2002). Effect of vertical dimension on efficacy of oral appliance therapy in obstructive sleep apnea. American Journal of Respiratory & Critical Care Medicine.
Pittman SD, Ayas NT, MacDonald MM, Malhotra A, Fogel RB, White DP. (2004). Using a wrist-worn device based on peripheral arterial tonometry to diagnose obstructive sleep apnea: in-laboratory and ambulatory validation. Sleep.
Pittman SD, Pillar G, Berry RB, Malhotra A, MacDonald MM, White DP. (2006). Follow-up assessment of CPAP efficacy in patients with obstructive sleep apnea using an ambulatory device based on peripheral arterial tonometry. Sleep & Breathing.
Platt AB, Field SH, Asch DA, et al. (2009). Neighborhood of residence is associated with daily adherence to CPAP therapy. Sleep.
Platt AB, Kuna ST, Field SH, et al. (2010). Adherence to sleep apnea therapy and use of lipid-lowering drugs: a study of the healthy-user effect. Chest.
Polo O, Brissaud L, Fraga J, Dejean Y, Billiard M. (1989). Partial upper airway obstruction in sleep after uvulopalatopharyngoplasty. Archives of Otolaryngology -- Head & Neck Surgery.
Popescu G, Latham M, Allgar V, Elliott MW. (2001). Continuous positive airway pressure for sleep apnoea/hypopnoea syndrome: usefulness of a 2 week trial to identify factors associated with long term use. Thorax.
Portier F, Portmann A, Czernichow P, et al. (2000). Evaluation of home versus laboratory polysomnography in the diagnosis of sleep apnea syndrome. American Journal of Respiratory & Critical Care Medicine.
Poulet C, Veale D, Arnol N, Levy P, Pepin JL, Tyrrell J. (2009). Psychological variables as predictors of adherence to treatment by continuous positive airway pressure. Sleep Medicine.
Powell N, Riley R, Guilleminault C, Troell R. (1996). A reversible uvulopalatal flap for snoring and sleep apnea syndrome. Sleep.
Powell NB, Riley RW, Guilleminault C. (1999). Radiofrequency tongue base reduction in sleep-disordered breathing: A pilot study. Otolaryngology - Head & Neck Surgery.
Powell NB, Riley RW, Troell RJ, Li K, Blumen MB, Guilleminault C. (1998). Radiofrequency volumetric tissue reduction of the palate in subjects with sleep-disordered breathing. Chest.
Powell NB, Zonato AI, Weaver EM, et al. (2001). Radiofrequency treatment of turbinate hypertrophy in subjects using continuous positive airway pressure: a randomized, double-blind, placebo-controlled clinical pilot trial. Laryngoscope.
Pradhan PS, Gliklich RE, Winkelman J. (1996). Screening for obstructive sleep apnea in patients presenting for snoring surgery. Laryngoscope.
Pribitkin EA, Schutte SL, Keane WM, et al. (1998). Efficacy of laser-assisted uvulopalatoplasty in obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Prinsell JR. (1999). Maxillomandibular advancement surgery in a site-specific treatment approach for obstructive sleep apnea in 50 consecutive patients. Chest.
Proctor A, Billings C, Billings C, Moloney ED. (2007). Improvement in energy and vitality over a short-term CPAP trial predicts long-term compliance in patients with obstructive sleep apnea. Journal of Sleep Research.
Punjabi NM, Shahar E, Redline S, et al. (2004). Sleep-disordered breathing, glucose intolerance, and insulin resistance: the Sleep Heart Health Study. American Journal of Epidemiology.
Quintana-Gallego E, Villa-Gil M, Carmona-Bernal C, et al. (2004). Home respiratory polygraphy for diagnosis of sleep-disordered breathing in heart failure. European Respiratory Journal.
Ramirez SG, Loube DI. (1996). Inferior sagittal osteotomy with hyoid bone suspension for obese patients with sleep apnea. Archives of Otolaryngology -- Head & Neck Surgery.
Randerath W, Parys K, Lehmann D, Sanner B, Feldmeyer F, Ruhle KH. (2000). Self-adjusting continuous positive airway pressure therapy based on the measurement of impedance. A comparison of free pressure variation and individually fixed higher minimum pressure. Respiration.
Randerath WJ, Parys K, Feldmeyer F, Sanner B, Ruhle KH. (1999). Self-adjusting nasal continuous positive airway pressure therapy based on measurement of impedance: A comparison of two different maximum pressure levels. Chest.
Rauscher H, Formanek D, Popp W, Zwick H. (1993). Nasal CPAP and weight loss in hypertensive patients with obstructive sleep apnoea. Thorax.
Rauscher H, Popp W, Zwick H. (1991). Quantification of sleep disordered breathing by computerized analysis of oximetry, heart rate and snoring. European Respiratory Journal.
Redline S, Tosteson T, Boucher MA, Millman RP. (1991). Measurement of sleep-related breathing disturbances in epidemiologic studies. Assessment of the validity and reproducibility of a portable monitoring device. Chest.
Rees K, Wraith PK, Berthon-Jones M, Douglas NJ. (1998). Detection of apnoeas, hypopnoeas and arousals by the AutoSet in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal.
Reichert JA, Bloch DA, Cundiff E, Votteri BA. (2003). Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Medicine.
Reimao R, Lemmi H, Akiskal H, Cocke E. (1986). Obstructive sleep apnea treated with uvulopalatopharyngoplasty: a systematic follow-up study. Southern Medical Journal.
Ribeiro Franco CM, Cestaro BJ, Jaguaribe AM, Ataide L. (2009). Study into the use of continuous positive airway pressure in obstructive sleep apnoea-hypopnoea syndrome patients with daytime drowsiness. Revista Portuguesa de Pneumologia.
Richard W, Kox D, den HC, van TH, de VN. (2007). One stage multilevel surgery (uvulopalatopharyngoplasty, hyoid suspension, radiofrequent ablation of the tongue base with/without genioglossus advancement), in obstructive sleep apnea syndrome. European Archives of Oto-Rhino-Laryngology.
Riley RW, Powell NB, Guilleminault C. (1990). Maxillofacial surgery and nasal CPAP. A comparison of treatment for obstructive sleep apnea syndrome. Chest.
Riley RW, Powell NB, Guilleminault C. (1990). Maxillary, mandibular, and hyoid advancement for treatment of obstructive sleep apnea: a review of 40 patients. Journal of Oral & Maxillofacial Surgery.
Riley RW, Powell NB, Guilleminault C. (1994). Obstructive sleep apnea and the hyoid: a revised surgical procedure. Otolaryngology - Head & Neck Surgery.
Riley RW, Powell NB, Guilleminault C. (1989). Maxillofacial surgery and obstructive sleep apnea: a review of 80 patients. Otolaryngology - Head & Neck Surgery.
Riley RW, Powell NB, Guilleminault C. (1993). Obstructive sleep apnea syndrome: a surgical protocol for dynamic upper airway reconstruction. Journal of Oral & Maxillofacial Surgery.
Riley RW, Powell NB, Li KK, Troell RJ, Guilleminault C. (2000). Surgery and obstructive sleep apnea: long-term clinical outcomes. Otolaryngology - Head & Neck Surgery.
Riley RW, Powell NB, Li KK, Weaver EM, Guilleminault C. (2003). An adjunctive method of radiofrequency volumetric tissue reduction of the tongue for OSAS. Otolaryngology - Head & Neck Surgery.
Ringqvist M, Walker-Engstrom ML, Tegelberg A, Ringqvist I. (2003). Dental and skeletal changes after 4 years of obstructive sleep apnea treatment with a mandibular advancement device: a prospective, randomized study. American Journal of Orthodontics & Dentofacial Orthopedics.
Robbins J, Redline S, Ervin A, Walsleben JA, Ding J, Nieto FJ. (2005). Associations of sleep-disordered breathing and cerebral changes on MRI. Journal of Clinical Sleep Medicine.
Robinson GV, Pepperell JC, Segal HC, Davies RJ, Stradling JR. (2004). Circulating cardiovascular risk factors in obstructive sleep apnoea: data from randomised controlled trials. Thorax.
Robinson S, Lewis R, Norton A, McPeake S. (2003). Ultrasound-guided radiofrequency submucosal tongue-base excision for sleep apnoea: a preliminary report. Clinical Otolaryngology & Allied Sciences.
Roche N, Herer B, Roig C, Huchon G. (2002). Prospective testing of two models based on clinical and oximetric variables for prediction of obstructive sleep apnea. Chest.
Rolfe I, Olson LG, Saunders NA. (1991). Long-term acceptance of continuous positive airway pressure in obstructive sleep apnea. American Review of Respiratory Disease.
Roosli C, Schneider S, Hausler R. (2006). Long-term results and complications following uvulopalatopharyngoplasty in 116 consecutive patients. European Archives of Oto-Rhino-Laryngology.
Rosenberg R, Roach JM, Scharf M, Amato DA. (2007). A pilot study evaluating acute use of eszopiclone in patients with mild to moderate obstructive sleep apnea syndrome. Sleep Medicine.
Roth T, White D, Schmidt-Nowara W, et al. (2006). Effects of armodafinil in the treatment of residual excessive sleepiness associated with obstructive sleep apnea/hypopnea syndrome: a 12-week, multicenter, double-blind, randomized, placebo-controlled study in nCPAP-adherent adults. Clinical Therapeutics.
Rubin AH, Eliaschar I, Joachim Z, Alroy G, Lavie P. (1983). Effects of nasal surgery and tonsillectomy on sleep apnea. Bulletin europeen de physiopathologie respiratoire.
Ryan CF, Love LL. (2000). Unpredictable results of laser assisted uvulopalatoplasty in the treatment of obstructive sleep apnoea. Thorax.
Ryan CM, Usui K, Floras JS, Bradley TD. (2005). Effect of continuous positive airway pressure on ventricular ectopy in heart failure patients with obstructive sleep apnoea. Thorax.
Ryan PJ, Hilton MF, Boldy DA, et al. (1995). Validation of British Thoracic Society guidelines for the diagnosis of the sleep apnoea/hypopnoea syndrome: can polysomnography be avoided. Thorax.
Saarelainen S, Himanen SL, Hasan J, Virkkala J, Koobi T. (2003). Whole-body impedance recording--a practical method for the diagnosis of sleep apnoea. Clinical Physiology & Functional Imaging.
Sagaspe P, Leger D, Taillard J, Bayon V, Chaumet G, Philip P. (2010). Might the Berlin Sleep Questionnaire applied to bed partners be used to screen sleep apneic patients. Sleep Medicine.
Sahlman J, Seppa J, Peltonen M, Pukkila M, Partinen M, Tuomilehto H. (2009). Surgical intervention represents a feasible option for patients with mild obstructive sleep apnoea. Acta Oto-Laryngologica.
Sakurai S, Nishijima T, Takahashi S, Yamauchi K, Arihara Z, Takahashi K. (2004). Clinical significance of daytime plasma orexin-A-like immunoreactivity concentrations in patients with obstructive sleep apnea hypopnea syndrome. Respiration.
Saletu A, Anderer P, Parapatics S, Matthai C, Matejka M, Saletu B. (2007). Effects of a mandibular repositioning appliance on sleep structure, morning behavior and clinical symptomatology in patients with snoring and sleep-disordered breathing. Neuropsychobiology.
Saletu B, Oberndorfer S, Anderer P, et al. (1999). Efficiency of continuous positive airway pressure versus theophylline therapy in sleep apnea: comparative sleep laboratory studies on objective and subjective sleep and awakening quality. Neuropsychobiology.
Salmi T, Telakivi T, Partinen M. (1989). Evaluation of automatic analysis of SCSB, airflow and oxygen saturation signals in patients with sleep related apneas. Chest.
Sampol G, Rodes G, Romero O, Jurado MJ, Lloberes P. (2007). Adherence to nCPAP in patients with coronary disease and sleep apnea without sleepiness. Respiratory Medicine.
Sandberg O, Franklin KA, Bucht G, Eriksson S, Gustafson Y. (2001). Nasal continuous positive airway pressure in stroke patients with sleep apnoea: a randomized treatment study. European Respiratory Journal.
Santos Junior JF, Abrahao M, Gregorio LC, Zonato AI, Gumieiro EH. (2007). Genioplasty for genioglossus muscle advancement in patients with obstructive sleep apnea-hypopnea syndrome and mandibular retrognathia. Revista Brasileira de Otorrinolaringologia.
Sato M, Suzuki M, Oshima T, et al. (2000). Long-term follow-up of obstructive sleep apnea syndrome following surgery in children and adults. Tohoku Journal of Experimental Medicine.
Scharf MB, Brannen DE, McDannold MD, Berkowitz DV. (1996). Computerized adjustable versus fixed NCPAP treatment of obstructive sleep apnea. Sleep.
Scharf MB, Stover R, McDannold MD, Spinner O, Berkowitz DV, Conrad C. (1999). Outcome evaluation of long-term nasal continuous positive airway pressure therapy in obstructive sleep apnea. American Journal of Therapeutics.
Scharf SM, Garshick E, Brown R, Tishler PV, Tosteson T, McCarley R. (1990). Screening for subclinical sleep-disordered breathing. Sleep.
Seemann RP, DiToppa JC, Holm MA, Hanson J. (2001). Does laser-assisted uvulopalatoplasty work? An objective analysis using pre- and postoperative polysomnographic studies. Journal of Otolaryngology.
Senior BA, Rosenthal L, Lumley A, Gerhardstein R, Day R. (2000). Efficacy of uvulopalatopharyngoplasty in unselected patients with mild obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Serafini FM, MacDowell AW, Rosemurgy AS, Strait T, Murr MM. (2001). Clinical predictors of sleep apnea in patients undergoing bariatric surgery. Obesity Surgery.
Sergi M, Rizzi M, Greco M, et al. (1998). Validity of diurnal sleep recording performed by an ambulatory device in the diagnosis of obstructive sleep apnoea. Respiratory Medicine.
Series F, Marc I. (2001). Importance of sleep stage- and body position-dependence of sleep apnoea in determining benefits to auto-CPAP therapy. European Respiratory Journal.
Series F, Marc I, Cormier Y, La FJ. (1993). Utility of nocturnal home oximetry for case finding in patients with suspected sleep apnea hypopnea syndrome. Annals of Internal Medicine.
Series F, Plante J, Lacasse Y. (2008). Reliability of home CPAP titration with different automatic CPAP devices. Respiratory Research.
Series F, St PS, Carrier G. (1992). Effects of surgical correction of nasal obstruction in the treatment of obstructive sleep apnea. American Review of Respiratory Disease.
Series F, St PS, Carrier G. (1993). Surgical correction of nasal obstruction in the treatment of mild sleep apnoea: importance of cephalometry in predicting outcome. Thorax.
Shalaby A, Atwood C, Hansen C, et al. (2006). Feasibility of automated detection of advanced sleep disordered breathing utilizing an implantable pacemaker ventilation sensor. Pacing & Clinical Electrophysiology.
Shalaby AA, Atwood CW, Hansen C, et al. (2007). Analysis of interaction of acute atrial overdrive pacing with sleep-related breathing disorder. American Journal of Cardiology.
Sharma S, Wali S, Pouliot Z, Peters M, Neufeld H, Kryger M. (1996). Treatment of obstructive sleep apnea with a self-titrating continuous positive airway pressure (CPAP) system. Sleep.
Shibata N, Nishimura T, Hasegawa K, Hattori C, Suzuki K. (2003). Influence of sleep respiratory disturbance on nocturnal blood pressure. Acta Oto-Laryngologica Supplement.
Shin JH, Chee YJ, Jeong DU, Park KS. (2010). Nonconstrained sleep monitoring system and algorithms using air-mattress with balancing tube method. IEEE Transactions on Information Technology in Biomedicine.
Shin SH, Ye MK, Kim CG. (2009). Modified uvulopalatopharyngoplasty for the treatment of obstructive sleep apnea-hypopnea syndrome: resection of the musculus uvulae. Otolaryngology - Head & Neck Surgery.
Shine NP, Lewis RH. (2009). Transpalatal advancement pharyngoplasty for obstructive sleep apnea syndrome: results and analysis of failures. Archives of Otolaryngology -- Head & Neck Surgery.
Shine NP, Lewis RH. (2008). The “Propeller” incision for transpalatal advancement pharyngoplasty: a new approach to reduce post-operative oronasal fistulae. Auris, Nasus, Larynx.
Simmons FB, Guilleminault C, Miles LE. (1984). The palatopharyngoplasty operation for snoring and sleep apnea: an interim report. Otolaryngology - Head & Neck Surgery.
Simmons FB, Guilleminault C, Silvestri R. (1983). Snoring, and some obstructive sleep apnea, can be cured by oropharyngeal surgery. Archives of Otolaryngology.
Simon-Tuval T, Reuveni H, Greenberg-Dotan S, Oksenberg A, Tal A, Tarasiuk A. (2009). Low socioeconomic status is a risk factor for CPAP acceptance among adult OSAS patients requiring treatment. Sleep.
Sin DD, Mayers I, Man GC, Ghahary A, Pawluk L. (2002). Can continuous positive airway pressure therapy improve the general health status of patients with obstructive sleep apnea?: a clinical effectiveness study. Chest.
Singh A, Al-Reefy H, Hewitt R, Kotecha B. (2008). Evaluation of ApneaGraph in the diagnosis of sleep-related breathing disorders. European Archives of Oto-Rhino-Laryngology.
Sinha AM, Bauer A, Skobel EC, et al. (2009). Long-term effects of dynamic atrial overdrive pacing on sleep-related breathing disorders in pacemaker or cardioverter defibrillator recipients. Pacing & Clinical Electrophysiology.
Skatvedt O, Akre H, Godtlibsen OB. (1996). Nocturnal polysomnography with and without continuous pharyngeal and esophageal pressure measurements. Sleep.
Skatvedt O, Akre H, Godtlibsen OB. (1996). Continuous pressure measurements in the evaluation of patients for laser assisted uvulopalatoplasty. European Archives of Oto-Rhino-Laryngology.
Skomro RP, Cotton DJ, Gjevre JA, et al. (2007). An empirical continuous positive airway pressure trial for suspected obstructive sleep apnea. Canadian Respiratory Journal.
Skomro RP, Gjevre J, Reid J, et al. (2010). Outcomes of home-based diagnosis and treatment of obstructive sleep apnea. Chest.
Smatt Y, Ferri J. (2005). Retrospective study of 18 patients treated by maxillomandibular advancement with adjunctive procedures for obstructive sleep apnea syndrome. Journal of Craniofacial Surgery.
Smith CE, Dauz ER, Clements F, et al. (2006). Telehealth services to improve nonadherence: A placebo-controlled study. Telemedicine Journal & E-Health.
Souter MA, Stevenson S, Sparks B, Drennan C. (2004). Upper airway surgery benefits patients with obstructive sleep apnoea who cannot tolerate nasal continuous positive airway pressure. Journal of Laryngology & Otology.
Stammnitz A, Jerrentrup A, Penzel T, Peter JH, Vogelmeier C, Becker HF. (2004). Automatic CPAP titration with different self-setting devices in patients with obstructive sleep apnoea. European Respiratory Journal.
Stevenson EW, Turner GT, Sutton FD, Doekel RC, Pegram V, Hernandez J. (1990). Prognostic significance of age and tonsillectomy in uvulopalatopharyngoplasty. Laryngoscope.
Steward DL. (2004). Effectiveness of multilevel (tongue and palate) radiofrequency tissue ablation for patients with obstructive sleep apnea syndrome. Laryngoscope.
Steward DL, Weaver EM, Woodson BT. (2005). Multilevel temperature-controlled radiofrequency for obstructive sleep apnea: extended follow-up. Otolaryngology - Head & Neck Surgery.
Steward DL, Weaver EM, Woodson BT. (2004). A comparison of radiofrequency treatment schemes for obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
Stockx EM, Camilleri P, Skuza EM, et al. (2010). New acoustic method for detecting upper airway obstruction in patients with sleep apnoea. Respirology.
Stoohs R, Guilleminault C. (1992). MESAM 4: an ambulatory device for the detection of patients at risk for obstructive sleep apnea syndrome (OSAS). Chest.
Stoohs R, Guilleminault C. (1990). Investigations of an automatic screening device (MESAM) for obstructive sleep apnoea. European Respiratory Journal.
Storre JH, Seuthe B, Fiechter R, et al. (2006). Average volume-assured pressure support in obesity hypoventilation: A randomized crossover trial. Chest.
Stradling JR, Barbour C, Pitson DJ, Davies RJ. (1997). Automatic nasal continuous positive airway pressure titration in the laboratory: patient outcomes. Thorax.
Stradling JR, Davies RJ. (2000). Is more NCPAP better?. Sleep.
Stuck BA, Kopke J, Hormann K, et al. (2005). Volumetric tissue reduction in radiofrequency surgery of the tongue base. Otolaryngology - Head & Neck Surgery.
Stuck BA, Maurer JT, Verse T, Hormann K. (2002). Tongue base reduction with temperature-controlled radiofrequency volumetric tissue reduction for treatment of obstructive sleep apnea syndrome. Acta Oto-Laryngologica.
Stuck BA, Starzak K, Hein G, Verse T, Hormann K, Maurer JT. (2004). Combined radiofrequency surgery of the tongue base and soft palate in obstructive sleep apnoea. Acta Oto-Laryngologica.
Su S, Baroody FM, Kohrman M, Suskind D. (2004). A comparison of polysomnography and a portable home sleep study in the diagnosis of obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
Sulit L, Storfer-Isser A, Kirchner HL, Redline S. (2006). Differences in polysomnography predictors for hypertension and impaired glucose tolerance. Sleep.
Sun X, Yi H, Cao Z, Yin S. (2008). Reorganization of sleep architecture after surgery for OSAHS. Acta Oto-Laryngologica.
Suzuki M, Saigusa H, Kurogi R, Morita S, Ishizuka Y. (2008). Postoperative monitoring of esophageal pressure in patients with obstructive sleep apnea-hypopnea syndrome who have undergone tonsillectomy with uvulopalatopharyngoplasty. Annals of Otology, Rhinology & Laryngology.
Svanborg E, Larsson H, Carlsson-Nordlander B, Pirskanen R. (1990). A limited diagnostic investigation for obstructive sleep apnea syndrome. Oximetry and static charge sensitive bed. Chest.
Taha BH, Dempsey JA, Weber SM, et al. (1997). Automated detection and classification of sleep-disordered breathing from conventional polysomnography data. Sleep.
Tanaka S, Shima M. (2010). Assessment of screening tests for sleep apnea syndrome in the workplace. Journal of Occupational Health.
Tarasiuk A, Greenberg-Dotan S, Simon T, Tal A, Oksenberg A, Reuveni H. (2006). Low socioeconomic status is a risk factor for cardiovascular disease among adult obstructive sleep apnea syndrome patients requiring treatment. Chest.
Taskin U, Yigit O, Acioglu E, Aricigil M, Toktas G, Guzelhan Y. (2010). Erectile dysfunction in severe sleep apnea patients and response to CPAP. International Journal of Impotence Research.
Tegelberg A, Walker-Engstrom ML, Vestling O, Wilhelmsson B. (2003). Two different degrees of mandibular advancement with a dental appliance in treatment of patients with mild to moderate obstructive sleep apnea. Acta Odontologica Scandinavica.
Terris DJ, Coker JF, Thomas AJ, Chavoya M. (2002). Preliminary findings from a prospective, randomized trial of two palatal operations for sleep-disordered breathing. Otolaryngology - Head & Neck Surgery.
Terris DJ, Kunda LD, Gonella MC. (2002). Minimally invasive tongue base surgery for obstructive sleep apnoea. Journal of Laryngology & Otology.
Thatcher GW, Maisel RH. (2003). The long-term evaluation of tracheostomy in the management of severe obstructive sleep apnea. Laryngoscope.
Thong JF, Pang KP. (2008). Clinical parameters in obstructive sleep apnea: are there any correlations?. Journal of otolaryngology - head & neck surgery = Le Journal d’oto-rhino-laryngologie et de chirurgie cervico-faciale.
Tiihonen P, Hukkanen T, Tuomilehto H, Mervaala E, Toyras J. (2009). Evaluation of a novel ambulatory device for screening of sleep apnea. Telemedicine Journal & E-Health.
Tiihonen P, Paakkonen A, Mervaala E, Hukkanen T, Toyras J. (2009). Design, construction and evaluation of an ambulatory device for screening of sleep apnea. Medical & Biological Engineering & Computing.
Tryfon S, Stanopoulos I, Dascalopoulou E, Argyropoulou P, Bouros D, Mavrofridis E. (2004). Sleep apnea syndrome and diastolic blood pressure elevation during exercise. Respiration.
Tsai WH, Remmers JE, Brant R, Flemons WW, Davies J, Macarthur C. (2003). A decision rule for diagnostic testing in obstructive sleep apnea. American Journal of Respiratory & Critical Care Medicine.
Tsara V, Kaimakamis E, Serasli E, Katsarou Z, Christaki P. (2009). Health related quality of life in Greek patients with sleep apnea-hypopnea syndrome treated with continuous positive airway pressure. Sleep Medicine.
Tschopp K, Thomaser EG, Staub C. (2009). Therapy of snoring and obstructive sleep apnea using the Velumount palatal device. Orl; Journal of Oto-Rhino-Laryngology & its Related Specialties.
Tsuiki S, Lowe AA, Almeida FR, Kawahata N, Fleetham JA. (2004). Effects of mandibular advancement on airway curvature and obstructive sleep apnoea severity. European Respiratory Journal.
Tugrul S, Akinci O, Ozcan PE, et al. (2003). Effects of sustained inflation and postinflation positive end-expiratory pressure in acute respiratory distress syndrome: focusing on pulmonary and extrapulmonary forms. Critical Care Medicine.
Turkington PM, Sircar M, Saralaya D, Elliott MW. (2004). Time course of changes in driving simulator performance with and without treatment in patients with sleep apnoea hypopnoea syndrome. Thorax.
Tvinnereim M, Cole P, Haight JS, Hoffstein V. (1995). Diagnostic airway pressure recording in sleep apnea syndrome. Acta Oto-Laryngologica.
Tvinnereim M, Mitic S, Hansen RK. (2007). Plasma radiofrequency preceded by pressure recording enhances success for treating sleep-related breathing disorders. Laryngoscope.
Ueda H, Almeida FR, Chen H, Lowe AA. (2009). Effect of 2 jaw exercises on occlusal function in patients with obstructive sleep apnea during oral appliance therapy: a randomized controlled trial. American Journal of Orthodontics & Dentofacial Orthopedics.
Uematsu M. (2010). Is right ventricular dysfunction in obstructive sleep apnea a potential screening tool. Circulation Journal.
Unterberg C, Luthje L, Szych J, Vollmann D, Hasenfuss G, Andreas S. (2005). Atrial overdrive pacing compared to CPAP in patients with obstructive sleep apnoea syndrome. European Heart Journal.
Ueno K, Kasai T, Brewer G, et al. (2010). Evaluation of the apnea-hypopnea index determined by the S8 auto-CPAP, a continuous positive airway pressure device, in patients with obstructive sleep apnea-hypopnea syndrome. Journal of Clinical Sleep Medicine.
Valham F, Mooe T, Rabben T, Stenlund H, Wiklund U, Franklin KA. (2008). Increased risk of stroke in patients with coronary artery disease and sleep apnea: a 10-year follow-up. Circulation.
van den Broek E, Richard W, van TH, de VN. (2008). UPPP combined with radiofrequency thermotherapy of the tongue base for the treatment of obstructive sleep apnea syndrome. European Archives of Oto-Rhino-Laryngology.
Van Meerhaeghe A, Delpire P, Stenuit P, Kerkhofs M. (2004). Operating characteristics of the negative expiratory pressure technique in predicting obstructive sleep apnoea syndrome in snoring patients. Thorax.
Van Surrell C, Lemaigre D, Leroy M, Foucher A, Hagenmuller MP, Raffestin B. (1995). Evaluation of an ambulatory device, CID 102, in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal.
Vazquez JC, Tsai WH, Flemons WW, et al. (2000). Automated analysis of digital oximetry in the diagnosis of obstructive sleep apnoea. Thorax.
Veale D, Chailleux E, Hoorelbeke-Ramon A, et al. (2000). Mortality of sleep apnoea patients treated by nasal continuous positive airway pressure registered in the ANTADIR observatory. Association Nationale pour le Traitement A Domicile de l’Insuffisance Respiratoire chronique. European Respiratory Journal.
Vecchierini MF, Leger D, Laaban JP, et al. (2008). Efficacy and compliance of mandibular repositioning device in obstructive sleep apnea syndrome under a patient-driven protocol of care. Sleep Medicine.
Ventura C, Oliveira AS, Dias R, et al. (2007). The role of nocturnal oximetry in obstructive sleep apnoea-hypopnoea syndrome screening. Revista Portuguesa de Pneumologia.
Verse T, Baisch A, Maurer JT, Stuck BA, Hormann K. (2006). Multilevel surgery for obstructive sleep apnea: short-term results. Otolaryngology - Head & Neck Surgery.
Verse T, Kroker BA, Pirsig W, Brosch S. (2000). Tonsillectomy as a treatment of obstructive sleep apnea in adults with tonsillar hypertrophy. Laryngoscope.
Verse T, Pirsig W, Junge-Hulsing B, Kroker B. (2000). Validation of the POLY-MESAM seven-channel ambulatory recording unit. Chest.
Vicente E, Marin JM, Carrizo S, Naya MJ. (2006). Tongue-base suspension in conjunction with uvulopalatopharyngoplasty for treatment of severe obstructive sleep apnea: long-term follow-up results. Laryngoscope.
Vilaseca I, Morello A, Montserrat JM, Santamaria J, Iranzo A. (2002). Usefulness of uvulopalatopharyngoplasty with genioglossus and hyoid advancement in the treatment of obstructive sleep apnea. Archives of Otolaryngology -- Head & Neck Surgery.
Viner S, Szalai JP, Hoffstein V. (1991). Are history and physical examination a good screening test for sleep apnea. Annals of Internal Medicine.
Virkkula P, Bachour A, Hytonen M, et al. (2006). Snoring is not relieved by nasal surgery despite improvement in nasal resistance. Chest.
von Kanel R, Loredo JS, Ancoli-Israel S, Dimsdale JE. (2006). Association between sleep apnea severity and blood coagulability: Treatment effects of nasal continuous positive airway pressure. Sleep & Breathing.
Waite PD, Wooten V, Lachner J, Guyette RF. (1989). Maxillomandibular advancement surgery in 23 patients with obstructive sleep apnea syndrome. Journal of Oral & Maxillofacial Surgery.
Waldhorn RE, Herrick TW, Nguyen MC, O’Donnell AE, Sodero J, Potolicchio SJ. (1990). Long-term compliance with nasal continuous positive airway pressure therapy of obstructive sleep apnea. Chest.
Walker EB, Frith RW, Harding DA, Cant BR. (1989). Uvulopalatopharyngoplasty in severe idiopathic obstructive sleep apnoea syndrome. Thorax.
Walker RP, Garrity T, Gopalsami C. (1999). Early polysomnographic findings and long-term subjective results in sleep apnea patients treated with laser-assisted uvulopalatoplasty. Laryngoscope.
Walker RP, Grigg-Damberger MM, Gopalsami C. (1999). Laser-assisted uvulopalatoplasty for the treatment of mild, moderate, and severe obstructive sleep apnea. Laryngoscope.
Walker RP, Grigg-Damberger MM, Gopalsami C. (1997). Uvulopalatopharyngoplasty versus laser-assisted uvulopalatoplasty for the treatment of obstructive sleep apnea. Laryngoscope.
Walker RP, Grigg-Damberger MM, Gopalsami C, Totten MC. (1995). Laser-assisted uvulopalatoplasty for snoring and obstructive sleep apnea: results in 170 patients. Laryngoscope.
Walker RP, Levine HL, Hopp ML, Greene D, Pang K. (2006). Palatal implants: a new approach for the treatment of obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Wang X-H, Yuan Y-D, Wang B-F, Xiao L-Y, Pan W-S, Shi YZ. (2006). Auricular acupoint pressing therapy in the treatment of obstructive sleep apnea syndrome. Chinese Journal of Clinical Rehabilitation.
Wassmuth Z, Mair E, Loube D, Leonard D. (2000). Cautery-assisted palatal stiffening operation for the treatment of obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery.
Watkins MR, Talmage JB, Thiese MS, Hudson TB, Hegmann KT. (2009). Correlation between screening for obstructive sleep apnea using a portable device versus polysomnography testing in a commercial driving population. Journal of Occupational & Environmental Medicine.
Watson RK, Thompson AS. (1992). Treatment outcome of sleep apnea. Connecticut Medicine.
Weatherwax KJ, Lin X, Marzec ML, Malow BA. (2003). Obstructive sleep apnea in epilepsy patients: the Sleep Apnea scale of the Sleep Disorders Questionnaire (SA-SDQ) is a useful screening instrument for obstructive sleep apnea in a disease-specific population. Sleep Medicine.
Weaver EM, Kapur V, Yueh B. (2004). Polysomnography vs self-reported measures in patients with sleep apnea. Archives of Otolaryngology -- Head & Neck Surgery.
Weaver TE, Chasens ER, Arora S. (2009). Modafinil improves functional outcomes in patients with residual excessive sleepiness associated with CPAP treatment. Journal of Clinical Sleep Medicine.
Westbrook PR, Levendowski DJ, Cvetinovic M, et al. (2005). Description and validation of the apnea risk evaluation system: a novel method to diagnose sleep apnea-hypopnea in the home. Chest.
White DP, Gibb TJ, Wall JM, Westbrook PR. (1995). Assessment of accuracy and analysis time of a novel device to monitor sleep and breathing in the home. Sleep.
Whitelaw WA, Brant RF, Flemons WW. (2005). Clinical usefulness of home oximetry compared with polysomnography for assessment of sleep apnea. American Journal of Respiratory & Critical Care Medicine.
Whittle AT, Finch SP, Mortimore IL, Mackay TW, Douglas NJ. (1997). Use of home sleep studies for diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax.
Wiest GH, Harsch IA, Fuchs FS, et al. (2002). Initiation of CPAP therapy for OSA: does prophylactic humidification during CPAP pressure titration improve initial patient acceptance and comfort. Respiration.
Williams AJ, Yu G, Santiago S, Stein M. (1991). Screening for sleep apnea using pulse oximetry and a clinical score. Chest.
Williams SC, Rogers NL, Marshall NS, Leung S, Starmer GA, Grunstein RR. (2008). The effect of modafinil following acute CPAP withdrawal: a preliminary study. Sleep & Breathing.
Williams SC, Marshall NS, Kennerson M, Rogers NL, Liu PY, Grunstein RR. (2010). Modafinil effects during acute continuous positive airway pressure withdrawal: a randomized crossover double-blind placebo-controlled trial. American Journal of Respiratory & Critical Care Medicine.
Wiltshire N, Kendrick AH, Catterall JR. (2001). Home oximetry studies for diagnosis of sleep apnea/hypopnea syndrome: limitation of memory storage capabilities. Chest.
Wolfe L, Massie CA, Mutlu GM, Gordon N, Casal E. (2007). Comparative efficacy of two expiratory pressure reduction systems in the treatment of obstructive sleep apnea. Chest.
Woodson BT. (2001). A tongue suspension suture for obstructive sleep apnea and snorers. Otolaryngology - Head & Neck Surgery.
Woodson BT, Conley SF. (1997). Prediction of uvulopalatopharyngoplasty response using cephalometric radiographs. American Journal of Otolaryngology.
Woodson BT, Derowe A, Hawke M, et al. (2000). Pharyngeal suspension suture with repose bone screw for obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Woodson BT, Fujita S. (1992). Clinical experience with lingualplasty as part of the treatment of severe obstructive sleep apnea. Otolaryngology - Head & Neck Surgery.
Woodson BT, Robinson S, Lim HJ. (2005). Transpalatal advancement pharyngoplasty outcomes compared with uvulopalatopharygoplasty. Otolaryngology - Head & Neck Surgery.
Yamadera W. (1995). Improvement in excessive daytime sleepiness after surgical treatment for obstructive sleep apnea syndrome. Psychiatry & Clinical Neurosciences.
Yamashiro Y, Kryger MH. (1995). Nocturnal oximetry: is it a screening tool for sleep disorders. Sleep.
Yi B, Zhang XE, Zhang ZK, Wang X, Huang XZ. (1999). Orthognathic surgery correction of mandibular hypoplasia accompanying obstructive sleep apnea syndrome. Chinese Journal of Dental Research.
Yi HL, Yin SK, Zhang YJ, et al. (2009). Z-palatopharyngoplasty for obstructive sleep apnea/hypopnea syndrome. Otolaryngology - Head & Neck Surgery.
Yin M, Miyazaki S, Ishikawa K. (2006). Evaluation of type 3 portable monitoring in unattended home setting for suspected sleep apnea: factors that may affect its accuracy. Otolaryngology - Head & Neck Surgery.
Yonekura A, Kawakatsu K, Suzuki K, Nishimura T. (2003). Laser midline glossectomy and lingual tonsillectomy as treatments for sleep apnea syndrome. Acta Oto-Laryngologica Supplement.
Young T, Blustein J, Finn L, Palta M. (1997). Sleep-disordered breathing and motor vehicle accidents in a population-based sample of employed adults. Sleep.
Young T, Palta M, Dempsey J, Peppard PE, Nieto FJ, Hla KM. (2009). Burden of sleep apnea: rationale, design, and major findings of the Wisconsin Sleep Cohort study. WMJ.
Zamarron C, Gude F, Barcala J, Rodriguez JR, Romero PV. (2003). Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest.
Zamarron C, Pichel F, Romero PV. (2005). Coherence between oxygen saturation and heart rate obtained from pulse oximetric recordings in obstructive sleep apnoea. Physiological Measurement.
Zamarron C, Romero PV, Gude F, Amaro A, Rodriguez JR. (2001). Screening of obstructive sleep apnoea: heart rate spectral analysis of nocturnal pulse oximetric recording. Respiratory Medicine.
Zamarron C, Romero PV, Rodriguez JR, Gude F. (1999). Oximetry spectral analysis in the diagnosis of obstructive sleep apnoea. Clinical Science.
Zohar Y, Finkelstein Y, Strauss M, Shvilli Y. (1993). Surgical treatment of obstructive sleep apnea. Technical variations. Archives of Otolaryngology -- Head & Neck Surgery.
Zohar Y, Finkelstein Y, Talmi YP, Bar-Ilan Y. (1991). Uvulopalatopharyngoplasty: evaluation of postoperative complications, sequelae, and results. Laryngoscope.
Zohar Y, Talmi YP, Frenkel H, et al. (1992). Cardiac function in obstructive sleep apnea patients following uvulopalatopharyngoplasty. Otolaryngology - Head & Neck Surgery.
Zonato AI, Bittencourt LR, Martinho FL, Gregorio LC, Tufik S. (2006). Upper airway surgery: the effect on nasal continuous positive airway pressure titration on obstructive sleep apnea patients. European Archives of Oto-Rhino-Laryngology.
Zorick F, Roehrs T, Conway W, Fujita S, Wittig R, Roth T. (1983). Effects of uvulopalatopharyngoplasty on the daytime sleepiness associated with sleep apnea syndrome. Bulletin europeen de physiopathologie respiratoire.
Zou D, Grote L, Peker Y, Lindblad U, Hedner J. (2006). Validation a portable monitoring device for sleep apnea diagnosis in a population based cohort using synchronized home polysomnography. Sleep.
Zou D, Grote L, Eder DN, Radlinski J, Hedner J. (2010). A double-blind, crossover study of Doxazosin and Enalapril on peripheral vascular tone and nocturnal blood pressure in sleep apnea patients. Sleep Medicine.
Zucconi M, Ferini-Strambi L, Castronovo V, Oldani A, Smirne S. (1996). An unattended device for sleep-related breathing disorders: validation study in suspected obstructive sleep apnoea syndrome. European Respiratory Journal.