# Appendix A Literature Search Strategy

Databases: Ovid MEDLINE, MEDLINE(R) In-Process, Cochrane Controlled Trials Register (CCTR)

Last run 2/17/2010

# | Searches | Results
1 | exp Sleep Apnea Syndromes/or exp Sleep Apnea, Obstructive/ | 19267 | Sleep Apnea
2 | exp Airway Resistance/ | 13219 | Sleep Apnea
3 | exp snoring/ | 2922 | Sleep Apnea
4 | Upper airway resistance syndrome.mp. | 229 | Sleep Apnea
5 | Respiratory disturbance.mp. | 1151 | Sleep Apnea
6 | obstructive sleep apn?ea.mp. | 11746 | Sleep Apnea
7 | or/1–6 | 35183 | Sleep Apnea
8 | randomized controlled trial.pt. | 561439 | Comparative Studies
9 | controlled clinical trial.pt. | 161324 | Comparative Studies
10 | randomized controlled trials/ | 67116 | Comparative Studies
11 | Random Allocation/ | 88433 | Comparative Studies
12 | Double-blind Method/ | 194574 | Comparative Studies
13 | Single-Blind Method/ | 22535 | Comparative Studies
14 | clinical trial.pt. | 748992 | Comparative Studies
15 | Clinical Trials.mp. or exp Clinical Trials/ | 282752 | Comparative Studies
16 | (clinic$ adj25 trial$).tw. | 234940 | Comparative Studies
17 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. | 223366 | Comparative Studies
18 | Placebos/ | 48648 | Comparative Studies
19 | placebo$.tw. | 236373 | Comparative Studies
20 | random$.tw. | 781376 | Comparative Studies
21 | trial$.tw. | 607720 | Comparative Studies
22 | (randomized control trial or clinical control trial).sd. | 227662 | Comparative Studies
23 | (latin adj square).tw. | 3635 | Comparative Studies
24 | Comparative Study.tw. or Comparative Study.pt. | 1644250 | Comparative Studies
25 | exp Evaluation studies/ | 149831 | Comparative Studies
26 | Follow-Up Studies/ | 437652 | Comparative Studies
27 | Prospective Studies/ | 331595 | Comparative Studies
28 | (control$ or prospectiv$ or volunteer$).tw. | 2591469 | Comparative Studies
29 | Cross-Over Studies/ | 45716 | Comparative Studies
30 | Or/8–29 | 5078479 | Comparative Studies
31 | exp Positive-Pressure Respiration/or exp Continuous Positive Airway Pressure/ | 18518 | Treatments
32 | exp Intermittent Positive-Pressure Ventilation/or exp Ventilators, Mechanical/or exp Masks/ | 16688 | Treatments
33 | general surgery/or neurosurgery/or otolaryngology/or surgery, plastic/or thoracic surgery/ | 80977 | Treatments
34 | Surgical Procedures, Operative/ | 46806 | Treatments
35 | oral appliances.mp. | 286 | Treatments
36 | exp Physical Therapy Modalities/or exp Exercise Therapy/ | 107007 | Treatments
37 | positional therapy.mp. | 41 | Treatments
38 | exp Weight Loss/ | 22268 | Treatments
39 | exp Exercise/or exp Exercise Therapy/ | 78677 | Treatments
40 | exp Therapeutics/ | 2836406 | Treatments
41 | exp Anesthesia/or Pre-operative screening/or Anesthetic agents/ | 164281 | Treatments
42 | Sleep Apnea, Obstructive/th | 2408 | Treatments
43 | *tonsillectomy/ | 4707 | Treatments
44 | or/31–43 | 3119682 | Treatments
45 | exp Polysomnography/ | 11867 | Sleep Apnea Diagnostic Terms
46 | exp Oximetry/ | 10559 | Sleep Apnea Diagnostic Terms
47 | exp Monitoring, Physiologic/ | 110172 | Sleep Apnea Diagnostic Terms
48 | pulse transit time.mp. | 246 | Sleep Apnea Diagnostic Terms
49 | exp Monitoring, Ambulatory/ | 18720 | Sleep Apnea Diagnostic Terms
50 | peripheral Arterial Tonometry.mp. | 62 | Sleep Apnea Diagnostic Terms
51 | exp Questionnaires/ | 224876 | Sleep Apnea Diagnostic Terms
52 | exp Diagnostic Tests, Routine/ | 5348 | Sleep Apnea Diagnostic Terms
53 | exp “Laboratory Techniques and Procedures”/ | 1586381 | Sleep Apnea Diagnostic Terms
54 | (Epworth or Stanford or Berlin or Pittsburgh or scale).af. | 470093 | Sleep Apnea Diagnostic Terms
55 | (friedman or surgical or staging).mp. | 887171 | Sleep Apnea Diagnostic Terms
56 | STOP-Bang.af. | 2 | Sleep Apnea Diagnostic Terms
57 | Sleep Apnea, Obstructive/di | 2379 | Sleep Apnea Diagnostic Terms
58 | or/45–57 | 3098114 | Sleep Apnea Diagnostic Terms
59 | exp “sensitivity and specificity”/ | 320624 | General Diagnostic Tests
60 | exp Predictive Value of Tests/ | 104513 | General Diagnostic Tests
61 | exp ROC CURVE/ | 17069 | General Diagnostic Tests
62 | exp Mass Screening/ | 102939 | General Diagnostic Tests
63 | exp diagnosis/ | 5190511 | General Diagnostic Tests
64 | exp REPRODUCIBILITY OF RESULTS/ | 203415 | General Diagnostic Tests
65 | exp false negative reactions/or false positive reactions/ | 30462 | General Diagnostic Tests
66 | predictive value.tw. | 44461 | General Diagnostic Tests
67 | (sensitivity or specificity).tw. | 582712 | General Diagnostic Tests
68 | accuracy.tw. | 162713 | General Diagnostic Tests
69 | screen$.tw. | 350059 | General Diagnostic Tests
70 | diagno$.tw. | 1333212 | General Diagnostic Tests
71 | roc.tw. | 12925 | General Diagnostic Tests
72 | reproducib$.tw. | 90416 | General Diagnostic Tests
73 | (false positive or false negative).tw. | 39967 | General Diagnostic Tests
74 | likelihood ratio.tw. | 4450 | General Diagnostic Tests
75 | accuracy.tw. | 162713 | General Diagnostic Tests
76 | di.fs. | 1684695 | General Diagnostic Tests
77 | or/59–76 | 6907870 | General Diagnostic Tests
78 | 7 and 30 and 44 | 6008 | Group 1: Comparative studies OSA & treatment
79 | limit 78 to english language [Limit not valid in CCTR; records were retained] | 5354 | Group 1: Comparative studies OSA & treatment
80 | limit 79 to humans [Limit not valid in CCTR; records were retained] | 4883 | Group 1: Comparative studies OSA & treatment
81 | 79 and humans.sh. | 4876 | Group 1: Comparative studies OSA & treatment
82 | 80 or 81 | 4883 | Group 1: Comparative studies OSA & treatment
83 | remove duplicates from 82 | 3751 | Group 1: Comparative studies OSA & treatment
84 | 7 and 44 | 11488 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
85 | 84 not 83 | 7737 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
86 | limit 85 to english language [Limit not valid in CCTR; records were retained] | 5933 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
87 | limit 86 to humans [Limit not valid in CCTR; records were retained] | 4943 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
88 | 86 and humans.sh. | 4942 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
89 | 87 or 88 | 4943 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
90 | remove duplicates from 89 | 4596 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
91 | limit 90 to (addresses or bibliography or biography or case reports or comment or congresses or consensus development conference or dictionary or directory or festschrift or in vitro or interactive tutorial or interview or lectures or legal cases or legislation or news or newspaper article or overall or patient education handout or periodical index or portraits or “scientific integrity review” or twin study) | 913 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
92 | 90 not 91 | 3683 | Group 2: All but comparative studies on OSA & treatment (not some study designs)
93 | 7 and 30 and 58 | 6424 | Group 3: Comparative studies specific to OSA diagnosis
94 | limit 93 to english language [Limit not valid in CCTR; records were retained] | 5775 | Group 3: Comparative studies specific to OSA diagnosis
95 | limit 94 to humans [Limit not valid in CCTR; records were retained] | 5492 | Group 3: Comparative studies specific to OSA diagnosis
96 | 94 and humans.sh. | 5453 | Group 3: Comparative studies specific to OSA diagnosis
97 | 95 or 96 | 5492 | Group 3: Comparative studies specific to OSA diagnosis
98 | remove duplicates from 97 | 4295 | Group 3: Comparative studies specific to OSA diagnosis
99 | 98 not (83 or 92) | 2477 | Group 3: Comparative studies specific to OSA diagnosis
100 | 7 and 58 and 77 | 11451 | Group 4: Other OSA diagnosis
101 | limit 100 to english language [Limit not valid in CCTR; records were retained] | 9709 | Group 4: Other OSA diagnosis
102 | limit 101 to humans [Limit not valid in CCTR; records were retained] | 9209 | Group 4: Other OSA diagnosis
103 | 101 and humans.sh. | 9199 | Group 4: Other OSA diagnosis
104 | 102 or 103 | 9209 | Group 4: Other OSA diagnosis
105 | 104 not (83 or 92 or 99) | 3623 | Group 4: Other OSA diagnosis
106 | remove duplicates from 105 | 3296 | Group 4: Other OSA diagnosis
107 | limit 7 to (guideline or meta analysis or practice guideline) | 151 | Group 5: Systematic Reviews and Practice Guidelines on OSA
108 | 7 and Cochrane Database of Systematic Reviews.jn. | 25 | Group 5: Systematic Reviews and Practice Guidelines on OSA
109 | 107 or 108 | 170 | Group 5: Systematic Reviews and Practice Guidelines on OSA
110 | remove duplicates from 109 | 129 | Group 5: Systematic Reviews and Practice Guidelines on OSA
111 | 110 not (83 or 92 or 99 or 106) | 41 | Group 5: Systematic Reviews and Practice Guidelines on OSA
| | | Group 5: Systematic Reviews and Practice Guidelines on OSA
112 | 83 or 92 or 99 or 106 or 111 | 13248 (+188, from 2/17/10, below)
113–120 run on 2/17/2010
113 | 7 and 30 | 12165 | Group 6: Cohort studies for KQ 2 & 6
114 | 113 not 112 | 5912 | Group 6: Cohort studies for KQ 2 & 6
115 | (ep or co or mo).fs. | 2293973 | Group 6: Cohort studies for KQ 2 & 6
116 | (incidence or longitudinal studies or prospective studies or survival analysis or follow-up studies or logistic models or Proportional Hazards Models or Linear Models or Regression Analysis).sh. | 967098 | Group 6: Cohort studies for KQ 2 & 6
117 | exp patient compliance/or exp medication adherence/or exp treatment refusal/ | 47071 | Group 6: Cohort studies for KQ 2 & 6
118 | or/115–117 | 2893257 | Group 6: Cohort studies for KQ 2 & 6
119 | 114 and 118 | 1771 | Group 6: Cohort studies for KQ 2 & 6
120 | limit 119 to (english language and humans) | 1088 | Group 6: Cohort studies for KQ 2 & 6
121 | 112 or 120 | 14524
122 | exp Orthodontic Appliances, Removable/ | 3929 | Group 1a: Additional interventions
123 | Palate, Soft/su or Pharynx/su or Uvula/su or Sleep Apnea Syndromes/su | 3669 | Group 1a: Additional interventions
124 | Sleep Apnea Syndromes/pc | 188 | Group 1a: Additional interventions
125 | or/122–124 | 7766 | Group 1a: Additional interventions
126 | 7 and 30 and 125 | 755 | Group 1a: Additional interventions
127 | 126 not (112 or 119) | 77 | Group 1a: Additional interventions
128 | limit 127 to (english language and humans) | 32 | Group 1a: Additional interventions
Update run on 9/30/2010
129 | Medline search (all above) limited to 201001$.ed to 201009$.ed | 631
130 | Cochrane searches (all above) limited to year = 2010 | 10
131 | Duplicates removed | 604