# Acronyms and Abbreviations

ACP: American College of Physicians
AHI: apnea-hypopnea index
ASA: American Society of Anesthesiologists
AUC: area under the receiver operating characteristics curve
AutoCPAP: autotitrating continuous positive airway pressure
BMI: body mass index
CER: Comparative Effectiveness Review
CI: confidence interval
CPAP: continuous positive airway pressure
ECG: electrocardiography
ESS: Epworth Sleepiness Scale
FOSQ: Functional Outcomes Sleep Questionnaire
ICU: intensive care unit
LAUP: laser-assisted uvulopalatoplasty
MAD: mandibular advancement device
MED: Medicaid Evidence-based Decisions project
MSLT: Multiple sleep latency test
ODI: Oxygen desaturation index
OSA: obstructive sleep apnea
PICOD: population, interventions, comparators, outcomes, and study designs
PSG: polysomnography
RCT: randomized controlled trial
RDI: respiratory disturbance index
REM: rapid eye movement
RFA: radiofrequency ablation
ROC: receiver operating characteristics
SAQLI: Sleep Apnea Quality of Life Index
SF-36: Short Form (36) Health Survey
SHHS: Sleep Heart Health Study
STOP: snoring, tiredness during daytime, observed apnea, and high blood pressure
STOP-Bang: STOP with BMI, age, neck circumference, and sex variables
TEP: technical expert panel
TMJ: temporomandibular joint
TOO: task order officer
UPPP: uvulopalatopharyngoplasty