# Summary and Discussion

There is very limited high-quality evidence, to support the diagnostic, preventive, and treatment practices for Clostridium difficile infection (CDI) carried out by providers in hospital, long-term care, and outpatient settings. Inconsistency in definitions of diarrhea, severity, and resolution of symptoms contributes to the difficulty in drawing conclusions from the evidence. Table 22 provides a summary of the evidence and results presented in this review.

Table 22 Summary of evidence

Key Questions | Level of Evidence | Summary/Conclusion/Comments
Key Question 1 - Diagnostics
Immunoassays for toxins A and B | Low to moderate | Ten studies directly compared at least two immunoassays for toxins A and B, providing 16 pairwise comparisons of 7 different immunoassays. Comparative data were not found for many currently used tests. There were no statistical differences between the sensitivities of immunoassays that were compared, however, the estimates of the differences in sensitivity were not very precise and could not rule out substantial differences. Substantial differences in false positives, i.e. specificity, were not found among the tests that were compared.
Gene detection tests vs. immunoassays for toxins A and B | Low to moderate | Four studies compared at least one toxin gene detection test to at least one immunoassay for toxins A and B, providing a total of nine direct comparisons. Comparative data were not always available for the three currently available gene detection tests. The gene detection tests could be substantially more sensitive than many immunoassays for toxins A and B, with no or relatively modest loss of specificity.
Patient characteristics | Insufficient | Insufficient patient information was provided in reports of comparative data.
Key Question 2 - Prevention
Antibiotic use | Low | Sixteen studies, including six bundled prevention practice studies, found appropriate prescribing practices are associated with decreased CDI incidence Harms were not reported.
Gloves | Low | One controlled trial found use of gloves in hospital settings reduced CDI incidence.
Disposable thermometer | Low | Three time series/before–after studies, two with controls, found use of disposable thermometers in hospital settings reduced CDI incidence.
Handwashing/ alcohol gel | Low | No study examined whether handwashing reduced CDI incidence. Two studies, one controlled trial and one before/after study, of use alcohol gel to reduce MRSA transmission did not find significant differences in CDI incidence
Disinfection | Low | Thirteen before–after studies of outbreaks or endemic hospital settings found intensive disinfection with a chemical compound that kills C. difficile spores reduced CDI incidence.
Sustainability | Insufficient | No evidence was available.
Risk factors | Low | Ten observational studies found evidence for antibiotic use, whether specific or general, increased risk of CDI. Severe underlying disease, acid suppression, and age are indicated as risk factors. A number of other potential factors may be indicated in single studies.
Multiple component strategies | Insufficient | Eleven time series/before–after studies examined bundles of prevention components in a single intervention. Data is insufficient to draw conclusions. Harms were not reported.
Key Question 3 - Antibiotic Treatment
Vancomycin versus Metronidazole | Moderate for clinical cure, low for all other outcomes | There were three head to head trials with a total of 335 subjects. Trials used various definitions of CDI patient and cure definitions, especially with regard to stool count and consistency. No significant differences in outcomes, including initial cure, clinical recurrence, mean days to resolved diarrhea, were found. Our results build upon, and are consistent with, the Cochrane Review completed by Bricker et al.106
Severe disease, vancomycin versus metronidazole | Insufficient | One RCT examined a prespecified subgroup of 69 subjects with severe CDI; improved clinical cure based on per-protocol analysis, but not with strict intention-to-treat analysis
Fidaxomycin versus vancomycin | Moderate | One large, high-quality RCT demonstrated decreased recurrence among those receiving fidaxomicin.
All other comparisons of standard treatments | Moderate for vancomycin vs. fidaxomicin, low for all other comparisons | There were eight trials examining: vancomycin versus bacitracin (two trials), vancomycin versus fidaxomicin, vancomycin versus nitazoxanide, vancomycin high versus low dose, vancomycin versus placebo, metronidazole versus nitazoxanide, and metronidazole versus metronidazole plus rifampin (one each). No differences.
Strain of organism | Low | One RCT (fidaxomicin versus vancomycin) demonstrated deecreased recurrence among those receiving fidaxomicin when the infecting organism was a non-NAP1 strain.
Patient characteristics | Insufficient | No comparative data were available.
Resistance of other pathogens | Insufficient | No data were available.
Key Question 4 - Nonstandard Treatment
Treating CDI, active control | Low | Probiotics, prebiotics, C. difficile immune whey, and colestipol, are not more effective in treating CDI than standard antibiotic treatment with oral vancomycin or metronidazole.
Treating CDI, placebo | Low | Administration of a probiotic with live bacteria to treat CDI in critically ill patients increases risk for greater morbidity and mortality from fungemia without any known benefit.
Treating recurrent CDI | Low | There is limited evidence from six case series that fecal flora reconstitution is effective in treating recurrent CDI for up to 1 year (3 weeks to 8 years).
Preventing CDI | Low | There is limited evidence that the nonstandard interventions in this review are not more effective than placebo for primary prevention of CDI.
Preventing recurrent CDI | Low to moderate | There is limited evidence from one subgroup analysis that a prebiotic may reduce diarrhea recurrence in patients treated for CDI more so than placebo with standard antibiotics. There is limited moderate strength evidence from one study that monoclonal antibodies are effective in preventing recurrence of CDI.

CDI = Clostridium difficile infection

## Diagnostic Testing (Key Question 1)

This review focused on comparing the sensitivity and specificity of diagnostic methods that rely, at least in part, on the most widely used commercial immunoassays for C. difficile toxin. Immunoassays that can detect both toxins A and B were of particular interest because hypothetically they are the most sensitive immunoassay for detecting toxins and they are very commonly used by laboratories in the United States. In addition, data from comparative evaluations that included newer commercial C difficile toxin gene detection tests were of interest.

In general, there is little evidence that the sensitivities of commonly used immunoassays for toxins A and B differ, and any differences in their percent of false positives (1 minus specificity) most likely are small (3 percent or less). However, the strength of the evidence is low due to the number of direct comparisons of the immunoassay that are available in the literature. The possibility exists that future research could impact the findings. Further, one article that examined eight tests is the sole source for many of the comparisons. The available comparative data doesn't rule out the possibility of larger differences between some of the immunoassays that have or have not been directly compared in adequate numbers. While the precision of the findings is such that we cannot rule out the possibility of differences in sensitivity on the order of 3 to 5 percent, it is unclear whether such differences would affect clinical decisionmaking.

Gene-based tests that used toxin B gene fragments tended to have better sensitivity than immunoassays for toxins A and B. Results, however, should be viewed with caution. Few studies contributed to the findings, and many direct comparisons were not found. Further, as mentioned above, the methodological differences between studies, including use of different reference tests, might have affected the toxin immunoassays more than the gene detection tests. Perhaps variation in the stability of the toxins in stool specimens as they were collected, stored, and processed contributed to the observed variation between studies in the estimates of the immunoassay's sensitivities, whereas detection via amplification of gene fragments could be less susceptible to specimen degradation. Use of a more sensitive toxigenic culture as the reference test may impact the estimated sensitivity of the immunoassays more than the toxin gene detection tests.203

These tests require varying skills, equipment, and time to carry out, and heterogeneity is a significant factor in reviewing the literature. Previous reviews by Planche et al.98 and Crobach et al.99 encountered difficulty comparing the sensitivities and specificities of the diagnostic tests in large part because there was too much variation between studies in the estimates of sensitivity and specificity of a particular test. Planche et al. used logistic regression with dummy variables to represent each immunoassay and found significant differences in sensitivity and specificity; however, the regression model did not include any covariates to try to account for the substantial heterogeneity between studies. We attempted to control for the heterogeneity between studies by examining the differences in sensitivity and specificity in stool samples tested within the same lab and did not find strong evidence of differences between tests within several immunoassays for toxins type A and B. The extent of any publication bias for these comparisons is unknown.

A clinically important question is whether the potential differences in the accuracy of the diagnostic tests being employed in practice would translate into differences in clinical behaviors or patient outcomes. Indeed, how well clinicians actually know the sensitivity and specificity of the test(s) for toxigenic C. difficile employed by their laboratories and incorporate this information, along with estimates of the prior probability of CDI (using Bayes formula) into their patient care decisions is not clear.

Clinical diagnosis is important in outpatient settings, and primary care in particular, as well as inpatient settings. Outpatient clinicians will need to be alert to the possibility of CDI, given that CDI can manifest several months after hospital exposure or antibiotic use.

## Prevention (Key Question 2)

Very little evidence connects prevention strategies and techniques directly to patient-related outcomes, such as CDI incidence. Available evidence is generally from before/after study designs or limited time series. Hospital settings with outbreaks or hyperendemic episodes further limit applicability of the findings, and leave open the question of the relative contribution of regression to the mean (i.e., that CDI rates returned to baseline rates even in the absence of effective interventions). The studies also varied in the degree to which they described CDI surveillance, diagnostic accuracy, or laboratory performance. In most, surveillance was passive and depended on a positive toxin test on a stool specimen sent by clinicians caring for a patient with diarrhea. Unknown numbers of cases might have been missed or misdiagnosed. Additionally, attention has not been given to describing a prevention strategy's potential harm (e.g., increase in other pathogens, reduction in direct patient care contact due to isolation or restrictive contact requirements, increased costs) or the long-term sustainability of a practice.

There is low-strength evidence that antibiotic prescribing practices appear to reduce CDI incidence, a finding consistent with the Cochrane review.41 None of the studies explicitly addressed the potential harms of changes in antibiotic use policy, but there are several theoretical harms. They include the possibility that preferred drugs will be less effective than drugs that physicians are discouraged from using, or drugs that are made unavailable for treating infections other than CDI. Preferred antimicrobials might have greater costs or greater toxicities unrelated to CDI. C. difficile strains might evolve to develop resistance to the preferred antibiotics, which might increase the likelihood that the recommended antibiotics might induce CDI.

While several studies found increased risk with specific antibiotics or antibiotic classes, the antibiotics that confer greater risk for CDI have changed over time and vary by location because of differences in prevalent toxigenic strains and especially the susceptibility patterns of those strains.100 Clindamycin resistance was identified soon after the role of C. difficile in pathogenesis was discovered.46,101,102 More recently, quinolones have assumed greater importance because strains have become more resistant over time.103

Fewer studies are available to support prevention practices aimed at breaking transmission. There was limited low-strength evidence that gloves, disposable thermometers, handwashing, and intensive disinfection solutions help to reduce CDI incidence. In addition, the presence and use of alcohol gel to prevent other hospital-acquired infections, such as MRSA, did not increase the rate of CDI incidence as might be expected if alcohol gel use replaced handwashing.

Similar to the antibiotic prescribing practice research, none of the studies aimed at breaking transmission addressed potential harms for other prevention practices. Costs of disinfection, time to perform disinfection, and the possible harm to surfaces and equipment should be anticipated. Failures with vapor disinfection systems would be possible and might lead to toxic exposures of personnel or patients. Nor is there evidence to inform infection control professionals whether such practices are sustainable after an intervention period. That is, we cannot answer whether environmental cleaning staff will have developed professional habits that will continue when the intense monitoring related to an intervention period discontinues.

The potential for prevention research is often compromised by the swift uptake of newly described prevention strategies with the belief that these will improve institutional practices, health care quality, and reduce CDI morbidity and mortality. Current prevention strategies often rely on studies using intermediate outcomes such as process. Newly acquired strategies are then added to current practice, bundling them into multiple component interventions. When introduced in outbreak or hyperendemic situations, these “bundled” multipronged prevention efforts in natural settings have been associated with reduction in CDI incidence. The bundles appear to be beneficial, but from a research standpoint, it is challenging to design research that would tease out the relative contributions of single components to the overall bundled prevention strategies to determine which ones are essential or what might be added.

The realities of the environment and the habits of people who occupy those environments are complicated, and care must be taken to avoid assuming the effectiveness of preventive practices based on apparent logic. For example, handwashing is a logical and simple sounding strategy. Studies103,133,204 have shown that surfaces in and near the bed of a patient with CDI are often contaminated with C. difficile, and it is easy for health care workers to recontaminate their hands by touching one of these surfaces. However, if handwashing is performed using the same facilities as the patient, depending on the state of cleanliness in the room, handwashing may be negated the moment a surface is touched by the freshly washed hands. Further, C. difficile spores may persist for up to 5 months on some surfaces.205 This very issue of complexity is in part what drives the aforementioned practice of adding prevention components with what might be, under other conditions, considered minimal available evidence.

## Standard Treatment (Key Question 3)

There is moderate evidence that the two most commonly used treatments, metronidazole and vancomycin, are similary effective for the initial cure of CDI. Our results build upon, and are consistent with, the Cochrane Review completed by Bricker et al.107 The total number of subjects from comparative studies on metronidazole and vancomycin is just 335 patients. This raises the possibility that, although a significant difference in effectiveness has not been detected, a true difference may exist.

In addition, there is moderate-strength evidence, based on a single large study, that fidaxomicin and vancomycin are similarly effective for initial cure of CDI, but that fidaxomicin use leads to significantly fewer recurrences. This difference in recurrence was observed only among non-NAP1 strains of C. difficile. There is no evidence for a difference in effectiveness for other agents, but again the possibility remains that such a difference exists. However, at this time any claims that one agent is superior to another for all cases of CDI are not supported by available evidence. The findings apply to general adult inpatients. Bias due to selectively reporting outcomes is possible if cut-points are changed for CDI definitions, that is, number or consistency of stools. The clinical differences of changes in cut-points are also unknown, however, so the clinical significance could remain.

We found insufficient evidence that vancomycin was superior to metronidazole for subjects classified as having severe disease. One subgroup analysis of a single trialused a prespecified analysis, and the severity classification appears to have been made before treatment allocation.70 However, the superiority of vancomycin over metronidazole does not persist when a strict intention-to-treat analysis is used. An argument can be made that even small increases in effect size are important to a high-risk patient population where time is of the essence.104 A study that has been presented in abstract form only would add to the data available for comparing metronidazole with vancomycin, but it has not yet been published in a peer-reviewed journal (See Table 23, study NCT00196794).

Table 23 Trials from ClinicalTrials.gov and other sources

Intervention Comparator | Last Update, Estimated Completion | Sponsor | Study Design | Population | Primary Outcome | Code
Not yet Recruiting – Diagnostic
PCR, EIA, or cytotoxin assay | Feb 2010, 2010 | Hamilton Health Science, McMaster C. Lee, PI | Comparative | N=500 12+ years stool specimens | Test performance | NCT01066221
Not yet Recruiting – Prevention
I: Lactobacillus acidophilus/ rhamnosus complex C: placebo | Jan 2010, 2012 | Vancouver Island Health Authority, C. Harder | RCT double blind | N=200 60+ patients on antibiotics | CDI incidence | NCT01048567
I: Colostrum derived antibodies C: placebo | Aug 2009, 2012 | Hadassah Medical Organization | RCT double blind 60 day followup Phase II, III | N=300 18+ patients symptomatic patient, lab-confirmed CDI | Recurrent CDI, new cases in close proximity | NCT00747071
Recruiting – Prevention
I: Saccharomyces Boulardii C:Placebo | July 2012 | Bernhard Nocht Institute for Tropical Medicine S. Ehrhardt, PI | RCT double blind, Phase III | N=1,520 18+ hospitalized patients | CDI incidence | NCT01143272
I: toxoid vaccine C: placebo | Apr 2011 | Sanofi-Aventis | RCT double blind 9 week followup | N=650 18+ patients with one CDI episode within last 10 days, not currently treated for recurrent | Recurrent CDI | NCT00772343
I: Lactobacillus casei probiotic C: placebo | Apr 2010, 2012 | University of Sussex, C. Rajkumar, PI | RCT double blind, 28 days, Phase II | N=1,200 55+ patients receiving antibiotics | Incidence and presence of toxin, prevent recurrence | NCT01087892
I: Clostridium butyricum MIYAIRI 588 Strain (CBM588 C: placebo) | Feb 2010, 2011 | Osel, Inc. P. Lee, PI | RCT double blind, Phase II | N=200 18+ patients treated with vancomycin or metronidazole for CDI | Recurrent CDI | NCT01077245
I: Probiotic VSL#3 C: placebo | Sept 2009, Sept 2010 | NHS, UK N. Haslam, PI | RCT double blind, 28 days, Phase II, III | N=450 18+ patients on antibiotics | CDI incidence | NCT00973908
I: Recombinant human lactoferrin C: placebo | Sept 2006 | John Hopkins W. Greenough, PI | RCT double blind | N=300 18+ LTC patients on enteral tube feeding | Not reported | NCT00377078
I: Hospital ward physical design C: traditional ward design | Mar 2009 | University of Calgary W. Ghali, PI | Prospective controlled trial | N=3,600 18+ patients | CDI incidence | NCT00563186
Recruiting – Treatment
I: CB-183,315 two doses tested C: Vancomycin | Apr 2010, 2011 | Cubist Pharmaceuticals | RCT double blinded, 3 arms, Phase II | N=210 18+ patients symptomatic patients, lab-confirmed, index or 1st recurrence | Not clear | NCT01085591
I: Loperamide (Imodium) C: placebo | Jan 2008, Dec 2009 | VA Houston, D. Musher, PI | RCT double blind, Phase IV | N=120 18+ patients on antibiotics | Symptomatic treatment of diarrhea | NCT00591357
I: Nitazoxanide C: NA | Mar 2006 | VA Houston, D. Musher, PI | Open label compassionate use Phase III | N=100 18+ patients with CDI who failed therapy | Resolution of symptoms | NCT00304356
Fecal bacteriology | Mar 2006 | VA Houston D. Musher, PI | Retro observational cross-sectional | N=80 18+ patients with CDI, patients lab-confirmed without CDI, patients who fail therapy, hospitalized patients on antibiotic with no diarrhea | | NCT00304876
Completed – Prevention
I: Bio-K+ CL-1285 probiotic, Lactobacillus acidophilus, Lactobacillus casei C: placebo | Aug 2009 | Bio-K Plus International, Inc. G. XingWang, PI | RCT double blind, Phase III | N=255 50-70 years, patients on antibiotic therapy | CDI incidence | NCT00958308
I: Lactobacillus acidophilus and casei C: placebo | Sept 2008 | Bio-K Plus International, Inc. J. Dylewski, PI | RCT double blind | N=480 18+ patients on antibiotics | CDI incidence | NCT00328263
I:Polycationic disinfectant C: alcohol-based gel and regular disinfectant with quat/chloramines | Aug 2008 | Helsinki University Soft protector TEKES, M. Kanerva, PI | Open label, parallel active control 6 months | 3 experimental wards plus control wards | CDI incidence | NCT00566306
Completed – Treatment
I:GT160-246 C: Vancomycin | Jul 2009 | Genzyme | RCT double blinded, Phase II | N=300 18+ patient with mild to moderate CDI | Not reported | NCT00034294
I: Rifaximin C: Vancomycin | Dec 2009 | Salix Pharmaceuticals A. Shaw, PI | RCT double blind, Phase III | N=300 18+ lab confirmed CDI | Resolution of baseline, recurrence | NCT00269399
I: OPT-80 C: Vancomycin | Feb 2010 | Optimer Pharmaceuticals, YK Shue, PI | RCT double blind, Phase III | N=536 16+ patients with CDI | Cure rate, recurrence rate | NCT00468728
I: Lactobacillus CL placebo (both arms used metronidazole) | Mar 2006 | VA Houston D. Musher | RCT double blind Phase IV | N=70 18+ patients lab confirmed CDI | Response to treatment | NCT00304863
Not ClinicalTrials.gov
FECAL trial I: bacteriotherapy C: Standard antibiotic treatment | | ZonMW, the Netherlands Organisation for Health Research and Development van Nood, PI | RCT, 10 week followup | N=120 18+ patients, proven relapse of CDI. Exclude ICU, immuno-compromised | Response to treatment | Netherlands. Non-citizens accepted if travel to Amsterdam

C = comparator; CDI = Clostridium difficile infection; EIA = enzyme immunoassay; I = intervention; ICU = intensive care unit; PCR = polymerase chain reaction; PI = Principal Investigator; RCT = randomized controlled trial

Outcome definitions varied significantly. For the assessment of initial cure, methods varied between only assessing symptoms, to a combination of symptoms and either laboratory values (stool studies, C-reactive protein levels, peripheral blood leukocyte count) or a physiologic measure (temperature). Similarly, definitions of resolved diarrhea ranged from greater than three formed stools in a 24-hour period70 to greater than two formed stools daily76 to “no loose stools.”73 Assessment of recurrence in these studies was similarly complicated by variable definitions, followup periods (21 days in two, 30 days in the other), and lack of detail regarding whether active or passive surveillance was used to detect recurrence.

None of the randomized controlled trials (RCT) studies included data regarding any other organisms, either with regard to colonization or subsequent clinical infection. Selection of vancomycin-resistant enterococci (VRE) in particular has long been a concern when treating CDI; usually this concern has involved the use of vancomycin, but increasingly it has been recognized that other antimicrobials can also select for increased rates of VRE carriage.

## Nonstandard Treatment (Key Question 4)

We sought to document the range of treatments under investigation for treatment and prevention of CDI, particularly recurrent CDI. Overall, definitions of CDI, interventions and measured outcomes are variable across the nonstandard prevention and treatment literature.

In attempts to expand treatment options for high rates of treatment nonresponse, treatment failure,206 relapse, and recurrence, researchers and clinicians are examining a number of potential lines of treatment options. The evidence for effectiveness of nonstandard interventions for treating CDI shows that probiotics, prebiotics, C. difficile immune whey, and colestipol are not more effective in treating CDI than standard antibiotic treatment with oral vancomycin or metronidazole or compared with placebo. The evidence supporting this conclusion is limited and of low strength. Administration of a probiotic to treat CDI in critically ill patients increases risk for greater morbidity and mortality from fungemia without any established benefit.

Prevention of CDI, both initial and recurrent cases, through interventions intended to improve gut flora and host immunity is also a very active topic in the literature. Indeed, the majority of ongoing trials accessed through ClinicalTrials.gov are of this type of research. (See the Future Research Needs section and Table 23 following this section.)

There is limited, low-strength evidence that the nonstandard prevention interventions are not more effective than placebo for primary prevention of CDI. There is limited evidence of moderate strength that administering the prebiotic oligofructose or a monoclonal antibody to C. difficile toxins A and B along with standard antibiotics for CDI are better than placebo and active control in preventing recurrence of CDI in patients treated for CDI. Although the studies for both treatment and prevention of CDI using a nonstandard intervention included components of experimental designs, few had adequate rigor to yield high quality findings or power to detect a significant difference between the interventions (or placebo) compared. In some studies, a low rate of CDI precluded statistical testing. Study designs in which probiotics are administered along with standard antibiotics for recurrent CDI result in a combined treatment for recurrent CDI and do not allow for restricted investigation of probiotics as a prevention of CDI recurrence only.

There were five systematic reviews207-210 and one meta-analysis211 about the effectiveness of probiotics for treating CDI, one systematic review about immunoglobulin treatment of CDI,212 and one systematic review included studies about prevention of CDI using probiotics210 (Appendix Table C12).

The five systematic reviews on the effectiveness of probiotics for treating CDI included three to six studies. The authors of the systematic reviews determined that the variability in methods, such as types of probiotics, outcome measures, and types of subjects, did not support pooling estimates in a meta-analysis. The conclusions of the systematic reviews were that there was no evidence (two reviews), sparse evidence (two reviews), and insufficient evidence (one review) of any benefit of probiotics for CDI. The systematic review on probiotics that also addressed prevention of CDI included only one prevention study and concluded there was sparse evidence supporting this use of probiotics. The one meta-analysis of using probiotics for CDI included six studies211 and has been met with criticism. The criticism noted, among other points, the combination of findings from studies of treatment and prevention of adults and children, conducting a pooled analysis on results from heterogeneous outcome measures, analysis of results of studies with low quality due to flawed designs or methods, and lack of independent review as the investigator reviewed their own studies. The conclusion from the meta-analysis was that there was benefit in using a probiotic, especially one containing S. boulardii, for reducing recurrence of CDI. The one systematic review of immunoglobulin was based on four retrospective studies and five case reports and concluded no recommendations could be made.212 This conclusion is supported by the findings of a recent retrospective case series with the largest sample size to date, which showed a higher mortality rate than previously reported.106 The authors suggested that the effect of immunoglobulin may be dependent upon the extent of systematic involvement in CDI.106

Caution is recommended regarding new, nonstandard treatments, and not extrapolating study findings beyond the data. For example, one cannot assume if a probiotic treatment is effective for antibiotic-associated diarrhea that it will be effective for CDI. Likewise, attention should be paid to which patients were included and excluded in probiotic treatment studies. Such studies generally exclude high-risk patients. Thus, there is no evidence for the use of probiotics in high risk patients. During a Technical Expert Panel call it was noted that some intensive care units have banned probiotics in order to avoid the potential for fungemia and bacteremia in very ill patients.

## Future Research

There are a number of important questions to be addressed regarding: (1) how to control both endemic infections and outbreaks; (2) what to do to prevent transmission after occurrence; (3) how to diagnose; (4) how to treat; and (5) how to change prevention strategies with outbreaks. Table 24 provides a summary of the research recommendations.

Table 24 Future research recommendations

Key Question | Research Gaps | Types of Studies Needed to Answer Questions | Future Research Recommendation
Key Question 1. How do different methods for detection of toxigenic C. difficile compare in their sensitivity, specificity, and predictive values? | Few direct comparisons are available. Methodological heterogeneity is an obstacle. Unknown what differences in sensitivity and specificity would alter clinician decisionmaking and patient outcomes. Unknown influence of patient and stool characteristics on differences in test sensitivity and specificity. | Comparison of diagnostic tests using same clinical samples in the same labs. Multicenter studies with well-documented patient samples. | Document stool sample characteristics, patient selection criteria, patient characteristics, signs and symptoms of suspected CDI and effects of differences on patient outcomes.
Key Question 2. What are effective prevention strategies? | Little evidence available with clinically important outcomes. | High-quality comparative studies evaluating effectiveness and harms of single and/or multicomponent prevention strategies, including cleaning, isolation, antibiotic restriction. Discrete simulation models. | Pool data from multiple participating hospital sites. Establish minimum data sets for observational data points that can inform models.
Key Question 3. What are the comparative effectiveness and harms of different antibiotic treatments? | Limited evidence available on whether vancomycin is more effective for severe CDI. | High-quality comparative studies with adequate power to detect significance in a priori subgroups. | A uniform and clinically relevant definition of severity. Subgroup analysis may include age, gender, comorbid conditions. Explicit reporting of adverse events.
Key Question 4. What are the effectiveness and harms of nonstandard adjunctive interventions? | Probiotics as a treatment adjuvant is not supported. Potential harms to seriously ill patients may outweigh potential benefits for further prevention research. Probiotics as prevention warrants further study. Further research of monoclonal antibodies for prevention is warranted. Further research of fecal transplant is warranted. | High-quality comparative studies with adequate power. | Placebo comparators would contribute indirect evidence that would help guide potential combination therapies. Quality research includes power analysis, intention to treat. Multicenter trials are likely needed to achieve adequate samples. Trials of probiotics for prevention are well represented in ongoing studies. Patient characteristics for subgroup analysis.
Umbrella issues | | | Adoption of standard definitions for diarrhea, CDI resolution.

CDI = Clostridium difficile infection

### Diagnostic Tests

It is difficult to apply the available evidence from comparative studies to help select the best diagnostic test(s) for clinical applications. Estimates of sensitivity and specificity for many diagnostics tests for toxigenic C. difficile can vary greatly between laboratories. Further, there is no high-grade evidence from direct, within-laboratory comparisons of the performance of currently available diagnostic tests. The reviewed comparative studies did not clearly define the testing scenario, including the setting, disease prevalence, patient selection criteria, patient characteristics, or the signs and symptoms of the suspected CDI, making it difficult to judge to whom the study results might apply. Ultimately, the clinical importance of estimated differences in sensitivity (true positives), false positives, specificity (true negatives) and false negatives, depends on how these types of test results would affect clinical decisions and patient outcomes.213

More research is needed to understand how test sensitivities and specificities are used to make decisions in clinical practice, and to define clinically meaningful differences based on their effects on clinical decisions and patient outcomes. Multicenter studies that (1) consistently use the most clinically relevant reference test, (2) use explicit clinical criteria to select patients and stool specimens to be tested, (3) randomly assign patients to different diagnostic tests, and (4) use key clinical outcomes as study endpoints are needed to fill this major gap in knowledge about diagnostic tests for toxigenic C. difficile.

Questions about whether the newer gene amplification and detection tests are more consistent across laboratories, and more sensitive than the currently used toxin immunoassays without substantial loss of specificity, need further study. Most importantly, studies are needed to demonstrate that use of tests that detect genetic residue related to C. difficile toxin production rather than the toxins per se lead to better patient outcomes.

### Prevention

A number of potential prevention strategies can, and should, be investigated as a single intervention in a controlled trial in order to understand its potential contribution to a prevention program. However, the main obstacle to research in this area is the contextual setting.

Prevention happens within an institutional environment. It happens as a comprehensive approach for multiple potential hospital-acquired infectious agents and attending to multiple potential vectors of transmission and host susceptibility. Researchers and decisionmakers may need to consider another approach to inform decisionmaking: a collaborative research process in which consensus agreements are reached for minimum data sets and followup periods, and definitions of interventions are agreed to in order to facilitate pooling data across organizations. Efforts to establish and define minimum datasets for surveillance purposes have been undertaken jointly by the Society for Healthcare Epidemiology of America and the Infectious Diseases Society of America.110 Lessons learned from this experience can guide future work in establishing expert and evidence-based minimum dataset projects, aligned with the needs of decisionmakers, consumers, and other stakeholders. Datasets of this nature could allow for employing more sophisticated epidemiological and decision analytic techniques to tease apart the relative contributions of different prevention strategies. Another approach to addressing lack of data to support prevention recommendations is to conduct studies that model C. difficile transmission and the impact the intervention has on interrupting transmission. This may have the additional benefit of identifying new, potentially more effective methods to prevent transmission as well. The nature of the decisions faced by infection control professionals is qualitatively different than a physician's clinical decisions for an individual CDI patient. Decision analytic techniques may be particularly valuable in this venue.

### Standard Treatment

The greatest needs for future studies for CDI treatment are consistent definitions and reporting of outcomes, a uniform and clinically relevant definition of disease severity, and trials with adequate power to detect clinically meaningful differences in outcomes. In particular, trials need to include adequate numbers of subjects to allow stratification by patient characteristics such as age, gender, and comorbid conditions in order to address questions regarding the most effective therapy for CDI. A well validated and clinically meaningful severity score would also assist in treatment decisions. Although most agents for CDI appear to be well tolerated, explicit reporting of adverse events by treatment allocation is another area where future research can improve our understanding of optimal management of this disease.

Although identifying the strain of C. difficile is of great relevance to researchers and can offer useful information to hospital epidemiologists, at present, strain identification is rarely performed in clinical settings. Thus, few clinicians treating CDI know which strain of C. difficile is causing an individual patient's disease and can at most make an assumption as to the strain type based on current epidemiology reported in the literature. This limitation makes any difference by strain in treatment efficacy of uncertain relevance.

### Nonstandard Treatment

Additional research on nonstandard interventions as adjunctive or alternatives to standard antibiotics for preventing and treating CDI is needed and encouraged. Studies to prevent recurrence of C. difficile are a priority of prevention. As no single approach has been shown to be superior, promoting studies of different types of interventions is reasonable at this time.

Fecal flora reconstitution is one novel therapy for which continued research is supported. Findings of one fecal flora reconstitution case show that the colonic microbial profile of the donor temporarily resembles that of the normal donor, which might explain its beneficial effect.126 Guidelines related to screening for safety and selecting donors that would need to be considered in future studies have been outlined.214 Of all the nonstandard interventions, probiotics have been investigated in the most studies, and the results are not encouraging. Unlike fecal flora reconstitution, probiotics provide only a single or few strains of bacteria, and thus may be insufficient to correct alterations in the complex and extensive microbiome to the extent needed be therapeutic. The genomic mapping of indigenous microflora may offer new information to guide future formulation of a probiotic that can effectively target alterations in the microbiome in CDI and other diseases of the colon.215,216 A third strategy related to modifying microbial ecology in CDI for which additional research is supported is administration of a nontoxigenic strain of C. difficile. Colonization with nontoxigenic C. difficile in hamsters protects against C. difficile disease after challenge with a toxigenic strain. The nontoxigenic strain of C. difficile is thought to directly compete with toxigenic strains of C. difficile.

Developing agents to treat severe cases of refractory CDI is another area in need of research. Identifying new antibiotics may be one approach. Two of the larger case series of immunoglobulin use are in severely ill patients, and results are inconsistent.105,106 Whether immunoglobulin might confer greater benefit if initiated earlier in the course of CDI prior to extensive systemic involvement is an area for further study.

Studies are needed to determine whether some patients might be more likely to respond to nonstandard interventions. Sampling in current studies of nonstandard interventions varies considerably, ranging from individuals who are just starting antibiotics for infections other than C. difficile, to those who have had multiple failures of antibiotic treatment for CDI itself, to those who have had C. difficile in the past. Whether any one type of nonstandard intervention is effective in all of these types of cases is a question. More information is needed about patients who are at high risk for recurrence of CDI.

The effects of sequencing therapies (antibiotic as well as nonstandard) on the resolution of CDI merits further research. Studies show a variety of procedures for administering probiotics to prevent CDI, such as during standard antibiotic therapy or for a period after standard treatment is completed. Determining the optimal timing to introduce nonstandard interventions to possibly maximize their effect is recommended. For example, studies in hamsters indicate that timing of administration of a nontoxigenic strain of C. difficile for successful colonization as potential protection against disease differs depending on whether the animal is receiving antibiotics to which C. difficile is susceptible or resistant.217

#### Methodological Improvements

It is essential that future studies of a nonstandard intervention for treatment or prevention of CDI be supported by a power analysis, adequate sample size, and an intent-to-treat analysis, in addition to other standard quality components of experimental design. Study designs must separate interventions for prevention versus treatment of recurrent CDI if this approach is desired. Multicenter studies may be necessary to achieve adequate sample sizes. Laboratory confirmation of a pathogenic C. difficile organism (e.g., by toxin testing) and clinical symptoms of disease (e.g., diarrhea) are essential not only for study eligibility but for determination of recurrence in long-term followup. Adoption of a standard definition of diarrhea as part of the definition of CDI is strongly recommended. Similarly, a standard definition of CDI resolution should be adopted. RCTs that compare more than one type of nonstandard intervention are suggested for efficiency.

Other organizations have also examined research gaps based on literature reviews and expert opinion. Key research issues identified during the Clostridium difficile Symposium on Emerging Issues and Research, convened in 2004, provides further information on research gaps.152 While many of the issues identified in the symposium are beyond the scope of this review, they merit mention. Table 23 provides a list of 23 relevant ongoing or recently completed trials not yet published for the diagnosis, prevention, and treatment of CDI. While there is considerable activity, none of the studies listed is expected to provide a definitive answer for any of the research needs discussed above. More studies that compare toxin gene detection tests to other diagnostic tests for toxigenic C. difficile are forthcoming and may support the notion that the gene detection tests are generally more sensitive.