# Results

The general search identified 1,078 citations from MEDLINE. Of these, 356 studies were pulled for full text screening. Of these 356 references, we included 69 randomized controlled trials (RCTs), systematic reviews, observational studies, and an additional 22 articles obtained from hand searching and review article bibliographies. We excluded 998 articles. A supplemental search for diagnostics identified 519 citations from MEDLINE, of which 516 references were excluded. Figure 4 provides a literature flow diagram. A bibliography of the excluded articles, and their reasons for exclusion, is provided in Appendix D.

Figure 4 Reference flow diagram

KQ = Key Question

Figure 4 is a flow diagram depicting the number of articles generated in the initial search and their travel through the screening process to final disposition for included or excluded status.

## Key Question 1 How do Different Methods for Detection of Toxigenic C. difficile Compare in Their Sensitivity and Specificity?

### Search Results

We included 13 references that provided comparative data about diagnostic tests of interest. The studies were published from 2001 to 2010. Five studies were from the United States, two were from the United Kingdom and Spain, and one each were from Belgium, Ireland, Israel, and the Netherlands. Table 1 provides a summary of the available comparisons. Overall, these reports included data on seven named immunoassays for toxins A and B, one two-stage method where an immunoassay for glutamate dehydrogenase was combined with an immunoassay for toxins A and B, and two tests to detect gene fragments involved in the production of toxin B. Only three comparative studies included one of the recently FDA-approved toxin gene detection tests. Thus, the number and type of paired (within study) comparisons available for each diagnostic test varied considerably, and not all possible comparisons were available. Evidence summary tables, including study quality items, are available in Appendix C of this report (see Appendix Table C1).

Table 1 Summary of diagnostic comparisons in included studies

Diagnostic Test | Premier Toxin A&B, Meridian | Tox A/B II, TechLab | Tox A/B QUIK CHEK, TechLab | ImmunoCard A&B, Meridian | Xpect Toxin A/B, Remel | ProSpecT Toxin A/B, Remel | C. diff Tox A/B, VIDAS
A and B Toxin Immunoassays
Premier Toxin A&B, Meridian | n/a | 4 studies | 1 study | 3 studies | 2 studies | 2 studies | 2 studies
Tox A/B II, TechLab | none | n/a | 2 studies | 2 studies | none | none | none
Tox A/B QUIK CHEK, TechLab | none | none | n/a | 4 studies | 3 studies | 1 study | 1 study
ImmunoCard A&B, Meridian | none | none | none | n/a | none | | 1 study
Xpect Toxin A/B, Remel | none | none | none | none | n/a | 1 study | 1 study
ProSpecT Toxin A/B, Remel | none | none | none | none | none | n/a | 1 study
C. diff Tox A/B, VIDAS | none | none | none | none | none | none | n/a
Gene Detection Tests
GeneOhm, Becton Dickinson | 1 study | 2 studies | 1 study | 1 study | 1 study | 1 study | 2 studies
GeneXpert, Cepheid | 1 study | none | none | none | none | none | 1 study

### Key Points

- Sixteen paired comparisons of seven immunoassays for toxins A and B provided low-grade evidence that the test sensitivities do not differ. There was moderate-grade evidence for no differences in test specificities for three comparisons and for a difference of 2 percent in one comparison. Otherwise, there was only low-grade evidence for or against differences in test specificities. There was insufficient evidence of differences between all tests that were not directly compared.
- Nine comparisons of two different gene detection tests to toxin immunoassays provided only low-grade evidence to support the notion that the gene-based tests are substantially more sensitive than immunoassays. There was moderate evidence that the test specificities in one comparison did not differ. Otherwise, there was only low-grade evidence for differences in either direction between test specificities. There was insufficient evidence of differences between all tests that were not directly compared.
- There was insufficient evidence to determine whether any differences in sensitivity or specificity between diagnostic tests depend on patient or specimen characteristics or the strain of toxigenic Clostridium difficile.

### Quality of the Comparative Studies

All studies used stool specimens from mostly inpatients that were submitted by clinicians to test for Clostridium difficile infection (CDI). However, the clinical scenarios that prompted the clinicians to test for CDI, such as the nature of the patient's diarrhea, or exposure to antibiotics, were not described in many reports. Seven of the 13 studies that provided data mentioned that the stool samples were liquid, unformed, or diarrhea, whereas the other reports did not clearly describe the consistency of the stool specimens. Six of the studies included more than one specimen from some patients, and three studies only reported the total number of stool specimens and not the number of patients. Two studies selected stool samples based on previous diagnostic test results to enhance the percentage of positive tests in their sample, and two included a facility with a recent outbreak of CDI or high prevalence. Thus, the reviewed reports were somewhat deficient in reporting pertinent information about patient selection criteria and the spectrum of patients/specimens included the comparisons (Appendix Table C2).

Differences within studies in the timing and handling of specimens for the different tests being compared were not a major issue in the reviewed studies. Verification using the reference standard was applied consistently to all stool specimens. However, the same reference standard was not used in all studies. Five of the 13 studies used a cell cytotoxicity test as the reference, five used a cell cytotoxicity test in conjunction with toxigenic culture, one used a toxin immunoassay in conjunction with toxigenic culture, one used multiple immunoassays for toxins A and B in conjunction with toxigenic culture, and one used an in-house gene detection test. None of the reference methods that were used are a true gold standard in that they are not 100 percent sensitive or specific for toxigenic C. difficile and their accuracies are not all the same. Within each study, the diagnostic tests were carried out independently of each other although the reports usually did not state that each test was interpreted without knowledge of other results. Only two reports explicitly stated that all diagnostic tests being compared, including the reference test, were conducted in a blinded manner. Sometimes the independence of the tests could be inferred from their sequence and the time needed to get results.

The handling of indeterminate test results presents problems when comparing the sensitivity and specificity of diagnostic tests. Some investigators repeated indeterminate tests and used the result of the second test as recommended, although some repeated tests were also indeterminate. Some assumed indeterminate results were negative and thereby could have inflated the number of false negatives. Some comparisons excluded indeterminate results; thus, the varying number of indeterminate tests did not count for or against a test. However, differences in the number of indeterminate results produced by different tests resulted in some differences in the stool specimens being used to compare the tests. Other types of subject or specimen withdrawal were not an issue in the studies that were reviewed.

### Detailed Analysis

#### Comparisons of Immunoassays for Toxins A and B

As summarized in Table 2, none of the seven immunoassays for toxins A and B was compared to all others. When more than one study compared the same two immunoassays, the heterogeneity in the differences in sensitivity was significant in only one out of nine cases. None of the nine pooled comparisons based on two to four studies indicated that any of the immunoassays were more sensitive than another. The pooled estimates of the differences (99 percent confidence interval [CI]) in test sensitivities were 0±6 percent, 1±7 percent, 3±6 percent, 3±7 percent, -1±10 percent, 3±8 percent, 6±12 percent, 1±9 percent, and 3±24 percent. The confidence intervals for single-study estimates of differences in sensitivity were wide. Thus, the available data often could not rule out substantial differences in sensitivities.

Table 2 Comparisons of immunoassays for toxins A and B

Study | Sensitivity (% True Positive) | | | % False Positives (1 Minus Specificity)
Study | Toxin Immunoassay X | Toxin Immunoassay Y | % Difference | Toxin Immunoassay X | Toxin Immunoassay Y | % Difference
Eastwood, 2009^32^ Musher, 2007^33^ Turgeon, 2003^38^ O'Connor, 2001^36^ Pooled Estimate heterogeneity^†^ | [underlined: Premier Toxin A&B, Meridian] 101/125 (80.8%) 52/54 (96.3%) 74/101 (73.3%) 50/61 (82.0%) | [underlined: Tox A/B II, TechLab] 100/125 (80.0%) 52/54 (96.3%) 78/101 (77.2%) 49/61 (80.3%) | 1 (-12 to 14)^*^ 0 (-9 to 9) -4 (-20 to 12) 2 (-17 to 20) 0 (-7 to 6) p=0.92;I^2^=0% | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) 5/77 (6.5%) 8/898 (0.9%) 1/139 (0.7%) | [underlined: Tox A/B II, TechLab] 19/475 (4.0%) 10/77 (13.0%) 5/902 (0.6%) 1/139 (0.7%) | -1 (-4 to 1) -6 (-19 to 6) 0 (-1 to 1) 0 (-3 to 3) 0 (-3 to 2) p=0.06;I^2^=60%
Eastwood, 2009^32^ Alcala, 2008^31^ Miendje Deyi, 2008^39^ Samra, 2008^34^ Pooled Estimate heterogeneity | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74.4%) 56/102 (54.9%) 22/23 (95.7%) 89/94 (94.7%) | [underlined: ImmunoCard A&B, Meridian] 86/115 (74.8%) 68/102 (66.7%) 21/23 (91.3%) 89/94 (94.7%) | 0 (-15 to 14) -12 (-29 to 6) 4 (-14 to 23) 0 (-8 to 8) -1 (-9 to 6) p=0.26;I^2^=25% | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) 12/265 (4.5%) 0/77 (0%) 3/106 (2.8%) | [underlined: ImmunoCard A&B, Meridian] 2/444 (0.4%) 13/265 (4.9%) 0/77 (0%) 3/106 (2.8%) | 0 (-1 to 1) 0 (-5 to 4) 0 (-3 to 3) 0 (-6 to 6) 0 (-1 to 1) p=0.98;I^2^=0%
Eastwood, 2009^32^ Sloan, 2008^35^ Musher, 2007^33^ Pooled Estimate heterogeneity | [underlined: Premier Toxin A&B, Meridian] 101/125 (80.8%) 21/44 (47.7%) 75/76 (98.7%) | [underlined: ImmunoCard A&B, Meridian] 86/115 (74.8%) 21/44 (47.7%) 73/76 (96.1%) | 6 (-8 to 20) 0 (-27 to 27) 3 (-4 to 9) 3 (-3 to 9) p=0.77;I^2^=0% | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) 3/156 (1.9%) 10/370 (2.7%) | [underlined: ImmunoCard A&B, Meridian] 2/444 (0.4%) 2/156 (1.3%) 4/370 (1.1%) | 2 (0 to 4) 1 (-3 to 4) 2 (-1 to 4) 2 (0 to 3) p=0.67;I^2^=0%
Eastwood, 2009^32^ Alcala, 2008^31^ Miendje Deyi, 2008^39^ Pooled Estimate heterogeneity | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74.4%) 56/102 (54.9%) 22/23 (95.7%) | [underlined: Xpect Toxin A/B, Remel] 86/117 (73.5%) 50/102 (49.0%) 21/23 (91.3%) | 1 (-14 to 15) 6 (-12 to 24) 4 (-14 to 23) 3 (-6 to 13) p=0.84;I^2^=0% | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) 12/265 (4.5%) 0/77 (0%) | [underlined: Xpect Toxin A/B, Remel] 3/475 (0.6%) 11/265 (4.2%) 0/77 (0%) | 0 (-1 to 1) 0 (-4 to 5) 0 (-3 to 3) 0 (-1 to 1) p=0.96;I^2^=0%
Eastwood, 2009^32^ Samra, 2008^34^ Pooled Estimate heterogeneity | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74.4%) 89/94 (94.7%) | [underlined: Tox A/B II, TechLab] 100/125 (80.0%) 88/94 (93.6%) | -6 (-19 to 8) 1 (-8 to 10) -1 (-11 to 8) p=0.22;I^2^=35% | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) 3/106 (2.8%) | [underlined: Tox A/B II, TechLab] 19/475 (4.0%) 6/106 (5.7%) | -3 (-6 to -1) -3 (-10 to 4) -3 (-6 to -1) p=0.85;I^2^=0%
Eastwood, 2009^32^ Musher, 2007^33^ Pooled Estimate heterogeneity | [underlined: Premier Toxin A&B, Meridian] 101/125 (80.8%) 52/54 (96.3%) | [underlined: ProSpecT Toxin A/B, Remel] 102/125 (81.6%) 49/54 (90.7%) | -1 (-14 to 12) 6 (-7 to 8) 3 (-6 to 11) p=0.31;I^2^=4% | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) 5/77 (6.5%) | [underlined: ProSpecT Toxin A/B, Remel] 32/475 (6.7%) 2/77 (2.6%) | -4 (-8 to -1) 4 (-5 to 13) -1 (-11 to 10) p=0.02;I^2^=80%
Eastwood, 2009^32^ Sloan, 2008^35^ Pooled Estimate heterogeneity | [underlined: Premier Toxin A&B, Meridian] 101/125 (80.8%) 21/44 (47.7%) | [underlined: Xpect Toxin A/B, Remel] 86/117 (73.5%) 21/44 (47.7%) | 7 (-7 to 21) 0 (-27 to 27) 6 (-7 to 18) p=0.54;I^2^=0% | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) 3/156 (1.9%) | [underlined: Xpect Toxin A/B, Remel] 3/475 (0.6%) 25/156 (16.0%) | 2 (0 to 4) -14 (-22 to -6) - 6 (-32 to 20) p=0.0001;I^2^=97%
Eastwood, 2009^32^ Samra, 2008^34^ Pooled Estimate heterogeneity | [underlined: Tox A/B II, TechLab] 100/125 (80.0%) 88/94 (93.6%) | [underlined: ImmunoCard A&B, Meridian] 86/115 (74.8%) 89/94 (94.7%) | 5 (-9 to 19) -1 (-10 to 8) 1 (-8 to 10) p=0.25;I^2^=24% | [underlined: Tox A/B II, TechLab] 19/475 (4.0%) 6/106 (5.7%) | [underlined: ImmunoCard A&B, Meridian] 2/444 (0.4%) 3/106 (2.8%) | 4 (1 to 6) 3 (-4 to 10) 3 (1 to 6) p=0.80;I^2^=0%
Eastwood, 2009^32^ van den Berg, 2007^162^ Pooled Estimate heterogeneity | [underlined: Premier Toxin A&B, Meridian] 101/125 (80.8%) 30/31 (96.8%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 100/116 (86.2%) 26/31 (83.8%) | -5 (-18 to 7) 13 (-6 to 32) 3 (-21 to 27) p=0.03;I^2^=78% | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) 29/509 (5.7%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 2/464 (0.4%) 15/509 (2.9%) | 2 (0 to 4) 3(-1 to 6) 2 (1 to 4) p=0.62;I^2^=0%
Eastwood, 2009^32^ | [underlined: Premier Toxin A&B, Meridian] 101/125 (80.8%) | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74.4%) | 6 (-7 to 20) | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) | 2 (0 to 4)
Eastwood, 2009^32^ | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74.4%) | [underlined: ProSpecT Toxin A/B, Remel] 102/125 (81.6%) | -7 (-21 to 6) | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) | [underlined: ProSpecT Toxin A/B, Remel] 32/475 (6.7%) | -6 (-9 to -3)
Eastwood, 2009^32^ | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74.4%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 100/116 (86.2%) | -12 (-25 to 1) | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 2/464 (0.4%) | 0 (-1 to 1)
Eastwood, 2009^32^ | [underlined: Xpect Toxin A/B, Remel] 86/117 (73.5%) | [underlined: ProSpecT Toxin A/B, Remel] 102/125 (81.6%) | -8 (-22 to 6) | [underlined: Xpect Toxin A/B, Remel] 3/475 (0.6%) | [underlined: ProSpecT Toxin A/B, Remel] 32/475 (6.7%) | -6 (-9 to -3)
Eastwood, 2009^32^ | [underlined: Xpect Toxin A/B, Remel] 86/117 (73.5%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 100/116 (86.2%) | -13 (-26 to 1) | [underlined: Xpect Toxin A/B, Remel] 3/475 (0.6%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 2/464 (0.4%) | 0 (-1 to 1)
Eastwood, 2009^32^ | [underlined: ProSpecT Toxin A/B, Remel] 102/125 (81.6%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 100/116 (86.2%) | -5 (-17 to 8) | [underlined: ProSpecT Toxin A/B, Remel] 32/475 (6.7%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 2/464 (0.4%) | 6 (3 to 9)
Alcala, 2010^164^ | [underlined: ImmunoCard A&B, Meridian] 42/62 (67.7%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 43/62 (69.4%) | -2 (-23 to 20) | [underlined: ImmunoCard A&B, Meridian] 21/425 (4.9%) | [underlined: VIDAS C. diff Tox A/B, bioMerieux] 8/425 (1.9%) | 3 (0 to 6)

* Values in parentheses are 99% confidence intervals for the difference between tests conservatively assuming statistical independence between the paired tests.

† The p-value is a chi-square test for nonrandom variation in the differences between studies, and I^2^ is the proportion of the total variance in the estimated differences that reflects true variation (i.e. heterogeneity between studies).

There was some significant heterogeneity in the corresponding estimates of differences in false positives (1 minus specificity) for two of the nine multiple study comparisons of immunoassays for toxins A and B. Ignoring the heterogeneity, the differences (99 percent CI) in false positives were 0±2 percent, 0±1 percent, 2±1 percent, 0±1 percent, -3±3 percent, -1±10 percent, -6±14 percent, 3±2 percent, and 2±2 percent. Thus, the available data often ruled out differences in false positives of only a few percent. One study that compared several immunoassays found some differences in the false positives of approximately 6 percent.

#### Gene Detection Tests Versus Immunoassays for Toxins A and B

As summarized in Table 3, two studies compared the same tests to detect genes related to toxin B production to the same immunoassay for toxins A and B.32,37 There was significant heterogeneity between the estimated differences in sensitivities for both comparisons; however, in each case both studies suggested the gene-based test was more sensitive than the immunoassay. The pooled estimate of the difference in sensitivities was 17 percent in favor of the gene based test with a 99 percent confidence interval of from 3 to 37 percent in one comparison, and 25 with a 99 percent confidence interval of from -36 to 86 percent in the other comparison. There was no heterogeneity in the corresponding estimated differences in false positive percentages of these tests. The pooled estimate of the differences in the false positives were 0 percent with a 99 percent confidence interval of from 1 percent to 1 percent for one comparison, and 2 with a 99 percent confidence interval of from -1 percent to 5 percent for the other comparison. The percentage of false positives tended to be greater with the gene detection test in the later comparison.

Table 3 Toxin gene detection tests compared to immunoassays

Study | Sensitivity (% True Positives) | | | % False Positives (1 Minus Specificity)
Study | Toxin Gene Test | Toxin Immunoassay | % Difference | Toxin Gene Test | Toxin Immunoassay | % Difference
Kvach, 2010^37^ Eastwood, 2009^32^ Pooled Estimate heterogeneity^†^ | [underlined: GeneOhm, Becton Dickinson] 96/105 (91%) 92/103 (89%) | [underlined: Tox A/B II, TechLab] 70/105 (67%) 100/125 (80%) | 25 (11 to 39)^*^ 9 (-3 to 21) 17 (-3 to 37) p=0.03; I^2^=79% | [underlined: GeneOhm, Becton Dickinson] 0/295 (0%) 16/449 (3.6%) | [underlined: Tox A/B II, TechLab] 1/295 (0.3%) 19/475 (4.0%) | 0 (-4 to 3) 0 (-2 to 1) 0 (-1 to 1) p=0.90; I^2^=0%
Swindells, 2010^165^ Eastwood, 2009^32^ Pooled Estimate heterogeneity^†^ | [underlined: GeneOhm, Becton Dickinson] 17/18 (94.4%) 92/103 (89%) | [underlined: VIDAS Clostridium difficile A and B, bioMerieux] 8/18 (44.4%) 100/116 (86%) | 50 (17 to 83) 3 (-8 to 14) 25 (-36 to 86) p<0.001; I^2^=92% | [underlined: GeneOhm, Becton Dickinson] 1/132 (0.8%) 16/449 (3.6%) | [underlined: VIDAS Clostridium difficile A and B, bioMerieux] 0/132 (0%) 2/464 (0.4%) | 1 (-2 to 3) 3 (1 to 6) 2 (-1 to 5) p=0.07; I^2^=70%
Eastwood, 2009^32^ | [underlined: GeneOhm, Becton Dickinson] 92/103 (89%) | [underlined: Premier Toxin A&B, Meridian] 101/125 (81%) | 9 (-3 to 21) | [underlined: GeneOhm, Becton Dickinson] 16/449 (3.6%) | [underlined: Premier Toxin A&B, Meridian] 12/475 (2.5%) | 1 (-2 to 4)
Eastwood, 2009^32^ | [underlined: GeneOhm, Becton Dickinson] 92/103 (89%) | [underlined: ImmunoCard A&B, Meridian] 86/115 (75%) | 15 (1 to 28) | [underlined: GeneOhm, Becton Dickinson] 16/449 (3.6%) | [underlined: ImmunoCard Toxin A&B, Meridian] 2/444 (0.4%) | 3 (1 to 6)
Eastwood, 2009^32^ | [underlined: GeneOhm, Becton Dickinson] 92/103 (89%) | [underlined: Tox A/B QUIK CHEK, TechLab] 93/125 (74%) | 15 (2 to 28) | [underlined: GeneOhm, Becton Dickinson] 16/449 (3.6%) | [underlined: Tox A/B QUIK CHEK, TechLab] 3/473 (0.6%) | 3 (0 to 5)
Eastwood, 2009^32^ | [underlined: GeneOhm, Becton Dickinson] 92/103 (89%) | [underlined: ProSpecT Toxin A/B, Remel] 102/125 (82%) | 8 (-4 to 20) | [underlined: GeneOhm, Becton Dickinson] 16/449 (3.6%) | [underlined: ProSpecT Toxin A/B, Remel] 32/475 (6.7%) | -3 (-7 to 1)
Eastwood, 2009^32^ | [underlined: GeneOhm, Becton Dickinson] 92/103 (89%) | [underlined: Xpect Toxin A/B, Remel] 86/117 (74%) | 16 (3 to 29) | [underlined: GeneOhm, Becton Dickinson] 16/449 (3.6%) | [underlined: Xpect Toxin A/B, Remel] 3/475 (0.6%) | 3 (0 to 5)
Swindells 2010^165^ | [underlined: GeneXpert, Cepheid] 18/18 (100%) | [underlined: VIDAS Clostridium difficile A and B, bioMerieux] 8/18 (44.4%) | 56 (25 to 86) | [underlined: GeneXpert, Cepheid] 1/132 (0.8%) | [underlined: VIDAS Clostridium difficile A and B, bioMerieux] 0/132 (0%) | 1 (-1 to 3)
Novak-Weekly, 2010^40^ | [underlined: GeneXpert, Cepheid] 68/72 (94%) | [underlined: Premier Toxin A&B, Meridian] 42/72 (58%) | 36 (20 to 53) | [underlined: GeneXpert, Cepheid] 13/356 (3.7%) | [underlined: Premier Toxin A&B, Meridian] 19/360 (5.3%) | -2 (-6 to 2)

* Values in parentheses are 99% confidence intervals for the difference between tests conservatively assuming statistical independence between the paired tests.

† The p-value is a chi-square test for nonrandom variation in the differences between studies, and I^2^ is the proportion of the total variance in the estimated differences that reflects true variation (i.e. heterogeneity between studies).

Three studies provided one pairwise comparisons of a gene detection test to an immunoassay for toxins A and B.32 The sensitivity of the gene detection test was consistently better, although the point difference ranged widely from 3 percent to 56 percent, and the confidence intervals didn't always exclude a difference of zero. The false positives for the gene-based test were approximately 3 percent greater compared to one of the immunoassays for toxins A and B.

The sensitivities of the two gene detection tests in the three studies ranged from 89 percent to 100 percent. In contrast, the sensitivities of the immunoassays for toxins A and B were much more variable, ranging from 44 percent to 86 percent. The methodological differences between studies, including use of different reference tests, might have affected the toxin immunoassays more than the gene detection tests. The estimated sensitivities of the immunoassays were remarkably low (only 44 or 58 percent) in two studies that used the generally most sensitive reference test (toxigenic culture).

## Key Question 2 What are Effective Prevention Strategies?

### Search Results

We found 1 Cochrane review,41 4 studies on antibiotic prescribing restrictions,42-45 12 on single preventive practices aimed at transmission interruption,46-55,67 and 10 that bundled multiple practices into a prevention strategy.56-65 Only two trials were controlled trials;46,49one was an interrupted time series study,42,66and the remaining studies were before/after designs.43-45,47,48,50-55,66,67 The included studies are provided in Table 4.

Table 4 Prevention interventions

Author/Year Country | Study Design | Population | Intervention | Outcome | Findings | Quality Issues
Antibiotic Use
Fowler, 2007^42^ UK | Prospective interrupted time series | Acute medical wards, elderly | Switch from broad to narrow spectrum antibiotics | CDI incidence | Incidence rate decreased (0.35, 95% CI 0.17 to 0.73) | No concurrent controls
Davey, 2005^41^ UK | Cochrane Review five included studies | Hospital inpatients | Improve antibiotic prescribing practices | CDI incidence | Four interventions were associated with significant reductions in CDI | Only one study was judged to be of “good” quality
O'Connor, 2004^44^ | Before–after | Geriatric unit N = 17 cases in 683 patients | Change in antibiotic policy; education, monitoring, feedback | CDI incidence | CDI rate decreased significantly. Use of restricted antibiotic decreased. RR 0.31 (95% CI 0.93 to 0.10) | Retrospective
Wilcox, 2004^43^ | Before–after time series | Elderly Medicine Unit inpatients | Change in antibiotic policy | CDI incidence | Use of restricted antibiotic decrease | No concurrent control
Ludlam, 1999^45^ UK | Prospective before–after time series | Hospital N = 4,284 | Change in antibiotic policy | CDI incidence | CDI rate decreased 50%. Use of restricted antibiotic decreased 92% | Patients on wards were antibiotic policy was unchanged acted as controls
Transmission Interruption – Gloves
Johnson, 1990^178^ USA | Controlled trial | | Education program to use gloves | CDI incidence | CDI incidence decreased from 7.7 cases/1,000 patient discharges to 1.5/1,000 discharges | Not randomized or blinded
Transmission Interruption – Disposable Thermometers
Brooks, 1992^47^ and 1998^48^ USA | Time series (before– after) | Hospital and long-term care | Single use thermometers | CDI incidence | Decrease in incidence: acute care – from 2.71/1,000 patient days to 1.76/1000 Long term-care – from 0.41/1,000 patient days to 0.11/1,000 patient days | No concurrent controls
Jernigan, 1998^49^ USA | Crossover RCT | Hospital patients admitted to 20 nursing units | Disposable thermometers versus electronic thermometers | Rate of nosocomial CDI | CDI rates were reduced 44% (95% CI, 21 to 93) with disposable thermometers compared with electronic thermometers. Rates of nosocomial diarrhea or nosocomial infections did not differ significantly between the two groups. | Two wards elected not to use disposable thermometers
Transmission Interruption – Hand washing
Kaier, 2009^52^ Germany | Before–after time series analysis | Tertiary care teaching hospital | Alcohol-based gel | CDI incidence | No association between alcohol-based hand rub and CDI incidence | Retrospective, no concurrent control
Vernaz, 2008^66^ Switzerland | Before–after time series analysis | Primary and tertiary care teaching hospital | Promotional campaigns to encourage use of alcohol-based hand rub | CDI incidence | No association between alcohol-based hand rub and CDI incidence | Retrospective, no concurrent control
Rupp, 2008^50^ USA | Controlled crossover trial | Adult medical-surgical ICUs | Alcohol-based gel | CDI incidence | Use of gel adherence rates increased from 37% to 68%. No change in CDI rates | Not blinded
Gordin, 2005^51^ USA | Before–after | Hospital | Alcohol-based gel | CDI incidence | No change in CDI rates
Transmission Interruption – Disinfection
Hacek 2010^67^ | Before–after | Hospital patients | Hypochlorite solution for patient room cleaning | CDI incidence | 48% reduction in CDI rates. (P<.0001, 95% CI 36–58%) | No concurrent controls
Mayfield, 2000^53^ USA | Before–after | 3 hospital units; one unit with high incidence, 2 with lower | Hypochlorite solution for patient room cleaning | CDI incidence | High incidence unit- CDI decreased from 8.6/1,000 patient days to 3.3/1,000 patient days. No change in other units | No concurrent controls
Kaatz, 1988^54^ USA | Outbreak | Hospital patients | Hypochlorite solution for patient room cleaning | CDI incidence | Contamination decreased and the outbreak ended. Phosphate-buffered hypochlorite was effective for disinfection. | Before–after design in the setting of an epidemic
Struelens, 1991^55^ | Before–after | Hospital patients | Intensive cleaning measures, aldehydes | CDI incidence | Protective efficacy 73% (95% CI 46–87%) | No concurrent controls
Multiple Interventions
Abbett, 2009^56^ USA | Prospective before–after study | Hospital patients | Infection control practices, laboratory notification procedures, and steps coordinate infection control and environmental services aimed to decrease the transmission of C. difficile between patients (i.e., a prevention checklist) | CDI incidence | Use of a checklist of hospital interventions to decrease the incidence of healthcare-associated CDI | No concurrent control
Boyce, 2008^57^ USA | Before–after time series | Hospital | Liquid vapor hydrogen peroxide decontamination system | CDI incidence | Nosocomial CDI incidence decreased and remained at lower levels | No concurrent control
Drudy, 2007^60^ Ireland | Prospective time series (before–after) | Hospital patients | Antimicrobial use, enhanced surveillance, education, hand hygiene, equipment, intensified environmental cleaning | CDI incidence | CDI incidence decreased from a peak of 21 cases/1,000 patient admissions to 5/1,000 patient admissions | No concurrent controls
Valiquette, 2007^63^ Canada | Retrospective time series (before–after) | Hospital patients | Antimicrobial use, education, isolation, equipment, intensified environmental cleaning | CDI incidence | Nonrestrictive measures to optimize antibiotic usage (leading to decreases in usage) led to a decrease in CDI incidence by 60% | Retrospective, no concurrent control
Whitaker, 2007^65^ USA | Prospective time series (before–after) | Hospital patients | Antimicrobial use, education, isolation, automated report functions, and standardized nursing unit isolation processes | CDI incidence | 66% reduction in the number of healthcare-associated CDI cases was achieved during the study | No concurrent controls
Zafar, 1998^64^ USA | Prospective time series (before–after) | Hospital patients | Isolation, patient/staff movement, hand hygiene, patient room practices, intensified environmental cleaning | CDI incidence | Incidence of CDI decreased by 60% from 1990 to 1996 following use of comprehensive infection control measures. | No concurrent controls
McNulty, 1997^61^ UK | Retrospective time series (before–after) | Hospital patients, elderly care unit | Antimicrobial use, isolation, patient/staff movement, hand hygiene, patient room practices, intensified environmental cleaning | CDI incidence | Thirty-seven cases of CDI occurred in the period before and 16 in the period after policy change (combined approach of infection control and strict antibiotic policies). | Retrospective, no concurrent control
Cartmill, 1994^59^ UK | Prospective time series (before–after) | Hospital patients | Antimicrobial use, enhanced surveillance, isolation, patient/staff movement, intensified environmental cleaning | CDI incidence | Subsequent to the intervention measures, there was a substantial and sustained decreased in the incidence of CDI | No concurrent controls
Pear, 1994^62^ USA | Prospective time series (before–after) | Hospital patients (Veterans Affairs) | Antimicrobial use, education, isolation, patient room practices, intensified environmental cleaning | CDI incidence | Nosocomial epidemic of CDI was controlled by analysis of antibiotic use patterns and by subsequent restriction of clindamycin | No concurrent controls
Brown, 1990^58^ USA | Retrospective time series (before–after) | Hospital patients | Antimicrobial policy, isolation | CDI incidence | CDI attack rate dropped progressively | Retrospective, no concurrent control

CDI = Clostridium difficile infection; CI = confidence interval; ICU = intensive care unit; RR = relative risk

Eight studies examining risk factors met the inclusion criteria and updated the period following a systematic review20 (Appendix Table C3). Five studies were conducted in the United States,111,166-169 two in Israel,112,170and one in the United Kingdom.171 The average CDI patient sample was 86 patients, with a range of 28 to 154. Studies varied in the degree to which the investigators verified that positive tests reflected disease.

### Key Points

- Overall, the evidence available to link prevention strategies to clinically important outcomes, such as CDI incidence, is of low strength and is not extensive.
- Four observations studies and one Cochrane review found prescribing practice interventions decreasing the use of high-risk antimicrobials are associated with decreased CDI incidence. Prescribing practices were also used in multicomponent interventions credited with reducing CDI incidence; however, it is difficult to isolate the specific effects of the prescribing practices.
- One controlled trial found glove use significantly reduced CDI incidence.
- Three observational studies, including two controlled, found disposable thermometer use is likely to reduce CDI incidence.
- No study examined the effect of handwashing, rather than alcohol gels, on CDI incidence. Four observational studies found use of alcohol gels as interventions for other infectious diseases, presumably in the presence of protocols requiring handwashing in the presence of CDI or visible soiling, did not increase CDI incidence.
- Three studies provide low evidence that disinfection with a chemical compound that kills C. difficile spores in the hospital environment prevents CDI, at least in epidemic or hyperendemic settings. Seven studies included disinfection in multicomponent interventions. Disinfection agents examined included hypochlorite solution, hydrogen peroxide, aldehydes, and detergent.
- Ten time series/before-after studies have examined bundled multiple interventions using before/after study designs. Data are insufficient to draw conclusions.
- Risk factors for developing CDI include antibiotic use, substantial chronic illness, hospitalization in an ICU, age, and acid suppression therapy.
- No data on patient harms or harms to hospital staff due to preventive interventions were reported.
- No studies assessed the sustainability of a prevention program beyond an intervention period.

### Quality of the Studies

Overall, the quality of the evaluated studies was considered low (Table 4). In the Cochrane review41 focusing on improving antibiotic prescribing practices, the evidence from one article172 was judged to be of “good” quality, and evidence from the others was considered “weak.” The evidence for the 10 single preventive practices aimed at transmission interruption was low because they predominately used before/after design and were done in response to epidemic or hyperendemic conditions. In particular, there is insufficient evidence that handwashing is associated with reduced CDI incidence, as no study assessed this intervention. Of the four studies assessing alcohol based rubs or gels, only one had concurrent controls. Thirteen studies examining environmental disinfections were all before/after studies, generally done in response to epidemics.

For the 10 articles that described multiple component preventive interventions, none had concurrent controls or was blinded, and there was considerable variability in the types of interventions, so pooling could not be done. In addition, it was indeterminable to attribute decreases in CDI incidence to any single intervention in all of these studies.

### Detailed Analysis

Due to the low-quality studies, we provide a qualitative narrative of the evidence for prevention practice interventions.

#### Antibiotic Use

The five studies summarized in the Cochrane review,41 and the additional four individual studies here,42-45 found that changes in antimicrobial education, policies, or formularies, which result in decreasing use of high-risk antimicrobials, are associated with decreased CDI incidence. It was not possible to clearly isolate the impact of the antibiotic-related interventions in the studies examining multiple interventions.58-60,62,63 In the individual studies, which were usually done in response to outbreaks, interventions in addition to those aimed at antibiotic use may have been done but not reported. The interventions and antibiotics targeted for reduction differed among the various studies.

The Cochrane review41 determined the impact of interventions to improve antibiotic prescribing practices for hospital inpatients on CDI incidence. The authors found that four interventions were associated with significant reductions in CDI incidence62,172-174 and that one was associated with a nonsignificant trend toward a reduction.61

A prospective controlled interrupted time series42 of an antibiotic improvement intervention on three acute medical wards for elderly people with 21-month predefined pre- and postintervention periods, evaluated a “narrow-spectrum” antibiotic policy (reinforced by an established program of audit and feedback of antibiotic usage and CDI rates). The program targeted broad-spectrum antibiotics (cephalosporins and amoxicillin/clavulanate) for reduction and narrow-spectrum antibiotics (benzyl penicillin, amoxicillin. and trimethoprim) for increase. CDI rates decreased significantly with incidence rate ratios of 0.35 (95 percent CI 0.17 – 0.73). Incidence of Methicillin-resistant Staphylococcus aureus (MRSA), the control, did not change significantly.

The effect of a new antibiotic policy favoring piperacillin-tazobactam over cefotaxime on the long-term incidence of CDI and antibiotic utilization in a large elderly medicine unit was studied in a before/after observational study.43 Restrictions were associated with reduced cefotaxime use and reduced CDI incidence. Subsequently, the piperacillin-tazobactam became unavailable at the end of 2001. Cefotaxime use and CDI incidence rates increased during 2002.

In a geriatrics department of a university hospital, antimicrobial recommendations for treatment of several common infectious diseases were changed from broad-spectrum cephalosporins to other drugs thought to be less likely to induce CDI.44 Investigators changed department policy to reflect these recommendations, educated providers, monitored antibiotic use, and gave periodic feedback to providers. Cephalosporin use dropped, and the relative risk of CDI decreased to 0.31 (95 percent CI 0.93 to 0.10) compared with usage before the policy change.

In a geriatrics department of another university hospital, broad-spectrum cephalosporin use was restricted due to an increase in CDI incidence.45 In the following year, cephalosporin use decreased 92 percent, and CDI incidence decreased 50 percent from the previous year incidence. CDI incidence did not change in other hospital departments.

#### Measures to Reduce Transmission

##### Gloves

One controlled trial examined the use of gloves to prevent C. difficile transmission, with CDI incidence monitored by active surveillance.46 An intensive education campaign on two wards urged personnel to use gloves when handling body substances, and gloves were made easily available to personnel working with patients. Two other wards with no education campaign served as control wards, and gloves on these wards were stocked in supply rooms. Incidence of CDI decreased significantly from 7.7 cases/1,000 patient discharges during the 6 months before intervention to 1.5/1,000 during the six months of intervention on the intervention wards. No significant change in CDI incidence was observed on the control wards. Asymptomatic C. difficile carriage also decreased significantly on the intervention wards but not on the control wards. The cost of 61,500 gloves (4,505 gloves/100 patients) used was $2,768 for the glove-using wards, compared with $1,895 (42,100 gloves; 3,532 gloves/100 patients) on the control wards.

##### Disposable Thermometers

Three studies, one randomized crossover design,49 and two before/after studies without concurrent controls47,48 have shown that use of disposable thermometers prevent CDI. In one hospital with an increased CDI incidence, 21 percent of electronic rectal thermometer handles were contaminated with C. difficile.47 Efforts to reinforce infection control practices were already in place, but CDI incidence remained elevated. A before/after trial was conducted in that hospital and a chronic care facility to determine if use of disposable thermometers instead of multiple-use electronic rectal thermometers would reduce the CDI incidence. Surveillance for CDI was active, but toxin was detected with a latex agglutination test. During the 6-month postintervention period, the CDI incidence decreased from 2.71/1,000 patient days to 1.76/1,000 patient days in the acute hospital and from 0.41/1,000 patient days to 0.11/1,000 patient days in the skilled nursing facility. The harms associated with use of disposable thermometers were costs for purchase of disposable thermometers and the need to dispose of these thermometers. In these institutions, annual outlays increased from $7,731 to $14,055. These costs were offset by the need to purchase fewer electronic thermometers and to sterilize them periodically and by decreased costs of treating CDI cases.

In a later report, the same group reported that the rate of C. difficile infections increased from 1991 to 1993, although it was unclear how many patients had symptoms of disease with C. difficile.48 One ward used disposable tympanic membrane thermometers instead of disposal oral or rectal thermometers. Different interventions were implemented in two other wards. Regression analysis determined that the C. difficile infection rate decreased 40 percent (relative risk [RR], 0.59, 95 percent CI, 0.47-0.67).

A randomized, controlled crossover study compared the use of disposable thermometers with electronic thermometers to prevent nosocomial CDI.49 Twenty hospital wards were randomly assigned to disposable thermometers or electronic thermometers for 6 months, and then the assignments were reversed for 5 months. CDI rates were reduced 44 percent (P=0.026, 95 percent CI, 0.21 to 0.93) with disposable thermometers compared to electronic thermometers. Rates of nosocomial diarrhea or nosocomial infections did not differ significantly between the two groups. A cost analysis estimated that the hospital using disposable thermometers would need to spend an additional $5,926 to prevent a single CDI case. It was estimated that a CDI case resulted in $2,000 to $6,000 in excess costs.

##### Handwashing

No study addressed whether handwashing was associated with reduced CDI incidence. Many institutions encourage the use of alcohol-based rubs or gels for hand hygiene unless hands are grossly soiled or unless a health care worker has had potential contact with C. difficile either from patient contact or environmental contamination. Neither alcohol nor soap will kill C. difficile spores, but when health care workers wash hands properly with soap, most spores are removed because of friction and the detergent action of soap. Complicated recommendations are difficult to remember and implement, and one concern has been that health care workers will use alcohol-based rubs or gels in circumstances where handwashing is preferred.

Four studies have addressed this concern. One 2-year, prospective, controlled, crossover trial compared alcohol-based hand gel provided in addition to hand soap containing the antimicrobial 0.3 percent chloroxylenol with antimicrobial soap alone in two intensive care units.50 In units using adjuvant alcohol-based gel, there was a significant, sustained improvement in the rate of hand hygiene adherence but no detectable change in the incidence of healthcare-associated CDI (diagnosis determined by clinicians).50 Employees still had access to soap and water when their hands were soiled or when they were caring for a patient with C. difficile, and if workers used soap and water in these circumstances, it would have decreased the likelihood that differences in CDI rates would be detected.

The second study used a before/after design.51 Hospital employees were encouraged to wash hands with the antimicrobial 0.3 percent triclosan in the first 3-year period, and an alcohol-based hand rub with 62.5 percent ethyl was placed in dispensers in inpatient and outpatient clinic rooms in the next 3 years. There was a 21 percent decrease in new, nosocomially acquired MRSA isolates and a 41 percent decrease in vancomycin-resistant enterococci (VRE) isolates, but the incidence of new CDI cases remained similar (diagnosis determined by clinicians/toxin A assay).51

A retrospective time-series analysis, the secondary objective, was done to determine the relationship between use of alcohol-based hand rub and antibiotic consumption on the incidence of CDI.52 CDI incidence was determined retrospectively from records of patients put in isolation for CDI. Multivariable time series analyses showed no association between alcohol-based hand rub and CDI incidence. Macrolide and third-generation cephalosporin use was associated with increased CDI incidence after lag times of 1 to 3 months.

A retrospective, interventional time-series analysis was used to determine the effects of two interventions on CDI incidence.66 The interventions were promotional campaigns to encourage use of alcohol-based hand rub for hand hygiene. Time series analysis was done with autoregressive integrated moving average models. There was no association between alcohol-based hand rub and CDI incidence.

##### Disinfection

Four studies examined if disinfection reduces the incidence of CDI as a single component intervention,53-55,67 and seven studies included disinfection in multicomponent interventions.56,57,59,60,63,65,68 Disinfection agents examined included hypochlorite solution, hydrogen peroxide, aldehydes, and detergent.

Three studies examined hypochlorite solution as a single intervention. One before/after intervention investigated whether cleaning patient rooms that tested positive for C. difficile toxin with unbuffered with 1:10 hypochlorite solution reduced the incidence of CDI in three patients' units.53 Before the intervention, patient rooms were cleaned with quaternary ammonium. In one housing bone marrow transplant patients and having the greatest rate before the intervention, the CDI incidence rate decreased significantly, from 8.6 to 3.3 cases per 1,000 patient-days (hazard ratio 0.37, 95 percent CI, 0.19 to 0.74) after hypochlorite was used to clean rooms. In the other two with lesser rates before the intervention, there was no significant change. In response to a subsequent outbreak of VRE infections, the hospital used quaternary ammonium solution for all patient room disinfection. The incidence of VRE infection decreased, but the CDI incidence rate increased. Hypochlorite disinfection was reinstituted and the CDI incidence rate subsequently decreased. A followup report documented subsequent increases in incidence and further interventions to control CDI.

An epidemiological investigation of an outbreak of CDI occurring in a single ward of a Michigan hospital documented nosocomial acquisition from the environment.54 After use of unbuffered hypochlorite to disinfect wards, contamination decreased and the outbreak ended. Subsequently, it was shown that phosphate-buffered hypochlorite was even more effective for disinfection.

Hypochlorite was used in various ways in conjunction with other interventions to prevent CDI in seven studies (multiple intervention table part B).56,57,59,60,63,65,68 The effect of the hypochlorite disinfection cannot be isolated from the other intervention components.

A high rate of CDI was noted in three hospitals joined in a single health care system. Hospitals changed the disinfectant used for the discharge cleaning of rooms of patients with CDI from a quaternary ammonium compound to dilute bleach.67 There was a 48 percent reduction in the prevalence of C difficile after the bleaching intervention (P=0.0001, 95 percent CI, 36 to 58).

Two before/after studies were conducted to evaluate whether disinfection with hydrogen peroxide as part of multiple component interventions reduces CDI incidence.57,63 In the first study, an abrupt increase in nosocomial CDI (defined as diarrhea with a positive toxin test) incidence led to multiple interventions in attempts to control the outbreak. Surveillance was based on laboratory and patient medical records.57 A liquid vapor hydrogen peroxide decontamination system was used to decontaminate five high incidence wards of C. difficile organisms.57 There followed a slight decrease in nosocomial CDI incidence. Liquid vapor hydrogen peroxide was then used to decontaminate patient rooms vacated by patients with CDI throughout the hospital on an ongoing basis. Nosocomial CDI incidence continued to decrease and remained at levels roughly equivalent to rates prior to the outbreak. Quality of the diagnosis and surveillance system was good. No harms to hospital personnel, patients, or equipment were observed. The authors noted that the area to be decontaminated must be appropriately sealed, hydrogen peroxide levels outside the area being decontaminated must be closely monitored, and hydrogen peroxide concentrations within the decontaminated area must be reduced to less than 1 part per million before allowing patients or health care workers to re-enter. A subsequent study by the same investigators reported that hydrogen peroxide vapor disinfection was feasible in their hospital.175 The peroxide vapor disinfection took 2 hours and 20 minutes to complete compared with 32 minutes for routine cleaning. The median cumulative times for all phases of cleaning and disinfection were 234 minutes (range 174–838) for peroxide vapor compared with 55 minutes (range 28–256) for conventional hypochlorite.

In the second study, 7 percent accelerated hydrogen peroxide was used for terminal disinfection of rooms of patients with CDI and comprehensive ward disinfection with sodium hypochlorite was done when three or more nosocomial CDI cases (defined as cases with positive toxin or with endoscopic or histological evidence of pseudomembranous colitis) remained elevated.63 Within 4 months of the time infection prevention measures were implemented, the investigators also took several steps to reduce antibiotic use. Nosocomial CDI incidence fell abruptly within 1 month of the changes in antibiotic use.

In one study using aldehydes as part of a multiple-component intervention, a cluster of CDI in a surgical ward led to a hospitalwide surveillance and control program.55 Control interventions included terminal room disinfection with 0.04 percent formaldehyde and 0.03 percent glutaraldehyde in wards with a cluster of two or more nosocomial CDI cases per month. During a 12-month period, the quarterly incidence of nosocomial CDI remained unchanged. C. difficile spores were recovered from 36.7 percent of the surfaces of case patient rooms versus 6.7 percent in control rooms. Subsequently, more intensive control measures were evaluated, which included daily meticulous room disinfection for each sporadic nosocomial CDI case. Surface disinfection reduced the contamination level fourfold (p = 0.04). In the following 12 months, the nosocomial CDI incidence fell to 0.3/1,000 admission (protective efficacy 73 percent, 95 percent CI, 46–87 percent). Multiple interventions, including disinfection, were used to control the outbreak. The study provides low evidence that disinfection, in this case with aldehydes, might have had a role in terminating the outbreak.

These ten studies provide low evidence that disinfection with a chemical compound that kills C. difficile spores in the hospital environment prevents CDI, at least in epidemic or hyperendemic settings. Decreased CDI incidence might have been from natural variation (regression to the mean) in some or all studies. As stated previously, disinfection was one of multiple interventions used to prevent CDI in seven studies; it is difficult to impossible to know which intervention or combination of interventions might have led to reduced CDI incidence.

#### Multiple Component Studies

Ten studies described the use of multiple preventive measures to control epidemic CDI, or endemic CDI that was felt to be excessive. Tables 5 and 6 list the categories of interventions in each of these articles. The number of interventions and the specific nature of any particular interventions varied widely. Studies employed between two and nine different types of interventions, including steps to optimize antimicrobial (six studies),58-63 enhanced surveillance (two studies),59,60 intensified staff education about infection prevention (three studies),60,62,63 new isolation procedures (four studies),59,61,63,64 and “enteric precautions” (two studies).58,61 Two studies emphasized handwashing61,64 and one alcohol-based gel for hand disinfection.60 Health care workers were required to wear gloves in three studies,61,62,64 and use of gowns for patient contact was required in two studies.61,64 Visitors were asked to comply with infection prevention procedures in one study.64 New dedicated patient care equipment was purchased in two studies,60,63 and in one of these, cleaning of dedicated patient equipment was intensified. Disposable rectal thermometers were used in one study.63 Intensified environmental cleaning was implemented in six studies.59-64 CDI patient movement was restricted in two studies.59,64

Table 5 (A) Studies of multiple interventions used together to reduce CDI incidence

Study | Type of Study | Epidemic or Excessive Incidence? | CDI incidence Decreased After intervention? | Interventions
Study | Type of Study | Epidemic or Excessive Incidence? | CDI incidence Decreased After intervention? | Improved Antimicrobial Use | Enhanced Surveillance, Analysis, and Reporting of CDI Data | Laboratory-Based Infection Prevention Alert System | Infection Prevention Education | Isolation (n=8) | | Patient/Staff Movement (n=3) | | Hand Hygiene (n=7)
Study | Type of Study | Epidemic or Excessive Incidence? | CDI incidence Decreased After intervention? | Improved Antimicrobial Use | Enhanced Surveillance, Analysis, and Reporting of CDI Data | Laboratory-Based Infection Prevention Alert System | Infection Prevention Education | Enteric Precautions | Isolation | CDI Patient Movement Restricted | Restriction of Nursing Cross-Cover | Enhanced Hand Washing | Alcohol-Based Rub or Gel
Abbett, 2009^56^ | Prospect time series (before–after) | Yes | Yes | | X | X | X | | X | | | X
Boyce, 2008^57^ | Prospect time series (before–after) | Yes | Yes | X | X | | | X | X | | | X
Brown, 1990^58^ | Retrospect time series (before–after | Yes | Yes | X | | | | X
Cartmill. 1994^59^ | Prospect time series (before–after) | Yes | Yes | X | X | | | | X | X
Drudy, 2007^60^ | Prospect time series (before–after) | Yes | Yes | X | X | | X | | | | | | X
McMullen, 2007^68^ | Prospect time series (before–after) | Yes | Yes | | | | | | | | | X
McNulty, 1997^61^ | Retrospect time series (before–after | Yes | Yes | X | | | | X | X | | X | X
Pear, 1994^62^ | Prospect time series (before–after) | Yes | Yes | X | | | X
Valiquette, 2007^63^ | Retrospect time series (before–after | Yes | Yes | X | | | X | | X
Whitaker, 2007^65^ | Prospect time series (before–after) | Yes | Yes | X | X | | X | | X | | | X
Zafar, 1998^64^ | Prospect time series (before–after) | No | Yes | | | | | | X | X | | X
Total number of studies evaluating specific intervention | | | | 8 | 5 | 1 | 5 | 3 | 7 | 2 | 1 | 6 | 1

CDI = Clostridium difficile infection

Table 6 (B) Studies of multiple interventions used together to reduce CDI incidence

Study | Type of Study | Interventions
Study | Type of Study | Practices Within Patient Rooms (n=5) | | | Equipment (n=4) | | Intensified Environmental Cleaning (n=10)
Study | Type of Study | Gloves for Patient Contact | Gowns or Aprons for Patient Contact | Visitors Comply With Infection Prevention Practices | Dedicated Equipment, Equipment Cleaning | Disposable Rectal Thermometers | Room Cleaning With Hypochlorite | Ward Cleaning With Hypochlorite | Room Cleaning With Hydrogen Peroxide | Ward Cleaning With Hydrogen Peroxide | Room Cleaning With Detergent | Unspecified
Abbett, 2009^56^ | Prospect time series (before–after) | | X | X | X | | X
Boyce, 2008^57^ | Prospect time series (before–after) | | | | | | X | | X | X
Brown, 1990^58^ | Retrospect time series (before–after
Cartmill, 1994^59^ | Prospect time series (before–after) | | | | | | X
Drudy, 2007^60^ | Prospect time series (before–after) | | | | X | | X
McMullen, 2007^68^ | Prospect time series (before–after) | | | | | | X | X
McNulty, 1997^61^ | Retrospect time series (before–after | X | X | | | | | | | | X
Pear, 1994^62^ | Prospect time series (before–after) | X | | | | | | | | | | X
Valiquette, 2007^63^ | Retrospect time Series (before–after | | | | X | X | X | | X | X
Whitaker, 2007^65^ | Prospect time series (before– after) | | | X | X | | X | X
Zafar, 1998^64^ | Prospect time series (before– after) | X | X | X | | | | | | | | X
Total number of studies evaluating specific intervention | | 3 | 3 | 3 | 4 | 1 | 7 | 2 | 2 | 2 | 1 | 2

Investigators often placed greater weight on one intervention over others because the timing of decreased CDI incidence appeared to follow implementation of a particular intervention. However, the time it takes for many interventions to become adopted in health care settings and the variance expected in disease incidence led us to conclude that it was not possible to attribute decreases in CDI incidence to a single intervention in any of these studies. Natural fluctuations are such that all outbreaks diminish after variable periods of time so that assigning causality to individual or a collection of prevention measures is impossible. The evidence from these studies that any single intervention or combination of interventions prevents CDI was low.

#### Harms

Harms, beyond cost, were not addressed in any study.

#### Risk Factors

Identified CDI risk factors can provide clues to researchers and health care providers for where to target prevention strategies. We identified one systematic review reviewed CDI risk factor literature through 1997^20^ and 12 risk factor studies published after the review. Bignardi's systematic review identified risk factors with “substantive” evidence: age, severity of underlying diseases, nonsurgical GI procedures, nasogastric tube, acid suppression medications, ICU, length of stay, duration of antibiotic course, and multiple antibiotics.20 Five studies identified specific antibiotics or antibiotic classes with increased CDI risk111,168,169,176,177 (Table 7), and two studies found that antibiotic use in general was associated with increased risk for CDI.111,171 Consistent with Bignardi's findings, the more recent literature also identified severe underlying disease as a risk factor in four studies112,166,167,171 and acid suppression in one.112

Table 7 Summary of risk factors for CDI

Study | Specific Antibiotic Use | General Antibiotic Use | Health Status or Disease Severity | Acid Suppression | Hospitalization in an ICU | Age | Miscellaneous
Peled, 2007^112^ | NE | NE | Functional capacity score OR = 9.1 | PPI OR = 6.1 Histamine blocker OR = 3.1 | NE | NE | Hypoalbuinemia OR = 3.8 Leukocytosis OR = 2.7
Samore, 2006^169^ | Clindamycin OR = 4.2 | NE | NE | NE | NE | NE
Yearsley, 2006^171^ | NE | OR = 13.1 | NE | OR = 1.90 | NE | NS | Female gender OR = 1.79
Vesta, 2005^166^ | NE | NS | Horn's Index P = 0.0022 | NE | NE | NS
Kyne, 2002^167^ | NS | NS | Severe underlying dz OR = 17.6 | NS | NE | NS
Mody, 2001^168^ | 3^rd^ generation cephalosporins OR = 3.6 | NE | NE | NE | NE | NE
Schwaber, 2000^170^ | Cephalosporin P = 0.03; 3^rd^ generation cephalosporins P = 0.02 | Greater number used P = 0.02 | NE | NE | NE | NS
Katz, 1997^111^ | Cephalosporin P = 0.001 | Antibiotic use past 30 days P =0.009; Antibiotic use prior to transfer/admission P =0.009 | NE | NE | NE | NE
Bignardi, 1998^20^ Searched to March 1996 | | Duration of antibiotic course; multiple antibiotics | Severity of underlying diseases | Anti-ulcer medications | Yes | Yes | Non-surgical gastrointestinal procedures, nasogastric tube, hospital length of stay

dz = disease; ICU = intensive care unit; NE = not examined by multivariate analysis; NS = not significant factor; OR = odds ratio; PPI = proton pump inhibitor

#### Sustainability

No studies addressed the sustainability of a prevention program.

## Key Question 3 What are the Comparative Effectiveness and Harms of Different Antibiotic Treatments?

### Search Results

Eleven randomized clinical trials were identified that evaluated different antimicrobials (or different doses of a single drug) available for treatment of CDI in the United States. These 11 studies, published from 1978 to 2009, ranged in size from 39 to 629 subjects. Table 8 provides a breakdown of the trial comparators. Vancomycin is the most frequently studied antimicrobial, examined in 8 of the 10 studies. The most frequent comparison was vancomycin versus metronidazole (three studies, one of which also included fusidic acid and teicoplanin treatment arms, which are not included in this analysis), followed by two studies of vancomycin versus bacitracin. The remaining comparisons (vancomycin vs. nitazoxanide, vancomycin vs. fidaxomicin, vancomycin high dose vs. low dose, vancomycin vs. placebo, metronidazole vs. nitazoxanide, and metronidazole vs. metronidazole plus rifampin) all occurred in single studies. Treatment duration was 10 days in 9 of 11 studies, with the other two having durations of 7 and 5 days. The typical study followup period was 21 to 31 days. The largest patient sample was 629; most studies were in the range of approximately 40 to 60 patients. (See Appendix Table C4.) Two studies that did not meet inclusion criteria merit brief mention: one179 appears to report on the same subjects included in another publication,78 while another180 has been presented in abstract form only.

Table 8 Summary of trial comparators for 10 trials of antibiotic treatment of CDI

| Vancomycin | Metronidazole
Vancomycin | 1 (N = 56) (dosing)
Metronidazole | 3 (N = 172 N = 62 N = 101)
Nitazoxanide | 1 (N = 50) | 1 (N = 142)
Bacitracin | 2 (N = 62 N = 42)
Metronidazole + Rifampin | | 1 (N = 39)
Fidaxomicin | 1 (N= 629)
Placebo | 1 (N = 44)

### Key Points

- Overall, study quality is low.
- Vancomycin and metronidazole, the most frequently clinically used antimicrobials, were the most frequently compared antimicrobials.
- Three RCT comparisons of vancomycin to metronidazole, with a total of 335 pooled subjects, found no significant differences in any examined outcome.
- One RCT comparing vancomycin to metronidazole, using a prespecified subgroup analysis of 69 patients, found a small but significant increase in the proportion of subjects with severe CDI who achieved initial clinical cure with vancomycin, using a treatment-received analysis. This difference was not significant using a strict intention-to-treat analysis.
- One study demonstrated that recurrence was significantly decreased with fidaxomicin versus vancomycin; initial cure was not significantly different between fidaxomicin and vancomycin.
- The decrease in recurrence seen with fidaxomicin use appeared to be limited to those patients with non-NAP1 strains.
- Harms were not reported with sufficient detail to compare the risks of any particular antimicrobial with another antimicrobial.
  ○ When harms were reported, they were generally not serious (nausea, emesis, etc.) and transient.

#### Minor Key Points

- No other head-to-head trial demonstrated superiority of any single antimicrobial for initial clinical cure, clinical recurrence, or mean days to resolution of diarrhea.
- Combination therapy with rifampin and metronidazole resulted in significantly higher mortality when compared to treatment with metronidazole only.
- Pooled data of 104 subjects comparing vancomycin to bacitracin showed significantly higher rates of organism or toxin clearance for vancomycin.
- No data were available to assess the importance of general patient characteristics or the strain of organism on the effectiveness of an antimicrobial.

### Quality of the Studies

Overall study quality is low. Only two studies specified that the investigators (who also assessed outcomes) were blinded with respect to treatment.70,82 Quality summary tables are available in Appendix C of this report (see Appendix Tables C5 and C6). Strength of evidence is summarized in Appendix Tables C7 and C8.

### Detailed Analysis

As vancomycin and metronidazole are the most frequently employed antimicrobials, and therefore of greatest interest to clinicians, results are broken into two sets: (1) vancomycin versus metronidazole and (2) all other comparisons of standard treatment trials.

#### Initial Cure

The percentage of subjects initially cured with vancomycin ranged from 84 percent to 94 percent among individual studies, with a mean value of 88 percent (Table 9). For subjects treated with metronidazole, the individual cure rates ranged from 73 percent to 94 percent, with a mean value of 81 percent. The relative risk for initial cure comparing vancomycin to metronidazole was 1.08 (95 percent CI 0.99 to 1.19).

Table 9 Initial clinical cure (# subjects / # randomized) for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | RR [95% CI]
Zar, 2007^70^ | 69/82 (84) | 66/90 (73) | 1.15 [0.98 to 1.34]
severe disease | 30/38 (79) | 29/44 (66) | 1.20 [0.92 to 1.57]
Wenisch, 1996^73^ | 29/31 (94) | 29/31 (94) | 1.00 [0.88 to 1.14]
Teasley, 1983^76^ | 51/56 (91) | 39/45 (87) | 1.05 [0.91 to 1.21]
Totals | 149/169 (88) | 134/166 (81) | 1.08 [0.99 to 1.19]

CI = confidence interval; RR = relative risk

With the exception of vancomycin versus placebo, no other treatment comparison resulted in significant differences in initial clinical cure (Table 10).

Table 10 Initial clinical cure (# subjects / # randomized) for all other standard treatment trials

Study | Treatment 1 | Treatment 2 / Control | Relative Risk [95% CI]
1. Vancomycin versus Nitazoxanide
Musher, 2009^69^ | 20/27 (74) | 17/23 (74) | 1.00 [0.72 to 1.39]
severe disease | 7/10 (70) | 8/10 (80) | 0.88 [0.53 to 1.46]
2. Vancomycin versus bacitracin
Dudley, 1986^74^* | 15/23 (65) | 12/16 (75) | 0.87 [0.58 to 1.31]
Young, 1985^77^ | 18/21 (86) | 16/21 (76) | 1.13 [0.84 to 1.51]
Totals | 33/44 (75) | 28/37 (76) | 1.01 [0.79 to 1.28]
4. Vancomycin versus fidaxomicin
Louie, 2011^79^ | 265/313 (85) | 253/289 (88) | 0.97 [0.91 to 1.04]
3. Vancomycin high-dose versus vancomycin low dose
Fekety, 1989^75^ | 22/28 (79) | 24/28 (86) | 0.92 [0.72 to 1.17]
4. Vancomycin versus placebo
Keighley, 1978^78^* | 9/12 (75) | 1/9 (11) | 6.75 [1.03 to 44.08]
5. Metronidazole versus Nitazoxanide
Musher, 2006^72^ | 28/44 (64) | 68/98 (69) 36/49 (73) 7-day 32/49 (65) 10-day | 0.92 [0.71 to 1.19]
6. Metronidazole versus metronidazole plus rifampin
Lagrotteria, 2006^71^ | 13/20 (65) | 12/19 (63) | 1.03 [0.64 to 1.65]

CI = confidence interval

Note: Treatment 1 is the first intervention listed in the first column, followed by treatment 2.

#### Clinical Recurrence

The percentage of subjects meeting the investigator-determined definition of recurrent disease (after meeting criteria for initial cure) ranged from 7 percent to 17 percent with vancomycin, with a mean value of 11 percent. For metronidazole the range was 5 percent to 21 percent, with a mean value of 12 percent. (Table 11) The relative risk for recurrence after vancomycin treatment compared to metronidazole was 0.92 (95 percent CI, 0.47 to 1.77)

Table 11 Clinical recurrence: # subjects / # initially cured (percent) for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | Relative Risk [95% CI]
Zar, 2007^70^ | 5/69 (7) | 9/66 (14) | 2.29 [0.49 to 10.76]
severe disease | 3/30 (10) | 6/29 (21) | 0.48 [0.13 to 1.75]
Wenisch, 1996^73^ | 5/29 (17) | 5/29 (17) | 1.00 [0.32 to 3.09]
Teasley, 1983^76^ | 6/51 (12) | 2/39 (5) | 0.53 [0.19 to 1.50]
Totals | 16/149 (11) | 16/134 (12) | 0.92 [0.47 to 1.77]

CI = confidence interval

Only the comparison between fidaxomicin and vancomycin showed a statistically significant difference (15 percent vs. 25 percent, P = 0.005); in all other trials there was no significant difference in percentage of patients with recurrence. Between trial comparisons for the percentage of patients with recurrence are of uncertain relevance because of the variable definitions of recurrence and duration of followup. (Table 12).

Table 12 Clinical recurrence: # subjects / # initially cured (percent) for all other standard treatment trials

Study | Treatment 1 | Treatment 2 / Control | Relative Risk [95% CI]
1. Vancomycin versus Nitazoxanide
Musher, 2009^69^ | 2/20 (10) | 1/17 (6) | 1.70 [0.17 to 17.16]
ߓsevere disease | 1/10 (10) | 1/10 (10) | 1.00 [0.07 to 13.87]
2. Vancomycin versus bacitracin
Dudley, 1986^74,*^ | 3/15 (20) | 5/12 (42) | 0.48 [0.14 to 1.62]
Young, 1985^77^ | 6/18 (33) | 5/12 (42) | 0.80 [0.31 to 2.04]
Totals | 9/33 (27) | 10/24 (42) | 0.65 [0.31 to 1.35]
3. Vancomycin high dose versus vancomycin low dose
Fekety, 1989^75^ | 4/22 (18) | 5/24 (21) | 0.87 [0.27 to 2.84]
4. Vancomycin versus fidaxomicin
Louie, 2011^79^ | 67/265 (25) | 39/253 (15) | 1.64 [1.15 to 2.34]
5. Vancomycin versus placebo
Keighley, 1978^78,*^ | NR | NR
6. Metronidazole versus Nitazoxanide
Musher, 2006^72^ | 8/28 (29) | 14/68 (21) 9/36 7-day 5/32 (3) 10-day | 1.39 [0.66 to 2.93]
7. Metronidazole versus metronidazole plus rifampin
Lagrotteria, 2006^71^ | 5/13 (38) | 5/12 (42) | 0.92 [0.35 to 2.41]

CI = confidence interval; NR = not reported

* Subjects without demonstrable C. difficile cytotoxin and/or positive culture for C. difficile were removed and not included in the efficacy analyses.

Note: Treatment 1 is the first intervention listed in the first column, followed by treatment 2.

#### Mean Days to Resolution of Diarrhea

Two of the three vancomycin versus metronidazole studies reported the mean time to resolution of diarrhea.73,76 No differences were seen between treatment arms (Table 13).

Table 13 Mean days to resolution of diarrhea/clinical improvement for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | WMD [95% CI]
Zar, 2007^70^ | Not reported | Not reported
Wenisch, 1996^73^ | 3.1 ± 1.1 | 3.2 ± 1.1 | 0.10 [-0.65 to 0.45]
Teasley, 1983^76^ | 2.8 ± 1.8 | 2.4 ± 1.9 | -0.40 [-0.35 to 1.15]
Totals | | | 0.07 [-0.37 to 0.52]

CI = confidence interval; WMD = weighted mean differences

No other treatment comparison resulted in significant differences in mean days to resolution of diarrhea (Table 14).

Table 14 Mean days to resolution of diarrhea/clinical improvement for all other standard treatment trials

Study | Treatment 1 | Treatment 2 / Control | WMD [95% CI]
1. Vancomycin Versus Nitazoxanide
Musher, 2009^69^ | Not reported | Not reported
2. Vancomycin Versus Bacitracin
Dudley, 1986^74^ | Not reported | Not reported
Young, 1985^77^ | 4.3 ± 1.8 | 4.8 ± 1.8 | -0.50 [-1.59 to 0.59]
Totals | | | -
3. Vancomycin High Dose Versus Vancomycin low Dose
Fekety, 1989^75^ | 4.3 ± 1.8 | 3.8 ± 1.4 | 0.50 [-0.44 to 1.44]
4. Vancomycin Versus Fidaxomicin
Louie, 2011^79^ | Median 3.3 | Median 2.4 | p = NS
5. Vancomycin Versus Placebo
Keighley, 1978^78^ | Not reported | Not reported
6. Metronidazole Versus Nitazoxanide
Musher, 2006^72^ | Not reported | Not reported
7. Metronidazole Versus Metronidazole Plus Rifampin
Lagrotteria, 2006^71^ | 6.6 | 7.0 | p = 0.73

CI = confidence interval; NS = not statistically significant; WMD = weighted mean differences

Note: Treatment 1 is the first intervention listed in the first column, followed by treatment 2.

#### All-Cause Mortality

Mortality was rare overall, in part due to the short study-followup periods. There were five deaths in each arm among the 335 subjects enrolled in studies comparing vancomycin with metronidazole (Table 15). Wenisch73 evaluated four drugs, including two not evaluated in this review, but did not provide mortality data by subject. Depending on in which study arm the mortalities occurred in the Wenisch study,73 there were between 10 and 13 total deaths in studies comparing vancomycin to metronidazole. Even if all three deaths in this study occurred in one arm, the difference in mortality could not reach statistical significance.

Table 15 All-cause mortality (# subjects / # randomized) for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | Nitazoxanide | Bacitracin | Placebo
Zar, 2007^70^ | 3/82 (4) | 5/90 (6)
Wenisch, 1996^73^ | 3 subjects died within first days of therapy (treatment groups not noted)
Teasley, 1983^76^ | 2/56 (4) | 0/45

All-cause mortality was significantly higher for combination metronidazole plus rifampin versus metronidazole alone (32 percent versus 5 percent).71 There were no differences in all-cause mortality in any of the other treatment comparisons (Table 16).

Table 16 All-cause mortality (# subjects / # randomized) for all other standard treatment trials

Study | Vancomycin | Metronidazole | Nitazoxanide | Fidaxomicin | Bacitracin | Placebo
Musher, 2009^69^ | | Overall mortality was 4% (2/49 subjects) (treatment groups not noted)
Lagrotteria, 2006^71^ | | 1/20 (5) 6/19 (32) + Rif
Musher, 2006^72^ | | 1+/44^*^ | 3+/98^*^
Fekety, 1989^75^ | 1/28 HD 1/28 LD
Dudley, 1986^74^ | 0/31 | 1/31 (3)
Young, 1985^77^ | 0/21 | 0/21
Keighley, 1978^78^ | 0 “colitis”/12 | 0 “colitis”/12
Louie, 2011^79,†^ | 21/323 (7) | | | 16/300 (5)

* A total of 13 deaths (9 percent) occurred, but only the 4 deaths above were denoted by treatment arm.

† Numbers based on safety population.

#### Other Outcomes

Where the outcomes were reported, no differences were found between vancomycin and metronidazole for clearance of toxin,73 laboratory-confirmed relapse,73 or persistence of the organism76 (Table 17). The clinical relevance of these outcomes is uncertain.

Table 17 Other outcomes (# subjects / # assessed) for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | Relative Risk [95% CI]
Zar, 2007^70^ | Not reported | Not reported
Wenisch, 1996^73^ | CT at day 6 22/31 (71) | CT at day 6 22/31 (71) | 1.00 [0.73 to 1.37]
Wenisch, 1996^73^ | LR at day 30 9/31 (29) | LR at day 30 9/31 (29) | 1.00 [0.46 to 2.18]
Teasley, 1983^76^ | P at day 21 11/43 (26) | P at day 21 14/35 (40) | 0.64 [0.33 to 1.23]

CI = confidence interval; CT = clearance of toxin; LR = laboratory-confirmed-relapse; P = persistence

Pooled data of 104 subjects comparing vancomycin to bacitracin showed significantly higher rates of organism or toxin clearance for vancomycin.74,77 No other differences were found in reported outcomes (Table 18).

Table 18 Outcomes for all standard treatment trials

Study | Vancomycin | Metronidazole | Fidaxomicin | Nitazoxanide | Bacitracin | Placebo
Clinical Initial Cure (# Subjects / # Randomized)
Musher, 2009^69^ | 20/27 (74) | | | 17/23 (74)
Zar, 2007^70^ | 69/82 (84) | 66/90 (73)
Lagrotteria, 2006^71^ | | 13/20 (65) 12/19 (63) + Rif
Musher, 2006^72^ | | 28/44 (64) | | 68/98 (69)
Wenisch, 1996^73^ | 29/31 (94) | 29/31 (94) | | | 27/29 (93)
de Lalla, 1992^187^ | 20/24 (83)
Fekety, 1989^75^ | 22/28 (79) HD 24/28 (86) LD
Dudley, 1986^74^ | 15/23^*^ (65) | | | | 12/16^*^ (75)
Young, 1985^77^ | 18/21 (86) | | | | 16/21 (76)
Teasley, 1983^76^ | 51/56 (91) | 39/45 (87)
Keighley, 1978^78,*^ | 9/12^*^ (75) | | | | | 1/9^*^ (11)
Louie, 2011^79^ | 265/313 (85) | | 253/289 (88)
Clinical Recurrence (# Subjects / # Initially Cured) for all Standard Treatment Trials
Musher, 2009^69^ | 2/20 (10) | | | 1/17 (6)
Zar, 2007^70^ | 5/69 (7) | 9/66 (14)
Lagrotteria, 2006^71^ | | 5/13 (38) 5/12 (42) + Rif
Musher, 2006^72^ | | 8/28 (29) | | 14/68 (21)
Wenisch, 1996^75^ | 5/29 (16) | 5/29 (16) | | | 8/27 (30)
de Lalla, 1992^186^ | 4/20 (20)
Fekety, 1989^75^ | 4/22 (18) HD 5/24 (21) LD
Dudley, 1986^74^ | 3/15 (20) | | | | 5/12 (42)
Young, 1985^77^ | 6/18 (33) | | | | 5/12^†^ (42)
Teasley, 1983^76^ | 6/51 (12) | 2/39 (5)
Keighley, 1978^78^ | Not reported | Not reported
Louie, 2011^79^ | 67/265 (25) | | 39/253 (15)
All-cause Mortality (# Subjects / # Randomized) for all Standard Treatment Trials
Musher, 2009^69^ | | Overall mortality was 4% (2/49 subjects) (treatment groups not noted)
Zar, 2007^70^ | 3/82 (4) | 5/90 (6)
Lagrotteria, 2006^71^ | | 1/20 (5) 6/19 (32) + Rif
Musher, 2006^72^ | 1+/44^‡^ | | | 3+/98^‡^
Wenisch, 1996^73^ | | 3 subjects died within first days of therapy (treatment groups not noted)
de Lalla, 1992^187^ | | 2 subjects died within first days of therapy (treatment groups not noted)
Fekety, 1989^75^ | 1/28 HD 1/28 LD
Dudley, 1986^74^ | 0/31 | 1/31 (3) | | | 1/31 (3)
Young, 1985^77^ | 0/21 | 0/21 | | | 0/21
Teasley, 1983^76^ | 2/56 (4) | 0/45
Keighley, 1978^78^ | 0 “colitis”/12 | 0 “colitis”/12
Louie, 2011^79^ | 21/323 (7) | | 16/300 (5)
Mean Days to Resolution of Diarrhea/Clinical Improvement
Musher, 2009^69^ | NR | | | Not reported
Zar, 2007^70^ | NR | Not reported
Lagrotteria, 2006^71^ | | 6.6 7.0 + Rif
Musher, 2006^72^ | | Not reported | | Not reported
Wenisch, 1996^73^ | 3.1 ± 1.1 | 3.2 ± 1.1
de Lalla, 1992^187^ | 3.6 ± 1.7
Fekety, 1989^75^ | 4.3 ± 1.8 HD 3.8 ± 1.4 LD
Dudley, 1986^74^ | Not reported | | | | NR
Young, 1985 | 4.3 ± 1.8 | | | | 4.8 ± 1.8
Teasley, 1983^76^ | 2.8 ± 1.8 | 2.4 ± 1.9
Keighley, 1978^78^ | Not reported | | | | | Not reported
Louie, 2011^79^ | Median 3.3 | | Median 2.4
Clearance of Organism (CO) / Toxin (CT) or Laboratory-confirmed-relapse (LR) / Persistence (P) for Evaluable Subjects
Musher, 2009^69^ | Not reported | | | Not reported
Zar, 2007^70^ | Not reported | Not reported
Lagrotteria, 2006^71^ | | LR 2 LR 4 (+ Rif)
Musher, 2006^72^ | | Not reported | | Not reported
Wenisch, 1996^73^ | CT 22/31 (71) LR 9/31 (29) | CT 22/31 (71) LR 9/31 (29) | | | CT 14/29 (48) LR 15/29 (52)
de Lalla, 1992^187^ | P 9/20 (45)
Fekety, 1989^75^ | CO 4/10 (40) HD CO 5/9 (56) LD
Dudley, 1986^74^ | CO 11/14 (79) CT 12/14 (86) | | | | CO 4/10 (40) CT 5/11 (45)
Young, 1985^77^ | CO 17/21 (81) CT 15/18 (83) | | | | CO 11/21 (52) CT 10/19 (53)
Teasley, 1983^76^ | P 11/43 (26) | P 14/35 (40)
Keighley, 1978^78^ | CO 11/12 (92) CT 12/12 (100) | | | | | CO 1/9 (11) CT 3/9 (33)
Louie, 2011^79^ | Not reported | | Not reported

HD = high dose; LD = low dose; NR = not reported; Rif = Rifampin

* Subjects without demonstrable C. difficile cytotoxin and/or positive culture for C. difficile were removed and not included in the efficacy analyses.

† 4 subjects excluded with no reasons given.

‡ A total of 13 deaths (9 percent) occurred, but only the 4 deaths above were denoted by treatment arm.

#### Harms

Reported adverse events were relatively uncommon, minor, and not associated with one drug compared with the other. One study reported two episodes of intolerance (nausea and vomiting) leading to subject withdrawal, one in each treatment arm.76 Another reported a subject with emesis that developed while on metronidazole, which resolved when treatment was changed to vancomycin; in the same study, another subject developed nausea while on vancomycin, which resolved when treatment was changed to metronidazole.70 The third study reported “gastrointestinal discomfort” (which did not result in cessation of therapy) in 10 percent of subjects receiving metronidazole, compared to none with vancomycin, a difference that did not reach significance.

#### Disease Severity

Only one study stratified patients by disease severity at the time of screening.70 Severity was dichotomized into two outcomes: mild or severe disease. This trial stratified treatment based on disease severity (mild versus severe). Sixty-nine subjects, 31 who received vancomycin and 38 who received metronidazole, met the prespecified definition of severe disease. Patients with two or more of the following were considered to be severe: 60 years old or older, temperature above 38.3 degrees Celsius, albumin level less than 2.5 mg/dL, or peripheral white blood count greater than 15,000 cells/mm3 within 48 hours. Using a treatment-received analysis, the authors reported that initial cure was more common among those receiving vancomycin (97 percent versus 76 percent), with a relative risk for initial cure of 1.27 (95 percent CI, 1.05 to 1.53). In a subsequent response181 to several letters,182-184 they reported a revised result, which incorporated a modified intention-to-treat analysis (including subjects who died in the first 5 days of therapy), and reclassification of two subjects as being initially cured. This slightly changed the relative risk for initial cure to 1.28 (95 percent CI, 1.03 to 1.59). However, using a strict intention-to-treat analysis, which includes subjects intolerant of therapy, lost to followup, and early deaths, and the original classification of initial cure, the percentage cured with vancomycin versus metronidazole was 79 percent versus 66 percent. This corresponds to a relative risk for initial cure of 1.20 (95 percent CI, 0.92 to 1.57) (Table 9). This is minimally changed to 1.20 (95 percent CI, 0.93 to 1.54) if the two subjects initially classified as failures are reclassified as cures. No other significant differences in outcomes were found by disease severity.

#### C. difficile Strain

A single study assessed initial cure and recurrence by strain, categorized as North American pulsed-field gel electrophoresis type 1 (NAP1) versus non-NAP1.^79^ Strain data was available for 324 of the 629 (51.5%) participants. For initial cure, no significant difference was observed, regardless of strain. However, among patients with non-NAP1 strains, those treated with fidaxomicin recurred less frequently than those treated with vancomycin (10 percent versus 28 percent; P < 0.001), whereas among patients with the NAP1 strain recurrence was similarly frequent regardless of treatment.

#### Patient Characteristics

Our search did not identify any evidence for comparative effectiveness by general patient characteristics such as age, gender, or treatment setting.

#### Resistance of Other Pathogens

The impact of treatment for CDI on other pathogens has not been addressed by the available studies that directly assigned subjects to different drugs. From observational studies, there is some evidence that treatment with either metronidazole or vancomycin can cause an increase in the incidence in the carriage of vancomycin resistant enterococci185,186 however, the magnitude of this effect and the clinical significance are uncertain.

## Key Question 4 What are the Effectiveness and Harms of Nonstandard Adjunctive Interventions?

### Search Results

A total of five RCTs on nonstandard adjunctive treatments of CDI (Table 19) and 13 studies that addressed prevention of CDI (Table 20) formed the basis of this analysis. Four of the studies on treatment of CDI compared a nonstandard intervention with an active control, that is, a standard antibiotic treatment for CDI, oral vancomycin or metronidazole.80-83 One study compared a nonstandard intervention with placebo.84 All of the 13 prevention studies compared the nonstandard intervention to placebo rather than to another intervention, reflecting the current state of this area of science. Five of the 13 prevention studies analyzed antibiotic-acquired diarrhea as a primary outcome and CDI as a secondary outcome.83,85,87,89,188 Numerous published case reports, as well as nonexperimental studies, describe additional nonstandard approaches for treatment of CDI and their possible harms (Table 21).

Table 19 Nonstandard intervention for treatment of initial and recurrent CDI

Study | Sample | Intervention/Comparison and Method | Resolution of CDI (Diarrhea and CD Toxin Positive Stool) | Other Outcomes | Study Quality
Nonstandard Intervention Versus Active Control for Recurrent CDI
Mattila, 2008^82^ Scand J Infect Dis FInland | 40 adults with ≥2 episodes of CDI in past 3 months and stool positive for C. difficile toxin 38 completed the study (95%) Mean age: 61.3 (CDIW 56.4 vs. metronidazole 65.7) Gender: Male 47% | C. difficile immune whey (CDIW) CDIW 200 ml liquid and placebo tablets three times per day × 14 d (n=18) Metronidazole 400 mg tablets and placebo liquid three times per day × 14 days (n=20) CD culture and toxin on days 0, 14, and 28 followup × 7 days Daily stool and symptom diary daily for 42 days Followup after day 28 used stool and symptom diary only | Response to study drugs at day 14 CDIW: 89% (16/18) Metronidazole: 100% (20/20) No statistical testing reported, Fisher's Exact test performed by reviewers p=0.22 | Response to study drugs at day 28 (14 days after treatment) CDIW: 61% (11/18) Metronidazole:60% (12/20) | Allocation concealment: not defined Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes Notes: Sample size not achieved because of bankruptcy of sponsor Although CD culture and toxin were measured and stool diary data collected at day 14, the reported primary endpoint, “response to …study drugs” was not defined nor defined in relation to these measures; the same is true for sustained response at day 28 Secondary outcome of time to treatment failure through day 70 was measured by diarrhea only and not by CD toxin in stool CDIW had no local or systemic side effects
Adjuvant Nonstandard Intervention Versus Active Control for Recurrent CDI
Surawicz, 2000^80^ Clin Infectious Diseases United States | 168 randomized adult inpatients and outpatients with recurrent CDI, 32 on high-dose vancomycin (This paper reported subgroup analysis of treatment of subjects on high-dose vancomycin only) Recurrent CDI subjects Mean age (years): 61.6 Gender: Male (M) 41% | Probiotic-Sacchromyces boulardii (1 g/d) + high dose oral vancomycin (2g/d) (n=16) Placebo (1 g/d) + high dose oral vancomycin (2g/d) (n=16) Probiotic/placebo started on day 7–day 28 CDI was defined as diarrhea (≥3 loose/watery stools/s × 2 days or >8 loose stools/day within 48 hours) and positive CD assay (culture then toxin A or B) measured at multiple time points | Probiotic and vancomycin: 13/16 (81.3%) Placebo and vancomycin: 8/16 (50%) Fisher's Exact test performed by reviewers p =0.06 | | Allocation concealment: adequate, centralized Blinding: double Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: none reported
Wullt, 2003^81^ Scan J Infect Dis Sweden | 29 adult patients with recurrent disease from 9 centers (positive CD toxin assay within 6 days of enrollment at least 1 prior episode CD diarrhea within past 2 months and ongoing diarrhea). 8 patients (28%) lost to followup were not included in analysis, 21 completed trial (72%) Mean age: 63.8 Gender: Male 5% | Probiotic-Lactobacillus plantarum in fruit drink with oats fermented by L. plantarum 299v (5 × 10^10^ cfu) × 38 days and Metronidazole (400 mg three times per day po) × 10 d Placebo fruit drink with chemically acidified oats and metronidazole Toxin testing on days 11–13 followup about diarrhea on days 37–41 and 70–75 Clinical cure was defined as no diarrhea (≥3 loose stools × 2 days) on days 5-10 of treatment: | Probiotic and metronidazole: 92% (11/12) Placebo and metronidazole: 100% (9/9) No statistical testing reported, Fisher's Exact test performed by reviewers p=1.0 | | Allocation concealment: Not defined Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes Notes: CD toxin not measured after day 11
McFarland, 1994^83^ JAMA United States | 124 in patients with active CDI and receiving standard antibiotic treatment (vancomycin or metronidazole) 104 (84%) completed the study Mean age 58.1 Gender: Male 23% 64 patients had initial CDI and 60 had recurrent CDI | Probiotic-Lyophilized S. boulardii 3×10^10^ cfu (1 g) orally in two 250 mg capsules/days × 4 weeks and standard therapy, vancomycin or metronidazole or both (n=57). Probiotic was given within 4 days of treatment Placebo and standard therapy, vancomycin or metronidazole or both (n=67). Both groups followed for 4 weeks and an additional 4 weeks CDI defined as diarrhea ≥3 stools/d × 2 consecutive days and 1 CD positive assay (culture, toxin A or toxin B) Treatment failure was defined as 2 consecutive days of diarrhea, and positive CD assay or pseudomembranes by endoscope at time of diarrhea, diarrhea no attributable to another cause | Resolution of CDI [underlined: Overall (all subjects, n=124)] Probiotic: 73.4% (42/57) Placebo: 55.2% (37/67) p = 0.05 [underlined: Subgroup analysis] Subjects treated for recurrent CD (n=60) Probiotic 65.4% (17/26) Placebo 35.3% (12/34) p=0.04 Subjects treated for initial CD (n=64) Probiotic 81.3% (25/31) Placebo 75.5% (25/33) p=0.86 | | Allocation concealment: Adequate, blinded study drug kits Blinding: double Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: yes Notes: No difference in nausea, pain, or vomiting
Nonstandard Intervention Versus Placebo
Mogg, 1982^84^ Br J Surg United Kingdom | 48 patients on a single surgical unit with severe diarrhea after antibiotic treatment 48 entered study and 10 withdrew (7 on resin and 3 on placebo), 38 analyzed (79%) No information on age and gender. Diarrhea defined as ≥3 loose stools/day or more than 1 L of drainage from colostomy Previous placebo group (n=22) from prior study of vancomycin and placebo on same unit. | Absorptive resin Colestipol 10 g every day mixed in fruit squash × 5 days (n=17) Placebo (sherbet) (n=21) Stool tested for CD cytotoxin at study start, on day 3 and last day of treatment (day 5) Outcome was defined as return of diarrheal stool to normal, (i.e., 2 solid stools in 24 hours) in stools that were positive for C. difficile OR its toxin | Colestipol: 3/12 (25%) Placebo: 3/14 (21%) | | Allocation concealment: Possibly adequate (“identical placebo”) Blinding: not reported Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes Notes: CD cytotoxin was not present in all subjects reported as cases No statistical testing Some historical controls included with concurrent controls CD treatment and prevention findings were combined (i.e., findings of subjects with C. difficile or its toxin in stool before receiving the intervention were combined with those who acquired these during the intervention)

CD = Clostridium difficile; CDI = Clostridium difficile infection

Table 20 Probiotic or prebiotic interventions for prevention of initial and recurrent CDI

Study/Design | Sample | Intervention/Comparison and Method | C. difficile Diarrhea (Diarrhea and CD Toxin +) | Later Recurrence of CD Diarrhea | CD Toxin+ | Notes of Study Quality and Side Effects
Primary Prevention of Initial CDI
Surawicz, 1989^85^ Gastroenterology United States RCT | 318 hospitalized patients given new antibiotics 180 completed study, 138 had C. difficile tested Mean age: 46.5 years Gender: Male 69% | Probiotic: Sacchromyces boulardii (250 mg capsule with 1 g S. boulardii bid (n=116) Placebo bid (n=64) Stools collected for CD culture at entry, day 5 then q 10 d, end of study, and when have diarrhea (diarrhea ≥3 loose/watery stools/s × 2 d); CD culture + stools were tested for cytotoxin; need 3 stools tested for CD and ≥8 days of monitoring for inclusion | [underlined: Overall incidence of CDI:] Probiotic: 3/116 (2.6%) Placebo: 5/64 (7.8%) Fisher's Exact test performed by reviewers p=0.13 [underlined: Incidence of diarrhea in 48 patients had stools that were CD toxin+]: Probiotic: 3/32 (9.4%) Placebo: 5/16 (31%), test of significance between groups p=0.07 | | | Allocation concealment: not defined Blinding: double Intention-to-treat analysis*: no, 138 not evaluated (43%) Withdrawals and dropouts adequately described: yes
McFarland, 1995^188^ Am J Gastroenterol United States RCT | 193 hospitalized adult patients receiving new beta-lactam antibiotic with or without another antibiotic and no diarrhea 129 (67%) completed study Mean age: 42 years Gender: Male 65% | Probiotic: Lyophilized S. boulardii 3×10^10^ cfu (1 g) orally in two 250 mg capsules/d within 72 hours of antibiotic and until max of 28 days (n=97) Placebo 1 g (undefined) (n=96) Followup for 7 days after stopping drug | [underlined: Overall incidence of AAD:] Probiotic: 3/97 (3.1%) Placebo: 4/96 (4.2%) Fisher's Exact test performed by reviewers p=0.72 [underlined: Development of ADD in 24 patients with positive CD assays:] Probiotic: 3/10 (30%) Placebo: 4/14 (29%) (The power of detecting a significant difference based on the sample size of 24 and the above rates was less than 3%) | | | Allocation concealment: adequate (appearance and odor of the capsules of interventions were identical, done centrally Blinding: double Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: yes Notes: 3 reviewers of diarrhea
Lewis, 1998^86^ J Infect United Kingdom RCT | 72 Hospitalized elderly (≥65 years) patients started on antibiotics Mean age (range): 74 (70-85) years Gender not reported (“no difference between sex”) | Probiotic: S. boulardii (113 mg) (Ultra-Levure, Biocodex, Montrouge, FR) 2×/day (n=33) Placebo (undefined) 2×/day (n=36) Stool sample sent to lab every 4^th^ day or if diarrhea (≥3 loose stools in 24 hours) to test for CD toxin | [underlined: Overall incidence of CDI:] 4 patients had diarrhea stools that were CD toxin+ (not reported by treatment arm) No statistically significant difference in diarrhea stools with + CD toxin between probiotic and placebo (data and percents not reported) | | CD toxin only Probiotic: 5/33 (15%) Placebo 3/36 (8%) No statistical testing done | Allocation concealment: adequate (pharmacy-controlled) Blinding: probably double, nursing staff blinded to treatment assignment Intention-to-treat analysis: no, 3 excluded Withdrawals and dropouts adequately described: yes
Thomas, 2001^87^ Mayo Clinics United States RCT | 302 hospitalized patients on antibiotics 267 (88%) completed study Mean age (range): 56 (18-93) years Gender: Male 54% | Probiotic: Lactobacillus GG (20 × 10^9^ cfu + inulin filler) (CAG Functional Foods, Nebraska) 1 capsule 2×/d × 14 d (n=133) Placebo (inulin filler) (n=134) | [underlined: Overall incidence of CDI:] Only 5 patients (1.9%) with positive CD toxin: Probiotic: 2/133 (1.5%) Placebo: 3/134 (2.2%), p >0.99 | | CD toxin in 1^st^ 21 days after enrollment per retrospective chart review data of patients with CD at hospital Probiotic: 5/133 (4%) Placebo: 3/134 (2%), no statistical testing | Allocation concealment: adequate (pharmacy-controlled) Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes Notes: CD results by randomized chart review How tested for CD toxin not reported No association of diarrhea with CD toxin+
Plummer, 2004^88^ International Microbiol United Kingdom RCT | 150 elderly hospitalized patients started on antibiotics 138 (92%) completed study Age and gender not reported | Probiotic: Lactobacillus acidophilus and Bifidobacterium bifidum, 2 × 10^10^ cfu in 1 capsule/d (Cultech, Saansea) for at least 20 of antibiotic therapy (n=69) Placebo (n=69) Start therapy within 36 hours of antibiotics, probiotic = 1.12 days after antibiotics placebo = 1.10 day Stools were cultured for C. difficile, then if culture +, CD toxins A and B were tested; - at start of study; - if diarrhea; - after antibiotics completed during hospitalization or discharge | [underlined: CD diarrhea, 1st testing, during diarrhea and antibiotic tx in hospital:] Probiotic: 2/69 (3%) Placebo: 5/69 (7%), no statistical testing reported, Fisher's Exact test performed by reviewers p=0.44 Proportion developing diarrhea positive for CD toxins was 4.35% lower in probiotic group (95% CI of –0.132 to 0.038). [underlined: CD diarrhea, 2^nd^ testing of same patients after antibiotics completed or at discharge:] Probiotic: 2/69 (3%) Placebo: 6/69 (9%) | | | Allocation concealment: not defined Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: no Notes: Diarrhea is undefined Study participation stopped if on antibiotics >20 days
Lewis, 2005^91^ Aliment Pharmacol Ther United Kingdom RCT | 450 hospital patients ≥65 years prescribed a broad spectrum antibiotic within past 24 hours 15 (3.3%) patients withdrew or were withdrawn from study N=435 who finished Mean age (range): 77 (70–84) years Gender: Male 49% | Prebiotic: Oligofructose (12 g/d) (n=215) Placebo (sucrose 12 g/day) (n=220) Taken during antibiotics + 7 days after Follow up for additional 7 days C difficile toxin was measured if diarrhea (1-2 loose stools/day) | 54 (12%) patients were culture-positive for C. difficile on study entry. Prebiotic: 19/213 (9%) Placebo: 21/220 (9.5%), no statistical testing reported, Fisher's Exact test performed by reviewers p=0.87 | | | Allocation concealment: Unclear Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes Notes: Subjects were withdrawn from study if they experienced significant diarrhea (>3 stools/day) Stated intent to treat but some % are for N=433 not 435 or 450 who enrolled No increase in bloating, stool form or interval between stools by prebiotic
Can, 2006 89 Med Sci Monit Turkey RCT | 151 adult inpatients between 25–50 years who had chemotherapy and antibiotics Gender: Male 95% | Probiotic: S. boulardii + antibiotics (β lactam) (n=73) Placebo + antibiotics(n=78) 2×/day started 48 hours or less after antibiotic therapy started for duration of antibiotic tx CD toxin A tested in those with diarrhea | [underlined: Overall incidence of CDI:] 8 patients had diarrhea, only two CD toxin + (both in the placebo group Probiotic: 0/73 (0%) Placebo: 2/78 (2.6%) Fisher's Exact test performed by reviewers p=0.50 | | | Allocation concealment: not defined Blinding: double Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: none reported Notes: Duration of probiotic may have been variable Diarrhea is undefined
Hickson, 2007^90^ BMJ RCT | 135 hospital patients taking antibiotics were given tx until tx was finished + 1 week; If discharged from hospital and stayed on antibiotics, they continued tx; CD testing and followup occurred for 4 weeks after tx ended 11/2002-1/2005 22 (16%) patients lost to followup and not included in the analyses 12 in probiotic group and 10 in placebo 4 pts not tested for CD (1 on probiotics and 3 on placebo) Mean age: 74 years Gender: Male 46% | Probiotic: L. casei DN-114 001 (L casei imunitass, 1 × 10^8^ cfu/ml) + S.thermophilus (1 × 10^8^ cfu/ml) + L. bulgaris (1 × 107 cfu/ml) in yogurt drink (Actimel, Danone, FR) (n=69) Placebo: sterile milkshake (Yazoo, Campina NE) (n=66) Drinks consumed during antibiotics therapy + 1 week CD toxins A and B tested in diarrheal stools CD diarrhea = CD toxins A and/or B and diarrhea stools (2 liquid stools/d × 3 or more days in an amount greater than normal for the patient) | [underlined: Overall incidence of CDI:] Probiotic: 0/57 Placebo: 9/53 (17%), p=0.001 Absolute risk reduction = 17% (95% CI 7% to 27%) NNT = 6 (4 to 14) | | | Allocation concealment: adequate (pharmacy -controlled) Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes Notes: Good compliance with drink, 75% for probiotic and 79% placebo Type CD toxin not specified No adverse events from either drink
Prevention of Recurrent CDI
McFarland, 1994^83^ JAMA United States | 124 in patients with active CDI and receiving standard antibiotic treatment (vancomycin or metronidazole) 104 (84%) completed the study Mean age 58.1 Gender: Male 23% 64 patients had initial CDI and 60 had recurrent CDI | Probiotic-Lyophilized S. boulardii 3×10^10^ cfu (1 g) orally in two 250 mg capsules/days × 4 weeks and standard therapy, vancomycin or metronidazole or both (n=57). Probiotic was given within 4 days of treatment Placebo and standard therapy, vancomycin or metronidazole or both (n=67). Both groups followed for 4 weeks and an additional 4 weeks CDI defined as diarrhea ≥3 stools/d × 2 consecutive days and 1 CD positive assay (culture, toxin A or toxin B) Treatment failure was defined as 2 consecutive days of diarrhea, and positive CD assay or pseudomembranes by endoscope at time of diarrhea, diarrhea no attributable to another cause | | Probiotic: 41.3% (51/124) subjects with no recurrence Placebo: 24.3% (8/33) with initial CDI had CDI recurrence and 64.7% (22/34) with recurrent CDI had another recurrence no statistical testing | | Allocation concealment: Adequate, blinded study drug kits Blinding: double Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: yes Notes: The absence of CDI recurrence for the probiotic group was reported as a percent of the entire sample and not of the probiotic group. No difference in nausea, pain, or vomiting
Surawicz, 2000^80^ Cl Infectious Diseases United States RCT | 32 randomized adult inpatients and outpatients, 32 with recurrent CDI CD disease subjects Age: 61.6 Gender: Male 41% | CDI subjects Probiotic: S. boulardii (1 g/d) + high dose oral vancomycin (2g/d) (n=16) Placebo (1 g/d) + high-dose oral vancomycin (2g/d) (n=16) Probiotic/placebo started on day 7 - day 28 CDI = diarrhea + (≥3 loose/watery stools/s × 2 days or >8 loose stools/day within 48 hours) and positive CD assay (culture then toxin A or B) measured at multiple time points | | Recurrence: Probiotic: 3/18 (17%) Placebo: 7/14 (50%), p=0.05 | | Allocation concealment: adequate, centralized Blinding: double Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: none reported
Wullt, 2003^81^ Scan J infect Dis RCT | 29 adult patients from 9 centers with + CD toxin assay within 6 days of enrollment at least 1 prior episode CDI diarrhea within past 2 months. And ongoing diarrhea 8 patients (28%) lost to followup were not included in analysis, 21 completed trial Mean age: 63.8 years Gender: Male 5% | Probiotic: L. plantarum in fruit drink with oats fermented by L. plantarum 299v (5 × 10^10^ cfu) × 38 days and Metronidazole (400 mg tid po) × 10 days Metronidazole + placebo fruit drink with chemically acidified oats | [underlined: Clinical cure:] no diarrhea (≥ 3 loose stools × 2 days) on days 5-10 of tx Probiotic: 11/12 (92%) Placebo: 9/9 (100%) | [underlined: Total recurrences:] Probiotic: 4/11 (36%) Placebo: 6/9 no statistical testing reported, Fisher's Exact test performed by reviewers p=0.37 | [underlined: CD toxin negative]: Probiotic:7/1 2 (58%) Placebo: 5/9 (56%), p=.642 | Allocation concealment: Not defined Blinding: double Intention-to-treat analysis: no Withdrawals and dropouts adequately described: yes
Lewis, 2005^92^ Clin Gastroenterol Hepatol RCT | 142 consecutive elderly (≥65 years) in patients with CDI and treated by their physician with metronidazole or vancomycin for 10 days (if treatment failure (diarrhea and CD toxin A and B) or intolerance with metronidazole). Mean age: 75 years Gender: Male 58% | Prebiotic: Oligofructose (12 g/d) (n=72) Placebo (sucrose 12 g/day) (n=70) Taken as soon as possible after dx of CD diarrhea and + 30 days after CDI diarrhea = 3 loose stools in 1 day and + CD toxin | | [underlined: Relapse of diarrhea] (CD was not retested) Prebiotic: 6/72 (8.3%) Placebo: 24/70 (34.3%), p<0.0001 | | Allocation concealment: Not defined Blinding: single Intention-to-treat analysis: no, 1 was lost to followup and 8 never resolved diarrhea to be able to relapse and were excluded Withdrawals and dropouts adequately described: yes Notes: CD was not measured at diarrhea recurrence
Lowy, 2010^95^ N Eng J Med United States and Canada RCT | 200 inpatients and outpatients were ≥18 years of age with diarrhea associated with a positive stool test for CD toxin(s) in the 14 days prior to enrollment and who were receiving either metronidazole or vancomycin Mean age (range): 64 (20-101) years Gender: Male 34% White race: 88% Black race: 6% Severe disease at enrollment: 40% | Monoclonal antibodies: intravenous infusion of fully human monoclonal antibodies against C. difficile toxins A (CDA1) and B (CDB1) × 1 (n=101) Placebo (0.9% sodium chloride) × 1 (n=99) Recurrence of C. difficile infection, was defined as a new episode of diarrhea associated with a new positive stool toxin test after the resolution of the initial CDI diarrheal episode and after discontinuation of metronidazole or vancomycin. Diarrhea was defined as three or more unformed stools per day for at least 2 consecutive days or more than six unformed stools in 1 day | | [underlined: Incidence of laboratory documented CDI - primary outcome):] Monoclonal antibodies: 7/101 (7%); inpatient = 7/50, outpatient = 0/51 Placebo: 25/99 (25%); inpatient = 13/52, outpatient = 12/47, p=0.0004 Recurrent diarrhea With/without laboratory confirmation of CDI and with/without antibiotic treatment for CDI Monoclonal antibodies: 28/101 (28%) Placebo: 49/99 (50%), p=0.0022 | | Allocation concealment: not defined Blinding: double and independent statistician and data and safety monitoring board Intention-to-treat analysis: yes Withdrawals and dropouts adequately described: yes Adverse events reported in 14 patients (antibody group = 9; placebo = 5) during infusion and in 11 patients (antibody group = 6; placebo = 5) during 2-hour period after infusion. All AE noted to be mild to moderate (headache reported most frequently) Death: antibody group = 7; placebo = 8 (p=0.79)

CD = Clostridium difficile; CDI = Clostridium difficile infection; RCT = randomized controlled trial

Table 21 Summary of case studies/series and potential harms of nonstandard interventions for CDI

Intervention | # of Reports | Patient N | Type of CDI Patient | Study Aim | Outcome | Reported Adverse Events
Fecal flora reconstitution | 6^96,97,128-130,193^ | 60 | Recurrent CDI | Treatment | 73% – 100% symptom free, up to 1 year | 1 case IBS
Cholestyramine | 2^191,192^ | 2 | CDI with PMC | Treatment, primary CDI | 1 patient rapid symptom relief | Not reported
IV hemoperfusion, vancomycin | 1^201^ | 2 | CDI with PMC | Treatment, primary CDI | PMC resolved in 7 days | Not reported
Probiotics | 3^93,189,190^ | 5 (plus 57 from literature review) | 4 ICU patients,1 recurrent CDI (plus 41 patients with fungemia, 14 ICU) | Treatment | | 1 case S. pneumonaie and secondary L. rhamnosus septicemia and death. 46% fungemia patients previously given probiotics
Nontoxigenic C. difficile strain | 1^200^ | 2 | CDI patients failing antibiotic treatment | Treatment | Symptom decrease, 1 patient resolved | Constipation
Monoclonal antibody for C. difficile toxin A | 1^194^ | 30 | Healthy young adults | Safety study | | 3 moderate AE (low BP, diarrhea), 18 mild AE (headache, nausea, loose stools, abdominal discomfort BP changes)
Intravenous Tigecycline | 1^198^ | 4 | CDI with PMC | Treatment, severe refractory | Symptom decrease within 7 days | Not reported
C. difficile toxoid vaccines | 2^199,202^ | 3 (plus 30 healthy adults) | First CDI relapse | Treatment (safety study) | | Mild headache, mild abdominal pain, rash, 1 CDI relapse patient polyarthritis
Intravenous immunoglobulin | 4^83,106,196,197^ | 37 | CDI, recurrent, refractory, severely ill | Treatment | 54% symptom resolution, of these, 20% patients had recurrence or toxin still present | 1 case pulmonary edema

AE = adverse event; BP = blood pressure; CDI = Clostridium difficile infection; IBS = irritable bowel syndrome; ICU = intensive care unit; IV = intravenous; PMC = pseudomembranous colitis

Due to the heterogeneity of the interventions, quantitative analysis was not possible. We therefore provide a narrative review of the literature.

### Key Points

- Overall, study quality was low.
- C. difficile immune whey in one study of 38 patients was similar to standard antibiotic treatment with metronidazole in treating recurrent CDI.
- Colestipol plus metronidazole in one study was not more effective than placebo plus metronidazole.
- Administration of a probiotic to treat CDI in critically ill patients increases risk for greater morbidity and mortality from fungemia without any known benefit.
- There is low-strength limited evidence that the nonstandard interventions in this review are not more effective than placebo for primary prevention of CDI.
- There is low-strength limited evidence from one subgroup analysis that a prebiotic may reduce diarrhea recurrence in patients treated for CDI more so than placebo with standard antibiotics.
- There is limited moderate-strength evidence from one study that monoclonal antibodies are effective in preventing recurrence of CDI.
- There is limited low-strength evidence from 6 case studies/series with 60 patients that fecal flora reconstitution is effective in treating recurrent CDI for up to 1 year.
- Data are inconclusive about the benefit of intravenous immunoglobulin as an adjuvant treatment for severe CDI.
- Definitions of CDI with regard to diarrhea, that is, number and consistency of stool, were inconsistent across studies.

### Quality of the Studies

The level of the quality of the evidence is low. Several study limitations lowered the quality of their findings. Among the most common were lack of a power analysis, inadequate power to detect significant differences, lack of an intent-to-treat analysis, and failure to define allocation concealment. In one study, the findings of subjects with CDI at the start of a nonstandard intervention were combined with those who developed CDI after the intervention.84 The problem of a nonstandardized, incomplete, or unspecified definition of CDI has already been noted. In one study, a culture of C. difficile (which could have indicated a nontoxigenic strain of the organism) was accepted in place of, or in addition to, a toxin test for the definition of CDI for some patients.84 Longer term followup for CDI incidence or recurrence sometimes relies on reports of diarrhea without retesting for C. difficile toxin. Although probiotics may have been intended solely for prevention of recurrent CDI in some studies, they were included among treatments for recurrent CDI because the probiotic was administered concurrently with a standard antibiotic during treatment and not after recurrent CDI was cured.80,83 Thus, it is not possible to restrict the effect of the probiotic for prevention of future CDI recurrence only. Whether the results of CDI as a secondary outcome are weaker than the primary outcome of AAD due to an underpowered subgroup analysis cannot be determined. There was known lack of adequate power for the primary outcome in one of these studies,87 and no power analysis for the primary outcome was reported in the other four studies.83,85,89,188 There was lack of standardization of the active control in two studies, allowing subjects to receive an antibiotic for CDI as prescribed by their physicians.91,95 Summaries of study quality and strength of evidence are provided in Appendix Tables C9 and C10.

### Detailed Analysis

#### Defining the Outcome of CDI

The operative definition of diarrhea, which is part of the definition of CDI, varied among the studies for prevention and treatment of CDI (Tables 19 and 20). Six of the studies defined diarrhea as three or more loose or liquid stools per day for 2 days.80,81,83-85,95 One study required that same number and consistency of stools but for only 1 day,86 and another study did not require the three stools per day to be loose or liquid.83 One study required two liquid stools on 3 or more days.90 The most liberal definition of diarrhea was one to two loose stools per day.91 Diarrhea due to C. difficile was not explicitly defined in four studies (6 percent).82,87-89

#### Treatment of CDI

The effectiveness of two types of nonstandard interventions were compared for treating CDI, agents that bind or absorb C. difficile toxins,82,84 and probiotics that aim to recolonize the intestinal flora with nonpathogenic bacteria80,81,83 (Table 19). All interventions were administered orally. Probiotics were the only intervention administered as an adjunct to standard antibiotic treatment for CDI;80,81,83 the other nonstandard interventions were administered independently. The probiotic in two studies contained Sacchromyces boulardii80,83 and in one it contained Lactobacillus plantarum.81

Subjects in the treatment studies had a mean age ranging from 58 to 67 years. Females comprised more than 70 percent of the sample in three of the six studies,80,81,83 and, in one study, the age and gender of subjects were not reported.84 Subjects were hospital inpatients in two studies.80,83,84

The findings of the studies in Table 19 are presented in the same direction, that is, as CDI resolution (versus treatment failure) to facilitate comparison and interpretation. In all studies of CDI treatment, the main outcome was the incidence of resolving CDI, which was defined as diarrhea in patients with a positive stool test for C. difficile toxin.

#### Treatment of Primary CDI

The rate of resolution of CDI was the lowest in the study comparing an absorptive resin (25 percent of subjects) to placebo (21 percent of subjects); no statistical results were reported.84 Resolution rates for probiotic (81 percent of patients) compared to placebo (76 percent of patients) were not statistically different in another study.83

#### Treatment of Recurrent CDI

In three comparative treatment studies the subjects recruited were treated for a recurrent (rather than an initial) episode of CDI.80-82 A third study conducted a subanalysis of their subjects with recurrent CDI.83 In all four studies, the nonstandard intervention was probiotic. There was no significant difference in the resolution of CDI between the interventions compared in three of the studies80-82 based on reported statistics or those conducted by the reviewers. In the study that analyzed a subset of their patients with recurrent CDI, a significantly higher percentage of subjects on a standard antibiotic plus a probiotic resolved diarrhea compared to those on a standard antibiotic and a placebo.83

#### Prevention of Primary CDI

The nonstandard interventions investigated for preventing CDI were (1) probiotics,85-90 (2) a prebiotic (oligofructose) that aims to support a normal ecology of bacteria,91,92 and (3) a monoclonal antibody to C. difficile toxins95 (Table 20). Six different probiotics were tested, and in two of the eight studies, the probiotic contained more than one strain of bacteria.88,90 Seven of the 12 CDI prevention trials using nonstandard interventions focused on primary prevention, i.e., avoiding a first occurrence of CDI.85-91 All of the studies of primary prevention of CDI investigated either a probiotic (six studies) or a prebiotic (one probiotic). Two studies that tested a nonstandard intervention for treating CDI also investigated its ability to prevent CDI recurrence.80,81

Subjects in the primary prevention studies had a mean age of 47 to 77 years. Females comprised less than one-third of the sample in two studies85,89and, in one study, the age and sex of the sample were not reported.88 Subjects in all of the primary prevention studies were hospitalized patients.

The overall incidence of CDI across intervention groups was relatively low, ranging from 2 percent to 9 percent. Only one of seven studies, which investigated a mixture of two probiotics (L. casei and S. thermophilus), showed a significantly lower incidence of CDI diarrhea compared to placebo;90 the investigators of this study acknowledged that the study was underpowered to detect a significant difference greater than by chance. In four studies, statistical testing was not reported.86,87,89,91 Based on reported statistics, or those conducted by the reviewers, there was no significant difference in the recurrence of CDI between any of the interventions and placebo in the six other studies.85-89,91

There is disagreement in the research community regarding the appropriateness of pooling results of probiotics due to the heterogeneity of probiotic organisms used and variability in dosing. We provide a forest plot (Figure 5) of the effects of probiotics on overall incidence of CDI from the primary prevention probiotic trials for those who view such aggregation as reasonable. The pooled RR is 0.40 (95 percent CI, 0.20 to 0.83). The prebiotic trial showed no effect.

Figure 5 Overall incidence of CDI from probiotic primary prevention trials

CI = confidence interval; M-H = Mantel-Haenszel test

Figure 5 is a forest plot type of diagram depicting the overall incidence of Clostridium difficile-associated disease (CDAD) from probiotic primary prevention versus placebo trials. The left column lists the names of the authors and the years of the publications for the studies for risk factors and the studies of incidence or prevalence of chronic diseases. Information on total CDAD evental under either treatment or placebo is also provided. The right column is a plot of the measure of effect with 95 percent confidence limits. The right column shows the relative risk for developing CDAD. Relative risk is presented by a square incorporating confidence intervals represented by horizontal lines. A vertical line representing no effect or zero differences in the scores is also plotted. If the confidence intervals for individual studies do not overlap with this line, it demonstrates differences in relative risk of probiotic prevention vs. placebo. Figure 5 shows that the pooled risk ratio of all six studies combined favors probiotic treatment.

#### Prevention of Recurrence of CDI

Five studies investigated the effectiveness of a nonstandard intervention to prevent the recurrence of CDI (Table 20). Three studies investigated a probiotic,80,81,83 one a prebiotic,92 and one a monoclonal antibody to C. difficile.95 The mean age of subjects ranged from 58 to 75 years. Females comprised 70 percent or more of the subjects in three studies.80,81,83 Hospital inpatients comprised the sample in two studies83,91 and were included along with nonhospitalized subjects in a second study.80 The overall recurrence rate of CDI across intervention groups ranged from 6.5 percent to 34.5 percent.

A significantly lower rate of CDI recurrence was reported in two studies following administration of the prebiotic oligofructose92 or a monoclonal antibody to C. difficile toxins A and B.95 In both studies, the recurrence rate of CDI was approximately three times as great in subjects on placebo compared with the intervention. There was no significant difference in the recurrence of CDI in subjects taking probiotics80,81 compared to controls. In one study comparing a probiotic versus placebo as adjuvants to standard antibiotics, no conclusions could be made since no statistical testing was conducted and findings of similar subgroups were not reported.83 For example, patients with initial or recurrent CDI participated in the study but the recurrence rate was not reported by the type of CDI as enrollment for the probiotic group.83

#### Additional Nonstandard Approaches

In addition to the nonstandard interventions for CDI addressed in this review, case reports, or nonexperimental studies reveal numerous other approaches for treating or preventing CDI (See Table 21; Appendix Table C11 is the evidence table). Use of other probiotics (for example, yogurt containing live bacterial cultures)93,189,190 and other cytotoxin absorbing resins191,192 have been reported.

Another approach under investigation for treatment of recurrent or refractory CDI is fecal flora reconstitution, which instills feces from a healthy donor into the colon of a patient with CDI. Six case studies/series have been published,96,97,128-130,193 four within the last 2 years. 128-130,193 Of a total of 60 patients; 52 patients (87 percent) resolved diarrhea and experienced no further relapse during followup. Two studies reported relapse of diarrhea in 7 of 34 patients (21 percent). Followup periods ranged from 3 weeks to 8 years.

Other nonstandard interventions include a monoclonal antibody to C. difficile toxin A,194 intravenous immunoglobulin,106,195-197 two nonstandard antibiotics, Tigecycline,198 a C. difficile toxoid vaccine,199 and a nontoxigenic strain of C. difficile.200

#### Potential Harms

Harmful effects of nonstandard interventions for CDI appear to be few, but not all studies or case reports included adverse effects in their finding (Tables 19–21). A serious potential harm associated with administration of probiotics for CDI in critically ill patients is fungemia.93,94 In one review of an outbreak, previous medical charts, and the literature, 46 percent of 60 critically ill patients who developed fungemia had been administered a probiotic, and 28 percent subsequently died.93 In addition, McFarland reported finding 12 cases of Lactobacillus bacteremia in patients (mostly children) taking a probiotic containing Lactobacillus.11 Minor adverse symptoms of probiotics and prebiotics were abdominal symptoms such as nausea, bloating, and vomiting, and they have not differed significantly from those of subjects receiving placebo or an active control.11,83,91 Headache (one subject), and abdominal pain, change in bowel habit, and polymyalgia rheumatica (one subject) occurred following C. difficile vaccination.199 Hypotension, diarrhea, headache, nausea, and abdominal discomfort were reported after administration of a monoclonal antibody to C. difficile toxin A.194