# Methods

## Topic Refinement

The topic for this report was nominated in a public process through the Agency for Healthcare Research Quality's nomination Web site. We drafted the initial key questions with input from a key informant panel composed of researchers; clinicians; professional organizations representing hospitals, infectious diseases, and clinicians; federal and state agencies; patient-safety advocates; and consumers. After approval from AHRQ, the key questions were posted to a public Web site. The public was invited to comment on these questions. After reviewing the public commentary and conferencing with the Technical Expert Panel (Appendix A), we drafted final key questions and submitted them to AHRQ for approval.

## Systematic Review

### Search Strategy

Our search strategy used the key word “difficile” to identify all articles related to C. difficile because we found the keyword to be a more sensitive term than the National Library of Medicine's Medical Subject Headings (MeSH) keyword nomenclature. Articles were limited to English language, humans, and MeSH filters for adult populations. We searched MEDLINE, AMED, the Cochrane Library, and ClinicalTrials.gov. Details of the major search strategies are provided in Appendix B.

To identify systematic reviews, we searched MEDLINE, the Cochrane Database of Systematic Reviews, and the Web sites of the National Institute for Clinical Excellence, Guidelines.gov, and the NHA Health Technology Assessment Programme. We used results from previously conducted meta-analyses and systematic reviews when appropriate. We also manually searched reference lists of review articles and articles that were read for the review. All citations were imported into Refworks for initial screening, and then EndNote X for database management.

During the manual search of included articles' reference lists, we found a number of studies not identified in our original search. We performed a forensic examination of those missed articles and determined that diagnostic test and prevention articles in particular were often not indexed by patient ages. We therefore performed a second search without the age filters. These search strategies are also included in Appendix B.

We conducted the initial searches in October 2009. The no-age filtered searches were conducted in February 2010 and updated in March and June 2010. An updated search was performed specifically for Key Question 3 (standard treatment) in August 2011, because of a significant new study that led to FDA approval of fidaxomicin in May 2011.

### Inclusion/Exclusion Criteria

In brief, we developed criteria for inclusion and exclusion of studies based on the patient populations, interventions, outcome measures, and types of evidence specified in the key questions. We retrieved full-text articles of potentially relevant abstracts and conducted a second review for inclusion by reapplying the inclusion criteria. Results published only in abstract form are generally not included in our reviews unless adequate information was available to assess the validity of the data. Full details by key question are provided below.

#### Key Question 1

##### Patients

We restricted the review to studies that used clinical stool specimens from patients suspected to have Clostridium difficile-associated infection (CDI). Information that described patient characteristics that could be related to CDI, hence test performance, was of particular interest.

##### Study Selection

We sought studies that concurrently compared at least two diagnostic tests in the same laboratory using the same stool samples and the same reference standard. This was done in order to reduce the heterogeneity in the estimates of differences in sensitivity and specificity, given the inter- and intralaboratory variation in the application of diagnostic tests for toxigenic C. difficile, the varying accuracy of the reference standards, and differences in patient and stool specimen characteristics. Diagnostic tests of interest were the immunoassays commonly used in the United States to test for the presence of both toxins A and B, and newer tests to detect the presence of C. difficile gene fragments involved in the production of toxin. We did not include articles that only compared tests that are not currently commercially available in the United States. We focused on tests for toxigenic C. difficile because the presence of toxins is a requisite for diagnosing clinical disease or CDI. We sought diagnostic studies that included patient outcomes or outcomes related to changes in therapy.

##### Measures of Diagnostic Accuracy

We sought to compare diagnostic tests in terms of differences in their sensitivity (true positives for toxigenic C. difficile) and specificity (true negatives for toxigenic C. difficile). These statistics are believed to be most relevant to clinical decisionmakers. To be consistent with other common statistical analyses, such as receiver operator characteristic curves and likelihood ratios, we present and discuss study results in positive terms, that is, true positives (sensitivity) and false positives (1 minus specificity). The review was restricted to studies that used toxigenic culture, cell cytotoxicity assay, or combinations of tests as the reference test for the presence or absence of toxigenic C. difficile. To be able to compare estimates of sensitivity and specificity, the report had to provide the counts of test results for those that were positive or negative according to the reference test. Direct comparisons of diagnostic tests without a reference test were not included.

#### Key Question 2

##### Patients

We included studies targeting adult patients at risk for exposure to C. difficile in hospital and long-term care facilities.

##### Interventions

We included studies that examined the effects of prevention strategies aimed at (1) breaking routes of transmission within institutional settings, the major focus of institutional infectious disease programs, and (2) reducing susceptibility to CDI through antibiotic prescribing practices. Reducing susceptibility to CDI through other agents is covered in Key Question 4.

##### Comparators

No restrictions were placed on the comparators, although we anticipated that most studies would use some form of usual processes of care.

##### Outcomes

We included only studies with CDI incidence, or other measures of CDI as an outcome. We excluded studies that used only process measures, or intermediate outcomes, such as reduced spore count in environmental samples, and did not tie these measures to CDI incidence. We looked for harms including difficulties experienced by employees responsible for environmental cleaning, or overtreatment harms, such as increased exposure risk to CDI if a patient without CDI is located in an isolation ward. We also sought evidence for how well prevention strategies and practices can be sustained past a study period or a period of intensive effort and monitoring.

##### Study Designs

Accepted study designs included randomized controlled trials (RCTs), prospective cohort, retrospective cohort, time series, and before/after trials.

In addition to studies examining prevention practices, we also identified good quality studies that identified specific risk factors for development of CDI to facilitate infectious disease control efforts to target likely effective preventive strategies. Inclusion criteria were: (1) prospective study design; (2) the methods for the risk factor analysis were specified; (3) the study included a clearly defined control group; (4) the study was of risk for CDI, not C. difficile colonization; (5) the CDI definition included diarrhea and a positive test for C. difficile toxin, and (6) the population was general hospital inpatients, not specialized patients. We included studies in which the influence of confounding variables was minimized in one of three ways: (1) randomization; (2) possible confounding variables were controlled in case and control selection process; or (3) multivariable analysis was done to determine the relative contribution of each potential risk factor included in the study.

#### Key Question 3

##### Patients

We included target populations of adult patients with clinical signs consistent with CDI in hospital, outpatient, or long-term care settings. We also looked for studies assessing efficacy when stratified by disease severity or strain, or by patient characteristics such as age, gender, comorbidity, and location of disease acquisition.

We sought studies that examined differences in treatment effect by disease severity. We did not exclude any studies based on the definitions they used for disease severity. In mild disease, discontinuation of the inciting antibiotic may be sufficient to resolve the symptoms of CDI,115,150 making it difficult to detect any difference in the efficacy of antimicrobial therapy. In severe disease, differences in treatment efficacy are easier to detect and are of more importance because of the high morbidity and mortality associated with severe CDI.151 However, a major difficulty with stratifying therapy by disease severity is the lack of a standardized, reproducible, and validated tool for measuring severity.110,152 Elements that have been incorporated into various severity definitions include, but are not limited to, age, degree of leukocytosis, fever, ileus, endoscopic findings, presence of fecal leukocytes, and need for intensive care unit treatment or colectomy.70

We sought studies that examined the comparative effectiveness of the antimicrobial treatments by organism strain. We also sought evidence of the potential impact of CDI treatment on developing antibiotic resistance in other infectious pathogens. There has historically been reluctance to use vancomycin as a first-line drug for CDI because of the drug's important role in treating serious bacterial infections, especially drug-resistant Gram-positive organisms such as methicillin-resistant Staphylococcus aureus and penicillin-resistant Streptococcus pneumoniae. However, with the increase in CDI incidence and severity,3,153 and a randomized trial reporting superiority to metronidazole in treating severe CDI,70 this reluctance has been largely overcome. This may also be due to the high levels of vancomycin, which would likely inhibit even strains with reduced susceptibilities to vancomycin, and the emerging recognition that vancomycin resistance is complex (versus a single mutation).154

##### Interventions

We sought studies that tested vancomycin, metronidazole, bacitracin, nitazoxanide, rifaximin, fidaxomicin, and rifampin, which have only been studied as an adjunct to other active drugs. As fusidic acid and teicoplanin are not currently approved for use in the United States, these treatments were excluded. Fidaxomicin was added as an intervention because FDA approval was granted in May 2011.

##### Comparators

We sought studies that compared two active antimicrobial treatments, although we accepted studies that included placebo as the comparator for the two antimicrobials of interest, vancomycin and metronidazole.

##### Outcomes

We included initial cure, recurrence (variably defined by symptoms with or without a positive test for C. difficile), and mortality, which are outcomes of interest to clinicians and are reported in most studies. We also included time to resolution of diarrhea, which may be important because of effects on patient comfort, duration of hospitalization, and for infection control purposes. While we included clearance of the organism or toxin where reported, it is an outcome of uncertain significance if it is used without taking into account the patient's clinical status. We included any reported harms to patients using any of the standard antimicrobial treatments.

##### Study Designs

We also included RCTs, prospective cohort or case control studies, retrospective cohort studies, and case control study designs.

#### Key Question 4

##### Patients

We included target populations of adult patients with clinical signs consistent with CDI in hospital, outpatient, or long-term care settings. Patients with relapsing or recurrent CDI are of special concern due to the demonstrated difficulty with permanent cure of the infectious organism, and are often the stated targeted patient population for nonstandard treatments. Likewise, preventing recurrence is an important clinical goal. We sought studies that examined either preventing or treating relapsing or recurrent CDI, as the target population or a specified subgroup. When more than one nonstandard intervention was administered concurrently during the treatment of CDI before resolution of CDI was documented, both interventions were classified as treatment. We accepted both a priori and post hoc subgroup analysis.

##### Interventions

We included all studies that examined any nonstandard interventions. Nonstandard interventions include a broad range of treatments, such as antimicrobial agents, agents that bind the toxins produced by C. difficile, or treatments that reduce a patient's susceptibility, from prebiotics or probiotics that support the gut flora to vaccinations or antibodies to enhance immune functions. We did not limit studies to a particular set of nonstandard interventions but instead sought to catalogue the range of interventions. However, we did not include the toxin binding agent tolevamer as an intervention, as it is no longer under development in the United States.

##### Comparators

We included studies that used either another active treatment, such as metronidazole, or placebo.

##### Outcome

We examined patient outcomes, such as resolution of symptoms for treatment studies, and CDI incidence and presence of toxins for prevention studies. We sought evidence for harms associated with nonstandard interventions, whether for treatment or prevention, such as side effects or secondary infections.

##### Study Designs

We anticipated few controlled trials for newer interventions and so included all study designs. We did not limit comparators for nonstandard interventions; however, we did exclude studies on nonhuman, in vivo, and healthy volunteers.

### Study Selection

Results of the literature search were imported to a bibliographic database for screening. At least two independent reviewers examined all titles and abstracts for eligibility based on the inclusion/exclusion criteria. Titles and abstracts with insufficient information to determine eligibility were pulled for full article text review. Disagreements between reviewers were resolved through consensus. Final results of the screening process were then imported to an EndNote file for database management.

### Data Extraction

We extracted the following data from included trials directly into study tables: study design; setting; population characteristics (including sex, age, ethnicity, diagnosis); eligibility and exclusion criteria; characteristics of the interventions; numbers screened, eligible, enrolled, and lost to followup according to the research design; method of outcome ascertainment; study quality items; and results for each outcome. All tables were subject to a quality check of all data items by independent reviewers.

### Quality Assessment

#### Key Question 1

To assess the quality of reports for diagnostic studies, we used the criteria developed for the Quality Assessment of Diagnostic Accuracy Studies.155,156 These criteria include: (1) tested specimens (patients, stool) and their selection were clearly described and representative of those that are tested in clinical practice; (2) the time period and handling of specimens between tests most likely did not change what is being measured; (3) all test procedures were adequately described and replicable; (4) the same credible reference test was used for all specimens, performed regardless of other test results; (5) the reference and diagnostic tests being evaluated were conducted and interpreted independently of each other, that is, blinded; (6) any clinical information that was used in the interpretation of test results was reported; (7) indeterminate results were reported and analyzed in a reasonable manner; and (8) excluded test results, specimens, or patients were reported and explained. This quality assessment does not have a method for scoring the criteria or reliably categorizing the studies. Some studies that did not meet a key criterion for inclusion in the review were excluded without further assessment of their quality.

Studies that are summarized in this review were rated as having “good” internal validity. Comparisons were made in the same laboratory using the same specimens and a credible reference standard. There were no major differences in the processing and storing of the specimens between tests that were independently conducted. Indeterminate results were discussed and handled in a reasonable manner.

#### Key Question 2

Quality assessment for nonrandomized studies used primarily in assessing prevention strategies was based on study design (case control versus case series), the selection of cases or cohorts and controls (how well matched), and adjustment for confounders. Studies were rated as higher quality if they met the following a priori defined criteria: (1) prospective, (2) had explicitly detailed the methods of their study, (3) patients were representative of typical CDI patients, and (4) used multivariate analysis to isolate the effect of the variable in question.

#### Key Questions 3 and 4

We rated the study quality of individual randomized controlled or clinically controlled trials using criteria based on Cochrane Collaboration recommended domains.157 These domains assess the risk of bias of studies included in a systematic review. The first domain is adequate allocation concealment, based on the approach by Schulz and Grimes.158 The second domain regards blinding methods, such as participant, investigator, or outcome assessor. The third domain regards how incomplete data are addressed: did the study analyze the data based on the intention-to-treat principle (i.e., were all subjects who were randomized included in the outcomes analyses), and were reasons for dropouts/attrition reported?

Studies were rated to be of good, fair, or poor quality. A rating of good generally indicates that the trial reported adequate allocation concealment, blinding, analysis by intent to treat, and reasons for dropouts or attrition. Studies were generally rated poor if the method of allocation concealment was inadequate or not defined, blinding was not defined, analysis by intent to treat was not utilized, and reasons for dropouts or attrition were not reported and/or there was a high rate of attrition.

### Rating the Body of Evidence

For randomized trials, the overall strength of evidence was evaluated using methods developed by AHRQ and the Effective Health Care Program.159 The strength of the evidence was evaluated based on four required domains: (1) risk of bias (do the studies for a given outcome or comparison have good internal validity); (2) consistency (the degree of similarity in the effect sizes [i.e., same direction of effect] of the included studies); (3) directness (reflecting a single, direct link between the intervention of interest and the outcome); and (4) precision (degree of certainty surrounding an effect estimate of a given outcome). The risk of bias, based on study design and conduct, is rated low, medium, or high. Consistency is rated consistent, inconsistent, or unknown/not applicable (e.g., a single study was evaluated). Directness can either be direct or indirect, and precision is either precise or imprecise. A precise estimate is one that would yield a clinically meaningful conclusion.

The evidence is rated using high, moderate, low, and insufficient for grades. A high grade indicates that further research is very unlikely to change the confidence in the estimate of effect, meaning that the evidence is believed to reflect the true effect. A moderate grade denotes further research may change our confidence in the estimate of effect and may, in fact, change the estimate. A low grade indicates that further research is very likely to have an important impact on the confidence in the estimate of effect and is likely to change the estimate. Thus, there is low confidence that the evidence reflects the true effect. An insufficient grade indicates that the evidence is unavailable or does not permit a conclusion. An overall rating of high strength of evidence would imply that the included studies were RCTs with a low risk of bias and consistent, direct, and precise domains.

We modified this approach for diagnostic tests in the following manner. As previously stated, all of the studies that provided comparative evidence for differences between diagnostic tests were selected based on having ‘good’ protection against bias (internal validity). Furthermore, all of the comparative studies were rated as providing only indirect evidence because none presented evidence that the differences in sensitivity and/or specificity of the diagnostic tests would lead to any differences in patient outcomes. Indeed, studies that provide evidence that the observed differences would or would not be clinically meaningful were not found, nor were estimates of how much of a difference would be required to make a different clinical decision about the diagnosis. Thus, any differences in the overall grades of the strength of evidence for comparisons of the diagnostic tests are based on the consistency (direction and size) of the estimated differences in sensitivity and specificity and the precision (width of the estimated confidence intervals).

### Applicability

Applicability of the treatment results, both standard and nonstandard adjuvant treatment, of this review are affected by the representativeness of the patient samples in the included studies, which are general adult inpatient populations. Applicability of diagnostic test results is limited by the samples used in the analyses; to the extent that they were typical clinical samples derived from patients with suspected CDI, they represent the typical patient population that was tested. However, the ability to explicitly state the applicability of such samples is dependent on the completeness of the study reporting on the characteristics of the patients/specimens that were selected for the study. Furthermore, the substantial heterogeneity between studies in estimates of sensitivity and specificity of many of the diagnostic tests being reviewed, and perhaps their differences, raises concerns about generalization of the results. The evidence tables in Appendix C identify reported details on the patient inclusion and exclusion criteria.

### Data Synthesis

For key questions with trial data, we applied quantitative techniques to estimate a summary effect size for reported outcomes for which heterogeneity of interventions and outcomes measures was minimal. Qualitative narratives were provided for key questions for which heterogeneity of interventions or measured patient outcomes was too great, or for which available studies were observational. Results of the quantitative and qualitative analyses are compared to relevant published systematic reviews for consistency of findings. (See Appendix C tables for details of systematic reviews.)

Data were analyzed in Review Manager 5.2.^160^ Random effects models were used to generate pooled estimates of relative risks and weighted mean differences with 95 percent confidence intervals. Statistical heterogeneity was summarized using the I^2^ statistic (50 percent indicates moderate heterogeneity and 75 percent or greater indicates high heterogeneity).161

#### Key Question 1

We focused on the differences between test sensitivities and specificities rather than on the specific test sensitivities and specificities themselves. Thus, methods of meta-analysis typically used for clinical trials with binary endpoints were employed rather than methods typically used for sensitivities and specificities, such as diagnostic odds ratios. To be able to estimate the correlation between two tests that were applied to the same patients/stool specimens, hence calculate proper confidence intervals on the differences of the sensitivities and specificities of two tests, the results of each test for each individual are needed.162 Many reports did not provide this information. Therefore, the estimated confidence intervals on the differences in sensitivities and specificities ignored the unknown correlation between test results. Ignoring the correlation most likely increased the estimated variances of the differences and the width of the confidence intervals depending on the direction and magnitude of the correlation between the estimates for the two tests.

Each study had two primary endpoints, difference in sensitivities and difference in specificities. Furthermore, some studies made multiple comparisons. Some adjustment for multiple endpoints and comparisons was made by calculating 99 percent confidence intervals on the differences.

### Publication Bias

Grey literature was searched for relevant trials and other material to inform the likelihood of publication bias. Regulatory sources included Federal Drug Administration, Health Canada, and Authorized Medicines for the European Union. Clinical trial registries accessed were ClinicalTrials.gov, Current Controlled Trials, Clinical Study Results, and World Health Organization's Clinical Trials. Grants and federally funded research sources included NIH RePORTER, a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions, and HSRProj, a database providing access to ongoing grants and contracts in health services research. Other sources searched were Hayes, Inc. Health Technology Assessment, New York Academy of Medicine's Grey Literature Index, Conference Papers Index, and Scopus.