# Excluded Studies

## Excluded References – C Difficile (General Search)

1 Treatment of Clostridium difficile associated diarrhea and colitis with an oral preparation of teicoplanin; a dose finding study. The Swedish CDAD Study Group. Scand J Infect Dis. 1994;26(3):309-16. Not eligible comparator. [pmid: 7939431].
2 Abbett SK, Yokoe DS, Lipsitz SR, et al. Proposed checklist of hospital interventions to decrease the incidence of healthcare-associated Clostridium difficile infection. Infect Control Hosp Epidemiol. Nov. 2009;30(11):1062-9. Not relevant to key questions. [pmid: 19751156].
3 Abrahamsson TR, Sinkiewicz G, Jakobsson T, et al. Probiotic lactobacilli in breast milk and infant stool in relation to oral intake during the first year of life. Journal of Pediatric Gastroenterology & Nutrition. Sep. 2009;49(3):349-54. Not included population. [pmid: 19525871].
4 Abrahao C, Carman RJ, Hahn H, et al. Similar frequency of detection of Clostridium perfringens enterotoxin and Clostridium difficile toxins in patients with antibiotic-associated diarrhea. European J Clin Microbiol & Infectious Diseases. Sep. 2001;20(9):676-7. Not included treatment type. [pmid: 11714055].
5 Abreu MT, Harpaz N. Diagnosis of colitis: making the initial diagnosis. [see comment]. Clin Gastroenterol Hepatol. Mar. 2007;5(3):295-301. Not included publication type. [pmid: 17368227].
6 Akhtar AJ, Shaheen M. Increasing incidence of clostridium difficile-associated diarrhea in African-American and Hispanic patients: association with the use of proton pump inhibitor therapy. Journal of the National Medical Association. May. 2007;99(5):500-4. Not included study design. [pmid: 17534007].
7 Akhtar AJ, Shaheen M. Increasing incidence of clostridium difficile-associated diarrhea in African-American and Hispanic patients: association with the use of proton pump inhibitor therapy. Journal of the National Medical Association. May. 2007;99(5):500-4. Duplicate listing. [pmid: 17534007].
8 Albright JB, Bonatti H, Mendez J, et al. Early and late onset Clostridium difficile-associated colitis following liver transplantation. Transplant International. Oct. 2007;20(10):856-66. Not included study design. [pmid: 17854444].
9 Aldeyab MA, Harbarth S, Vernaz N, et al. Quasiexperimental study of the effects of antibiotic use, gastric acid-suppressive agents, and infection control practices on the incidence of Clostridium difficile-associated diarrhea in hospitalized patients. Antimicrob Agents Chemother. May. 2009;53(5):2082-8. Not included study design. [pmid: 19289520].
10 Aldeyab MA, Harbarth S, Vernaz N, et al. Quasiexperimental study of the effects of antibiotic use, gastric acid-suppressive agents, and infection control practices on the incidence of Clostridium difficile-associated diarrhea in hospitalized patients. Antimicrob Agents Chemother. May. 2009;53(5):2082-8. Duplicate listing. [pmid: 19289520].
11 Al-Eidan FA, McElnay JC, Scott MG, et al. Clostridium difficile-associated diarrhoea in hospitalised patients. Journal of Clinical Pharmacy & Therapeutics. Apr. 2000;25(2):101-9. Not on topic. [pmid: 10849187].
12 Alestig K, Carlberg H, Nord CE, et al. Effect of cefoperazone on faecal flora. J Antimicrob Chemother. Aug. 1983;12(2):163-7. Not on topic. [pmid: 6619054].
13 Ali SO, Welch JP, Dring RJ. Early surgical intervention for fulminant pseudomembranous colitis. American Surgeon. Jan. 2008;74(1):20-6. Not included population. [pmid: 18274423].
14 Altaie SS, Meyer P, Dryja D. Comparison of two commercially available enzyme immunoassays for detection of Clostridium difficile in stool specimens. J Clin Microbiol. Jan. 1994;32(1):51-3. Not relevant to key questions. [pmid: 8126205].
15 Altiparmak MR, Trablus S, Pamuk ON, et al. Diarrhoea following renal transplantation. Clinical transplantation. Jun. 2002;16(3):212-6. Not included study design. [pmid: 12010146].
16 Al-Tureihi FI, Hassoun A, Wolf-Klein G, et al. Albumin, length of stay, and proton pump inhibitors: key factors in Clostridium difficile-associated disease in nursing home patients. Journal of the American Medical Directors Association. Mar-Apr. 2005;6(2):105-8. Not included study design. [pmid: 15871884].
17 Ambrose NS, Burdon DW, Keighley MR. A prospective randomized trial to compare mezlocillin and metronidazole with cefuroxime and metronidazole as prophylaxis in elective colorectal operations. J Hosp Infect. Dec. 1983;4(4):375-82. Not included population. [pmid: 6198367].
18 Ament ME, Berquist W, Vargas J. Advances in ulcerative colitis. Pediatrician. 1988;15(1-2):45-57. Not on topic. [pmid: 3050919].
19 Anand A, Bashey B, Mir T, et al. Epidemiology, clinical manifestations, and outcome of Clostridium difficile-associated diarrhea. Am J Gastroenterol. Apr. 1994;89(4):519-23. Not included study design. [pmid: 8147353].
20 Anand A, Glatt AE. Clostridium difficile infection associated with antineoplastic chemotherapy: a review. Clinic Infect Dis. Jul. 1993;17(1):109-13. Not included study design.
21 Ananthakrishnan AN, McGinley EL, Binion DG. Excess hospitalisation burden associated with Clostridium difficile in patients with inflammatory bowel disease. Gut. Feb. 2008;57(2):205-10. Not included population. [pmid: 17905821].
22 Anastasi JK, Capili B. HIV and diarrhea in the era of HAART: 1998 New York State hospitalizations. Am J Infect Control. Jun. 2000;28(3):262-6. Not included study design. [pmid: 10840348].
23 Anastasi JK, Capili B. HIV and diarrhea in the era of HAART: 1998 New York State hospitalizations. Am J Infect Control. Jun. 2000;28(3):262-6. Duplicate listing. [pmid: 10840348].
24 Andrews CN, Raboud J, Kassen BO, et al. Clostridium difficile-associated diarrhea: predictors of severity in patients presenting to the emergency department. Can J Gastroenterol. Jun. 2003;17(6):369-73. Not included study design. [pmid: 12813602].
25 Ang CW, Heyes G, Morrison P, et al. The acquisition and outcome of ICU-acquired Clostridium difficile infection in a single centre in the UK. Journal of Infection. Dec. 2008;57(6):435-40. Not included study design. [pmid: 19013649].
26 Ang P, Cheong WK, Khoo KS. Pseudomembranous colitis in a patient treated with paclitaxel for carcinoma of the breast: a case report. Ann Acad Med Singapore. Jan. 2000;29(1):132-4. Not included publication type. [pmid: 10748982].
27 Antoine M, Khitrik-Palchuk M, Saif MW. Long-term survival in a patient with acinar cell carcinoma of pancreas. A case report and review of literature. Jop: Journal of the Pancreas. [Electronic Resource]. 2007;8(6):783-9. Not included publication type. [pmid: 17993731].
28 Apisarnthanarak A, Razavi B, Mundy LM. Adjunctive intracolonic vancomycin for severe Clostridium difficile colitis: case series and review of the literature. [see comment]. Clinic Infect Dis. Sep. 15. 2002;35(6):690-6. Not included study design.
29 Aradhyula S, Manian FA, Hafidh SA, et al. Significant absorption of oral vancomycin in a patient with clostridium difficile colitis and normal renal function. Southern medical journal. May. 2006;99(5):518-20. Not included publication type. [pmid: 16711316].
30 Arango JI, Restrepo A, Schneider DL, et al. Incidence of Clostridium difficile-associated diarrhea before and after autologous peripheral blood stem cell transplantation for lymphoma and multiple myeloma. Bone marrow transplantation. Mar. 2006;37(5):517-21. Not on topic. [pmid: 16435018].
31 Archimandritis A, Souyioultzis S, Katsorida M, et al. Clostridium difficile colitis associated with a ‘triple’ regimen, containing clarithromycin and metronidazole, to eradicate Helicobacter pylori. Journal of internal medicine. Mar. 1998;243(3):251-3. Not included publication type. [pmid: 9627163].
32 Aronsson B, Blomback M, Eriksson S, et al. Low levels of coagulation inhibitors in patients with Clostridium difficile infection. Infection. Mar-Apr. 1992;20(2):58-60. Not on topic. [pmid: 1533851].
33 Aronsson B, Granstrom M, Mollby R, et al. Serum antibody response to Clostridium difficile toxins in patients with Clostridium difficile diarrhoea. Infection. May-Jun. 1985;13(3):97-101. Not included study design. [pmid: 4030111].
34 Aronsson B, Mollby R, Nord CE. Clostridium difficile and antibiotic associated diarrhoea in Sweden. Scand J Infect Dis Supplement. 1982;35:53-8. Not included study design.
35 Aronsson B, Mollby R, Nord CE. Diagnosis and epidemiology of Clostridium difficile enterocolitis in Sweden. J Antimicrob Chemother. Dec. 1984;14(Suppl D):85-95. Not included study design. [pmid: 6520069].
36 Aroori S, Blencowe N, Pye G, et al. Clostridium difficile: how much do hospital staff know about it?. Annals of the Royal College of Surgeons of England. Sep. 2009;91(6):464-9. Not included study design. [pmid: 19558760].
37 Arrich J, Sodeck GH, Sengolge G, et al. Clostridium difficile causing acute renal failure: case presentation and review. World Journal of Gastroenterology. Feb. 28. 2005;11(8):1245-7. Not included publication type. [pmid: 15754415].
38 Arsura EL, Fazio RA, Wickremesinghe PC. Pseudomembranous colitis following prophylactic antibiotic use in primary cesarean section. American Journal of Obstetrics & Gynecology. Jan. 1. 1985;151(1):87-9. Not included publication type. [pmid: 3966512].
39 Aseeri M, Schroeder T, Kramer J, et al. Gastric acid suppression by proton pump inhibitors as a risk factor for clostridium difficile-associated diarrhea in hospitalized patients. Am J Gastroenterol. Sep. 2008;103(9):2308-13. Not included study design. [pmid: 18702653].
40 Ash L, Baker ME, O'Malley CM Jr, et al. Colonic abnormalities on CT in adult hospitalized patients with Clostridium difficile colitis: prevalence and significance of findings. AJR.American Journal of Roentgenology. May. 2006;186(5):1393-400. Not included study design. [pmid: 16632736].
41 Asha NJ, Tompkins D, Wilcox MH. Comparative analysis of prevalence, risk factors, and molecular epidemiology of antibiotic-associated diarrhea due to Clostridium difficile, Clostridium perfringens, and Staphylococcus aureus. J Clin Microbiol. Aug. 2006;44(8):2785-91. Not included study design. [pmid: 16891493].
42 Aziz EE, Ayis S, Gould FK, et al. Risk factors for the development of Clostridium difficile toxin-associated diarrhoea: a pilot study. Pharmacoepidemiology & Drug Safety. Jun-Jul. 2001;10(4):303-8. Not included study design. [pmid: 11760491].
43 Bacci S, St-Martin G, Olesen B, et al. Outbreak of Clostridium difficile 027 in North Zealand, Denmark, 2008-2009. Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2009. 2009;14(16). Not relevant to key questions.
44 Bacon AE 3rd, Fekety R. Immunoglobulin G directed against toxins A and B of Clostridium difficile in the general population and patients with antibiotic-associated diarrhea. Diagnostic Microbiology & Infectious Disease. Apr. 1994;18(4):205-9. Not included population. [pmid: 7924215].
45 Bahadursingh AN, Vagefi PA, Longo WE. Fulminant Clostridium difficile colitis in a patient with spinal cord injury: case report. Journal of Spinal Cord Medicine. 2004;27(3):266-8. Not included publication type. [pmid: 15478532].
46 Baines SD, O'Connor R, Saxton K, et al. Activity of vancomycin against epidemic Clostridium difficile strains in a human gut model. J Antimicrob Chemother. Mar. 2009;63(3):520-5. Not included publication type. [pmid: 19112083].
47 Bajaj JS, Ananthakrishnan AN, Hafeezullah M, et al. Clostridium difficile is associated with poor outcomes in patients with cirrhosis: A national and tertiary center perspective. Am J Gastroenterol. Jan. 2010;105(1):106-13. Not relevant to key questions. [pmid: 19844204].
48 Bakken JS. Resolution of recurrent Clostridium difficile-associated diarrhea using staggered antibiotic withdrawal and kefir. Minnesota medicine. Jul. 2009;92(7):38-40. Background. [pmid: 19708314].
49 Balamurugan R, Balaji V, Ramakrishna BS. Estimation of faecal carriage of Clostridium difficile in patients with ulcerative colitis using real time polymerase chain reaction. Indian Journal of Medical Research. May. 2008;127(5):472-7. Not included study design. [pmid: 18653911].
50 Banning M. Ageing and the gut. Nursing Older People. Feb. 2008;20(1):17-21. Not included publication type. [pmid: 18372803].
51 Barany P, Stenvinkel P, Nord CE, et al. Clostridium difficile infection--a poor prognostic sign in uremic patients?. Clinical nephrology. Jul. 1992;38(1):53-7. Not included study design. [pmid: 1499170].
52 Barbut F, Beaugerie L, Delas N, et al. Comparative value of colonic biopsy and intraluminal fluid culture for diagnosis of bacterial acute colitis in immunocompetent patients. Infectious Colitis Study Group Clinic Infect Dis. Aug. 1999;29(2):356-60. Not included study design.
53 Barbut F, Corthier G, Charpak Y, et al. Prevalence and pathogenicity of Clostridium difficile in hospitalized patients. A French multicenter study. Arch Intern Med. Jul. 8. 1996;156(13):1449-54. Not included study design. [pmid: 8678714].
54 Barbut F, Decre D, Burghoffer B, et al. Antimicrobial susceptibilities and serogroups of clinical strains of Clostridium difficile isolated in France in 1991 and 1997. Antimicrob Agents Chemother. Nov. 1999;43(11):2607-11. Not included population. [pmid: 10543736].
55 Barbut F, Decre D, Lalande V, et al. Clinical features of Clostridium difficile-associated diarrhoea due to binary toxin (actin-specific ADP-ribosyltransferase)-producing strains. Journal of medical microbiology. Feb. 2005;54(Pt 2):181-5. Not included study design. [pmid: 15673514].
56 Barbut F, Gariazzo B, Bonne L, et al. Clinical features of Clostridium difficile-associated infections and molecular characterization of strains: results of a retrospective study, 2000-2004. Infect Control Hosp Epidemiol. Feb. 2007;28(2):131-9. Not included study design. [pmid: 17265393].
57 Barbut F, Leluan P, Antoniotti G, et al. Value of routine stool cultures in hospitalized patients with diarrhea. European J Clin Microbiol & Infectious Diseases. Apr. 1995;14(4):346-9. Not included study design. [pmid: 7649200].
58 Barbut F, Mario N, Meyohas MC, et al. Investigation of a nosocomial outbreak of Clostridium difficile-associated diarrhoea among AIDS patients by random amplified polymorphic DNA (RAPD) assay. J Hosp Infect. Mar. 1994;26(3):181-9. Not included study design. [pmid: 7911484].
59 Barbut F, Meynard JL, Guiguet M, et al. Clostridium difficile-associated diarrhea in HIV-infected patients: epidemiology and risk factors. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. Nov. 1. 1997;16(3):176-81. Not included study design. [pmid: 9390569].
60 Barbut F, M P, D M, B J, K E, P I, ESGoCd. Prospective study of Clostridium difficile infections in Europe with phenotypic and genotypic characterisation of the isolates. Clinical Microbiology & Infection. Nov. 2007;13(11):1048-57. Not relevant to key questions. [pmid: 17850341].
61 Barker HC, Haworth CS, Williams D, et al. Clostridium difficile pancolitis in adults with cystic fibrosis. Journal of Cystic Fibrosis. Sep. 2008;7(5):444-7. Not included publication type. [pmid: 18585983].
62 Barriere SL. Review of in vitro activity, pharmacokinetic characteristics, safety, and clinical efficacy of cefprozil, a new oral cephalosporin. Ann Pharmacother. Sep. 1993;27(9):1082-9. Not included study design. [pmid: 8219444].
63 Bartlett JG. Clinical practice. Antibiotic-associated diarrhea. [see comment]. New England Journal of Medicine. Jan. 31. 2002;346(5):334-9. Not included publication type. [pmid: 11821511].
64 Bartlett JG, Gerding DN. Clinical recognition and diagnosis of Clostridium difficile infection. Clinic Infect Dis. Jan. 15. 2008;46(Suppl 1):S12-8. Background.
65 Bassaris HP, Lianou PE, Legakis NJ, et al. Interaction between Clostridium difficile and polymorphonuclear leucocytes from the elderly and post-operative cancer patients: phagocytosis and bactericidal function. Medical Microbiology & Immunology. 1984;173(1):49-55. Not included population. [pmid: 6472200].
66 Bate G. Comparison of Minitek Anaerobe II, API An-Ident, and RapID ANA systems for identification of Clostridium difficile. American Journal of Clinical Pathology. Jun. 1986;85(6):716-8. Not included study design. [pmid: 3518405].
67 Battle EH, Elliott SY. Three cases of hemorrhagic colitis in West Virginia due to Escherichia coli O157:H7. West Virginia Medical Journal. Nov-Dec. 1995;91(7):320-1. Not included publication type. [pmid: 8533400].
68 Bauer MP, Goorhuis A, Koster T, et al. Community-onset Clostridium difficile-associated diarrhoea not associated with antibiotic usage--two case reports with review of the changing epidemiology of Clostridium difficile-associated diarrhoea. Netherlands Journal of Medicine. May. 2008;66(5):207-11. Not included publication type. [pmid: 18490799].
69 Bauer MP, Veenendaal D, Verhoef L, et al. Clinical and microbiological characteristics of community-onset Clostridium difficile infection in The Netherlands. Clinical Microbiology & Infection. Dec. 2009;15(12):1087-92. Not relevant to key questions. [pmid: 19624512].
70 Bauer TM, Lalvani A, Fehrenbach J, et al. Derivation and validation of guidelines for stool cultures for enteropathogenic bacteria other than Clostridium difficile in hospitalized adults. JAMA. Jan. 17. 2001;285(3):313-9. Not on topic. [pmid: 11176841].
71 Bauwens JE, McFarland LV, Melcher SA. Recurrent Clostridium difficile disease following ciprofloxacin use. Ann Pharmacother. Sep. 1997;31(9):1090. Not included publication type. [pmid: 9296254].
72 Baxter R, Ray GT, Fireman BH. Case-control study of antibiotic use and subsequent Clostridium difficile-associated diarrhea in hospitalized patients. Infect Control Hosp Epidemiol. Jan. 2008;29(1):44-50. Not included study design. [pmid: 18171186].
73 Beaugerie L, Flahault A, Barbut F, et al. Antibiotic-associated diarrhoea and Clostridium difficile in the community. Aliment Pharmacol Ther. Apr. 1. 2003;17(7):905-12. Not included study design. [pmid: 12656693].
74 Beaugerie L, Metz M, Barbut F, et al. Klebsiella oxytoca as an agent of antibiotic-associated hemorrhagic colitis. Clin Gastroenterol Hepatol. Sep. 2003;1(5):370-6. Not included publication type. [pmid: 15017655].
75 Beaugerie L, Ngo Y, Goujard F, et al. Etiology and management of toxic megacolon in patients with human immunodeficiency virus infection. Gastroenterol. Sep. 1994;107(3):858-63. Not included publication type.
76 Beaujean DJ, Blok HE, Vandenbroucke-Grauls CM, et al. Surveillance of nosocomial infections in geriatric patients. J Hosp Infect. Aug. 1997;36(4):275-84. Not included study design. [pmid: 9261757].
77 Beaulieu M, Williamson D, Pichette G, et al. Risk of Clostridium difficile-associated disease among patients receiving proton-pump inhibitors in a Quebec medical intensive care unit. Infect Control Hosp Epidemiol. Nov. 2007;28(11):1305-7. Not included study design. [pmid: 17926283].
78 Beck A, McNeil C, Abdelsayed G, et al. Salmonella pseudomembranous colitis. Connecticut medicine. Jun-Jul. 2007;71(6):339-42. Not included publication type. [pmid: 17619469].
79 Beloosesky Y, Grosman B, Marmelstein V, et al. Convulsions induced by metronidazole treatment for Clostridium difficile-associated disease in chronic renal failure. American Journal of the Medical Sciences. May. 2000;319(5):338-9. Not included publication type. [pmid: 10830559].
80 Ben-Horin S, Margalit M, Bossuyt P, et al. Combination immunomodulator and antibiotic treatment in patients with inflammatory bowel disease and clostridium difficile infection. Clin Gastroenterol Hepatol. Sep. 2009;7(9):981-7. Not included study design. [pmid: 19523534].
81 Bennett RG, Greenough WB 3rd. Approach to acute diarrhea in the elderly. Gastroenterology clinics of North America. Sep. 1993;22(3):517-33. Not included publication type. [pmid: 8406728].
82 Bennett RG, Laughon BE, Mundy LM, et al. Evaluation of a latex agglutination test for Clostridium difficile in two nursing home outbreaks. J Clin Microbiol. May. 1989;27(5):889-93. Not included population. [pmid: 2745696].
83 Berman L, Carling T, Fitzgerald TN, et al. Defining surgical therapy for pseudomembranous colitis with toxic megacolon. J Clin Gastroenterol. May-Jun. 2008;42(5):476-80. Not included publication type. [pmid: 18277885].
84 Bilgrami S, Feingold JM, Dorsky D, et al. Incidence and outcome of Clostridium difficile infection following autologous peripheral blood stem cell transplantation. Bone marrow transplantation. May. 1999;23(10):1039-42. Not included study design. [pmid: 10373070].
85 Biller P, Shank B, Lind L, et al. Moxifloxacin therapy as a risk factor for Clostridium difficile-associated disease during an outbreak: attempts to control a new epidemic strain. Infect Control Hosp Epidemiol. Feb. 2007;28(2):198-201. Not included study design. [pmid: 17265402].
86 Bingley PJ, Harding GM. Clostridium difficile colitis following treatment with metronidazole and vancomycin. Postgrad Med J. Nov. 1987;63(745):993-4. Not included publication type. [pmid: 3451227].
87 Bingley PJ, Harding GM. Clostridium difficile colitis following treatment with metronidazole and vancomycin. Postgrad Med J. Nov. 1987;63(745):993-4. Duplicate listing. [pmid: 3451227].
88 Birnbaum J, Bartlett JG, Gelber AC. Clostridium difficile: an under-recognized cause of reactive arthritis?. Clinical rheumatology. Feb. 2008;27(2):253-5. Not included publication type. [pmid: 17902012].
89 Bishara J, Peled N, Pitlik S, et al. Mortality of patients with antibiotic-associated diarrhoea: the impact of Clostridium difficile. J Hosp Infect. Apr. 2008;68(4):308-14. Not included study design. [pmid: 18353491].
90 Bishara J, Peled N, Pitlik S, et al. Mortality of patients with antibiotic-associated diarrhoea: the impact of Clostridium difficile. J Hosp Infect. Apr. 2008;68(4):308-14. Duplicate listing. [pmid: 18353491].
91 Bixquert Jimenez M. Treatment of irritable bowel syndrome with probiotics. An etiopathogenic approach at last?. Revista Espanola de Enfermedades Digestivas. Aug. 2009;101(8):553-64. Not relevant to key questions. [pmid: 19785495].
92 Bliss DZ, Johnson S, Savik K, et al. Fecal incontinence in hospitalized patients who are acutely ill. Nursing research. Mar-Apr. 2000;49(2):101-8. Not included study design. [pmid: 10768587].
93 Bliss DZ, Johnson S, Savik K, et al. Acquisition of Clostridium difficile and Clostridium difficile-associated diarrhea in hospitalized patients receiving tube feeding. Annals of Internal Medicine. Dec. 15. 1998;129(12):1012-9. Not included study design. [pmid: 9867755].
94 Bloedt K, Riecker M, Poppert S, et al. Evaluation of new selective culture media and a rapid fluorescence in situ hybridization assay for identification of Clostridium difficile from stool samples. Journal of medical microbiology. Jul. 2009;58(Pt 7):874-7. Not included population. [pmid: 19502365].
95 Blossom DB, Lewis FM, McDonald LC. The changing spectrum of clostridium difficile associated disease: implications for dentistry. Journal of the American Dental Association. Jan. 2008;139(1):42-7. Not included publication type. [pmid: 18167383].
96 Blot E, Escande MC, Besson D, et al. Outbreak of Clostridium difficile-related diarrhoea in an adult oncology unit: risk factors and microbiological characteristics. J Hosp Infect. Mar. 2003;53(3):187-92. Not included study design. [pmid: 12623319].
97 Blum RN, Berry CD, Phillips MG, et al. Clinical illnesses associated with isolation of dysgonic fermenter 3 from stool samples. J Clin Microbiol. Feb. 1992;30(2):396-400. Not included publication type. [pmid: 1537908].
98 Bobulsky GS, Al-Nassir WN, Riggs MM, et al. Clostridium difficile skin contamination in patients with C. difficile-associated disease. Clinic Infect Dis. Feb. 1. 2008;46(3):447-50. Not on topic.
99 Bodey G, Abi-Said D, Rolston K, et al. Imipenem or cefoperazone-sulbactam combined with vancomycin for therapy of presumed or proven infection in neutropenic cancer patients. European J Clin Microbiol & Infectious Diseases. Aug. 1996;15(8):625-34. Not on topic. [pmid: 8894569].
100 Bolton RP. Clostridium difficile-associated colitis after neomycin treated with metronidazole. BMJ. Dec. 8. 1979;2(6203):1479-80. Not included publication type. [pmid: 526821].
101 Bolton RP, Culshaw MA. Faecal metronidazole concentrations during oral and intravenous therapy for antibiotic associated colitis due to Clostridium difficile. Gut. Oct. 1986;27(10):1169-72. Not included study design. [pmid: 3781329].
102 Bombassaro AM, Wetmore SJ, John MA. Clostridium difficile colitis following antibiotic prophylaxis for dental procedures. Journal (Canadian Dental Association). Jan. 2001;67(1):20-2. Not included publication type. [pmid: 11209501].
103 Bonatti H, Brandacher G, Margreiter R, et al. Infectious complications in three double hand recipients: experience from a single center. Transplantation proceedings. Mar. 2009;41(2):517-20. Not included publication type. [pmid: 19328916].
104 Bond F, Payne G, Borriello SP, et al. Usefulness of culture in the diagnosis of Clostridium difficile infection. European J Clin Microbiol & Infectious Diseases. Mar. 1995;14(3):223-6. Not included population. [pmid: 7614964].
105 Bond JH. Office-based management of diarrhea. Geriatrics. Feb. 1982;37(2):61-4. 52. 5. Not included publication type.
106 Borriello SP, Barclay FE. An in-vitro model of colonisation resistance to Clostridium difficile infection. Journal of medical microbiology. Jun. 1986;21(4):299-309. Not included population. [pmid: 3723582].
107 Bouza E, Burillo A, Munoz P. Antimicrobial therapy of Clostridium difficile-associated diarrhea. Medical Clinics of North America. Nov. 2006;90(6):1141-63. Not included publication type. [pmid: 17116441].
108 Bouza E, Perez MJ, Munoz P, et al. Continuous aspiration of subglottic secretions in the prevention of ventilator-associated pneumonia in the postoperative period of major heart surgery. Chest. Nov. 2008;134(5):938-46. Not on topic. [pmid: 18641114].
109 Bouza E, Perez MJ, Munoz P, et al. Continuous aspiration of subglottic secretions in the prevention of ventilator-associated pneumonia in the postoperative period of major heart surgery. Chest. Nov. 2008;134(5):938-46. Duplicate listing. [pmid: 18641114].
110 Bouza E, Sousa D, Munoz P, et al. Bloodstream infections: a trial of the impact of different methods of reporting positive blood culture results. Clinic Infect Dis. Oct. 15. 2004;39(8):1161-9. Not on topic.
111 Bouza E, Torres MV, Radice C, et al. Direct E-test (AB Biodisk) of respiratory samples improves antimicrobial use in ventilator-associated pneumonia. Clinic Infect Dis. Feb. 1. 2007;44(3):382-7. Not on topic.
112 Boyce JM, Havill NL, Otter JA, et al. Widespread environmental contamination associated with patients with diarrhea and methicillin-resistant Staphylococcus aureus colonization of the gastrointestinal tract. Infect Control Hosp Epidemiol. Oct. 2007;28(10):1142-7. Not included study design. [pmid: 17828690].
113 Brandt LJ, Kosche KA, Greenwald DA, et al. Clostridium difficile-associated diarrhea in the elderly. Am J Gastroenterol. Nov. 1999;94(11):3263-6. Background. [pmid: 10566727].
114 Brazier JS, Borriello SP. Microbiology, epidemiology and diagnosis of Clostridium difficile infection. Current Topics in Microbiology & Immunology. 2000;250:1-33. Not included publication type. [pmid: 10981355].
115 Brennen C, Wagener MM, Muder RR. Vancomycin-resistant Enterococcus faecium in a long-term care facility. Journal of the American Geriatrics Society. Feb. 1998;46(2):157-60. Not included publication type. [pmid: 9475442].
116 Brettle RP, Poxton IR, Murdoch JM, et al. Clostridium difficile in association with sporadic diarrhoea. BMJ Clinical Research Ed. Jan. 23. 1982;284(6311):230-3. Not included publication type. [pmid: 6799113].
117 Bricker E, Garg R, Nelson R, et al. Antibiotic treatment for Clostridium difficile-associated diarrhea in adults. [update in Cochrane Database Syst Rev. 2007;(3):CD004610; PMID:17636768]. Cochrane Database Syst Rev. 2005;(1):004610. Background.
118 Brismar B, Edlund C, Nord CE. Effect of ceftibuten on the normal intestinal microflora. Infection. Nov-Dec. 1993;21(6):373-5. Not included study design. [pmid: 8132366].
119 Brismar B, Edlund C, Nord CE. Impact of cefpodoxime proxetil and amoxicillin on the normal oral and intestinal microflora. Eur J Clin Microbiol Infect Dis. Sep. 1993;12(9):714-9. Not included study design. [pmid: 8243490].
120 Brown EA, Talbot GH, Provencher M, et al. Anaerobic bacteremia in patients with acute leukemia. Infect Control Hosp Epidemiol. Feb. 1989;10(2):65-9. Not included publication type. [pmid: 2647821].
121 Brown RJ, Batts DH, Hughes GS, et al. Comparison of oral cefpodoxime proxetil and penicillin V potassium in the treatment of group A streptococcal pharyngitis/tonsillitis. The Cefpodoxime Pharyngitis Study Group. Clinical therapeutics. Sep-Oct. 1991;13(5):579-88. Not on topic. [pmid: 1799915].
122 Bruce D, Ritchie C, Jennings LC, et al. Clostridium difficile-associated colitis: cross infection in predisposed patients with renal failure. New Zealand Medical Journal. Apr. 28. 1982;95(706):265-7. Not included publication type. [pmid: 6953368].
123 Buchner AM, Sonnenberg A. Medical diagnoses and procedures associated with clostridium difficile colitis. Am J Gastroenterol. Mar. 2001;96(3):766-72. Not included study design. [pmid: 11280548].
124 Buchner AM, Sonnenberg A. Epidemiology of Clostridium difficile infection in a large population of hospitalized US military veterans. Dig Dis Sci. Jan. 2002;47(1):201-7. Not included study design. [pmid: 11837725].
125 Buggy BP, Fekety R, Silva J Jr. Therapy of relapsing Clostridium difficile-associated diarrhea and colitis with the combination of vancomycin and rifampin. J Clin Gastroenterol. Apr. 1987;9(2):155-9. Not included study design. [pmid: 3571889].
126 Bulstrode NW, Bradbury AW, Barrett S, et al. Clostridium difficile colitis after aortic surgery. European Journal of Vascular & Endovascular Surgery. Sep. 1997;14(3):217-20. Not included study design. [pmid: 9345243].
127 Bulusu M, Narayan S, Shetler K, et al. Leukocytosis as a harbinger and surrogate marker of Clostridium difficile infection in hospitalized patients with diarrhea. Am J Gastroenterol. Nov. 2000;95(11):3137-41. Not on topic. [pmid: 11095331].
128 Burdon DW. Treatment of pseudomembranous colitis and antibiotic-associated diarrhoea. J Antimicrob Chemother. Dec. 1984;14(Suppl D):103-9. Not included study design. [pmid: 6394575].
129 Burt RK, Loh Y, Cohen B, et al. Autologous non-myeloablative haemopoietic stem cell transplantation in relapsing-remitting multiple sclerosis: a phase I/II study. Lancet Neurology. Mar. 2009;8(3):244-53. Not on topic. [pmid: 19186105].
130 Burt RK, Loh Y, Cohen B, et al. Autologous non-myeloablative haemopoietic stem cell transplantation in relapsing-remitting multiple sclerosis: a phase I/II study. Lancet Neurology. Mar. 2009;8(3):244-53. Duplicate listing. [pmid: 19186105].
131 Butterworth SA, Koppert E, Clarke A, et al. Recent trends in diagnosis and treatment of Clostridium difficile in a tertiary care facility. American Journal of Surgery. May. 1998;175(5):403-7. Not included publication type. [pmid: 9600288].
132 Byl B, Jacobs F, Struelens MJ, et al. Extraintestinal Clostridium difficile infections. Clinic Infect Dis. Apr. 1996;22(4):712. Not included study design.
133 Byrd RP Jr, Roy TM, Ossorio MA, et al. Delayed onset of pseudomembranous colitis after rifampin therapy. Southern medical journal. Jun. 1997;90(6):644-6. Not included publication type. [pmid: 9191744].
134 Byrn JC, Maun DC, Gingold DS, et al. Predictors of mortality after colectomy for fulminant Clostridium difficile colitis. Archives of Surgery. discussion 155. Feb. 2008;143(2):150-4. Not included study design. [pmid: 18283139].
135 Cadle RM, Mansouri MD, Darouiche RO. Vancomycin-induced elevation of liver enzyme levels. Ann Pharmacother. Jun. 2006;40(6):1186-9. Not included study design. [pmid: 16720708].
136 Cadle RM, Mansouri MD, Logan N, et al. Association of proton-pump inhibitors with outcomes in Clostridium difficile colitis. American Journal of Health-System Pharmacy. Nov. 15. 2007;64(22):2359-63. Not included study design. [pmid: 17989446].
137 Calame W, Weseler AR, Viebke C, et al. Gum arabic establishes prebiotic functionality in healthy human volunteers in a dose-dependent manner. British Journal of Nutrition. Dec. 2008;100(6):1269-75. Not included study design. [pmid: 18466655].
138 Calame W, Weseler AR, Viebke C, et al. Gum arabic establishes prebiotic functionality in healthy human volunteers in a dose-dependent manner. British Journal of Nutrition. Dec. 2008;100(6):1269-75. Duplicate listing. [pmid: 18466655].
139 Calfee DP. Clostridium difficile: a reemerging pathogen. Geriatrics. Sep. 1. 2008;63(9):10-21. Not included publication type. [pmid: 18763846].
140 Camilleri M, Toouli J, Herrera MF, et al. Intra-abdominal vagal blocking (VBLOC therapy): clinical results with a new implantable medical device. Surgery. Jun. 2008;143(6):723-31. Not on topic. [pmid: 18549888].
141 Candiotto A, Pascoli I, Gritti A, et al. Toxic megacolon complicating a Clostridium difficile infection in a pregnant woman. Journal of Medical Microbiology. Jan. 2010;59(Pt 1):124-6. Not relevant to key questions. [pmid: 19745034].
142 Cappell MS, Philogene C. Clostridium difficile infection is a treatable cause of diarrhea in patients with advanced human immunodeficiency virus infection: a study of seven consecutive patients admitted from 1986 to 1992 to a university teaching hospital. Am J Gastroenterol. Jun. 1993;88(6):891-7. Not included study design. [pmid: 8503386].
143 Carbone J, Sarmiento E, Palomo J, et al. The potential impact of substitutive therapy with intravenous immunoglobulin on the outcome of heart transplant recipients with infections. Transplantation proceedings. Sep. 2007;39(7):2385-8. Not on topic. [pmid: 17889198].
144 Carbonell AM, Kercher KW, Matthews BD, et al. The laparoscopic repair of suprapubic ventral hernias. Surgical endoscopy. Feb. 2005;19(2):174-7. Not on topic. [pmid: 15580440].
145 Carignan A, Allard C, Pepin J, et al. Risk of Clostridium difficile infection after perioperative antibacterial prophylaxis before and during an outbreak of infection due to a hypervirulent strain. Clinic Infect Dis. Jun. 15. 2008;46(12):1838-43. Not included study design.
146 Carmeli Y, Eliopoulos G, Mozaffari E, et al. Health and economic outcomes of vancomycin-resistant enterococci. Arch Intern Med. Oct. 28. 2002;162(19):2223-8. Not on topic. [pmid: 12390066].
147 Carmeli Y, Eliopoulos GM, Samore MH. Antecedent treatment with different antibiotic agents as a risk factor for vancomycin-resistant Enterococcus. Emerging Infectious Diseases. Aug. 2002;8(8):802-7. Not on topic. [pmid: 12141965].
148 Carmeli Y, Eliopoulos GM, Samore MH. Antecedent treatment with different antibiotic agents as a risk factor for vancomycin-resistant Enterococcus. Emerging Infectious Diseases. Aug. 2002;8(8):802-7. Duplicate listing. [pmid: 12141965].
149 Carpenter DR, Zielinski DA. How do you treat--and control--C. difficile infection?. American Journal of Nursing. Sep. 1992;92(9):22-4. Not included publication type. [pmid: 1510097].
150 Carrer M, Vazquez GJ, Lebron RI, et al. The microbial etiologies of diarrhea in hospitalized patients from the Puerto Rico Medical Center Hospitals. Puerto Rico health sciences journal. Mar. 2005;24(1):41-4. Not on topic. [pmid: 15895876].
151 Cartmill TD, Shrimpton SB, Panigrahi H, et al. Nosocomial diarrhoea due to a single strain of Clostridium difficile: a prolonged outbreak in elderly patients. Age Ageing. Jul. 1992;21(4):245-9. Not included study design. [pmid: 1514452].
152 Cascinu S, Catalano G. Have enteric infections a role in 5-fluorouracil-associated diarrhea?. Supportive Care in Cancer. Sep. 1995;3(5):322-3. Not included study design. [pmid: 8520881].
153 Causey MW, Spencer MP, Steele SR. Clostridium difficile enteritis after colectomy. American Surgeon. Dec. 2009;75(12):1203-6. Not relevant to key questions. [pmid: 19999913].
154 Cerquetti M, Molinari A, Sebastianelli A, et al. Characterization of surface layer proteins from different Clostridium difficile clinical isolates. Microbial pathogenesis. Jun. 2000;28(6):363-72. Not on topic. [pmid: 10839973].
155 Chachaty E, Depitre C, Mario N, et al. Presence of Clostridium difficile and antibiotic and beta-lactamase activities in feces of volunteers treated with oral cefixime, oral cefpodoxime proxetil, or placebo. Antimicrob Agents Chemother. Sep. 1992;36(9):2009-13. Not on topic. [pmid: 1416894].
156 Chakrabarti S, Lees A, Jones SG, et al. Clostridium difficile infection in allogeneic stem cell transplant recipients is associated with severe graft-versus-host disease and non-relapse mortality. Bone marrow transplantation. Oct. 2000;26(8):871-6. Not included study design. [pmid: 11081387].
157 Chan S, Kelly M, Helme S, et al. Outcomes following colectomy for Clostridium difficile colitis. International Journal Of Surgery. Feb. 2009;7(1):78-81. Not included study design. [pmid: 19070558].
158 Chandok N, Kamath PS. Working out the bug in the accordion. Gastroenterol. Jul. 2009;137(1):e5-6. Not included publication type.
159 Chang AY, Hui L, Asbury R, et al. Ifosfamide, carboplatin and etoposide (ICE) in metastatic and refractory breast cancer. Cancer Chemotherapy & Pharmacology. 1999;44(Suppl):S26-8. Not on topic. [pmid: 10602907].
160 Chang KC, Leung CC, Yew WW, et al. Analyses of fluoroquinolones and Clostridium difficile-associated diarrhoea in tuberculosis patients. International Journal of Tuberculosis & Lung Disease. Mar. 2009;13(3):341-6. Not on topic. [pmid: 19275794].
161 Chang TW, Gorbach SL, Bartlett JG, et al. Bacitracin treatment of antibiotic-associated colitis and diarrhea caused by Clostridium difficile toxin. Gastroenterol. Jun. 1980;78(6):1584-6. Not included study design.
162 Chang VT, Nelson K. The role of physical proximity in nosocomial diarrhea. Clinic Infect Dis. Sep. 2000;31(3):717-22. Not included study design.
163 Changela U, Cannon JP, Aneziokoro C, et al. Risk factors and mortality associated with Clostridium difficile-associated diarrhoea at a VA hospital. International journal of antimicrobial agents. Dec. 2004;24(6):562-6. Not included study design. [pmid: 15555878].
164 Chaudhry R, Joshy L, Kumar L, et al. Changing pattern of Clostridium difficile associated diarrhoea in a tertiary care hospital: a 5 year retrospective study. Indian Journal of Medical Research. Apr. 2008;127(4):377-82. Not included study design. [pmid: 18577793].
165 Chaun H. Colonic disorders in adult cystic fibrosis. Can J Gastroenterol. Sep. 2001;15(9):586-90. Not included publication type. [pmid: 11573101].
166 Chemaly RF, Hanmod SS, Jiang Y, et al. Tigecycline use in cancer patients with serious infections: a report on 110 cases from a single institution. Medicine. Jul. 2009;88(4):211-20. Not on topic. [pmid: 19593226].
167 Cheng SH, Lu JJ, Young TG, et al. Clostridium difficile--associated diseases: comparison of symptomatic infection versus carriage on the basis of risk factors, toxin production, and genotyping results. Clinic Infect Dis. Jul. 1997;25(1):157-8. Not included population.
168 Cherifi S, Robberecht J, Miendje Y. Saccharomyces cerevisiae fungemia in an elderly patient with Clostridium difficile colitis. Acta Clinica Belgica. Jul-Aug. 2004;59(4):223-4. Not included study design. [pmid: 15597730].
169 Cherry RD, Portnoy D, Jabbari M, et al. Metronidazole: an alternate therapy for antibiotic-associated colitis. Gastroenterol. May. 1982;82(5 Pt 1):849-51. Not included study design.
170 Chi DS, Waltzman RJ, Barakat RR, et al. Primary intravenous paclitaxel and platinum chemotherapy for high-risk Stage I epithelial ovarian carcinoma. European journal of gynaecological oncology. 1999;20(4):277-80. Not on topic. [pmid: 10475122].
171 Choban PS, Heckler R, Burge JC, et al. Increased incidence of nosocomial infections in obese surgical patients. American Surgeon. Nov. 1995;61(11):1001-5. Not on topic. [pmid: 7486411].
172 Choudhry MN, Soran H, Ziglam HM. Overuse and inappropriate prescribing of proton pump inhibitors in patients with Clostridium difficile-associated disease. QJM. Jun. 2008;101(6):445-8. Not included study design. [pmid: 18411220].
173 Christensen PD, Starklint H, Tvede M, et al. Excessive hypercalcaemia and mixed connective tissue disease. Acta Medica Scandinavica. 1986;220(3):285-8. Not included publication type. [pmid: 3776702].
174 Church JM, Fazio VW. The significance of quantitative results of C. difficile cultures and toxin assays in patients with diarrhea. Dis Colon Rectum. Nov. 1985;28(11):765-9. Not included study design. [pmid: 3902411].
175 Church JM, Fazio VW. A role for colonic stasis in the pathogenesis of disease related to Clostridium difficile. Dis Colon Rectum. Dec. 1986;29(12):804-9. Not included study design. [pmid: 3792161].
176 Clayton EM, Rea MC, Shanahan F, et al. The vexed relationship between Clostridium difficile and inflammatory bowel disease: an assessment of carriage in an outpatient setting among patients in remission. Am J Gastroenterol. May. 2009;104(5):1162-9. Not included study design. [pmid: 19319128].
177 Cleary RK, Grossmann R, Fernandez FB, et al. Metronidazole may inhibit intestinal colonization with Clostridium difficile. Dis Colon Rectum. Apr. 1998;41(4):464-7. Not included population. [pmid: 9559631].
178 Cloud J, Noddin L, Pressman A, et al. Clostridium difficile strain NAP-1 is not associated with severe disease in a nonepidemic setting. Clin Gastroenterol Hepatol. Aug. 2009;7(8):868-73.e2. Not included study design. [pmid: 19465153].
179 Cober ED, Malani PN. Clostridium difficile infection in the “oldest” old: clinical outcomes in patients aged 80 and older. Journal of the American Geriatrics Society. Apr. 2009;57(4):659-62. Not included study design. [pmid: 19392957].
180 Cohen SH, Tang YJ, Hansen B, et al. Isolation of a toxin B-deficient mutant strain of Clostridium difficile in a case of recurrent C. difficile-associated diarrhea. Clinic Infect Dis. Feb. 1998;26(2):410-2. Not included study design.
181 Colarian J. Clostridium difficile colitis following antiviral therapy in the acquired immunodeficiency syndrome. Am J Med. Jun. 1988;84(6):1081. Not included study design. [pmid: 3163893].
182 Cooper GS, Lederman MM, Salata RA. A predictive model to identify Clostridium difficile toxin in hospitalized patients with diarrhea. Am J Gastroenterol. Jan. 1996;91(1):80-4. Background. [pmid: 8561149].
183 Cope A, Anderson J, Wilkins E. Clostridium difficile toxin-induced reactive arthritis in a patient with chronic Reiter's syndrome. Eur J Clin Microbiol Infect Dis. Jan. 1992;11(1):40-3. Not included study design. [pmid: 1563383].
184 Costas M, Holmes B, Ganner M, et al. Identification of outbreak-associated and other strains of Clostridium difficile by numerical analysis of SDS-PAGE protein patterns. Epidemiology & Infection. Aug. 1994;113(1):1-12. Not included study design. [pmid: 8062865].
185 Cox GJ, Matsui SM, Lo RS, et al. Etiology and outcome of diarrhea after marrow transplantation: a prospective study. Gastroenterol. Nov. 1994;107(5):1398-407. Not on topic.
186 Cozart JC, Kalangi SS, Clench MH, et al. Clostridium difficile diarrhea in patients with AIDS versus non-AIDS controls. Methods of treatment and clinical response to treatment. J Clin Gastroenterol. Apr. 1993;16(3):192-4. Not included study design. [pmid: 8505488].
187 Crabtree T, Aitchison D, Meyers BF, et al. Clostridium difficile in cardiac surgery: risk factors and impact on postoperative outcome. Annals of Thoracic Surgery. Apr. 2007;83(4):1396-402. Not included study design. [pmid: 17383346].
188 Crabtree TD, Pelletier SJ, Gleason TG, et al. Clinical characteristics and antibiotic utilization in surgical patients with Clostridium difficile-associated diarrhea. American Surgeon. discussion 511-2. Jun. 1999;65(6):507-11. Not included study design. [pmid: 10366203].
189 Crabtree TD, Pelletier SJ, Raymond DP, et al. Effect of changes in surgical practice on the rate and detection of nosocomial infections: a prospective analysis. Shock. Apr. 2002;17(4):258-62. Not on topic. [pmid: 11954823].
190 Crogan NL, Evans BC. Clostridium difficile: an emerging epidemic in nursing homes. Geriatric nursing. May-Jun. 2007;28(3):161-4. Not included publication type. [pmid: 17642100].
191 Cronberg S, Castor B, Thoren A. Fusidic acid for the treatment of antibiotic-associated colitis induced by Clostridium difficile. Infection. Jul-Aug. 1984;12(4):276-9. Not relevant to key questions. [pmid: 6490173].
192 Crum-Cianflone N. Clostridium innocuum Bacteremia in a patient with acquired immunodeficiency syndrome. American Journal of the Medical Sciences. Jun. 2009;337(6):480-2. Not on topic. [pmid: 19525665].
193 Crum-Cianflone N. Clostridium innocuum Bacteremia in a patient with acquired immunodeficiency syndrome. American Journal of the Medical Sciences. Jun. 2009;337(6):480-2. Duplicate listing. [pmid: 19525665].
194 Cudmore MA, Silva J Jr, Fekety R, et al. Clostridium difficile colitis associated with cancer chemotherapy. Arch Intern Med. Feb. 1982;142(2):333-5. Not included study design. [pmid: 7036924].
195 Cunney RJ, Magee C, McNamara E, et al. Clostridium difficile colitis associated with chronic renal failure. Nephrology Dialysis Transplantation. Nov. 1998;13(11):2842-6. Not included study design.
196 Cuzzolin L, Zambreri D, Donini M, et al. Influence of radiotherapy on intestinal microflora in cancer patients. Journal of Chemotherapy. Jun. 1992;4(3):176-9. Not included study design. [pmid: 1517812].
197 Cuzzolin L, Zambreri D, Donini M, et al. Influence of radiotherapy on intestinal microflora in cancer patients. Journal of Chemotherapy. Jun. 1992;4(3):176-9. Duplicate listing. [pmid: 1517812].
198 D'Agata EM, Mount DB, Thayer V, et al. Hospital-acquired infections among chronic hemodialysis patients. American Journal of Kidney Diseases. Jun. 2000;35(6):1083-8. Not included study design. [pmid: 10845821].
199 Dalton BR, Lye-Maccannell T, Henderson EA, et al. Proton pump inhibitors increase significantly the risk of Clostridium difficile infection in a low-endemicity, non-outbreak hospital setting. Aliment Pharmacol Ther. Mar. 15. 2009;29(6):626-34. Not on topic. [pmid: 19183143].
200 Daniele B, Rossi GB, Losito S, et al. Ischemic colitis associated with paclitaxel. J Clin Gastroenterol. Aug. 2001;33(2):159-60. Not included publication type. [pmid: 11468447].
201 Danna PL, Urban C, Bellin E, et al. Role of candida in pathogenesis of antibiotic-associated diarrhoea in elderly inpatients. Lancet. Mar. 2. 1991;337(8740):511-4. Not on topic. [pmid: 1671890].
202 Dansinger ML, Johnson S, Jansen PC, et al. Protein-losing enteropathy is associated with Clostridium difficile diarrhea but not with asymptomatic colonization: a prospective, case-control study. Clinic Infect Dis. Jun. 1996;22(6):932-7. Not included study design.
203 Daw NC, Santana VM, Iacono LC, et al. Phase I and pharmacokinetic study of topotecan administered orally once daily for 5 days for 2 consecutive weeks to pediatric patients with refractory solid tumors. Journal of Clinical Oncology. Mar. 1. 2004;22(5):829-37. Not on topic. [pmid: 14990638].
204 De Andres S, Ferreiro D, Ibanez M, et al. Clostridium difficile colitis associated with valaciclovir. Pharmacy World & Science. Feb. 2004;26(1):8-9. Not included study design. [pmid: 15018252].
205 De La Cochetiere MF, Durand T, Lalande V, et al. Effect of antibiotic therapy on human fecal microbiota and the relation to the development of Clostridium difficile. Microbial ecology. Oct. 2008;56(3):395-402. Not included study design. [pmid: 18209965].
206 de Lalla F, Nicolin R, Rinaldi E, et al. Prospective study of oral teicoplanin versus oral vancomycin for therapy of pseudomembranous colitis and Clostridium difficile-associated diarrhea. Antimicrob Agents Chemother. Oct. 1992;36(10):2192-6. Not included treatment type. [pmid: 1444298].
207 de Lalla F, Santoro D, Rinaldi E, et al. Teicoplanin in the treatment of infections by staphylococci, Clostridium difficile and other gram-positive bacteria. J Antimicrob Chemother. Jan. 1989;23(1):131-42. Not included study design. [pmid: 2526109].
208 de Leeuw P, de Mot H, Dugernier T, et al. Primary infection of ascitic fluid with Clostridium difficile. Journal of Infection. Jul. 1990;21(1):77-80. Not included publication type. [pmid: 2384684].
209 Debast SB, Vaessen N, Choudry A, et al. Successful combat of an outbreak due to Clostridium difficile PCR ribotype 027 and recognition of specific risk factors. Clinical Microbiology & Infection. May. 2009;15(5):427-34. Not relevant to key questions. [pmid: 19416295].
210 Delmee M, Ramboer I, Van Broeck J, et al. Epidemiology of Clostridium difficile toxinotype III, PCR-ribotype 027 associated disease in Belgium, 2006. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2006;11(9):E060914.2. Not included study design. [pmid: 17075147].
211 Depitre C, Avesani V, Delmee M, et al. Detection of Clostridium difficile toxins in stools. Comparison between a new enzyme immunoassay for toxin A and other routine tests. Gastroenterologie clinique et biologique. 1993;17(4):283-6. Not relevant to key questions. [pmid: 8339887].
212 Deptula A, Kruszynska E, Mikucka A, et al. Toxin A-producing Clostridium difficile as an aetiological factor of post-traumatic wound infection. Journal of medical microbiology. Jul. 2009;58(Pt 7):963-4. Not included publication type. [pmid: 19502374].
213 Dettenkofer M, Ebner W, Bertz H, et al. Surveillance of nosocomial infections in adult recipients of allogeneic and autologous bone marrow and peripheral blood stem-cell transplantation. Bone marrow transplantation. May. 2003;31(9):795-801. Not included study design. [pmid: 12732887].
214 Dhalla IA, Mamdani MM, Simor AE, et al. Are broad-spectrum fluoroquinolones more likely to cause Clostridium difficile-associated disease?. Antimicrob Agents Chemother. Sep. 2006;50(9):3216-9. Not included study design. [pmid: 16940135].
215 Dhawan B, Chaudhry R, Sharma N. Incidence of Clostridium difficile infection: a prospective study in an Indian hospital. J Hosp Infect. Dec. 1999;43(4):275-80. Not included study design. [pmid: 10658803].
216 Dial S, Alrasadi K, Manoukian C, et al. Risk of Clostridium difficile diarrhea among hospital inpatients prescribed proton pump inhibitors: cohort and case-control studies. CMAJ. Jul. 6. 2004;171(1):33-8. Not included study design. [pmid: 15238493].
217 Dial S, Delaney JA, Schneider V, et al. Proton pump inhibitor use and risk of community-acquired Clostridium difficile-associated disease defined by prescription for oral vancomycin therapy. CMAJ. Sep. 26. 2006;175(7):745-8. Not included study design. [pmid: 17001054].
218 Dial S, Kezouh A, Dascal A, et al. Patterns of antibiotic use and risk of hospital admission because of Clostridium difficile infection. CMAJ. Oct. 7. 2008;179(8):767-72. Not included study design. [pmid: 18838451].
219 Dial S, Kezouh A, Dascal A, et al. Patterns of antibiotic use and risk of hospital admission because of Clostridium difficile infection. CMAJ. Oct. 7. 2008;179(8):767-72. Duplicate listing. [pmid: 18838451].
220 Dickinson RJ, O'Connor HJ, Pinder I, et al. Double blind controlled trial of oral vancomycin as adjunctive treatment in acute exacerbations of idiopathic colitis. Gut. Dec. 1985;26(12):1380-4. Not included population. [pmid: 3910524].
221 Diep JT, Kerr LD, Sarebahi S, et al. Opportunistic infections mimicking gastrointestinal vasculitis in systemic lupus erythematosus. JCR: Journal of Clinical Rheumatology. Aug. 2007;13(4):213-6. Not included study design.
222 Dignan CR, Greenson JK. Can ischemic colitis be differentiated from C difficile colitis in biopsy specimens?. [see comment]. American Journal of Surgical Pathology. Jun. 1997;21(6):706-10. Not included study design. [pmid: 9199649].
223 Djuretic T, Ryan MJ, Fleming DM, et al. Infectious intestinal disease in elderly people. Communicable Disease Report.CDR Review. Jul. 19. 1996;6(8):R107-12. Not included study design. [pmid: 8755672].
224 Do AN, Fridkin SK, Yechouron A, et al. Risk factors for early recurrent Clostridium difficile-associated diarrhea. Clinic Infect Dis. Apr. 1998;26(4):954-9. Not included study design.
225 Donskey CJ, Ray AJ, Hoyen CK, et al. Colonization and infection with multiple nosocomial pathogens among patients colonized with vancomycin-resistant Enterococcus. Infect Control Hosp Epidemiol. Apr. 2003;24(4):242-5. Not included study design. [pmid: 12725351].
226 Drees M, Snydman DR, O'Sullivan CE. Repeated enzyme immunoassays have limited utility in diagnosing Clostridium difficile. Eur J Clin Microbiol Infect Dis. May. 2008;27(5):397-9. Not included study design. [pmid: 18189148].
227 Drummond LJ, McCoubrey J, Smith DG, et al. Changes in sensitivity patterns to selected antibiotics in Clostridium difficile in geriatric in-patients over an 18-month period. Journal of medical microbiology. Mar. 2003;52(Pt 3):259-63. Not included study design. [pmid: 12621092].
228 Dubberke ER, Butler AM, Hota B, et al. Multicenter study of the impact of community-onset Clostridium difficile infection on surveillance for C. difficile infection. Infect Control Hosp Epidemiol. Jun. 2009;30(6):518-25. Not included study design. [pmid: 19419269].
229 Dubberke ER, Butler AM, Reske KA, et al. Attributable outcomes of endemic Clostridium difficile-associated disease in nonsurgical patients. Emerging Infectious Diseases. Jul. 2008;14(7):1031-8. Not included study design. [pmid: 18598621].
230 Dubberke ER, Butler AM, Reske KA, et al. Attributable outcomes of endemic Clostridium difficile-associated disease in nonsurgical patients. Emerging Infectious Diseases. Jul. 2008;14(7):1031-8. Duplicate listing. [pmid: 18598621].
231 Dubberke ER, McMullen KM, Mayfield JL, et al. Hospital-associated Clostridium difficile infection: is it necessary to track community-onset disease?. Infect Control Hosp Epidemiol. Apr. 2009;30(4):332-7. Not included study design. [pmid: 19239377].
232 Dubberke ER, Reske KA, McDonald LC, et al. ICD-9 codes and surveillance for Clostridium difficile-associated disease. Emerging Infectious Diseases. Oct. 2006;12(10):1576-9. Not included study design. [pmid: 17176576].
233 Dubberke ER, Reske KA, Olsen MA, et al. Short- and long-term attributable costs of Clostridium difficile-associated disease in nonsurgical inpatients. Clinic Infect Dis. Feb. 15. 2008;46(4):497-504. Not included study design.
234 Dubberke ER, Reske KA, Olsen MA, et al. Evaluation of Clostridium difficile-associated disease pressure as a risk factor for C difficile-associated disease. Arch Intern Med. May. 28. 2007;167(10):1092-7. Not included study design. [pmid: 17533213].
235 Dubberke ER, Reske KA, Yan Y, et al. Clostridium difficile--associated disease in a setting of endemicity: identification of novel risk factors. Clinic Infect Dis. Dec. 15. 2007;45(12):1543-9. Not included study design.
236 Edlund C, Alvan G, Barkholt L, et al. Pharmacokinetics and comparative effects of telithromycin (HMR 3647) and clarithromycin on the oropharyngeal and intestinal microflora. J Antimicrob Chemother. Nov. 2000;46(5):741-9. Not on topic. [pmid: 11062193].
237 Edlund C, Stark C, Nord CE. The relationship between an increase in beta-lactamase activity after oral administration of three new cephalosporins and protection against intestinal ecological disturbances. J Antimicrob Chemother. Jul. 1994;34(1):127-38. Not on topic. [pmid: 7961199].
238 Ehrenpreis ED, Lievens MW, Craig RM. Clostridium difficile-associated diarrhea after norfloxacin. J Clin Gastroenterol. Apr. 1990;12(2):188-9. Not included publication type. [pmid: 2324482].
239 Eidhin DN, Ryan AW, Doyle RM, et al. Sequence and phylogenetic analysis of the gene for surface layer protein, slpA, from 14 PCR ribotypes of Clostridium difficile. Journal of medical microbiology. Jan. 2006;55(Pt 1):69-83. Not included study design. [pmid: 16388033].
240 Elmer GW. Probiotics: “living drugs”. American Journal of Health-System Pharmacy. Jun. 15. 2001;58(12):1101-9. Not included publication type. [pmid: 11449853].
241 Elmer GW, McFarland LV. Biotherapeutic agents in the treatment of infectious diarrhea. Gastroenterology clinics of North America. Sep. 2001;30(3):837-54. Not included publication type. [pmid: 11586560].
242 Elmer GW, Surawicz CM, McFarland LV. Biotherapeutic agents. A neglected modality for the treatment and prevention of selected intestinal and vaginal infections. [see comment]. JAMA. Mar. 20. 1996;275(11):870-6. Not included study design. [pmid: 8596226].
243 Emery EA, Ahmad S, Koethe JD, et al. Banana flakes control diarrhea in enterally fed patients. Nutrition in Clinical Practice. Apr. 1997;12(2):72-5. Not on topic. [pmid: 9155405].
244 Emoto M, Kawarabayashi T, Hachisuga MD, et al. Clostridium difficile colitis associated with cisplatin-based chemotherapy in ovarian cancer patients. Gynecologic oncology. Jun. 1996;61(3):369-72. Not included publication type. [pmid: 8641617].
245 Enzensberger R, Shah PM, Knothe H. Impact of oral ciprofloxacin on the faecal flora of healthy volunteers. Infection. Nov-Dec. 1985;13(6):273-5. Not on topic. [pmid: 2934338].
246 Eriksson S, Aronsson B. Medical implications of nosocomial infection with Clostridium difficile. Scand J Infect Dis. 1989;21(6):733-4. Background. [pmid: 2617213].
247 Eron LJ, Goldenberg RI, Park CH, et al. Ceftazidime therapy of serious bacterial infections. Antimicrob Agents Chemother. Feb. 1983;23(2):236-41. Not on topic. [pmid: 6340601].
248 Eron LJ, Park CH, Hixon DL, et al. Ceftazidime in patients with Pseudomonas infections. J Antimicrob Chemother. Jul. 1983;12(Suppl A):161-9. Not on topic. [pmid: 6225762].
249 Fan YJ, Chen SJ, Yu YC, et al. A probiotic treatment containing Lactobacillus, Bifidobacterium and Enterococcus improves IBS symptoms in an open label trial. Journal of Zhejiang University.Science.B. Dec. 2006;7(12):987-91. Not included population. [pmid: 17111468].
250 Farrell RJ, LaMont JT. Pathogenesis and clinical manifestations of Clostridium difficile diarrhea and colitis. Current Topics in Microbiology & Immunology. 2000;250:109-25. Not included publication type. [pmid: 10981360].
251 Farver DK, Hedge DD, Lee SC. Ramoplanin: a lipoglycodepsipeptide antibiotic. Ann Pharmacother. May. 2005;39(5):863-8. Not included publication type. [pmid: 15784805].
252 Fass RJ, Plouffe JF, Russell JA. Intravenous/oral ciprofloxacin versus ceftazidime in the treatment of serious infections. Am J Med. Nov. 30. 1989;87(5A):164S-8S. Not on topic. [pmid: 2589361].
253 Fawley WN, Wilcox MH. Molecular epidemiology of endemic Clostridium difficile infection. Epidemiology & Infection. Jun. 2001;126(3):343-50. Not included study design. [pmid: 11467790].
254 Fekety R. Recent advances in management of bacterial diarrhea. Reviews of infectious diseases. Mar-Apr. 1983;5(2):246-57. Not included publication type. [pmid: 6405474].
255 Fekety R, McFarland LV, Surawicz CM, et al. Recurrent Clostridium difficile diarrhea: characteristics of and risk factors for patients enrolled in a prospective, randomized, double-blinded trial. Clinic Infect Dis. Mar. 1997;24(3):324-33. Not included study design.
256 Fekety R, O'Connor R, Silva J. Rifampin and pseudomembranous colitis. Reviews of infectious diseases. Jul-Aug. 1983;5(Suppl 3):S524-7. Not included study design. [pmid: 6635443].
257 Fekety R, Silva J, Buggy B, et al. Treatment of antibiotic-associated colitis with vancomycin. J Antimicrob Chemother. Dec. 1984;14(Suppl D):97-102. Not included study design. [pmid: 6520070].
258 Feldman RJ, Kallich M, Weinstein MP. Bacteremia due to Clostridium difficile: case report and review of extraintestinal C. difficile infections. Clinic Infect Dis. Jun. 1995;20(6):1560-2. Not included publication type.
259 Fenner L, Frei R, Gregory M, et al. Epidemiology of Clostridium difficile-associated disease at University Hospital Basel including molecular characterisation of the isolates 2006-2007. Eur J Clin Microbiol Infect Dis. Dec. 2008;27(12):1201-7. Not included study design. [pmid: 18560909].
260 Fernandez A, Anand G, Friedenberg F. Factors associated with failure of metronidazole in Clostridium difficile-associated disease. J Clin Gastroenterol. May-Jun. 2004;38(5):414-8. Not included study design. [pmid: 15100520].
261 Ferroni A, Merckx J, Ancelle T, et al. Nosocomial outbreak of Clostridium difficile diarrhea in a pediatric service. Eur J Clin Microbiol Infect Dis. Dec. 1997;16(12):928-33. Not included study design. [pmid: 9495676].
262 Fille M, Larcher C, Dierich MP, et al. Evaluation of four methods for detection of Clostridium difficile or C. difficile toxin: cytotoxin assay, culture, latex agglutination, and a new rapid immunoassay (C. difficile toxin A test). Zeitschrift fur Gastroenterologie. Feb. 1998;36(2):143-9. Not included population. [pmid: 9544497].
263 Fitzpatrick F, McIlvenny G, Oza A, et al. Hospital infection society prevalence survey of Healthcare Associated Infection 2006: comparison of results between Northern Ireland and the Republic of Ireland. J Hosp Infect. Jul. 2008;69(3):265-73. Not included study design. [pmid: 18547678].
264 Fletcher KR, Cinalli M. Identification, optimal management, and infection control measures for Clostridium difficile-associated disease in long-term care. Geriatric nursing. quiz 182. May-Jun. 2007;28(3):171-81. Not included study design. [pmid: 17561015].
265 Follmar KE, Condron SA, Turner II, et al. Treatment of metronidazole-refractory Clostridium difficile enteritis with vancomycin. Surgical Infections. Apr. 2008;9(2):195-200. Not included study design. [pmid: 18426352].
266 Forward LJ, Tompkins DS, Brett MM. Detection of Clostridium difficile cytotoxin and Clostridium perfringens enterotoxin in cases of diarrhoea in the community. Journal of medical microbiology. Sep. 2003;52(Pt 9):753-7. Not included study design. [pmid: 12909650].
267 Foulke GE, Silva J Jr. Clostridium difficile in the intensive care unit: management problems and prevention issues. Critical care medicine. Aug. 1989;17(8):822-6. Not included study design. [pmid: 2752778].
268 Francioli P, Clement M, Geroulanos S, et al. Ceftazidime in severe infections: a Swiss multicentre study. J Antimicrob Chemother. Jul. 1983;12(Suppl A):139-46. Not on topic. [pmid: 6225761].
269 Freeman HJ, Rabeneck L, Owen D. Survival after necrotizing enterocolitis of leukemia treated with oral vancomycin. Gastroenterol. Oct. 1981;81(4):791-4. Not on topic.
270 Freeman J, Baines SD, Saxton K, et al. Effect of metronidazole on growth and toxin production by epidemic Clostridium difficile PCR ribotypes 001 and 027 in a human gut model. J Antimicrob Chemother. Jul. 2007;60(1):83-91. Not included population. [pmid: 17483547].
271 Freifeld AG, Walsh T, Marshall D, et al. Monotherapy for fever and neutropenia in cancer patients: a randomized comparison of ceftazidime versus imipenem. Journal of Clinical Oncology. Jan. 1995;13(1):165-76. Not on topic. [pmid: 7799016].
272 Frenz MB, McIntyre AS. Reducing delays in the diagnosis and treatment of Clostridium difficile diarrhoea. QJM. Aug. 2003;96(8):579-82. Not on topic. [pmid: 12897343].
273 Friedenberg F, Fernandez A, Kaul V, et al. Intravenous metronidazole for the treatment of Clostridium difficile colitis. Dis Colon Rectum. Aug. 2001;44(8):1176-80. Not included study design. [pmid: 11535859].
274 Funada H, Ishizaki T, Kuroda T, et al. Cefotaxime-associated diarrhea and Clostridium difficile. Japanese Journal of Antibiotics. Apr. 1984;37(4):555-7. Not included publication type. [pmid: 6088823].
275 Furrie E, Senok AC, Frank DN, et al. Pondering probiotics. Clinical Immunology. Oct. 2006;121(1):19-22. Not included publication type. [pmid: 16807114].
276 Gadducci A, Gargini A, Palla E, et al. Neutropenic enterocolitis in an advanced epithelial ovarian cancer patient treated with paclitaxel/platinum-based chemotherapy: a case report and review of the literature. Anticancer Research. May-Jun. 2005;25(3c):2509-13. Not included publication type. [pmid: 16080485].
277 Garbutt JM, Littenberg B, Evanoff BA, et al. Enteric carriage of vancomycin-resistant Enterococcus faecium in patients tested for Clostridium difficile. Infect Control Hosp Epidemiol. Oct. 1999;20(10):664-70. Not included study design. [pmid: 10530643].
278 Garcia C, Samalvides F, Vidal M, et al. Epidemiology of Clostridium difficile-associated diarrhea in a Peruvian tertiary care hospital. American Journal of Tropical Medicine & Hygiene. Nov. 2007;77(5):802-5. Not included study design. [pmid: 17984329].
279 Garcia-Osogobio S, Takahashi T, Gamboa-Dominguez A, et al. Toxic pseudomembranous colitis in a patient with ulcerative colitis. Inflammatory bowel diseases. Aug. 2000;6(3):188-90. Not included publication type. [pmid: 10961591].
280 Garey KW, Dao-Tran TK, Jiang ZD, et al. A clinical risk index for Clostridium difficile infection in hospitalised patients receiving broad-spectrum antibiotics. J Hosp Infect. Oct. 2008;70(2):142-7. Not included study design. [pmid: 18723249].
281 Garey KW, Graham G, Gerard L, et al. Prevalence of diarrhea at a university hospital and association with modifiable risk factors. Ann Pharmacother. Jun. 2006;40(6):1030-4. Not included study design. [pmid: 16684806].
282 Garey KW, Jiang ZD, Yadav Y, et al. Peripartum Clostridium difficile infection: case series and review of the literature. American Journal of Obstetrics & Gynecology. Oct. 2008;199(4):332-7. Not included study design. [pmid: 18639213].
283 Garey KW, Sethi S, Yadav Y, et al. Meta-analysis to assess risk factors for recurrent Clostridium difficile infection. J Hosp Infect. Dec. 2008;70(4):298-304. Background. [pmid: 18951661].
284 Garibaldi RA. Residential care and the elderly: the burden of infection. J Hosp Infect. Dec. 1999;43(Suppl):S9-18. Not included publication type. [pmid: 10658754].
285 Garner CE, Smith S, de Lacy Costello B, et al. Volatile organic compounds from feces and their potential for diagnosis of gastrointestinal disease. FASEB Journal. Jun. 2007;21(8):1675-88. Not on topic. [pmid: 17314143].
286 Gellad ZF, Alexander BD, Liu JK, et al. Severity of Clostridium difficile-associated diarrhea in solid organ transplant patients. Transplant Infectious Disease. Dec. 2007;9(4):276-80. Not included study design. [pmid: 17635835].
287 Gentry LO. Role for newer beta-lactam antibiotics in treatment of osteomyelitis. Am J Med. Jun. 7. 1985;78(6A):134-9. Not on topic. [pmid: 3859212].
288 George WL, Rolfe RD, Harding GK, et al. Clostridium difficile and cytotoxin in feces of patients with antimicrobial agent-associated pseudomembranous colitis. Infection. 1982;10(4):205-8. Not included study design. [pmid: 7129642].
289 Gerding DN, Olson MM, Peterson LR, et al. Clostridium difficile-associated diarrhea and colitis in adults. A prospective case-controlled epidemiologic study. Arch Intern Med. Jan. 1986;146(1):95-100. Not included study design. [pmid: 3942469].
290 Geroulanos S, Donfried B, Schumacher F, et al. Cefuroxime versus ceftriaxone prophylaxis in cardiovascular surgery. Drugs Under Experimental & Clinical Research. 1985;11(3):201-5. Not on topic. [pmid: 3915287].
291 Ghai S, Ghai V, Sunderji S. Fulminant postcesarean Clostridium difficile pseudomembranous colitis. Obstetrics & Gynecology. Feb. 2007;109(2 Pt2):541-3. Not included publication type. [pmid: 17267888].
292 Ghai S, Ghai V, Sunderji S. Fulminant postcesarean Clostridium difficile pseudomembranous colitis. Obstetrics & Gynecology. Feb. 2007;109(2 Pt2):541-3. Duplicate listing. [pmid: 17267888].
293 Gifford AH, Kirkland KB. Risk factors for Clostridium difficile-associated diarrhea on an adult hematology-oncology ward. Eur J Clin Microbiol Infect Dis. Dec. 2006;25(12):751-5. Not included study design. [pmid: 17072575].
294 Gill VJ, Travis LB, Williams DY. Clinical and microbiological observations on CDC group DF-3, a gram-negative coccobacillus. J Clin Microbiol. Aug. 1991;29(8):1589-92. Not on topic. [pmid: 1761678].
295 Goldstein EJ, Citron DM, Merriam CV, et al. In vitro activities of the new semisynthetic glycopeptide telavancin (TD-6424), vancomycin, daptomycin, linezolid, and four comparator agents against anaerobic gram-positive species and Corynebacterium spp. Antimicrob Agents Chemother. Jun. 2004;48(6):2149-52. Not included population. [pmid: 15155214].
296 Gonzalez-Valencia G, Munoz O, Torres JF. Toxigenicity and adherence in Clostridium difficile strains isolated from patients with and without diarrhoea. Archivos de Investigacion Medica. Apr-Jun. 1991;22(2):189-96. Not included study design. [pmid: 1819993].
297 Goorhuis A, Bakker D, Corver J, et al. Emergence of Clostridium difficile infection due to a new hypervirulent strain, polymerase chain reaction ribotype 078. Clinic Infect Dis. Nov. 1. 2008;47(9):1162-70. Not included study design.
298 Goorhuis A, Van der Kooi T, Vaessen N, et al. Spread and epidemiology of Clostridium difficile polymerase chain reaction ribotype 027/toxinotype III in The Netherlands. Clinic Infect Dis. Sep. 15. 2007;45(6):695-703. Not included study design.
299 Gopal Rao G, Mahankali Rao CS, Starke I. Clostridium difficile-associated diarrhoea in patients with community-acquired lower respiratory infection being treated with levofloxacin compared with beta-lactam-based therapy. J Antimicrob Chemother. Mar. 2003;51(3):697-701. Not on topic. [pmid: 12615873].
300 Gopal Rao G, Patel M. Urinary tract infection in hospitalized elderly patients in the United Kingdom: the importance of making an accurate diagnosis in the post broad-spectrum antibiotic era. J Antimicrob Chemother. Jan. 2009;63(1):5-6. Not included study design. [pmid: 19022779].
301 Gopal Rao G, Patel M. Urinary tract infection in hospitalized elderly patients in the United Kingdom: the importance of making an accurate diagnosis in the post broad-spectrum antibiotic era. J Antimicrob Chemother. Jan. 2009;63(1):5-6. Duplicate listing. [pmid: 19022779].
302 Gorbach SL. Clostridium difficile settles in a nursing home. Hospital Practice (Office Edition). 157. Feb. 15. 1989;24(2):152-60. 145. 9. Not included publication type.
303 Gorbach SL, Cornick NA, Silva M. Effect of bismuth subsalicylate on fecal microflora. Reviews of infectious diseases. Jan-Feb. 1990;12(Suppl 1):S21-3. Not on topic. [pmid: 2305174].
304 Gorenek L, Dizer U, Besirbellioglu B, et al. The diagnosis and treatment of Clostridium difficile in antibiotic-associated diarrhea. Hepato-gastroenterology. Jan-Feb. 1999;46(25):343-8. Not relevant to key questions. [pmid: 10228818].
305 Gorschluter M, Glasmacher A, Hahn C, et al. Clostridium difficile infection in patients with neutropenia. Clinic Infect Dis. Sep. 15. 2001;33(6):786-91. Not included study design.
306 Gorschluter M, Marklein G, Hofling K, et al. Abdominal infections in patients with acute leukaemia: a prospective study applying ultrasonography and microbiology. British journal of haematology. May. 2002;117(2):351-8. Not included study design. [pmid: 11972517].
307 Gould PC, Khawaja FI, Rosenthal WS. Antibiotic-associated hemorrhagic colitis. Am J Gastroenterol. Jul. 1982;77(7):491-3. Not included study design. [pmid: 6979926].
308 Gravel D, Miller M, Simor A, et al. Health care-associated Clostridium difficile infection in adults admitted to acute care hospitals in Canada: a Canadian Nosocomial Infection Surveillance Program Study. Clinic Infect Dis. Mar. 1. 2009;48(5):568-76. Background.
309 Gravel D, Miller M, Simor A, et al. Health care-associated Clostridium difficile infection in adults admitted to acute care hospitals in Canada: a Canadian Nosocomial Infection Surveillance Program Study. Clinic Infect Dis. Mar. 1. 2009;48(5):568-76. Duplicate listing.
310 Greenstein AJ, Byrn JC, Zhang LP, et al. Risk factors for the development of fulminant Clostridium difficile colitis. Surgery. May. 2008;143(5):623-9. Not included study design. [pmid: 18436010].
311 Griebie M, Adams GL. Clostridium difficile colitis following head and neck surgery. Report of cases. Archives of Otolaryngology. Aug. 1985;111(8):550-3. Not included study design. [pmid: 4026668].
312 Grube BJ, Heimbach DM, Marvin JA. Clostridium difficile diarrhea in critically ill burned patients. Archives of Surgery. Jun. 1987;122(6):655-61. Not relevant to key questions. [pmid: 3579579].
313 Grundfest-Broniatowski S, Quader M, Alexander F, et al. Clostridium difficile colitis in the critically ill. Dis Colon Rectum. Jun. 1996;39(6):619-23. Not on topic. [pmid: 8646945].
314 Guenter PA, Settle RG, Perlmutter S, et al. Tube feeding-related diarrhea in acutely Ill patients. Jpen: Journal of Parenteral & Enteral Nutrition. May-Jun. 1991;15(3):277-80. Not relevant to key questions. [pmid: 1650854].
315 Gujja D, Friedenberg FK. Predictors of serious complications due to Clostridium difficile infection. Aliment Pharmacol Ther. Mar. 15. 2009;29(6):635-42. Not on topic. [pmid: 19077106].
316 Gunderson CC, Gupta MR, Lopez F, et al. Clostridium difficile colitis in lung transplantation. Transplant Infectious Disease. Jul. 2008;10(4):245-51. Not on topic. [pmid: 18312477].
317 Hackford AW, Tally FP, Reinhold RB, et al. Prospective study comparing imipenem-cilastatin with clindamycin and gentamicin for the treatment of serious surgical infections. Archives of Surgery. Mar. 1988;123(3):322-6. Not on topic. [pmid: 3277587].
318 Hackford AW, Tally FP, Reinhold RB, et al. Prospective study comparing imipenem-cilastatin with clindamycin and gentamicin for the treatment of serious surgical infections. Archives of Surgery. Mar. 1988;123(3):322-6. Duplicate listing. [pmid: 3277587].
319 Hafiz S, McEntegart MG, Morton RS, et al. Clostridium defficiel in the urogenital tract of males and females. Lancet. Feb. 22. 1975;1(7904):420-1. Not on topic. [pmid: 48610].
320 Halim HA, Peterson GM, Friesen WT, et al. Case-controlled review of Clostridium difficile-associated diarrhoea in southern Tasmania. Journal of Clinical Pharmacy & Therapeutics. Oct-Dec. 1997;22(5-6):391-7. Not relevant to key questions. [pmid: 19160724].
321 Hall C, Curran F, Burdon DW, et al. A randomized trial to compare amoxycillin/clavulanate with metronidazole plus gentamicin in prophylaxis in elective colorectal surgery. J Antimicrob Chemother. Nov. 1989;24(Suppl B):195-202. Not relevant to key questions. [pmid: 2691480].
322 Hall J, Horsley M. Diagnosis and management of patients with Clostridium difficile-associated diarrhoea. [see comment]. Nursing Standard. quiz 58. Jul. 25-31. 2007;21(46):49-56. Not relevant to key questions. [pmid: 17711247].
323 Hall J, Horsley M. Diagnosis and management of patients with Clostridium difficile-associated diarrhoea. Nursing Standard. quiz 58. Jul. 25-31. 2007;21(46):49-56. Not included publication type. [pmid: 17711247].
324 Hall JF, Berger D. Outcome of colectomy for Clostridium difficile colitis: a plea for early surgical management. American Journal of Surgery. Sep. 2008;196(3):384-8. Not included treatment type. [pmid: 18519126].
325 Hall JF, Berger D. Outcome of colectomy for Clostridium difficile colitis: a plea for early surgical management. American Journal of Surgery. Sep. 2008;196(3):384-8. Duplicate listing. [pmid: 18519126].
326 Hannah A, Scott AM, Akhurst T, et al. Abnormal colonic accumulation of fluorine-18-FDG in pseudomembranous colitis. Journal of Nuclear Medicine. Oct. 1996;37(10):1683-5. Not on topic. [pmid: 8862310].
327 Harbarth S, Samore MH, Carmeli Y. Antibiotic prophylaxis and the risk of Clostridium difficile-associated diarrhoea. J Hosp Infect. Jun. 2001;48(2):93-7. Not relevant to key questions. [pmid: 11428874].
328 Hardt C, Berns T, Treder W, et al. Univariate and multivariate analysis of risk factors for severe Clostridium difficile-associated diarrhoea: importance of co-morbidity and serum C-reactive protein. World Journal of Gastroenterology. Jul. 21. 2008;14(27):4338-41. Not on topic. [pmid: 18666322].
329 Hardt C, Berns T, Treder W, et al. Univariate and multivariate analysis of risk factors for severe Clostridium difficile-associated diarrhoea: importance of co-morbidity and serum C-reactive protein. World Journal of Gastroenterology. Jul. 21. 2008;14(27):4338-41. Duplicate listing. [pmid: 18666322].
330 Harrahill M. Clostridium difficile colitis following an open fracture: complications occur, even with straightforward trauma and straightforward decisions. Journal of Emergency Nursing. Jun. 2003;29(3):294-6. Not relevant to key questions. [pmid: 12776090].
331 Harsch IA, Hahn EG, Konturek PC. Pseudomembranous colitis after eradication of Helicobacter pylori infection with a triple therapy. Medical Science Monitor. Jul-Aug. 2001;7(4):751-4. Not on topic. [pmid: 11433206].
332 Harter C, Schulze B, Goldschmidt H, et al. Piperacillin/tazobactam vs ceftazidime in the treatment of neutropenic fever in patients with acute leukemia or following autologous peripheral blood stem cell transplantation: a prospective randomized trial. Bone marrow transplantation. Feb. 2006;37(4):373-9. Not relevant to key questions. [pmid: 16400334].
333 Hartley MG, Hudson MJ, Swarbrick ET, et al. Sulphasalazine treatment and the colorectal mucosa-associated flora in ulcerative colitis. Aliment Pharmacol Ther. Apr. 1996;10(2):157-63. Not on topic. [pmid: 8730244].
334 Hashimoto M, Sugawara Y, Tamura S, et al. Clostridium difficile-associated diarrhea after living donor liver transplantation. World Journal of Gastroenterology. Apr. 14. 2007;13(14):2072-6. Not relevant to key questions. [pmid: 17465450].
335 Hassoun A, Ibrahim F. Use of intravenous immunoglobulin for the treatment of severe Clostridium difficile colitis. Am J Geriatr Pharmacother. Mar. 2007;5(1):48-51. Not relevant to key questions. [pmid: 17608247].
336 Hastie KJ, Weymont G, Lewis DA. An outbreak of Clostridium difficile associated diarrhoea in urological practice: a potential consequence of excessive antibiotic prophylaxis?. Journal of the Royal College of Surgeons of Edinburgh. Jun. 1989;34(3):146-8. Not relevant to key questions. [pmid: 2810164].
337 Hawker PC, Hine KR, Burdon DW, et al. Fatal pseudomembranous colitis despite eradication of Clostridium difficile. BMJ Clinical Research Ed. Jan. 10. 1981;282(6258):109-10. Not relevant to key questions. [pmid: 6779895].
338 Hayakawa T, Imaeda H, Nakamura M, et al. Association of pseudomembranous colitis with Henoch-Schonlein purpura. Journal of gastroenterology. Jun. 2005;40(6):641-5. Not on topic. [pmid: 16007399].
339 Hayetian FD, Read TE, Brozovich M, et al. Ileal perforation secondary to Clostridium difficile enteritis: report of 2 cases. Archives of Surgery. Jan. 2006;141(1):97-9. Not included publication type. [pmid: 16415419].
340 Heard SR, Wren B, Barnett MJ, et al. Clostridium difficile infection in patients with haematological malignant disease. Risk factors, faecal toxins and pathogenic strains. Epidemiology & Infection. Feb. 1988;100(1):63-72. Not relevant to key questions. [pmid: 3123260].
341 Hecht JR, Olinger EJ. Clostridium difficile colitis secondary to intravenous vancomycin. Dig Dis Sci. Jan. 1989;34(1):148-9. Not relevant to key questions. [pmid: 2910675].
342 Heimburger DC, Sockwell DG, Geels WJ. Diarrhea with enteral feeding: prospective reappraisal of putative causes. Nutrition. Sep-Oct. 1994;10(5):392-6. Not relevant to key questions. [pmid: 7819650].
343 Helgason KO, Raby SJ, Kamel HM, et al. Cytomegalovirus colitis in a critically ill patient following elective repair of an abdominal aortic aneurysm. Anaesthesia & Intensive Care. Jan. 2008;36(1):107-9. Not on topic. [pmid: 18326142].
344 Henrich TJ, Krakower D, Bitton A, et al. Clinical risk factors for severe Clostridium difficile-associated disease. Emerging Infectious Diseases. Mar. 2009;15(3):415-22. Not relevant to key questions. [pmid: 19239754].
345 Herpers BL, Vlaminckx B, Burkhardt O, et al. Intravenous tigecycline as adjunctive or alternative therapy for severe refractory Clostridium difficile infection. Clinic Infect Dis. Jun. 15. 2009;48(12):1732-5. Not relevant to key questions.
346 Heyland DK, Dodek P, Muscedere J, et al. Critical care medicine. Mar. 2008;36(3):737-44. Not on topic.
347 Hirschhorn LR, Trnka Y, Onderdonk A, et al. Epidemiology of community-acquired Clostridium difficile-associated diarrhea. J Infect Dis. Jan. 1994;169(1):127-33. Not relevant to key questions. [pmid: 8277174].
348 Hitchcock J, Jepson AP, Main J, et al. Establishment of an outpatient and home parenteral antimicrobial therapy service at a London teaching hospital: a case series. J Antimicrob Chemother. Sep. 2009;64(3):630-4. Not on topic. [pmid: 19549671].
349 Hogenauer C, Langner C, Beubler E, et al. Klebsiella oxytoca as a causative organism of antibiotic-associated hemorrhagic colitis. New England Journal of Medicine. Dec. 7. 2006;355(23):2418-26. Not on topic. [pmid: 17151365].
350 Hooker M. Clostridium difficile. Clinical journal of oncology nursing. Dec. 2007;11(6):801-4. Not on topic. [pmid: 18063537].
351 Hopkins MJ, Macfarlane GT. Changes in predominant bacterial populations in human faeces with age and with Clostridium difficile infection. Journal of medical microbiology. May. 2002;51(5):448-54. Not relevant to key questions. [pmid: 11990498].
352 Hopkins MJ, Sharp R, Macfarlane GT. Age and disease related changes in intestinal bacterial populations assessed by cell culture, 16S rRNA abundance, and community cellular fatty acid profiles. Gut. Feb. 2001;48(2):198-205. Not relevant to key questions. [pmid: 11156640].
353 Hopkins MJ, Sharp R, Macfarlane GT. Variation in human intestinal microbiota with age. Digestive & Liver Disease. Sep. 2002;34(Suppl 2):S12-8. Not relevant to key questions. [pmid: 12408433].
354 Hossain M, Crook TJ, Keoghane SR. Clostridium difficile in urology. Annals of the Royal College of Surgeons of England. Jan. 2008;90(1):36-9. Not on topic. [pmid: 18201498].
355 Hossain M, Crook TJ, Keoghane SR. Clostridium difficile in urology. Annals of the Royal College of Surgeons of England. Jan. 2008;90(1):36-9. Duplicate listing. [pmid: 18201498].
356 Howitt JR, Grace JW, Schaefer MG, et al. Clostridium difficile-positive stools: a retrospective identification of risk factors. Am J Infect Control. Sep. 2008;36(7):488-91. Duplicate listing. [pmid: 18786452].
357 Howitt JR, Grace JW, Schaefer MG, et al. Clostridium difficile-positive stools: a retrospective identification of risk factors. Am J Infect Control. Sep. 2008;36(7):488-91. Not relevant to key questions. [pmid: 18786452].
358 Hsu MS, Wang JT, Huang WK, et al. Prevalence and clinical features of Clostridium difficile-associated diarrhea in a tertiary hospital in northern Taiwan. Journal of Microbiology, Immunology & Infection. Jun. 2006;39(3):242-8. Not relevant to key questions.
359 Hu MY, Katchar K, Kyne L, et al. Prospective derivation and validation of a clinical prediction rule for recurrent Clostridium difficile infection. Gastroenterol. Apr. 2009;136(4):1206-14. Not relevant to key questions.
360 Hu MY, Maroo S, Kyne L, et al. A prospective study of risk factors and historical trends in metronidazole failure for Clostridium difficile infection. Clin Gastroenterol Hepatol. Dec. 2008;6(12):1354-60. Duplicate listing. [pmid: 19081526].
361 Hu MY, Maroo S, Kyne L, et al. A prospective study of risk factors and historical trends in metronidazole failure for Clostridium difficile infection. Clin Gastroenterol Hepatol. Dec. 2008;6(12):1354-60. Not relevant to key questions. [pmid: 19081526].
362 Husain A, Aptaker L, Spriggs DR, et al. Gastrointestinal toxicity and Clostridium difficile diarrhea in patients treated with paclitaxel-containing chemotherapy regimens. Gynecologic oncology. Oct. 1998;71(1):104-7. Not relevant to key questions. [pmid: 9784328].
363 Hutin Y, Molina JM, Casin I, et al. Risk factors for Clostridium difficile-associated diarrhoea in HIV-infected patients. AIDS. Nov. 1993;7(11):1441-7. Not relevant to key questions. [pmid: 8280409].
364 Ibrahim EH, Mehringer L, Prentice D, et al. Early versus late enteral feeding of mechanically ventilated patients: results of a clinical trial. Jpen: Journal of Parenteral & Enteral Nutrition. May-Jun. 2002;26(3):174-81. Not on topic. [pmid: 12005458].
365 Imase K, Takahashi M, Tanaka A, et al. Efficacy of Clostridium butyricum preparation concomitantly with Helicobacter pylori eradication therapy in relation to changes in the intestinal microbiota. Microbiology & Immunology. Mar. 2008;52(3):156-61. Not relevant to key questions. [pmid: 18402597].
366 Impallomeni M, Galletly NP, Wort SJ, et al. Increased risk of diarrhoea caused by Clostridium difficile in elderly patients receiving cefotaxime. BMJ. Nov. 18. 1995;311(7016):1345-6. Not relevant to key questions. [pmid: 7496287].
367 Incavo SJ, Muller DL, Krag MH, et al. Vertebral osteomyelitis caused by Clostridium difficile. A case report and review of the literature. Spine. Jan. 1988;13(1):111-3. Duplicate listing. [pmid: 3381119].
368 Incavo SJ, Muller DL, Krag MH, et al. Vertebral osteomyelitis caused by Clostridium difficile. A case report and review of the literature. Spine. Jan. 1988;13(1):111-3. Not relevant to key questions. [pmid: 3381119].
369 Indra A, Schmid D, Huhulescu S, et al. Characterization of clinical Clostridium difficile isolates by PCR ribotyping and detection of toxin genes in Austria, 2006-2007. Journal of medical microbiology. Jun. 2008;57(Pt 6):702-8. Not relevant to key questions. [pmid: 18480326].
370 Iseman DT, Hamza SH, Eloubeidi MA. Pseudomembranous (Clostridium difficile) colitis. Gastrointestinal endoscopy. Dec. 2002;56(6):907. Not relevant to key questions. [pmid: 12447310].
371 Issa M, Vijayapal A, Graham MB, et al. Impact of Clostridium difficile on inflammatory bowel disease. Clin Gastroenterol Hepatol. Mar. 2007;5(3):345-51. Not relevant to key questions. [pmid: 17368234].
372 Itani KM, Wilson SE, Awad SS, et al. Ertapenem versus cefotetan prophylaxis in elective colorectal surgery. New England Journal of Medicine. Dec. 21. 2006;355(25):2640-51. Not on topic. [pmid: 17182989].
373 Ito Y, Moriwaki H, Muto Y, et al. Effect of lactulose on short-chain fatty acids and lactate production and on the growth of faecal flora, with special reference to Clostridium difficile. Journal of medical microbiology. Jan. 1997;46(1):80-4. Not on topic. [pmid: 9003750].
374 Jain S, Koirala J, Castro-Pavia F. Isolated gastrointestinal histoplasmosis: case report and review of the literature. Southern medical journal. Feb. 2004;97(2):172-4. Not on topic. [pmid: 14982268].
375 Jansen JM, Bartelsman JF. Fulminant Clostridium difficile colitis. Gut. 24. Jan. 2008;57(1):15. Not relevant to key questions. [pmid: 18094201].
376 Jarvis B, Shevchuk YM. Recurrent Clostridium difficile diarrhea associated with mitoxantrone and etoposide: a case report and review. Pharmacotherapy. May-Jun. 1997;17(3):606-11. Not relevant to key questions. [pmid: 9165566].
377 Jarvis W, Nunez-Montiel O, Thompson F, et al. Comparison of bacterial isolation, cytotoxicity assay, and counterimmunoelectrophoresis for the detection of Clostridium difficile and its toxin. J Infect Dis. Apr. 1983;147(4):778. Not relevant to key questions. [pmid: 6842010].
378 Jen MH, Holmes AH, Bottle A, et al. Descriptive study of selected healthcare-associated infections using national Hospital Episode Statistics data 1996-2006 and comparison with mandatory reporting systems. J Hosp Infect. Dec. 2008;70(4):321-7. Not on topic. [pmid: 18849092].
379 Jennings LJ, Hanumadass M. Silver sulfadiazine induced Clostridium difficile toxic megacolon in a burn patient: case report. Burns. Nov. 1998;24(7):676-9. Not included study design. [pmid: 9882070].
380 Jensen GL, Bross JE, Bourbeau PP, et al. Risk factors for Clostridium difficile stool cytotoxin b among critically ill patients: role of sucralfate. J Infect Dis. Jul. 1994;170(1):227-30. Not relevant to key questions. [pmid: 8014506].
381 Jewkes J, Larson HE, Price AB, et al. Aetiology of acute diarrhoea in adults. Gut. May. 1981;22(5):388-92. Not included study design. [pmid: 7250751].
382 Jiang ZD, DuPont HL, Garey K, et al. A common polymorphism in the interleukin 8 gene promoter is associated with Clostridium difficile diarrhea. Am J Gastroenterol. May. 2006;101(5):1112-6. Not relevant to key questions. [pmid: 16573784].
383 Jiang ZD, Garey KW, Price M, et al. Association of interleukin-8 polymorphism and immunoglobulin G anti-toxin A in patients with Clostridium difficile-associated diarrhea. Clin Gastroenterol Hepatol. Aug. 2007;5(8):964-8. Not relevant to key questions. [pmid: 17618838].
384 Jillella AP, Ustun C, Robach E, et al. Infectious complications in patients receiving mobilization chemotherapy for autologous peripheral blood stem cell collection. Journal of hematotherapy & stem cell research. Apr. 2003;12(2):155-60. Not on topic. [pmid: 12804174].
385 Job ML, Jacobs NF Jr. Drug-induced Clostridium difficile-associated disease. Drug Safety. Jul. 1997;17(1):37-46. Not included publication type. [pmid: 9258629].
386 Jodorkovsky D, Young Y, Abreu MT. Clinical outcomes of patients with ulcerative colitis and co-existing Clostridium difficile infection. Dig Dis Sci. Feb. 2010;55(2):415-20. Not relevant to key questions. [pmid: 19255850].
387 Johal SS, Hammond J, Solomon K, et al. Clostridium difficile associated diarrhoea in hospitalised patients: onset in the community and hospital and role of flexible sigmoidoscopy. Gut. May. 2004;53(5):673-7. Not relevant to key questions. [pmid: 15082585].
388 Johal SS, Lambert CP, Hammond J, et al. Colonic IgA producing cells and macrophages are reduced in recurrent and non-recurrent Clostridium difficile associated diarrhoea. Journal of clinical pathology. Sep. 2004;57(9):973-9. Not relevant to key questions. [pmid: 15333661].
389 Johnson DK, Balmaseda MT. Pseudomembranous colitis in spinal cord injury. Archives of Physical Medicine & Rehabilitation. Jun. 1985;66(6):394-6. Not on topic. [pmid: 4004539].
390 Johnson EM, Remucal MJ, Gillingham KJ, et al. Complications and risks of living donor nephrectomy. Transplantation. Oct. 27. 1997;64(8):1124-8. Not on topic. [pmid: 9355827].
391 Johnson S, Gerding DN, Janoff EN. Systemic and mucosal antibody responses to toxin A in patients infected with Clostridium difficile. J Infect Dis. Dec. 1992;166(6):1287-94. Not relevant to key questions. [pmid: 1431247].
392 Johnson S, Homann SR, Bettin KM, et al. Treatment of asymptomatic Clostridium difficile carriers (fecal excretors) with vancomycin or metronidazole. A randomized, placebo-controlled trial. Annals of Internal Medicine. Aug. 15. 1992;117(4):297-302. Not relevant to key questions. [pmid: 1322075].
393 Johnson S, Sambol SP, Brazier JS, et al. International typing study of toxin A-negative, toxin B-positive Clostridium difficile variants. J Clin Microbiol. Apr. 2003;41(4):1543-7. Not relevant to key questions. [pmid: 12682143].
394 Johnson S, Schriever C, Galang M, et al. Interruption of recurrent Clostridium difficile-associated diarrhea episodes by serial therapy with vancomycin and rifaximin. Clinic Infect Dis. Mar. 15. 2007;44(6):846-8. Not relevant to key questions.
395 Johnson S, Schriever C, Patel U, et al. Rifaximin Redux: treatment of recurrent Clostridium difficile infections with rifaximin immediately post-vancomycin treatment. Anaerobe. Dec. 2009;15(6):290-1. Not relevant to key questions. [pmid: 19698797].
396 Jones EM, MacGowan AP. Back to basics in management of Clostridium difficile infections. Lancet. Aug. 15. 1998;352(9127):505-6. Not relevant to key questions. [pmid: 9716052].
397 Jones S, Yu VL, Johnson JT, et al. Pharmacokinetic and therapeutic trial of sultamicillin in acute sinusitis. Antimicrob Agents Chemother. Dec. 1985;28(6):832-3. Not on topic. [pmid: 3002247].
398 Joseph R, Demeyer D, Vanrenterghem D, et al. First isolation of Clostridium difficile PCR ribotype 027, toxinotype III in Belgium. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Oct. 2005;10(10):E051020.4. Not relevant to key questions. [pmid: 16790888].
399 Juang P, Skledar SJ, Zgheib NK, et al. Clinical outcomes of intravenous immune globulin in severe clostridium difficile-associated diarrhea. Am J Infect Control. Mar. 2007;35(2):131-7. Duplicate listing. [pmid: 17327194].
400 Juang P, Skledar SJ, Zgheib NK, et al. Clinical outcomes of intravenous immune globulin in severe clostridium difficile-associated diarrhea. Am J Infect Control. Mar. 2007;35(2):131-7. Not relevant to key questions. [pmid: 17327194].
401 Jung K, Aronsson B. Rapid diagnosis of Clostridium difficile-associated diarrhoea using a latex agglutination test. APMIS. Jul. 1990;98(7):652-4. Not relevant to key questions. [pmid: 2397115].
402 Karasawa T, Nojiri T, Hayashi Y, et al. Laboratory diagnosis of toxigenic Clostridium difficile by polymerase chain reaction: presence of toxin genes and their stable expression in toxigenic isolates from Japanese individuals. Journal of gastroenterology. Feb. 1999;34(1):41-5. Not relevant to key questions. [pmid: 10204609].
403 Karlstrom O, Fryklund B, Tullus K, et al. A prospective nationwide study of Clostridium difficile-associated diarrhea in Sweden. The Swedish C. difficile Study Group. Clinic Infect Dis. Jan. 1998;26(1):141-5. Not relevant to key questions.
404 Katchar K, Taylor CP, Tummala S, et al. Association between IgG2 and IgG3 subclass responses to toxin A and recurrent Clostridium difficile-associated disease. Clin Gastroenterol Hepatol. Jun. 2007;5(6):707-13. Not relevant to key questions. [pmid: 17544998].
405 Kato H, Kato N, Watanabe K, et al. Identification of toxin A-negative, toxin B-positive Clostridium difficile by PCR. J Clin Microbiol. Aug. 1998;36(8):2178-82. Not relevant to key questions. [pmid: 9665986].
406 Kato H, Kita H, Karasawa T, et al. Colonisation and transmission of Clostridium difficile in healthy individuals examined by PCR ribotyping and pulsed-field gel electrophoresis. Journal of medical microbiology. Aug. 2001;50(8):720-7. Not relevant to key questions. [pmid: 11478676].
407 Katz DA, Bates DW, Rittenberg E, et al. Predicting Clostridium difficile stool cytotoxin results in hospitalized patients with diarrhea. J Gen Intern Med. Jan. 1997;12(1):57-62. Duplicate listing. [pmid: 9034947].
408 Katz DA, Lynch ME, Littenberg B. Clinical prediction rules to optimize cytotoxin testing for Clostridium difficile in hospitalized patients with diarrhea. Am J Med. May. 1996;100(5):487-95. Not relevant to key questions. [pmid: 8644759].
409 Kaukoranta-Tolvanen SS, Renkonen OV, Gordin A, et al. Effect of erythromycin acistrate and erythromycin stearate on human colonic microflora. Scand J Infect Dis. 1989;21(6):717-20. Not included population. [pmid: 2617212].
410 Kawamura Y, Fujiwara H, Mishima N, et al. First Streptococcus agalactiae isolates highly resistant to quinolones, with point mutations in gyrA and parC. Antimicrob Agents Chemother. Nov. 2003;47(11):3605-9. Not on topic. [pmid: 14576126].
411 Kawecki D, Chmura A, Pacholczyk M, et al. Bacterial infections in the early period after liver transplantation: etiological agents and their susceptibility. Medical Science Monitor. Dec. 2009;15(12):CR628-37. Not relevant to key questions. [pmid: 19946234].
412 Kawecki D, Chmura A, Pacholczyk M, et al. Detection of Clostridium difficile in stool samples from patients in the early period after liver transplantation. Transplantation proceedings. Nov. 2007;39(9):2812-5. Not on topic. [pmid: 18021993].
413 Kazakova SV, Ware K, Baughman B, et al. A hospital outbreak of diarrhea due to an emerging epidemic strain of Clostridium difficile. Arch Intern Med. Dec. 11-25. 2006;166(22):2518-24. Not relevant to key questions. [pmid: 17159019].
414 Kelly CP. A 76-year-old man with recurrent Clostridium difficile-associated diarrhea: review of C. difficile infection. [see comment]. JAMA. Mar. 4. 2009;301(9):954-62. Not relevant to key questions. [pmid: 19190304].
415 Kelly CP. A 76-year-old man with recurrent Clostridium difficile-associated diarrhea: review of C. difficile infection. JAMA. Mar. 4. 2009;301(9):954-62. Not included publication type. [pmid: 19190304].
416 Kelly CP, Chetham S, Keates S, et al. Survival of anti-Clostridium difficile bovine immunoglobulin concentrate in the human gastrointestinal tract. Antimicrob Agents Chemother. Feb. 1997;41(2):236-41. Not relevant to key questions. [pmid: 9021173].
417 Kelly MT, Champagne SG, Sherlock CH, et al. Commercial latex agglutination test for detection of Clostridium difficile-associated diarrhea. J Clin Microbiol. Jul. 1987;25(7):1244-7. Not relevant to key questions. [pmid: 3611316].
418 Kenneally C, Rosini JM, Skrupky LP, et al. Analysis of 30-day mortality for clostridium difficile-associated disease in the ICU setting. Chest. Aug. 2007;132(2):418-24. Not relevant to key questions. [pmid: 17573523].
419 Kent KC, Rubin MS, Wroblewski L, et al. The impact of Clostridium difficile on a surgical service: a prospective study of 374 patients. Annals of Surgery. Feb. 1998;227(2):296-301. Not relevant to key questions. [pmid: 9488530].
420 Kerr RB, McLaughlin DI, Sonnenberg LW. Control of Clostridium difficile colitis outbreak by treating asymptomatic carriers with metronidazole. Am J Infect Control. Oct. 1990;18(5):332-5. Not relevant to key questions. [pmid: 2252226].
421 Kerr RB, McLaughlin DI, Sonnenberg LW. Control of Clostridium difficile colitis outbreak by treating asymptomatic carriers with metronidazole. Am J Infect Control. Oct. 1990;18(5):332-5. Duplicate listing. [pmid: 2252226].
422 Keven K, Basu A, Re L, et al. Clostridium difficile colitis in patients after kidney and pancreas-kidney transplantation. Transplant Infectious Disease. Mar. 2004;6(1):10-4. Not on topic. [pmid: 15225221].
423 Khan MA, Brunt EM, Longo WE, et al. Persistent Clostridium difficile colitis: a possible etiology for the development of collagenous colitis. Dig Dis Sci. May. 2000;45(5):998-1001. Not relevant to key questions. [pmid: 10795766].
424 Kilic A, Schuchert MJ, Pennathur A, et al. Minimally invasive myotomy for achalasia in the elderly. Surgical endoscopy. Apr. 2008;22(4):862-5. Not on topic. [pmid: 18027037].
425 Kim KA, Wry P, Hughes E Jr, et al. Clostridium difficile small-bowel enteritis after total proctocolectomy: a rare but fatal, easily missed diagnosis. Report of a case. Dis Colon Rectum. Jun. 2007;50(6):920-3. Not on topic. [pmid: 17468989].
426 Kim SW, Peck KR, Jung SI, et al. Pseudomonas aeruginosa as a potential cause of antibiotic-associated diarrhea. Journal of Korean medical science. Dec. 2001;16(6):742-4. Not on topic. [pmid: 11748355].
427 Kimura Y, Sato K, Tokuda H, et al. Combination therapy with direct hemoperfusion using polymyxin B-immobilized fiber and oral vancomycin improves fulminant pseudomembranous colitis by reducing the elevated endogenous cannabinoids and inflammatory cytokines: report of a case. Hepato-gastroenterology. May-Jun. 2008;55(84):956-8. Not relevant to key questions. [pmid: 18705306].
428 Klarin B, Wullt M, Palmquist I, et al. Lactobacillus plantarum 299v reduces colonisation of Clostridium difficile in critically ill patients treated with antibiotics. Acta Anaesthesiologica Scandinavica. Sep. 2008;52(8):1096-102. Not relevant to key questions. [pmid: 18840110].
429 Kleinkauf N, Weiss B, Jansen A, et al. Confirmed cases and report of clusters of severe infections due to Clostridium difficile PCR ribotype 027 in Germany. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Nov. 2007;12(11):E071115.2. Not on topic. [pmid: 18005642].
430 Klipfel AA, Schein M, Fahoum B, et al. Acute abdomen and Clostridium difficile colitis: still a lethal combination. Digestive surgery. 2000;17(2):160-3. Not relevant to key questions. [pmid: 10781981].
431 Knudsen JD, Tvede M. Demonstration of toxin A and B by polymerase chain reaction and McCoy cell assay in clinical isolates of Clostridium difficile from Denmark. APMIS. Jan. 1993;101(1):18-22. Not relevant to key questions. [pmid: 8457321].
432 Kocar IH, Caliskaner Z, Pay S, et al. Clostridium difficile infection in patients with reactive arthritis of undetermined etiology. Scandinavian journal of rheumatology. 1998;27(5):357-62. Not relevant to key questions. [pmid: 9808399].
433 Kofsky P, Rosen L, Reed J, et al. Clostridium difficile--a common and costly colitis. Dis Colon Rectum. Mar. 1991;34(3):244-8. Not on topic. [pmid: 1999131].
434 Koga H, Aoyagi K, Yoshimura R, et al. Can quinolones cause hemorrhagic colitis of late onset? Report of three cases. Dis Colon Rectum. Nov. 1999;42(11):1502-4. Not on topic. [pmid: 10566543].
435 Koh TH, Tan AL, Tan ML, et al. Epidemiology of Clostridium difficile infection in a large teaching hospital in Singapore. Pathology. Aug. 2007;39(4):438-42. Not relevant to key questions. [pmid: 17676487].
436 Komatsu M, Kato H, Aihara M, et al. High frequency of antibiotic-associated diarrhea due to toxin A-negative, toxin B-positive Clostridium difficile in a hospital in Japan and risk factors for infection. European J Clin Microbiol & Infectious Diseases. Sep. 2003;22(9):525-9. Not relevant to key questions. [pmid: 12938013].
437 Koning CJ, Jonkers DM, Stobberingh EE, et al. The effect of a multispecies probiotic on the intestinal microbiota and bowel movements in healthy volunteers taking the antibiotic amoxycillin. Am J Gastroenterol. Jan. 2008;103(1):178-89. Not relevant to key questions. [pmid: 17900321].
438 Koss K, Clark MA, Sanders DS, et al. The outcome of surgery in fulminant Clostridium difficile colitis. Colorectal Disease. Feb. 2006;8(2):149-54. Not relevant to key questions. [pmid: 16412077].
439 Kreisel D, Savel TG, Silver AL, et al. Surgical antibiotic prophylaxis and Clostridium difficile toxin positivity. Archives of Surgery. Sep. 1995;130(9):989-93. Not relevant to key questions. [pmid: 7661686].
440 Krogsgaard K, Boesgaard S, Aldershvile J, et al. Cytomegalovirus infection rate among heart transplant patients in relation to anti-thymocyte immunoglobulin induction therapy. Copenhagen Heart Transplant Group. Scand J Infect Dis. 1994;26(3):239-47. Not on topic. [pmid: 7939422].
441 Kuipers EJ, Surawicz CM. Clostridium difficile infection. Lancet. May. 3. 2008;371(9623):1486-8. Not included publication type. [pmid: 18456087].
442 Kumar B, Vaishnavi C, Sandhu K, et al. Clostridium difficile toxin assay in psoriatic patients. Tropical Gastroenterology. Oct-Dec. 2004;25(4):164-7. Not relevant to key questions. [pmid: 15912974].
443 Kunin CM, Dobbins JJ, Melo JC, et al. Infectious complications in four long-term recipients of the Jarvik-7 artificial heart. JAMA. Feb. 12. 1988;259(6):860-4. Not on topic. [pmid: 3336199].
444 Kuntz JL, Cavanaugh JE, Becker LK, et al. Clostridium difficile-associated disease in patients in a small rural hospital. Infect Control Hosp Epidemiol. Nov. 2007;28(11):1236-9. Not relevant to key questions. [pmid: 17926273].
445 Kurd MF, Pulido L, Joshi A, et al. Clostridium difficile infection after total joint arthroplasty: who is at risk?. Journal of Arthroplasty. Sep. 2008;23(6):839-42. Not relevant to key questions. [pmid: 18534454].
446 Kyne L, Hamel MB, Polavaram R, et al. Health care costs and mortality associated with nosocomial diarrhea due to Clostridium difficile. Clinic Infect Dis. Feb. 1. 2002;34(3):346-53. Not relevant to key questions.
447 Kyne L, Merry C, O'Connell B, et al. Simultaneous outbreaks of two strains of toxigenic Clostridium difficile in a general hospital. J Hosp Infect. Feb. 1998;38(2):101-12. Not relevant to key questions. [pmid: 9522288].
448 Kyne L, Merry C, O'Connell B, et al. Factors associated with prolonged symptoms and severe disease due to Clostridium difficile. Age Ageing. Mar. 1999;28(2):107-13. Not relevant to key questions. [pmid: 10350405].
449 Kyne L, Warny M, Qamar A, et al. Asymptomatic carriage of Clostridium difficile and serum levels of IgG antibody against toxin A. New England Journal of Medicine. Feb. 10. 2000;342(6):390-7. Not relevant to key questions. [pmid: 10666429].
450 Kyne L, Warny M, Qamar A, et al. Association between antibody response to toxin A and protection against recurrent Clostridium difficile diarrhoea. Lancet. Jan. 20. 2001;357(9251):189-93. Not relevant to key questions. [pmid: 11213096].
451 Labbe AC, Poirier L, Maccannell D, et al. Clostridium difficile infections in a Canadian tertiary care hospital before and during a regional epidemic associated with the BI/NAP1/027 strain. Antimicrob Agents Chemother. Sep. 2008;52(9):3180-7. Duplicate listing. [pmid: 18573937].
452 Labbe AC, Poirier L, Maccannell D, et al. Clostridium difficile infections in a Canadian tertiary care hospital before and during a regional epidemic associated with the BI/NAP1/027 strain. Antimicrob Agents Chemother. Sep. 2008;52(9):3180-7. Not relevant to key questions. [pmid: 18573937].
453 Lahn M, Tyler G, Daubener W, et al. Improvement of Clostridium difficile isolation by heat-shock and typing of the isolated strains by SDS-PAGE. European journal of epidemiology. May. 1993;9(3):327-34. Not relevant to key questions. [pmid: 8405320].
454 Lai KK, Melvin ZS, Menard MJ, et al. Clostridium difficile-associated diarrhea: epidemiology, risk factors, and infection control. Infect Control Hosp Epidemiol. Sep. 1997;18(9):628-32. Not relevant to key questions. [pmid: 9309434].
455 Lam MY, Feller ER, Lonks JR, et al. Inflammatory bowel disease potpourri: a vignette-based discussion. Medicine & Health, Rhode Island. Apr. 2009;92(4):121-4. Not relevant to key questions.
456 Lam S, Singer C, Tucci V, et al. The challenge of vancomycin-resistant enterococci: a clinical and epidemiologic study. Am J Infect Control. Jun. 1995;23(3):170-80. Duplicate listing. [pmid: 7677262].
457 Lambert ML, Mertens K, Ramboer I, et al. Nation-wide prospective surveillance of Clostridium difficile infections in hospitals in Belgium, July 2007-June 2008. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2009;14(14):2-4. Not relevant to key questions. [pmid: 19371509].
458 LaMont JT, Trnka YM. Therapeutic implications of Clostridium difficile toxin during relapse of chronic inflammatory bowel disease. Lancet. Feb. 23. 1980;1(8165):381-3. Not on topic. [pmid: 6101841].
459 Lamontagne F, Labbe AC, Haeck O, et al. Impact of emergency colectomy on survival of patients with fulminant Clostridium difficile colitis during an epidemic caused by a hypervirulent strain. Annals of Surgery. Feb. 2007;245(2):267-72. Background. [pmid: 17245181].
460 Larson AM, Fung AM, Fang FC. Evaluation of tcdB real-time PCR in a three-step diagnostic algorithm for detection of toxigenic Clostridium difficile. J Clin Microbiol. Jan. 2010;48(1):124-30. Not relevant to key questions. [pmid: 19923482].
461 Lau SK, Woo PC, Leung KW, et al. Emergence of cotrimoxazole- and quinolone-resistant Campylobacter infections in bone marrow transplant recipients. Eur J Clin Microbiol Infect Dis. Feb. 2002;21(2):127-9. Not on topic. [pmid: 11939393].
462 Lauritsen K, Laursen LS, Bukhave K, et al. In vivo profiles of eicosanoids in ulcerative colitis, Crohn's colitis, and Clostridium difficile colitis. Gastroenterol. Jul. 1988;95(1):11-7. Not on topic.
463 Law EJ, Kanavage CB, Assad R, et al. Massive haemorrhage due to rectosigmoid ulcers in a patient with extensive burns. Burns. Apr. 1992;18(2):167-9. Not on topic. [pmid: 1590937].
464 Lawrence SJ, Puzniak LA, Shadel BN, et al. Clostridium difficile in the intensive care unit: epidemiology, costs, and colonization pressure. Infect Control Hosp Epidemiol. Feb. 2007;28(2):123-30. Not relevant to key questions. [pmid: 17265392].
465 Le D, Rusin W, Hill B, et al. Post-operative antibiotic use in nonperforated appendicitis. American Journal of Surgery. Dec. 2009;198(6):748-52. Not relevant to key questions. [pmid: 19969124].
466 Leal J, Gregson DB, Ross T, et al. Epidemiology of Clostridium species bacteremia in Calgary, Canada, 2000-2006. Journal of Infection. Sep. 2008;57(3):198-203. Not on topic. [pmid: 18672296].
467 Leav BA, Blair B, Leney M, et al. Serum anti-toxin B antibody correlates with protection from recurrent Clostridium difficile infection (CDI). Vaccine. Jan. 22. 2010;28(4):965-9. Not relevant to key questions. [pmid: 19941990].
468 LeBlanc L, Pepin J, Toulouse K, et al. Fluoroquinolones and risk for methicillin-resistant Staphylococcus aureus, Canada. Emerging Infectious Diseases. Sep. 2006;12(9):1398-405. Not on topic. [pmid: 17073089].
469 Lee JS, Auyeung TW. A comparison of two feeding methods in the alleviation of diarrhoea in older tube-fed patients: a randomised controlled trial. Age Ageing. Jul. 2003;32(4):388-93. Not on topic. [pmid: 12851181].
470 Lee KS, Shin WG, Jang MK, et al. Who are susceptible to pseudomembranous colitis among patients with presumed antibiotic-associated diarrhea?. Dis Colon Rectum. Oct. 2006;49(10):1552-8. Not on topic. [pmid: 17028914].
471 Leffler DA, Lamont JT. A 69-year-old woman presenting to the hospital with 48 hours of abdominal pain and diarrhea. Clin Gastroenterol Hepatol. Oct. 2009;7(10):1046-8. Not relevant to key questions. [pmid: 19500692].
472 Lemann F, Chambon C, Barbut F, et al. Arbitrary primed PCR rules out Clostridium difficile cross-infection among patients in a haematology unit. J Hosp Infect. Feb. 1997;35(2):107-15. Not relevant to key questions. [pmid: 9049815].
473 Leung AC, Orange G, McLay A, et al. Clostridium difficile-associated colitis in uremic patients. Clinical nephrology. Nov. 1985;24(5):242-8. Not on topic. [pmid: 4075596].
474 Levett PN. Clostridium difficile in habitats other than the human gastro-intestinal tract. Journal of Infection. May. 1986;12(3):253-63. Not included publication type. [pmid: 3522751].
475 Levy DG, Stergachis A, McFarland LV, et al. Antibiotics and Clostridium difficile diarrhea in the ambulatory care setting. Clinical therapeutics. Jan. 2000;22(1):91-102. Not relevant to key questions. [pmid: 10688393].
476 Lew MA, Kehoe K, Ritz J, et al. Ciprofloxacin versus trimethoprim/sulfamethoxazole for prophylaxis of bacterial infections in bone marrow transplant recipients: a randomized, controlled trial. Journal of Clinical Oncology. Jan. 1995;13(1):239-50. Not on topic. [pmid: 7799026].
477 Lewis R. Investigation of Clostridium difficile diarrhoea in a district general hospital: room for improvement?. J Hosp Infect. Nov. 1987;10(3):243-7. Not on topic. [pmid: 2891751].
478 Lewis S, Burmeister S, Brazier J. Effect of the prebiotic oligofructose on relapse of Clostridium difficile-associated diarrhea: a randomized, controlled study. Clin Gastroenterol Hepatol. May. 2005;3(5):442-8. Not relevant to key questions. [pmid: 15880313].
479 Lidman C, Burman LG, Lagergren A, et al. Limited value of routine microbiological diagnostics in patients hospitalized for community-acquired pneumonia. Scand J Infect Dis. 2002;34(12):873-9. Not on topic. [pmid: 12587618].
480 Linden SK, Florin TH, McGuckin MA. Mucin dynamics in intestinal bacterial infection. PLoS ONE. [Electronic Resource]. 2008;3(12):e3952. Not on topic. [pmid: 19088856].
481 Linden SK, Florin TH, McGuckin MA. Mucin dynamics in intestinal bacterial infection. PLoS ONE. [Electronic Resource]. 2008;3(12):e3952. Duplicate listing. [pmid: 19088856].
482 Linneberg A, Ostergaard C, Tvede M, et al. IgG antibodies against microorganisms and atopic disease in Danish adults: the Copenhagen Allergy Study. Journal of Allergy & Clinical Immunology. Apr. 2003;111(4):847-53. Not on topic. [pmid: 12704368].
483 Lode H, Von der Hoh N, Ziege S, et al. Ecological effects of linezolid versus amoxicillin/clavulanic acid on the normal intestinal microflora. Scand J Infect Dis. 2001;33(12):899-903. Not on topic. [pmid: 11868762].
484 Lofgren RP, Tadlock LM, Soltis RD. Acute oligoarthritis associated with Clostridium difficile pseudomembranous colitis. Arch Intern Med. Mar. 1984;144(3):617-9. Not on topic. [pmid: 6608328].
485 Long S, Fenelon L, Fitzgerald S, et al. First isolation and report of clusters of Clostridium difficile PCR 027 cases in Ireland. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Apr. 2007;12(4):E070426.3. Not on topic. [pmid: 17868610].
486 Longo WE, Mazuski JE, Virgo KS, et al. Outcome after colectomy for Clostridium difficile colitis. Dis Colon Rectum. Oct. 2004;47(10):1620-6. Not included treatment type. [pmid: 15540290].
487 Loo VG, Poirier L, Miller MA, et al. A predominantly clonal multi-institutional outbreak of Clostridium difficile-associated diarrhea with high morbidity and mortality. New England Journal of Medicine. Dec. 8. 2005;353(23):2442-9. Background. [pmid: 16322602].
488 Loosli J, Gyr K, Stalder H, et al. Etiology of acute infectious diarrhea in a highly industrialized area of Switzerland. Gastroenterol. Jan. 1985;88(1 Pt 1):75-9. Not on topic.
489 Louie T, Miller M, Donskey C, et al. Clinical outcomes, safety, and pharmacokinetics of OPT-80 in a phase 2 trial with patients with Clostridium difficile infection. Antimicrob Agents Chemother. Jan. 2009;53(1):223-8. Duplicate listing. [pmid: 18955525].
490 Louther J. Enteric precautions for Clostridium difficile. American Journal of Nursing. Apr. 1996;96(4):19. Not relevant to key questions. [pmid: 8600710].
491 Lowe DO, Mamdani MM, Kopp A, et al. Proton pump inhibitors and hospitalization for Clostridium difficile-associated disease: a population-based study. Clinic Infect Dis. Nov. 15. 2006;43(10):1272-6. Not relevant to key questions.
492 Loy CE. Antibiotic-associated diarrhoea: an overlooked aetiology?. British journal of biomedical science. 2005;62(4):166-9. Not on topic. [pmid: 16411375].
493 Lu SS, Schwartz JM, Simon DM, et al. Clostridium difficile-associated diarrhea in patients with HIV positivity and AIDS: a prospective controlled study. Am J Gastroenterol. Aug. 1994;89(8):1226-9. Not on topic. [pmid: 8053439].
494 Lumpkins K, Bochicchio GV, Joshi M, et al. Clostridium difficile infection in critically injured trauma patients. Surgical Infections. Oct. 2008;9(5):497-501. Not on topic. [pmid: 18687049].
495 Lundeen SJ, Otterson MF, Binion DG, et al. Clostridium difficile enteritis: an early postoperative complication in inflammatory bowel disease patients after colectomy. Journal of Gastrointestinal Surgery. Feb. 2007;11(2):138-42. Not included treatment type. [pmid: 17390162].
496 MacGowan AP, Feeney R, Brown I, et al. Health care resource utilization and antimicrobial use in elderly patients with community-acquired lower respiratory tract infection who develop Clostridium difficile-associated diarrhoea. J Antimicrob Chemother. Apr. 1997;39(4):537-41. Not relevant to key questions. [pmid: 9145829].
497 MacGregor G, Smith AJ, Thakker B, et al. Yoghurt biotherapy: contraindicated in immunosuppressed patients?. Postgrad Med J. Jun. 2002;78(920):366-7. Duplicate listing. [pmid: 12151695].
498 Magee JT, Brazier JS, Hosein IK, et al. An investigation of a nosocomial outbreak of Clostridium difficile by pyrolysis mass spectrometry. Journal of medical microbiology. Nov. 1993;39(5):345-51. Not relevant to key questions. [pmid: 8246251].
499 Malinen E, Rinttila T, Kajander K, et al. Analysis of the fecal microbiota of irritable bowel syndrome patients and healthy controls with real-time PCR. Am J Gastroenterol. Feb. 2005;100(2):373-82. Not on topic. [pmid: 15667495].
500 Manabe YC, Vinetz JM, Moore RD, et al. Clostridium difficile colitis: an efficient clinical approach to diagnosis. Annals of Internal Medicine. Dec. 1. 1995;123(11):835-40. Background. [pmid: 7486465].
501 Manian FA, Aradhyula S, Greisnauer S, et al. Is it Clostridium difficile infection or something else? A case-control study of 352 hospitalized patients with new-onset diarrhea. Southern medical journal. Aug. 2007;100(8):782-6. Not relevant to key questions. [pmid: 17713303].
502 Mann SD, Pitt J, Springall RG, et al. Clostridium difficile infection--an unusual cause of refractory pouchitis: report of a case. Dis Colon Rectum. Feb. 2003;46(2):267-70. Not on topic. [pmid: 12576902].
503 Mantzaris GJ, Archavlis E, Christoforidis P, et al. A prospective randomized controlled trial of oral ciprofloxacin in acute ulcerative colitis. Am J Gastroenterol. Mar. 1997;92(3):454-6. Not on topic. [pmid: 9068468].
504 Marciniak C, Chen D, Stein AC, et al. Prevalence of Clostridium difficile colonization at admission to rehabilitation. Archives of Physical Medicine & Rehabilitation. Aug. 2006;87(8):1086-90. Not on topic. [pmid: 16876554].
505 Marcon AP, Gamba MA, Vianna LA. Nosocomial diarrhea in the intensive care unit. Brazilian Journal of Infectious Diseases. Dec. 2006;10(6):384-9. Not relevant to key questions. [pmid: 17420910].
506 Marinella MA, Burdette SD, Bedimo R, et al. Leukemoid reactions complicating colitis due to Clostridium difficile. Southern medical journal. Oct. 2004;97(10):959-63. Not relevant to key questions. [pmid: 15558922].
507 Markowitz JE, Brown KA, Mamula P, et al. Failure of single-toxin assays to detect clostridium difficile infection in pediatric inflammatory bowel disease. Am J Gastroenterol. Sep. 2001;96(9):2688-90. Not included population. [pmid: 11569696].
508 Marra AR, Edmond MB, Wenzel RP, et al. Hospital-acquired Clostridium difficile-associated disease in the intensive care unit setting: epidemiology, clinical course and outcome. BMC Infectious Diseases. 2007;7:42. Not relevant to key questions. [pmid: 17517130].
509 Marrie TJ, Faulkner RS, Badley BW, et al. Pseudomembranous colitis: isolation of two species of cytotoxic clostridia and successful treatment with vancomycin. CMAJ. Nov. 4. 1978;119(9):1058-60. Not relevant to key questions. [pmid: 743667].
510 Marrie TJ, Furlong M, Faulkner RS, et al. Clostridium difficile: epidemiology and clinical features. Canadian Journal of Surgery. Jul. 1982;25(4):438-42. Not on topic.
511 Martinusen S, Chen D, Frighetto L, et al. Comparison of cefoxitin and ceftizoxime in a hospital therapeutic interchange program. CMAJ. Apr. 1. 1993;148(7):1161-9. Not on topic. [pmid: 8457957].
512 Martirosian G, Wize J, Sokol-Leszczynska B, et al. Comparison of Delmee and Polish serogroup-specific Clostridium difficile strains. Acta Microbiologica Polonica. 1993;42(3-4):251-7. Not on topic. [pmid: 7516616].
513 Marts BC, Longo WE, Vernava AM 3rd, et al. Patterns and prognosis of Clostridium difficile colitis. Dis Colon Rectum. Aug. 1994;37(8):837-45. Not on topic. [pmid: 8055732].
514 Marx CE, Morris A, Wilson ML, et al. Fecal leukocytes in stool specimens submitted for Clostridium difficile toxin assay. Diagnostic Microbiology & Infectious Disease. May-Jun. 1993;16(4):313-5. Not on topic. [pmid: 8495586].
515 Mathai MG, Shanthaveerapa HN, Byrd RP Jr, et al. Fatal pseudomembranous colitis in a continent urinary neobladder. Journal of the Kentucky Medical Association. Jun. 2002;100(6):234-7. Not on topic. [pmid: 12101580].
516 Matute AJ, Schurink CA, Krijnen RM, et al. Double-blind, placebo-controlled study comparing the effect of azithromycin with clarithromycin on oropharyngeal and bowel microflora in volunteers. Eur J Clin Microbiol Infect Dis. Jun. 2002;21(6):427-31. Not on topic. [pmid: 12111597].
517 Mayfield JL, Leet T, Miller J, et al. Environmental control to reduce transmission of Clostridium difficile. Clinic Infect Dis. Oct. 2000;31(4):995-1000. Not relevant to key questions.
518 Mayumi T, Takezawa J, Takahashi H, et al. IL-15 is elevated in the patients of postoperative enterocolitis. Cytokine. Nov. 1999;11(11):888-93. Not on topic. [pmid: 10547278].
519 McCarter MD, Abularrage C, Velasco FT, et al. Diarrhea and Clostridium difficile-associated diarrhea on a surgical service. Archives of Surgery. Dec. 1996;131(12):1333-7. Not on topic. [pmid: 8956776].
520 McCarthy J, Stingemore N. Clostridium difficile infection of a prosthetic joint presenting 12 months after antibiotic-associated diarrhoea. Journal of Infection. Jul. 1999;39(1):94-6. Not on topic. [pmid: 10468137].
521 McCullough JM, Dielman DG, Peery D. Oral vancomycin-induced rash: case report and review of the literature. DICP. Dec. 1991;25(12):1326-8. Not relevant to key questions. [pmid: 1840008].
522 McCusker ME, Harris AD, Perencevich E, et al. Fluoroquinolone use and Clostridium difficile-associated diarrhea. Emerging Infectious Diseases. Jun. 2003;9(6):730-3. Not relevant to key questions. [pmid: 12781017].
523 McDonald LC, Owings M, Jernigan DB. Clostridium difficile infection in patients discharged from US short-stay hospitals, 1996-2003. Emerging Infectious Diseases. Mar. 2006;12(3):409-15. Not relevant to key questions. [pmid: 16704777].
524 McDonald M, Ward P, Harvey K. Antibiotic-associated diarrhoea and methicillin-resistant Staphylococcus aureus. Medical Journal of Australia. May. 29. 1982;1(11):462-4. Not on topic. [pmid: 7048039].
525 McEllistrem MC, Carman RJ, Gerding DN, et al. A hospital outbreak of Clostridium difficile disease associated with isolates carrying binary toxin genes. Clinic Infect Dis. Jan. 15. 2005;40(2):265-72. Not relevant to key questions.
526 McErlean A, Kelly O, Bergin S, et al. The importance of microbiological investigations, medications and artificial feeding in diarrhoea evaluation. Irish journal of medical science. Jan-Mar. 2005;174(1):21-5. Not on topic. [pmid: 15868885].
527 McFarland LV. Epidemiology of infectious and iatrogenic nosocomial diarrhea in a cohort of general medicine patients. Am J Infect Control. Oct. 1995;23(5):295-305. Not on topic. [pmid: 8585641].
528 McFarland LV. Epidemiology of infectious and iatrogenic nosocomial diarrhea in a cohort of general medicine patients. Am J Infect Control. Oct. 1995;23(5):295-305. Duplicate listing. [pmid: 8585641].
529 McFarland LV. Evidence-based review of probiotics for antibiotic-associated diarrhea and Clostridium difficile infections. Anaerobe. Dec. 2009;15(6):274-80. Not relevant to key questions. [pmid: 19825425].
530 McFarland LV, Brandmarker SA, Guandalini S. Pediatric Clostridium difficile: a phantom menace or clinical reality?. Journal of Pediatric Gastroenterology & Nutrition. Sep. 2000;31(3):220-31. Not included population. [pmid: 10997362].
531 McFarland LV, Clarridge JE, Beneda HW, et al. Fluoroquinolone use and risk factors for Clostridium difficile-associated disease within aVeterans Administration health care system. Clinic Infect Dis. Nov. 1. 2007;45(9):1141-51. Not relevant to key questions.
532 McFarland LV, Elmer GW, Surawicz CM. Breaking the cycle: treatment strategies for 163 cases of recurrent Clostridium difficile disease. Am J Gastroenterol. Jul. 2002;97(7):1769-75. Not relevant to key questions. [pmid: 12135033].
533 McFarland LV, Stamm WE. Review of Clostridium difficile-associated diseases. Am J Infect Control. Jun. 1986;14(3):99-109. Not included publication type. [pmid: 3524319].
534 McFarland LV, Stamm WE. Review of Clostridium difficile-associated diseases. Am J Infect Control. Jun. 1986;14(3):99-109. Duplicate listing. [pmid: 3524319].
535 McFarland LV, Surawicz CM, Greenberg RN, et al. Possible role of cross-transmission between neonates and mothers with recurrent Clostridium difficile infections. Am J Infect Control. Jun. 1999;27(3):301-3. Not relevant to key questions. [pmid: 10358237].
536 McFarland LV, Surawicz CM, Greenberg RN, et al. Possible role of cross-transmission between neonates and mothers with recurrent Clostridium difficile infections. Am J Infect Control. Jun. 1999;27(3):301-3. Duplicate listing. [pmid: 10358237].
537 McFarland LV, Surawicz CM, Greenberg RN, et al. Prevention of beta-lactam-associated diarrhea by Saccharomyces boulardii compared with placebo. Am J Gastroenterol. Mar. 1995;90(3):439-48. Not relevant to key questions. [pmid: 7872284].
538 McFarland LV, Surawicz CM, Rubin M, et al. Recurrent Clostridium difficile disease: epidemiology and clinical characteristics. Infect Control Hosp Epidemiol. Jan. 1999;20(1):43-50. Not relevant to key questions. [pmid: 9927265].
539 McGuire T, Dobesh P, Klepser D, et al. Clinically important interaction between statin drugs and Clostridium difficile toxin?. Medical Hypotheses. Dec. 2009;73(6):1045-7. Not relevant to key questions. [pmid: 19656639].
540 McMurdo ME, Argo I, Phillips G, et al. Cranberry or trimethoprim for the prevention of recurrent urinary tract infections? A randomized controlled trial in older women. J Antimicrob Chemother. Feb. 2009;63(2):389-95. Not on topic. [pmid: 19042940].
541 McMurdo ME, Argo I, Phillips G, et al. Cranberry or trimethoprim for the prevention of recurrent urinary tract infections? A randomized controlled trial in older women. J Antimicrob Chemother. Feb. 2009;63(2):389-95. Duplicate listing. [pmid: 19042940].
542 McNeeley SG Jr, Anderson GD, Sibai BM. Clostridium difficile colitis associated with single-dose cefazolin prophylaxis. Obstetrics & Gynecology. Nov. 1985;66(5):737-8. Not included study design. [pmid: 4058831].
543 McNeeley SG Jr, Anderson GD, Sibai BM. Clostridium difficile colitis associated with single-dose cefazolin prophylaxis. Obstetrics & Gynecology. Nov. 1985;66(5):737-8. Duplicate listing. [pmid: 4058831].
544 McPherson S, Rees CJ, Ellis R, et al. Intravenous immunoglobulin for the treatment of severe, refractory, and recurrent Clostridium difficile diarrhea. Dis Colon Rectum. May. 2006;49(5):640-5. Not relevant to key questions. [pmid: 16525744].
545 Meadowcroft AM, Diaz PR, Latham GS. Clostridium difficile toxin-induced colitis after use of clindamycin phosphate vaginal cream. Ann Pharmacother. Mar. 1998;32(3):309-11. Not on topic. [pmid: 9533061].
546 Meijer-Severs GJ, Van Santen E, Meijer BC. Short-chain fatty acid and organic acid concentrations in feces of healthy human volunteers and their correlations with anaerobe cultural counts during systemic ceftriaxone administration. Scandinavian journal of gastroenterology. Jul. 1990;25(7):698-704. Not on topic. [pmid: 2396083].
547 Meijer-Severs GJ, van Santen E, Puister SM, et al. The effect of FCE 22891, a new oral penem, on faecal flora anaerobes and their fermentation end products in patients with chronic obstructive pulmonary disease. Infection. Sep-Oct. 1993;21(5):311-7. Not on topic. [pmid: 8300248].
548 Mermel LA, Osborn TG. Clostridium difficile associated reactive arthritis in an HLA-B27 positive female: report and literature review. Journal of Rheumatology. Jan. 1989;16(1):133-5. Not relevant to key questions. [pmid: 2654390].
549 Messinger-Rapport BJ, Morley JE, Thomas DR, et al. Intensive session: New approaches to medical issues in long-term care. Journal of the American Medical Directors Association. Sep. 2007;8(7):421-33. Not relevant to key questions. [pmid: 17845944].
550 Methe H, Kim JO, Kofler S, et al. Statins decrease Toll-like receptor 4 expression and downstream signaling in human CD14+ monocytes. Arteriosclerosis, Thrombosis & Vascular Biology. Jul. 2005;25(7):1439-45. Not on topic.
551 Meyer AM, Ramzan NN, Loftus EV Jr, et al. The diagnostic yield of stool pathogen studies during relapses of inflammatory bowel disease. J Clin Gastroenterol. Oct. 2004;38(9):772-5. Not on topic. [pmid: 15365403].
552 Millard G. Further experience with augmentin in the treatment of skin infections. Scottish medical journal. 1982;27(Spec):S35-8. Not on topic. [pmid: 7167811].
553 Miller AT, Tabrizian P, Greenstein AJ, et al. Long-term follow-up of patients with fulminant Clostridium difficile colitis. Journal of Gastrointestinal Surgery. May. 2009;13(5):956-9. Not relevant to key questions. [pmid: 19224298].
554 Miller JM, Walton JC, Tordecilla LL. Recognizing and managing Clostridium difficile-associated diarrhea. MEDSURG Nursing. Dec. 1998;7(6):352-6. 348. 9. Not included publication type.
555 Miller M, Gravel D, Mulvey M, et al. Health care-associated Clostridium difficile infection in Canada: patient age and infecting strain type are highly predictive of severe outcome and mortality. Clinic Infect Dis. Jan. 15. 2010;50(2):194-201. Not relevant to key questions.
556 Miller SD, Blake M, Miliotis M, et al. Antibiotic-associated diarrhoea and pseudomembranous colitis caused by Clostridium difficile. A review of 40 cases. South African Medical Journal.Suid-Afrikaanse Tydskrif Vir Geneeskunde. Jun. 11. 1983;63(24):936-9. Not relevant to key questions. [pmid: 6857419].
557 Miller SD, Koornhof HJ. Clostridium difficile colitis associated with the use of antineoplastic agents. European J Clin Microbiol. Feb. 1984;3(1):10-3. Not on topic. [pmid: 6705768].
558 Milstone EB, McDonald AJ, Scholhamer CF Jr. Pseudomembranous colitis after topical application of clindamycin. Archives of Dermatology. Mar. 1981;117(3):154-5. Not on topic. [pmid: 6452096].
559 Modena S, Gollamudi S, Friedenberg F. Continuation of antibiotics is associated with failure of metronidazole for Clostridium difficile-associated diarrhea. J Clin Gastroenterol. Jan. 2006;40(1):49-54. Not relevant to key questions. [pmid: 16340634].
560 Mogg GA, Keighley MR, Burdon DW, et al. Antibiotic-associated colitis--a review of 66 cases. Br J Surg. Oct. 1979;66(10):738-42. Not on topic. [pmid: 509051].
561 Morales Chamorro R, Serrano Blanch R, Mendez Vidal MJ, et al. Pseudomembranous colitis associated with chemotherapy with 5-fluorouracil. Clinical & Translational Oncology: Official Publication of the Federation of Spanish Oncology Societes & of the National Cancer Institute of Mexico. Jul. 2005;7(6):258-61. Not on topic.
562 Morelli MS, Rouster SD, Giannella RA, et al. Clinical application of polymerase chain reaction to diagnose Clostridium difficile in hospitalized patients with diarrhea. Clin Gastroenterol Hepatol. Aug. 2004;2(8):669-74. Not relevant to key questions. [pmid: 15290659].
563 Morgan RJ Jr, Doroshow JH, Venkataraman K, et al. High-dose infusional doxorubicin and cyclophosphamide: a feasibility study of tandem high-dose chemotherapy cycles without stem cell support. Clinical Cancer Research. Dec. 1997;3(12 Pt 1):2337-45. Not on topic. [pmid: 9815632].
564 Morimoto Y, Nomura K, Tsutsumi Y, et al. Clostridium difficile-associated diarrhea with hematochezia is associated with ulcer formation. Scandinavian journal of gastroenterology. Aug. 2008;43(8):967-70. Not relevant to key questions. [pmid: 19086279].
565 Morris AM, Jobe BA, Stoney M, et al. Clostridium difficile colitis: an increasingly aggressive iatrogenic disease?. [see comment]. Archives of Surgery. Oct. 2002;137(10):1096-100. Not relevant to key questions. [pmid: 12361411].
566 Morris JG Jr, Jarvis WR, Nunez-Montiel OL, et al. Clostridium difficile. Colonization and toxin production in a cohort of patients with malignant hematologic disorders. Arch Intern Med. May. 1984;144(5):967-9. Not on topic. [pmid: 6370168].
567 Moshkowitz M, Ben Baruch E, Kline Z, et al. Clinical manifestations and outcome of Pseudomembranous colitis in an elderly population in Israel. Israel Medical Association Journal: Imaj. Apr. 2004;6(4):201-4. Not relevant to key questions.
568 Moshkowitz M, Ben-Baruch E, Kline Z, et al. Risk factors for severity and relapse of pseudomembranous colitis in an elderly population. Colorectal Disease. Feb. 2007;9(2):173-7. Not relevant to key questions. [pmid: 17223943].
569 Moskovitz M, Bartlett JG. Recurrent pseudomembranous colitis unassociated with prior antibiotic therapy. Arch Intern Med. Apr. 1981;141(5):663-4. Not relevant to key questions. [pmid: 7224749].
570 Munoz P, Palomo J, Yanez J, et al. Clinical microbiological case: a heart transplant recipient with diarrhea and abdominal pain. Recurring C. difficile infection. Clinical Microbiology & Infection. Aug. 2001;7(8):458-9. 451. 2. Not relevant to key questions.
571 Munro R, Foldes M, Morris G. An evaluation of a rapid latex test for the diagnosis of Clostridium difficile-associated diarrhea. Pathology. Oct. 1988;20(4):349-52. Not relevant to key questions. [pmid: 3241736].
572 Murphy C, Vernon M, Cullen M. Intravenous immunoglobulin for resistant Clostridium difficile infection. Age Ageing. Jan. 2006;35(1):85-6. Not relevant to key questions. [pmid: 16303776].
573 Musher DM, Logan N, Mehendiratta V, et al. Clostridium difficile colitis that fails conventional metronidazole therapy: response to nitazoxanide. J Antimicrob Chemother. Apr. 2007;59(4):705-10. Not relevant to key questions. [pmid: 17337513].
574 Mwachari C, Batchelor BI, Paul J, et al. Chronic diarrhoea among HIV-infected adult patients in Nairobi, Kenya. Journal of Infection. Jul. 1998;37(1):48-53. Not relevant to key questions. [pmid: 9733379].
575 Mwachari C, Batchelor BI, Paul J, et al. Chronic diarrhoea among HIV-infected adult patients in Nairobi, Kenya. Journal of Infection. Jul. 1998;37(1):48-53. Duplicate listing. [pmid: 9733379].
576 Mylotte JM, Graham R, Kahler L, et al. Epidemiology of nosocomial infection and resistant organisms in patients admitted for the first time to an acute rehabilitation unit. Clinic Infect Dis. Mar. 2000;30(3):425-32. Not relevant to key questions.
577 Nadelman RB, Arlin Z, Wormser GP. Life-threatening complications of empiric ceftriaxone therapy for ‘seronegative Lyme disease’. Southern medical journal. Oct. 1991;84(10):1263-5. Not on topic. [pmid: 1925730].
578 Nair S, Yadav D, Corpuz M, et al. Clostridium difficile colitis: factors influencing treatment failure and relapse--a prospective evaluation. Am J Gastroenterol. Oct. 1998;93(10):1873-6. Not relevant to key questions. [pmid: 9772047].
579 Nanke Y, Kotake S, Akama H, et al. Pancytopenia and colitis with Clostridium difficile in a rheumatoid arthritis patient taking methotrexate, antibiotics and non-steroidal anti-inflammatory drugs. Clinical rheumatology. 2001;20(1):73-5. Not on topic. [pmid: 11254248].
580 Nasereddin LM, Bakri FG, Shehabi AA. Clostridium difficile infections among Jordanian adult hospitalized patients. Am J Infect Control. Dec. 2009;37(10):864-6. Not relevant to key questions. [pmid: 19712999].
581 Nash SV, Bourgeault R, Sands M. Colonic disease associated with a positive assay for Clostridium difficile toxin: a retrospective study. J Clin Gastroenterol. Sep. 1997;25(2):476-9. Not relevant to key questions. [pmid: 9412955].
582 Nathanson DR, Sheahan M, Chao L, et al. Intracolonic use of vancomycin for treatment of clostridium difficile colitis in a patient with a diverted colon: report of a case. Dis Colon Rectum. Dec. 2001;44(12):1871-2. Not included treatment type. [pmid: 11742178].
583 Navarro-Llavat M, Domenech E, Bernal I, et al. Prospective, observational, cross-sectional study of intestinal infections among acutely active inflammatory bowel disease patients. Digestion. 2009;80(1):25-9. Not on topic. [pmid: 19439968].
584 Navon JD, Weinberg AC, Ahlering TE. Continent urinary diversion using a Modified Indiana Pouch in elderly patients. American Surgeon. Oct. 1994;60(10):786-8. Not on topic. [pmid: 7944043].
585 Nawaz A, Mohammed I, Ahsan K, et al. Clostridium difficile colitis associated with treatment of Helicobacter pylori infection. Am J Gastroenterol. Jul. 1998;93(7):1175-6. Not on topic. [pmid: 9672359].
586 Nayar DM, Vetrivel S, McElroy J, et al. Toxic megacolon complicating Escherichia coli O157 infection. Journal of Infection. Apr. 2006;52(4):e103-6. Not on topic. [pmid: 16126276].
587 Neill MA, Rice SK, Ahmad NV, et al. Cryptosporidiosis: an unrecognized cause of diarrhea in elderly hospitalized patients. Clinic Infect Dis. Jan. 1996;22(1):168-70. Not on topic.
588 Nelson R. Antibiotic treatment for Clostridium difficile-associated diarrhea in adults. [update of Cochrane Database Syst Rev. 2005;(1):CD004610; PMID:15674956]. Cochrane Database Syst Rev. 2007;(3):004610. Background.
589 Nelson RL, Glenny AM, Song F. Antimicrobial prophylaxis for colorectal surgery. Cochrane Database Syst Rev. 2009;(1):001181. Not included publication type.
590 Nemat H, Khan R, Ashraf MS, et al. Diagnostic value of repeated enzyme immunoassays in Clostridium difficile infection. Am J Gastroenterol. Aug. 2009;104(8):2035-41. Not included publication type. [pmid: 19367273].
591 Neunlist M, Barouk J, Michel K, et al. Toxin B of Clostridium difficile activates human VIP submucosal neurons, in part via an IL-1beta-dependent pathway. American Journal of Physiology - Gastrointestinal & Liver Physiology. Nov. 2003;285(5):G1049-55. Not on topic. [pmid: 12801886].
592 Nguyen GC, Kaplan GG, Harris ML, et al. A national survey of the prevalence and impact of Clostridium difficile infection among hospitalized inflammatory bowel disease patients. Am J Gastroenterol. Jun. 2008;103(6):1443-50. Duplicate listing. [pmid: 18513271].
593 Nguyen GC, Kaplan GG, Harris ML, et al. A national survey of the prevalence and impact of Clostridium difficile infection among hospitalized inflammatory bowel disease patients. Am J Gastroenterol. Jun. 2008;103(6):1443-50. Not relevant to key questions. [pmid: 18513271].
594 Nguyen NQ, Chapman M, Fraser RJ, et al. Prokinetic therapy for feed intolerance in critical illness: one drug or two?. Critical care medicine. Nov. 2007;35(11):2561-7. Not on topic. [pmid: 17828038].
595 Nguyen NQ, Ching K, Fraser RJ, et al. Risk of Clostridium difficile diarrhoea in critically ill patients treated with erythromycin-based prokinetic therapy for feed intolerance. Intensive care medicine. Jan. 2008;34(1):169-73. Not on topic. [pmid: 17701160].
596 Niemczyk M, Leszczyniski P, Wyzgal J, et al. Infections caused by clostridium difficile in kidney or liver graft recipients. Annals of Transplantation. 2005;10(2):70-4. Not on topic. [pmid: 16218037].
597 Nilsson-Ehle I, Nord CE, Ursing B. Ceftriaxone: pharmacokinetics and effect on the intestinal microflora in patients with acute bacterial infections. Scand J Infect Dis. 1985;17(1):77-82. Not on topic. [pmid: 3992209].
598 Nomura K, Fujimoto Y, Yamashita M, et al. Absence of pseudomembranes in Clostridium difficile-associated diarrhea in patients using immunosuppression agents. Scandinavian journal of gastroenterology. 2009;44(1):74-8. Not on topic. [pmid: 18781540].
599 Nonhoff C, Struelens MJ, Serruys E. Evaluation of gas-liquid chromatography (GLC) for rapid detection of Clostridium difficile in fecal specimens. Acta Clinica Belgica. 1995;50(2):76-80. Not relevant to key questions. [pmid: 7597879].
600 Nord CE, Brismar B, Kasholm-Tengve B, et al. Effect of piperacillin/tazobactam therapy on intestinal microflora. Scand J Infect Dis. 1992;24(2):209-13. Not relevant to key questions. [pmid: 1322559].
601 Nord CE, Kager L, Philipson A, et al. Effect of imipenem/cilastatin on the colonic microflora. Reviews of infectious diseases. Jul-Aug. 1985;7(Suppl 3):S432-4. Not on topic. [pmid: 3863218].
602 Norman FF, Perez-Molina J, Perez de Ayala A, et al. Clostridium difficile-associated diarrhea after antibiotic treatment for traveler's diarrhea. Clinic Infect Dis. Apr. 1. 2008;46(7):1060-3. Not on topic.
603 Norrby SR, Dotevall L, Eriksson M, et al. Efficacy and safety of cefpirome (HR810). J Antimicrob Chemother. Oct. 1988;22(4):541-7. Not on topic. [pmid: 3204079].
604 Novak E, Paxton LM, Bye A, et al. Human safety and pharmacokinetics of a single intramuscular dose of a novel spectinomycin analog, trospectomycin (U-63,366F). Antimicrob Agents Chemother. Dec. 1990;34(12):2342-7. Not on topic. [pmid: 2150907].
605 Novak-Weekley SM, Hollingsworth MH. Comparison of the premier toxin A and B assay and the TOX A/B II assay for diagnosis of Clostridium difficile infection. Clinical & Vaccine Immunology: CVI. Mar. 2008;15(3):575-8. Not relevant to key questions. [pmid: 18175802].
606 Novelli A, Mazzei T, Fallani S, et al. Betalactam therapy and intestinal flora. Journal of Chemotherapy. May. 1995;7(Suppl 1):25-31. Duplicate listing. [pmid: 8618110].
607 Novelli A, Mazzei T, Fallani S, et al. Betalactam therapy and intestinal flora. Journal of Chemotherapy. May. 1995;7(Suppl 1):25-31. Not relevant to key questions. [pmid: 8618110].
608 O'Brien JA, Lahue BJ, Caro JJ, et al. The emerging infectious challenge of clostridium difficile-associated disease in Massachusetts hospitals: clinical and economic consequences. Infect Control Hosp Epidemiol. Nov. 2007;28(11):1219-27. Not relevant to key questions. [pmid: 17926270].
609 O'Horo J, Safdar N. The role of immunoglobulin for the treatment of Clostridium difficile infection: a systematic review. International Journal of Infectious Diseases. Nov. 2009;13(6):663-7. Not relevant to key questions. [pmid: 19186089].
610 Oldfield EC 3rd, Wallace MR. The role of antibiotics in the treatment of infectious diarrhea. Gastroenterology clinics of North America. Sep. 2001;30(3):817-36. Not on topic. [pmid: 11586559].
611 Orrhage K, Sjostedt S, Nord CE. Effect of supplements with lactic acid bacteria and oligofructose on the intestinal microflora during administration of cefpodoxime proxetil. J Antimicrob Chemother. Oct. 2000;46(4):603-12. Not relevant to key questions. [pmid: 11020259].
612 Oshima Y, Nishida K, Kawazoye S, et al. Successful treatment of cytomegalovirus colitis with ganciclovir in a patient with adult T cell leukemia lymphoma: case report. Journal of Chemotherapy. Jun. 1999;11(3):215-9. Not on topic. [pmid: 10435685].
613 Oshima Y, Nishida K, Kawazoye S, et al. Successful treatment of cytomegalovirus colitis with ganciclovir in a patient with adult T cell leukemia lymphoma: case report. Journal of Chemotherapy. Jun. 1999;11(3):215-9. Duplicate listing. [pmid: 10435685].
614 Owens RC Jr, Donskey CJ, Gaynes RP, et al. Antimicrobial-associated risk factors for Clostridium difficile infection. Clinic Infect Dis. Jan. 15. 2008;46(Suppl 1):S19-31. Background.
615 Oyofo BA, Subekti D, Tjaniadi P, et al. Enteropathogens associated with acute diarrhea in community and hospital patients in Jakarta, Indonesia. FEMS Immunology & Medical Microbiology. Oct. 11. 2002;34(2):139-46. Not relevant to key questions. [pmid: 12381465].
616 Ozaki E, Kato H, Kita H, et al. Clostridium difficile colonization in healthy adults: transient colonization and correlation with enterococcal colonization. Journal of medical microbiology. Feb. 2004;53(Pt 2):167-72. Not relevant to key questions. [pmid: 14729940].
617 Ozawa TT, Valadez T. Clostridium difficile infection associated with levofloxacin treatment. Tennessee Medicine. Mar. 2002;95(3):113-5. Not relevant to key questions. [pmid: 11898264].
618 Palmore TN, Sohn S, Malak SF, et al. Risk factors for acquisition of Clostridium difficile-associated diarrhea among outpatients at a cancer hospital. Infect Control Hosp Epidemiol. Aug. 2005;26(8):680-4. Not relevant to key questions. [pmid: 16156323].
619 Paltansing S, van den Berg RJ, Guseinova RA, et al. Characteristics and incidence of Clostridium difficile-associated disease in The Netherlands, 2005. Clinical Microbiology & Infection. Nov. 2007;13(11):1058-64. Not relevant to key questions. [pmid: 17922780].
620 Pandey S, Slawik S, Cross K, et al. Laparoscopic appendicectomy: a training model for laparoscopic right hemicolectomy?. Colorectal Disease. Jul. 2007;9(6):536-9. Not on topic. [pmid: 17509048].
621 Panichi G, Pantosti A, Gentile G, et al. Clostridium difficile colitis in leukemia patients. European journal of cancer & clinical oncology. Oct. 1985;21(10):1159-63. Not included study design.
622 Pant C, Madonia PN, Jordan P, et al. Harbingers for Clostridium difficile-associated diarrhea. Journal of Investigative Medicine. Jan. 2009;57(1):40-2. Not relevant to key questions. [pmid: 19092680].
623 Park BJ, Alexander HR, Libutti SK, et al. Treatment of primary peritoneal mesothelioma by continuous hyperthermic peritoneal perfusion (CHPP). Annals of Surgical Oncology. Sep. 1999;6(6):582-90. Not on topic. [pmid: 10493628].
624 Parry MF, Rha CK. Pseudomembranous colitis caused by topical clindamycin phosphate. Archives of Dermatology. May. 1986;122(5):583-4. Not included study design. [pmid: 2939805].
625 Pashby NL, Bolton RP, Sherriff RJ. Oral metronidazole in Clostridium difficile colitis. BMJ. Jun. 16. 1979;1(6178):1605-6. Not included study design.
626 Patel R, Hughes RW Jr. An unusual case of myxedema megacolon with features of ischemic and pseudomembranous colitis. May Clinic Proc. Apr. 1992;67(4):369-72. Not included study design.
627 Paterson DL. Clostridium difficile diarrhoea associated with chemotherapy for ovarian cancer. Australian & New Zealand Journal of Obstetrics & Gynaecology. Aug. 1997;37(3):348-9. Not included study design. [pmid: 9325524].
628 Peach SL, Gaya H, Borriello SP. Faecal carriage of Clostridium difficile in cystic fibrosis patients. Annali dell'Istituto Superiore di Sanita. 1986;22(3):953-7. Not relevant to key questions.
629 Peacock JE Jr, Pegram PS, Weber SF, et al. Prospective, randomized comparison of sequential intravenous followed by oral ciprofloxacin with intravenous ceftazidime in the treatment of serious infections. Am J Med. Nov. 30. 1989;87(5A):185S-90S. Not on topic. [pmid: 2686421].
630 Pechine S, Gleizes A, Janoir C, et al. Immunological properties of surface proteins of Clostridium difficile. Journal of medical microbiology. Feb. 2005;54(Pt 2):193-6. Not relevant to key questions. [pmid: 15673516].
631 Pekova L, Shomov G, Mladenova I, et al. Clostridium difficile-associated disease with lethal outcome in a 77-year-old woman. A case report. Minerva gastroenterologica e dietologica. Dec. 2007;53(4):383-6. Not included study design. [pmid: 18043555].
632 Penders J, Thijs C, Vink C, et al. Factors influencing the composition of the intestinal microbiota in early infancy. Pediatrics. Aug. 2006;118(2):511-21. Not relevant to key questions. [pmid: 16882802].
633 Pepin J, Alary ME, Valiquette L, et al. Increasing risk of relapse after treatment of Clostridium difficile colitis in Quebec, Canada. Clinic Infect Dis. Jun. 1. 2005;40(11):1591-7. Not relevant to key questions.
634 Pepin J, Routhier S, Gagnon S, et al. Management and outcomes of a first recurrence of Clostridium difficile-associated disease in Quebec, Canada. Clinic Infect Dis. Mar. 15. 2006;42(6):758-64. Not relevant to key questions.
635 Pepin J, Saheb N, Coulombe MA, et al. Emergence of fluoroquinolones as the predominant risk factor for Clostridium difficile-associated diarrhea: a cohort study during an epidemic in Quebec. Clinic Infect Dis. Nov. 1. 2005;41(9):1254-60. Not relevant to key questions.
636 Pepin J, Valiquette L, Alary ME, et al. Clostridium difficile-associated diarrhea in a region of Quebec from 1991 to 2003: a changing pattern of disease severity. CMAJ. Aug. 31. 2004;171(5):466-72. Not relevant to key questions. [pmid: 15337727].
637 Pepin J, Valiquette L, Cossette B. Mortality attributable to nosocomial Clostridium difficile-associated disease during an epidemic caused by a hypervirulent strain in Quebec. CMAJ. Oct. 25. 2005;173(9):1037-42. Not relevant to key questions. [pmid: 16179431].
638 Pepin J, Valiquette L, Gagnon S, et al. Outcomes of Clostridium difficile-associated disease treated with metronidazole or vancomycin before and after the emergence of NAP1/027. Am J Gastroenterol. Dec. 2007;102(12):2781-8. Not relevant to key questions. [pmid: 17900327].
639 Pepin J, Vo TT, Boutros M, et al. Risk factors for mortality following emergency colectomy for fulminant Clostridium difficile infection. Dis Colon Rectum. Mar. 2009;52(3):400-5. Not on topic. [pmid: 19333038].
640 Peppe J, Porzio A, Davidson DM. A new formulation of tolevamer, a novel nonantibiotic polymer, is safe and well-tolerated in healthy volunteers: a randomized phase I trial. British journal of clinical pharmacology. Jul. 2008;66(1):102-9. Duplicate listing. [pmid: 18341677].
641 Philbrick AM, Ernst ME. Amoxicillin-associated hemorrhagic colitis in the presence of Klebsiella oxytoca. Pharmacotherapy. Nov. 2007;27(11):1603-7. Not included study design. [pmid: 17963468].
642 Phillips C. Serum antibody responses to Clostridium difficile toxin A: predictive and protective?. Gut. Aug. 2001;49(2):167-8. Not included study design. [pmid: 11454789].
643 Pidala MJ, Slezak FA, Porter JA. Island flap anoplasty for anal canal stenosis and mucosal ectropion. American Surgeon. Mar. 1994;60(3):194-6. Not included study design. [pmid: 8116980].
644 Pochapin M. The effect of probiotics on Clostridium difficile diarrhea. Am J Gastroenterol. Jan. 2000;95(1 Suppl):S11-3. Not relevant to key questions. [pmid: 10634221].
645 Poduval RD, Kamath RP, Corpuz M, et al. Clostridium difficile and vancomycin-resistant enterococcus: the new nosocomial alliance. Am J Gastroenterol. Dec. 2000;95(12):3513-5. Not relevant to key questions. [pmid: 11151886].
646 Pogue JM, DePestel DD, Kaul DR, et al. Systemic absorption of oral vancomycin in a peripheral blood stem cell transplant patient with severe graft-versus-host disease of the gastrointestinal tract. Transplant Infectious Disease. Oct. 2009;11(5):467-70. Not relevant to key questions. [pmid: 19638004].
647 Pokorney BH, Nichols TW Jr. Pseudomembranous colitis. A complication of sulfasalazine therapy in a patient with Crohn's colitis. Am J Gastroenterol. Oct. 1981;76(4):374-6. Not relevant to key questions. [pmid: 6119900].
648 Pokorny CS, Bye PT, MacLeod C, et al. Antibiotic-associated colitis and cystic fibrosis. Dig Dis Sci. Sep. 1992;37(9):1464-8. Not included study design. [pmid: 1505297].
649 Porco FV, Visconte EB. Pseudomonas aeruginosa as a cause of infectious diarrhea successfully treated with oral ciprofloxacin. Ann Pharmacother. Nov. 1995;29(11):1122-3. Not included study design. [pmid: 8573957].
650 Prendergast TM, Marini CP, D'Angelo AJ, et al. Surgical patients with pseudomembranous colitis: factors affecting prognosis. Surgery. discussion 774-5. Oct. 1994;116(4):768-74. Not relevant to key questions. [pmid: 7940177].
651 Price MF, Dao-Tran T, Garey KW, et al. Epidemiology and incidence of Clostridium difficile-associated diarrhoea diagnosed upon admission to a university hospital. J Hosp Infect. Jan. 2007;65(1):42-6. Not relevant to key questions. [pmid: 17145108].
652 Privitera G, Scarpellini P, Ortisi G, et al. Prospective study of Clostridium difficile intestinal colonization and disease following single-dose antibiotic prophylaxis in surgery. Antimicrob Agents Chemother. Jan. 1991;35(1):208-10. Not relevant to key questions. [pmid: 2014978].
653 Pryor WM, Bye WA, Curran DH, et al. Acute diarrhoea in adults: a prospective study. Medical Journal of Australia. Nov. 16. 1987;147(10):490-3. Not relevant to key questions. [pmid: 3683260].
654 Pulvirenti JJ, Mehra T, Hafiz I, et al. Epidemiology and outcome of Clostridium difficile infection and diarrhea in HIV infected inpatients. Diagnostic Microbiology & Infectious Disease. Dec. 2002;44(4):325-30. Not relevant to key questions. [pmid: 12543536].
655 Pupaibool J, Khantipong M, Suankratay C. A study of Clostridium difficile-associated disease at King Chulalongkorn Memorial Hospital, Thailand. Journal of the Medical Association of Thailand. Jan. 2008;91(1):37-43. Not included study design. [pmid: 18386542].
656 Quinn TC, Stamm WE, Goodell SE, et al. The polymicrobial origin of intestinal infections in homosexual men. New England Journal of Medicine. Sep. 8. 1983;309(10):576-82. Not relevant to key questions. [pmid: 6308444].
657 Rafferty ME, Baltch AL, Smith RP, et al. Comparison of restriction enzyme analysis, arbitrarily primed PCR, and protein profile analysis typing for epidemiologic investigation of an ongoing Clostridium difficile outbreak. J Clin Microbiol. Oct. 1998;36(10):2957-63. Not relevant to key questions. [pmid: 9738050].
658 Raibaud P, Ducluzeau R, Dubos F, et al. Implantation of bacteria from the digestive tract of man and various animals into gnotobiotic mice. American Journal of Clinical Nutrition. Nov. 1980;33(11 Suppl):2440-7. Not relevant to key questions. [pmid: 7001883].
659 Ramaswamy R, Grover H, Corpuz M, et al. Prognostic criteria in Clostridium difficile colitis. Am J Gastroenterol. Mar. 1996;91(3):460-4. Not relevant to key questions. [pmid: 8633491].
660 Ramirez-Ronda CH, Balleste CR, Melendez B, et al. Management of urinary tract infections, decubitus ulcer and pneumonia in the aging person. Boletin - Asociacion Medica de Puerto Rico. Nov-Dec. 2003;95(6):42-50. Not included study design. [pmid: 15449791].
661 Rammer M, Kirchgatterer A, Hobling W, et al. Lansoprazole-associated collagenous colitis: a case report. Zeitschrift fur Gastroenterologie. Jul. 2005;43(7):657-60. Not on topic. [pmid: 16001348].
662 Ramos A, Martinez-Taboada VM, Fito C, et al. Clostridium difficile-associated diarrhea in rheumatoid arthritis patients who are receiving therapy with low-dose chlorambucil. Arthritis & Rheumatism. Nov. 1997;40(11):2090-1. Not relevant to key questions. [pmid: 9365100].
663 Raveh D, Rabinowitz B, Breuer GS, et al. Risk factors for Clostridium difficile toxin-positive nosocomial diarrhoea. International journal of antimicrobial agents. Sep. 2006;28(3):231-7. Not relevant to key questions. [pmid: 16908119].
664 Razavi B. Reactive arthritis after Helicobacter pylori eradication. Lancet. Feb. 26. 2000;355(9205):720. Not included study design. [pmid: 10703805].
665 Razzaq R, Sukumar SA. Ultrasound diagnosis of clinically undetected Clostridium difficile toxin colitis. Clinical radiology. May. 2006;61(5):446-52. Not included study design. [pmid: 16679120].
666 Redelings MD, Sorvillo F, Mascola L. Increase in Clostridium difficile-related mortality rates, United States, 1999-2004. Emerging Infectious Diseases. Sep. 2007;13(9):1417-9. Not relevant to key questions. [pmid: 18252127].
667 Ricciardi R, Rothenberger DA, Madoff RD, et al. Increasing prevalence and severity of Clostridium difficile colitis in hospitalized patients in the United States. Archives of Surgery. discussion 631. Jul. 2007;142(7):624-31. Not relevant to key questions. [pmid: 17638799].
668 Riley TV, Cooper M, Bell B, et al. Community-acquired Clostridium difficile-associated diarrhea. Clinic Infect Dis. Jun. 1995;20(Suppl 2):S263-5. Not relevant to key questions.
669 Riley TV, Karthigasu KT. Chronic osteomyelitis due to Clostridium difficile. BMJ Clinical Research Ed. Apr. 24. 1982;284(6324):1217-8. Not on topic. [pmid: 6803907].
670 Riley TV, Wetherall F, Bowman J, et al. Diarrheal disease due to Clostridium difficile in general practice. Pathology. Oct. 1991;23(4):346-9. Not relevant to key questions. [pmid: 1784528].
671 Riva G, Luppi M, Potenza L, et al. Cytomegalovirus and Clostridium Difficile co-infection in severe ulcero-hemorrhagic colitis during induction chemotherapy for acute lymphoblastic leukemia. Haematologica. Jan. 2005;90(1):ER01. Not included study design.
672 Roda PI. Clostridium difficile colitis induced by cytarabine. American Journal of Clinical Oncology. Oct. 1987;10(5):451-2. Not included study design. [pmid: 3477943].
673 Rodemann JF, Dubberke ER, Reske KA, et al. Incidence of Clostridium difficile infection in inflammatory bowel disease. Clin Gastroenterol Hepatol. Mar. 2007;5(3):339-44. Not relevant to key questions. [pmid: 17368233].
674 Rogers MA, Blumberg N, Saint S, et al. Hospital variation in transfusion and infection after cardiac surgery: a cohort study. BMC Medicine. 2009;7:37. Not relevant to key questions. [pmid: 19646221].
675 Rogers MA, Fries BE, Kaufman SR, et al. Mobility and other predictors of hospitalization for urinary tract infection: a retrospective cohort study. BMC Geriatrics. 2008;8:31. Not relevant to key questions. [pmid: 19032784].
676 Roghmann MC, McCarter RJ Jr, Brewrink J, et al. Clostridium difficile infection is a risk factor for bacteremia due to vancomycin-resistant enterococci (VRE) in VRE-colonized patients with acute leukemia. Clinic Infect Dis. Nov. 1997;25(5):1056-9. Not relevant to key questions.
677 Rolny P, Jarnerot G, Mollby R. Occurrence of Clostridium difficile toxin in inflammatory bowel disease. Scandinavian journal of gastroenterology. Jan. 1983;18(1):61-4. Not relevant to key questions. [pmid: 6144171].
678 Rossel P, Sortsoe Jensen H, Qvist P, et al. Prognosis of adult-onset idiopathic bile acid malabsorption. Scandinavian journal of gastroenterology. Jun. 1999;34(6):587-90. Not on topic. [pmid: 10440608].
679 Rotimi VO, Mokaddas EM, Jamal WY, et al. Hospital-acquired Clostridium difficile infection amongst ICU and burn patients in Kuwait. Medical Principles & Practice. Jan-Mar. 2002;11(1):23-8. Not relevant to key questions. [pmid: 12116691].
680 Rouphael NG, O'Donnell JA, Bhatnagar J, et al. Clostridium difficile-associated diarrhea: an emerging threat to pregnant women. American Journal of Obstetrics & Gynecology. Jun. 2008;198(6):635.e1-.e6. Not relevant to key questions. [pmid: 18395693].
681 Rubin MS, Bodenstein LE, Kent KC. Severe Clostridium difficile colitis. Dis Colon Rectum. Apr. 1995;38(4):350-4. Not relevant to key questions. [pmid: 7720439].
682 Rudensky B, Rosner S, Sonnenblick M, et al. The prevalence and nosocomial acquisition of Clostridium difficile in elderly hospitalized patients. Postgrad Med J. Jan. 1993;69(807):45-7. Duplicate listing. [pmid: 8446550].
683 Rudensky B, Rosner S, Sonnenblick M, et al. The prevalence and nosocomial acquisition of Clostridium difficile in elderly hospitalized patients. Postgrad Med J. Jan. 1993;69(807):45-7. Not relevant to key questions. [pmid: 8446550].
684 Safdar N, Barigala R, Said A, et al. Feasibility and tolerability of probiotics for prevention of antibiotic-associated diarrhoea in hospitalized US military veterans. Journal of Clinical Pharmacy & Therapeutics. Dec. 2008;33(6):663-8. Not relevant to key questions. [pmid: 19138244].
685 Saginur R, Hawley CR, Bartlett JG. Colitis associated with metronidazole therapy. J Infect Dis. Jun. 1980;141(6):772-4. Not included study design. [pmid: 7391617].
686 Sailhamer EA, Carson K, Chang Y, et al. Fulminant Clostridium difficile colitis: patterns of care and predictors of mortality. Archives of Surgery. discussion 439-40. May. 2009;144(5):433-9. Not relevant to key questions. [pmid: 19451485].
687 Salazar M, Baskin L, Garey KW, et al. Clostridium difficile-related death rates in Texas 1999-2005. Journal of Infection. Nov. 2009;59(5):303-7. Not relevant to key questions. [pmid: 19735673].
688 Salgado CD, Giannetta ET, Farr BM. Failure to develop vancomycin-resistant Enterococcus with oral vancomycin treatment of Clostridium difficile. Infect Control Hosp Epidemiol. May. 2004;25(5):413-7. Not relevant to key questions. [pmid: 15188848].
689 Sambol SP, Merrigan MM, Lyerly D, et al. Toxin gene analysis of a variant strain of Clostridium difficile that causes human clinical disease. Infect Immun. Oct. 2000;68(10):5480-7. Not relevant to key questions. [pmid: 10992443].
690 Samore MH, DeGirolami PC, Tlucko A, et al. Clostridium difficile colonization and diarrhea at a tertiary care hospital. Clinic Infect Dis. Feb. 1994;18(2):181-7. Background.
691 Samuel SC, Hancock P, Leigh DA. An investigation into Clostridium perfringens enterotoxin-associated diarrhoea. J Hosp Infect. Jul. 1991;18(3):219-30. Not on topic. [pmid: 1680904].
692 Sanchez TH, Brooks JT, Sullivan PS, et al. Bacterial diarrhea in persons with HIV infection, United States, 1992-2002. Clinic Infect Dis. Dec. 1. 2005;41(11):1621-7. Not relevant to key questions.
693 Sanchez-Hurtado K, Corretge M, Mutlu E, et al. Systemic antibody response to Clostridium difficile in colonized patients with and without symptoms and matched controls. Journal of medical microbiology. Jun. 2008;57(Pt 6):717-24. Not relevant to key questions. [pmid: 18480328].
694 Satin AJ, Harrison CR, Hancock KC, et al. Relapsing Clostridium difficile toxin-associated colitis in ovarian cancer patients treated with chemotherapy. Obstetrics & Gynecology. Sep. 1989;74(3 Pt 2):487-9. Not included study design. [pmid: 2761938].
695 Satin AJ, Harrison CR, Hancock KC, et al. Relapsing Clostridium difficile toxin-associated colitis in ovarian cancer patients treated with chemotherapy. Obstetrics & Gynecology. Sep. 1989;74(3 Pt 2):487-9. Duplicate listing. [pmid: 2761938].
696 Saunders MD, Kimmey MB. Colonic pseudo-obstruction: the dilated colon in the ICU. Seminars in gastrointestinal disease. Jan. 2003;14(1):20-7. Not on topic. [pmid: 12610851].
697 Savage AM, Alford RH. Nosocomial spread of Clostridium difficile. Infection Control. Jan-Feb. 1983;4(1):31-3. Not included study design. [pmid: 6550579].
698 Scalera NM, File TM Jr. How long should we treat community-acquired pneumonia?. Current opinion in infectious diseases. Apr. 2007;20(2):177-81. Not on topic. [pmid: 17496577].
699 Scanvic-Hameg A, Chachaty E, Rey J, et al. Impact of quinupristin/dalfopristin (RP59500) on the faecal microflora in healthy volunteers. J Antimicrob Chemother. Jan. 2002;49(1):135-9. Not on topic. [pmid: 11751777].
700 Scheurer D. Diagnostic and treatment delays in recurrent Clostridium difficile-associated disease. J Hosp Med (Online). Mar. 2008;3(2):156-9. Not on topic.
701 Scheurer DB, Hicks LS, Cook EF, et al. Accuracy of ICD-9 coding for Clostridium difficile infections: a retrospective cohort. Epidemiology & Infection. Aug. 2007;135(6):1010-3. Not relevant to key questions. [pmid: 17156501].
702 Schmiedeskamp M, Harpe S, Polk R, et al. Use of International Classification of Diseases, Ninth Revision, Clinical Modification codes and medication use data to identify nosocomial Clostridium difficile infection. Infect Control Hosp Epidemiol. Nov. 2009;30(11):1070-6. Not relevant to key questions. [pmid: 19803724].
703 Schmitt-Grohe S, Wiggert E, Steffan J, et al. Severe antibiotic-associated colitis in a patient with cystic fibrosis and colonic wall thickening. Journal of Pediatric Gastroenterology & Nutrition. Feb. 2002;34(2):224-6. Not included study design. [pmid: 11840045].
704 Schneeweiss S, Korzenik J, Solomon DH, et al. Infliximab and other immunomodulating drugs in patients with inflammatory bowel disease and the risk of serious bacterial infections. Aliment Pharmacol Ther. Aug. 2009;30(3):253-64. Not relevant to key questions. [pmid: 19438424].
705 Schuler A. Risks versus benefits of long-term proton pump inhibitor therapy in the elderly. Geriatric nursing. Jul-Aug. 2007;28(4):225-9. Not included study design. [pmid: 17936957].
706 Schwaber MJ, Simhon A, Block C, et al. Factors associated with nosocomial diarrhea and Clostridium difficile-associated disease on the adult wards of an urban tertiary care hospital. Eur J Clin Microbiol Infect Dis. Jan. 2000;19(1):9-15. Duplicate listing.
707 Schweitzer MA, Sweiss I, Silver DL, et al. The clinical spectrum of Clostridium difficile colitis in immunocompromised patients. American Surgeon. discussion 607-8. Jul. 1996;62(7):603-7. Not relevant to key questions. [pmid: 8651560].
708 Sciscione AC, Villeneuve JB, Pitt HA, et al. Surgery for pancreatic tumors during pregnancy: a case report and review of the literature. American Journal of Perinatology. Jan. 1996;13(1):21-5. Not included study design. [pmid: 8645381].
709 Scully BE, Henry SA. Clinical experience with aztreonam in the treatment of gram-negative bacteremia. Reviews of infectious diseases. Nov-Dec. 1985;7(Suppl 4):S789-93. Not on topic. [pmid: 3909338].
710 Seder CW, Villalba MR Jr, Robbins J, et al. Early colectomy may be associated with improved survival in fulminant Clostridium difficile colitis: an 8-year experience. American Journal of Surgery. Mar. 2009;197(3):302-7. Duplicate listing. [pmid: 19245905].
711 Seder CW, Villalba MR Jr, Robbins J, et al. Early colectomy may be associated with improved survival in fulminant Clostridium difficile colitis: an 8-year experience. American Journal of Surgery. Mar. 2009;197(3):302-7. Not relevant to key questions. [pmid: 19245905].
712 Sensini A, Marroni M, Bassotti G, et al. Clostridium difficile-associated reactive arthritis in an HLA-B27 negative male. J Clin Gastroenterol. Jun. 1993;16(4):354-5. Not included study design. [pmid: 8331275].
713 Sethi AK, Al-Nassir WN, Nerandzic MM, et al. Persistence of skin contamination and environmental shedding of Clostridium difficile during and after treatment of C. difficile infection. Infect Control Hosp Epidemiol. Jan. 2010;31(1):21-7. Not relevant to key questions. [pmid: 19929371].
714 Sethi AK, Al-Nassir WN, Nerandzic MM, et al. Skin and environmental contamination with vancomycin-resistant Enterococci in patients receiving oral metronidazole or oral vancomycin treatment for Clostridium difficile-associated disease. Infect Control Hosp Epidemiol. Jan. 2009;30(1):13-7. Not relevant to key questions. [pmid: 19046063].
715 Settle CD, Wilcox MH, Fawley WN, et al. Prospective study of the risk of Clostridium difficile diarrhoea in elderly patients following treatment with cefotaxime or piperacillin-tazobactam. Aliment Pharmacol Ther. Dec. 1998;12(12):1217-23. Not relevant to key questions. [pmid: 9882029].
716 Seyler L, Lalvani A, Collins L, et al. Safety and cost savings of an improved three-day rule for stool culture in hospitalised children and adults. J Hosp Infect. Oct. 2007;67(2):121-6. Not on topic. [pmid: 17900758].
717 Shadel BN, Puzniak LA, Gillespie KN, et al. Surveillance for vancomycin-resistant enterococci: type, rates, costs, and implications. Infect Control Hosp Epidemiol. Oct. 2006;27(10):1068-75. Not relevant to key questions. [pmid: 17006814].
718 Shah S, Lewis A, Leopold D, et al. Gastric acid suppression does not promote clostridial diarrhoea in the elderly. QJM. Mar. 2000;93(3):175-81. Not relevant to key questions. [pmid: 10751237].
719 Shah V, Marino C, Altice FL. Albendazole-induced pseudomembranous colitis. Am J Gastroenterol. Jul. 1996;91(7):1453-4. Not included study design. [pmid: 8678015].
720 Sharma P, Bomireddy R, Phillips S. Clostridium difficile-associated diarrhoea after internal fixation of intertrochanteric femoral fractures. Eur J Clin Microbiol Infect Dis. Oct. 2003;22(10):615-8. Not relevant to key questions. [pmid: 13680392].
721 Shastri YM, Bergis D, Povse N, et al. Prospective multicenter study evaluating fecal calprotectin in adult acute bacterial diarrhea. Am J Med. Dec. 2008;121(12):1099-106. Not on topic. [pmid: 19028207].
722 Shedda S, Campbell I, Skinner I. Clostridium difficile splenic abscess. Australian & New Zealand Journal of Surgery. Feb. 2000;70(2):147-8. Not relevant to key questions. [pmid: 10711482].
723 Shehabi AA, Abu-Ragheb HA, Allaham NA. Prevalence of Clostridium difficile-associated diarrhoea among hospitalized Jordanian patients. Eastern Mediterranean Health Journal. Jul-Sep. 2001;7(4-5):750-5. Not relevant to key questions. [pmid: 15332775].
724 Sheikh RA, Yasmeen S, Pauly MP, et al. Pseudomembranous colitis without diarrhea presenting clinically as acute intestinal pseudo-obstruction. Journal of gastroenterology. Sep. 2001;36(9):629-32. Not included study design. [pmid: 11578068].
725 Shen B, Goldblum JR, Hull TL, et al. Clostridium difficile-associated pouchitis. Dig Dis Sci. Dec. 2006;51(12):2361-4. Not relevant to key questions. [pmid: 17103037].
726 Shen BO, Jiang ZD, Fazio VW, et al. Clostridium difficile infection in patients with ileal pouch-anal anastomosis. Clin Gastroenterol Hepatol. Jul. 2008;6(7):782-8. Not relevant to key questions. [pmid: 18467184].
727 Sheth H, Bernardini J, Burr R, et al. Clostridium difficile infections in outpatient dialysis cohort. Infect Control Hosp Epidemiol. Jan. 2010;31(1):89-91. Not relevant to key questions. [pmid: 19929691].
728 Shetler K, Nieuwenhuis R, Wren SM, et al. Decompressive colonoscopy with intracolonic vancomycin administration for the treatment of severe pseudomembranous colitis. Surgical endoscopy. Jul. 2001;15(7):653-9. Not relevant to key questions. [pmid: 11591962].
729 Shim JK, Johnson S, Samore MH, et al. Primary symptomless colonisation by Clostridium difficile and decreased risk of subsequent diarrhoea. Lancet. Feb. 28. 1998;351(9103):633-6. Background. [pmid: 9500319].
730 Shimoni Z, Averbuch Y, Shir E, et al. The addition of fiber and the use of continuous infusion decrease the incidence of diarrhea in elderly tube-fed patients in medical wards of a general regional hospital: a controlled clinical trial. J Clin Gastroenterol. Nov-Dec. 2007;41(10):901-5. Not on topic. [pmid: 18090158].
731 Shin BM, Lee EJ, Kuak EY, et al. Comparison of VIDAS CDAB and CDA immunoassay for the detection of Clostridium difficile in a tcdA- tcdB+ C. difficile prevalent area. Anaerobe. Dec. 2009;15(6):266-9. Not relevant to key questions. [pmid: 19772927].
732 Shin JW, Yong D, Kim MS, et al. Sudden increase of vancomycin-resistant enterococcal infections in a Korean tertiary care hospital: possible consequences of increased use of oral vancomycin. Journal of Infection & Chemotherapy. discussion 104-5. Mar. 2003;9(1):62-7. Not relevant to key questions. [pmid: 12673410].
733 Shinagawa N, Tachi Y, Ishikawa S, et al. Prophylactic antibiotics for patients undergoing elective biliary tract surgery: a prospective randomized study of cefotiam and cefoperazone. Japanese Journal of Surgery. Jan. 1987;17(1):1-8. Not on topic. [pmid: 2952826].
734 Shuttleworth R, Taylor M, Jones DM. Antimicrobial susceptibilities of Clostridium difficile. Journal of clinical pathology. Oct. 1980;33(10):1002-5. Not relevant to key questions. [pmid: 7430354].
735 Si JM, Yu YC, Fan YJ, et al. Intestinal microecology and quality of life in irritable bowel syndrome patients. World Journal of Gastroenterology. Jun. 15. 2004;10(12):1802-5. Not on topic. [pmid: 15188510].
736 Siegal D, Syed F, Hamid N, et al. Campylobacter jejuni pancolitis mimicking idiopathic ulcerative colitis. Heart & Lung. Jul-Aug. 2005;34(4):288-90. Not on topic. [pmid: 16027651].
737 Siegle RJ, Fekety R, Sarbone PD, et al. Effects of topical clindamycin on intestinal microflora in patients with acne. Journal of the American Academy of Dermatology. Aug. 1986;15(2 Pt 1):180-5. Not relevant to key questions. [pmid: 2943760].
738 Silva J Jr, Batts DH, Fekety R, et al. Treatment of Clostridium difficile colitis and diarrhea with vancomycin. Am J Med. Nov. 1981;71(5):815-22. Not relevant to key questions. [pmid: 7304654].
739 Simor AE, Bradley SF, Strausbaugh LJ, et al. Clostridium difficile in long-term-care facilities for the elderly. Infect Control Hosp Epidemiol. Nov. 2002;23(11):696-703. Not relevant to key questions. [pmid: 12452300].
740 Simor AE, Yake SL, Tsimidis K. Infection due to Clostridium difficile among elderly residents of a long-term-care facility. Clinic Infect Dis. Oct. 1993;17(4):672-8. Not relevant to key questions.
741 Sims RV, Hauser RJ, Adewale AO, et al. Acute gastroenteritis in three community-based nursing homes. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Sep. 1995;50(5):M252-6. Not relevant to key questions.
742 Slotwiner-Nie PK, Brandt LJ. Infectious diarrhea in the elderly. Gastroenterology clinics of North America. Sep. 2001;30(3):625-35. Not relevant to key questions. [pmid: 11586549].
743 Soderlin MK, Alasaarela E, Hakala M. Reactive arthritis induced by Clostridium difficile enteritis as a complication of Helicobacter pylori eradication. Clinical rheumatology. 1999;18(4):337-8. Not included study design. [pmid: 10468177].
744 Soes L, Molbak K, Strobaek S, et al. The emergence of Clostridium difficile PCR ribotype 027 in Denmark--a possible link with the increased consumption of fluoroquinolones and cephalosporins?. Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2009. 2009;14(15). Not relevant to key questions.
745 Solaymani-Mohammadi S, Coyle CM, Factor SM, et al. Amebic colitis in an antigenically and serologically negative patient: usefulness of a small-subunit ribosomal RNA gene-based polymerase chain reaction in diagnosis. Diagnostic Microbiology & Infectious Disease. Nov. 2008;62(3):333-5. Not on topic. [pmid: 18691843].
746 Soler P, Nogareda F, Cano R. Rates of Clostridium difficile infection in patients discharged from Spanish hospitals, 1997-2005. Infect Control Hosp Epidemiol. Sep. 2008;29(9):887-9. Not relevant to key questions. [pmid: 18681812].
747 Song HJ, Shim KN, Jung SA, et al. Antibiotic-associated diarrhea: candidate organisms other than Clostridium difficile. Korean Journal of Internal Medicine. Mar. 2008;23(1):9-15. Not included study design. [pmid: 18363274].
748 Song HJ, Shim KN, Jung SA, et al. Antibiotic-associated diarrhea: candidate organisms other than Clostridium difficile. Korean Journal of Internal Medicine. Mar. 2008;23(1):9-15. Duplicate listing. [pmid: 18363274].
749 Song X, Bartlett JG, Speck K, et al. Rising economic impact of clostridium difficile-associated disease in adult hospitalized patient population. Infect Control Hosp Epidemiol. Sep. 2008;29(9):823-8. Not relevant to key questions. [pmid: 18643746].
750 Soyletir G, Eskiturk A, Kilic G, et al. Clostridium difficile acquisition rate and its role in nosocomial diarrhoea at a university hospital in Turkey. European journal of epidemiology. Aug. 1996;12(4):391-4. Not relevant to key questions. [pmid: 8891544].
751 Spigaglia P, Mastrantonio P. Comparative analysis of Clostridium difficile clinical isolates belonging to different genetic lineages and time periods. Journal of medical microbiology. Nov. 2004;53(Pt 11):1129-36. Not relevant to key questions. [pmid: 15496392].
752 Stalam M, Kaye D. Antibiotic agents in the elderly. Infectious disease clinics of North America. Sep. 533. 2004;18(3):viii-49. Not on topic.
753 Stamper PD, Alcabasa R, Aird D, et al. Comparison of a commercial real-time PCR assay for tcdB detection to a cell culture cytotoxicity assay and toxigenic culture for direct detection of toxin-producing Clostridium difficile in clinical samples. J Clin Microbiol. Feb. 2009;47(2):373-8. Duplicate listing. [pmid: 19073875].
754 Stamper PD, Alcabasa R, Aird D, et al. Comparison of a commercial real-time PCR assay for tcdB detection to a cell culture cytotoxicity assay and toxigenic culture for direct detection of toxin-producing Clostridium difficile in clinical samples. J Clin Microbiol. Feb. 2009;47(2):373-8. Not relevant to key questions. [pmid: 19073875].
755 Starks I, Ayub G, Walley G, et al. Single-dose cefuroxime with gentamicin reduces Clostridium difficile-associated disease in hip-fracture patients. J Hosp Infect. Sep. 2008;70(1):21-6. Not relevant to key questions. [pmid: 18621442].
756 Starr JM, Impallomeni M. Risk of diarrhoea, Clostridium difficile and cefotaxime in the elderly. Biomedicine & Pharmacotherapy. 1997;51(2):63-7. Not relevant to key questions.
757 Stein BL, Lamoureux E, Miller M, et al. Glutaraldehyde-induced colitis. Canadian Journal of Surgery. Apr. 2001;44(2):113-6. Not on topic.
758 Stein GE, Christensen S, Mummaw N. Treatment of acute uncomplicated urinary tract infection with ceftibuten. Infection. Mar-Apr. 1991;19(2):124-6. Not relevant to key questions. [pmid: 2050421].
759 Stella PA. Evaluation of a commercial latex agglutination assay for screening for Clostridium difficile-associated disease. Clinical Laboratory Science. Sep-Oct. 1994;7(5):311-3. Not relevant to key questions. [pmid: 10150387].
760 Stelzmueller I, Goegele H, Biebl M, et al. Clostridium difficile colitis in solid organ transplantation--a single-center experience. Dig Dis Sci. Nov. 2007;52(11):3231-6. Not relevant to key questions. [pmid: 17406820].
761 Sultana Q, Chaudhry NA, Munir M, et al. Diagnosis of Clostridium difficile antibiotic associated diarrhoea culture versus toxin assay. JPMA - Journal of the Pakistan Medical Association. Aug. 2000;50(8):246-9. Not relevant to key questions.
762 Sundar S, Chan SY. Cholestatic jaundice and pseudomembranous colitis following combination therapy with doxorubicin and docetaxel. Anti-Cancer Drugs. Apr. 2003;14(4):327-9. Not included study design. [pmid: 12679738].
763 Surawicz CM. Update on gastrointestinal infections: Clostridium difficile and other bugs. Current gastroenterology reports. Oct. 1999;1(5):363-4. Not relevant to key questions. [pmid: 10980973].
764 Surawicz CM. Treatment of recurrent Clostridium difficile-associated disease. Nature Clinical Practice Gastroenterology & Hepatology. Nov. 2004;1(1):32-8. Not relevant to key questions.
765 Surawicz CM, McFarland LV, Elmer G, et al. Treatment of recurrent Clostridium difficile colitis with vancomycin and Saccharomyces boulardii. Am J Gastroenterol. Oct. 1989;84(10):1285-7. Not included study design. [pmid: 2679049].
766 Svanteson B, Thoren A, Castor B, et al. Acute diarrhoea in adults: aetiology, clinical appearance and therapeutic aspects. Scand J Infect Dis. 1988;20(3):303-14. Not on topic. [pmid: 3406670].
767 Svenungsson B, Burman LG, Jalakas-Pornull K, et al. Epidemiology and molecular characterization of Clostridium difficile strains from patients with diarrhea: low disease incidence and evidence of limited cross-infection in a Swedish teaching hospital. J Clin Microbiol. Sep. 2003;41(9):4031-7. Not relevant to key questions. [pmid: 12958221].
768 Svenungsson B, Lagergren A, Ekwall E, et al. Enteropathogens in adult patients with diarrhea and healthy control subjects: a 1-year prospective study in a Swedish clinic for infectious diseases. Clinic Infect Dis. May. 2000;30(5):770-8. Not on topic.
769 Svenungsson B, Lagergren A, Lundberg A. Clostridium difficile cytotoxin B in adults with diarrhea: a comparison of patients treated or not treated with antibiotics prior to infection. Clinical Microbiology & Infection. Aug. 2001;7(8):447-50. Not relevant to key questions. [pmid: 11591210].
770 Synnott K, Mealy K, Merry C, et al. Timing of surgery for fulminating pseudomembranous colitis. Br J Surg. Feb. 1998;85(2):229-31. Not included study design. [pmid: 9501823].
771 Szajewska H, Setty M, Mrukowicz J, et al. Probiotics in gastrointestinal diseases in children: hard and not-so-hard evidence of efficacy. Journal of Pediatric Gastroenterology & Nutrition. May. 2006;42(5):454-75. Not relevant to key questions. [pmid: 16707966].
772 Tabaqchali S, Holland D, O'Farrell S, et al. Typing scheme for Clostridium difficile: its application in clinical and epidemiological studies. Lancet. Apr. 28. 1984;1(8383):935-8. Not on topic. [pmid: 6143871].
773 Tabaqchali S, O'Farrell S, Holland D, et al. Method for the typing of Clostridium difficile based on polyacrylamide gel electrophoresis of [35S]methionine-labeled proteins. J Clin Microbiol. Jan. 1986;23(1):197-8. Not relevant to key questions. [pmid: 3700603].
774 Tae CH, Jung SA, Song HJ, et al. The first case of antibiotic-associated colitis by Clostridium difficile PCR ribotype 027 in Korea. Journal of Korean medical science. Jun. 2009;24(3):520-4. Not included study design. [pmid: 19543521].
775 Tal S, Gurevich A, Guller V, et al. Risk factors for recurrence of Clostridium difficile-associated diarrhea in the elderly. Scand J Infect Dis. 2002;34(8):594-7. Not relevant to key questions. [pmid: 12238576].
776 Talbot GH, Cassileth PA, Paradiso L, et al. Oral enoxacin for infection prevention in adults with acute nonlymphocytic leukemia. The Enoxacin Prophylaxis Study Group. Antimicrob Agents Chemother. Mar. 1993;37(3):474-82. Not on topic. [pmid: 8460916].
777 Talbot RW, Walker RC, Beart RW Jr. Changing epidemiology, diagnosis, and treatment of Clostridium difficile toxin-associated colitis. Br J Surg. Jun. 1986;73(6):457-60. Not relevant to key questions. [pmid: 3719271].
778 Tay JK, Bodle EE, Fisher DA, et al. Screening for vancomycin-resistant enterococci using stools sent for Clostridium difficile cytotoxin assay is effective: results of a survey of 300 Patients in a large Singapore Teaching Hospital. Ann Acad Med Singapore. Nov. 2007;36(11):926-9. Not on topic. [pmid: 18071603].
779 Tayek JA, Bistrian BR, Blackburn GL. The effects of acute clostridium difficile diarrhea on fecal nitrogen content in adult hospitalized patients. Journal of the American College of Nutrition. Jun. 1987;6(3):255-9. Not relevant to key questions. [pmid: 3598023].
780 Taylor CP, Tummala S, Molrine D, et al. Open-label, dose escalation phase I study in healthy volunteers to evaluate the safety and pharmacokinetics of a human monoclonal antibody to Clostridium difficile toxin A. Vaccine. Jun. 25. 2008;26(27-28):3404-9. Duplicate listing. [pmid: 18502001].
781 Taylor ME, Oppenheim BA. Hospital-acquired infection in elderly patients. J Hosp Infect. Apr. 1998;38(4):245-60. Not on topic. [pmid: 9602974].
782 Taylor ME, Oppenheim BA, Chadwick PR, et al. Detection of glycopeptide-resistant enterococci in routine diagnostic faeces specimens. J Hosp Infect. Sep. 1999;43(1):25-32. Not included study design. [pmid: 10462636].
783 Teare JP, Booth JC, Brown JL, et al. Pseudomembranous colitis following clarithromycin therapy. European journal of gastroenterology & hepatology. Mar. 1995;7(3):275-7. Not included study design. [pmid: 7743311].
784 Teare JP, Booth JC, Brown JL, et al. Pseudomembranous colitis following clarithromycin therapy. European journal of gastroenterology & hepatology. Mar. 1995;7(3):275-7. Duplicate listing. [pmid: 7743311].
785 Tedesco FJ. Bacitracin therapy in antibiotic-associated pseudomembranous colitis. Dig Dis Sci. Oct. 1980;25(10):783-4. Not relevant to key questions. [pmid: 6903494].
786 Tedesco FJ, Hardin RD, Harper RN, et al. Infectious colitis endoscopically simulating inflammatory bowel disease: a prospective evaluation. Gastrointestinal endoscopy. Aug. 1983;29(3):195-7. Not on topic. [pmid: 6618115].
787 Thamlikitkul V, Danpakdi K, Chokloikaew S. Incidence of diarrhea and Clostridium difficile toxin in stools from hospitalized patients receiving clindamycin, beta-lactams, or nonantibiotic medications. J Clin Gastroenterol. Mar. 1996;22(2):161-3. Not relevant to key questions. [pmid: 8742665].
788 Theunissen C, Knoop C, Nonhoff C, et al. Clostridium difficile colitis in cystic fibrosis patients with and without lung transplantation. Transplant Infectious Disease. Jul. 2008;10(4):240-4. Not on topic. [pmid: 17630999].
789 Thibault A, Miller MA, Gaese C. Risk factors for the development of Clostridium difficile-associated diarrhea during a hospital outbreak. Infect Control Hosp Epidemiol. Jun. 1991;12(6):345-8. Not relevant to key questions. [pmid: 2071877].
790 Thomas CE, Mayer SA, Gungor Y, et al. Myasthenic crisis: clinical features, mortality, complications, and risk factors for prolonged intubation. Neurology. May. 1997;48(5):1253-60. Not on topic. [pmid: 9153452].
791 Thomas DR, Bennett RG, Laughon BE, et al. Postantibiotic colonization with Clostridium difficile in nursing home patients. Journal of the American Geriatrics Society. Apr. 1990;38(4):415-20. Not relevant to key questions. [pmid: 2329250].
792 Thompson I. Clostridium difficile-associated disease: update and focus on non-antibiotic strategies. Age Ageing. Jan. 2008;37(1):14-8. Not relevant to key questions. [pmid: 18033775].
793 Thorson MA, Bliss DZ, Savik K. Re-examination of risk factors for non-Clostridium difficile-associated diarrhoea in hospitalized patients. Journal of advanced nursing. May. 2008;62(3):354-64. Not relevant to key questions. [pmid: 18426460].
794 Titov L, Lebedkova N, Shabanov A, et al. Isolation and molecular characterization of Clostridium difficile strains from patients and the hospital environment in Belarus. J Clin Microbiol. Mar. 2000;38(3):1200-2. Not relevant to key questions. [pmid: 10699022].
795 Titu LV, Zafar N, Phillips SM, et al. Emergency laparoscopic surgery for complicated diverticular disease. Colorectal Disease. May. 2009;11(4):401-4. Not on topic. [pmid: 18616737].
796 Tomblyn M, Gordon L, Singhal S, et al. Rarity of toxigenic Clostridium difficile infections after hematopoietic stem cell transplantation: implications for symptomatic management of diarrhea. Bone marrow transplantation. Oct. 2002;30(8):517-9. Not relevant to key questions. [pmid: 12379891].
797 Toor AA, van Burik JA, Weisdorf DJ. Infections during mobilizing chemotherapy and following autologous stem cell transplantation. Bone marrow transplantation. Dec. 2001;28(12):1129-34. Not on topic. [pmid: 11803354].
798 Tresallet C, Nguyen-Thanh Q, Aubriot-Lorton MH, et al. Small-bowel infarction from disseminated aspergillosis. Dis Colon Rectum. Sep. 2004;47(9):1515-8. Not included study design. [pmid: 15486750].
799 Trevisani F, Simoncini M, Alampi G, et al. Colitis associated to chemotherapy with 5-fluorouracil. Hepato-gastroenterology. May-Jun. 1997;44(15):710-2. Not included study design. [pmid: 9222677].
800 Triadafilopoulos G, Hallstone AE. Acute abdomen as the first presentation of pseudomembranous colitis. Gastroenterol. Sep. 1991;101(3):685-91. Not included study design.
801 Triadafilopoulos G, Shah MH, Pothoulakis C. The chemotactic response of human granulocytes to Clostridium difficile toxin A is age dependent. Am J Gastroenterol. Oct. 1991;86(10):1461-5. Not relevant to key questions. [pmid: 1928037].
802 Trnka YM, Lamont JT. Clostridium difficile colitis. Advances in Internal Medicine. 1984;29:85-107. Not relevant to key questions. [pmid: 6369936].
803 Trowbridge S. Hospital-acquired infections and infection control practices: what are the consequences to the elderly patient?. Perspectives. 2009;33(1):16-22. Not on topic. [pmid: 19514546].
804 Trudel JL, Deschenes M, Mayrand S, et al. Toxic megacolon complicating pseudomembranous enterocolitis. Dis Colon Rectum. Oct. 1995;38(10):1033-8. Not relevant to key questions. [pmid: 7555415].
805 Tsironi E, Irving PM, Feakins RM, et al. “Diversion” colitis caused by Clostridium difficile infection: report of a case. Dis Colon Rectum. Jul. 2006;49(7):1074-7. Not included study design. [pmid: 16729217].
806 Tsujimura H, Sakai C, Ishii A, et al. Fatal fulminant Clostridium difficile colitis during CHOP therapy for lymphoma: an autopsy case. Internal Medicine. 2007;46(7):401-4. Not included study design. [pmid: 17409606].
807 Tumbarello M, Tacconelli E, Leone F, et al. Clostridium difficile-associated diarrhoea in patients with human immunodeficiency virus infection: a case-control study. European journal of gastroenterology & hepatology. Mar. 1995;7(3):259-63. Duplicate listing. [pmid: 7743309].
808 Tumbarello M, Tacconelli E, Leone F, et al. Clostridium difficile-associated diarrhoea in patients with human immunodeficiency virus infection: a case-control study. European journal of gastroenterology & hepatology. Mar. 1995;7(3):259-63. Not relevant to key questions. [pmid: 7743309].
809 Turner RJ. Pseudomembranous enterocolitis after gynecologic endoscopy. Journal of the American Association of Gynecologic Laparoscopists. Feb. 1994;1(2):168-70. Not included study design. [pmid: 9138866].
810 Uhnoo I, Wadell G, Svensson L, et al. Aetiology and epidemiology of acute gastro-enteritis in Swedish children. Journal of Infection. Jul. 1986;13(1):73-89. Not on topic. [pmid: 3734469].
811 Urban E, Tusnadi A, Terhes G, et al. Prevalence of gastrointestinal disease caused by Clostridium difficile in a university hospital in Hungary. J Hosp Infect. Jul. 2002;51(3):175-8. Not relevant to key questions. [pmid: 12144795].
812 Vaishnavi C, Kaur S. Clostridium perfringens enterotoxin in antibiotic-associated diarrhea. Indian journal of pathology & microbiology. Apr-Jun. 2008;51(2):198-9. Not on topic.
813 Valentine RJ, Hagino RT, Jackson MR, et al. Gastrointestinal complications after aortic surgery. Journal of Vascular Surgery. discussion 411-2. Sep. 1998;28(3):404-11. Not on topic.
814 Valiquette L, Pepin J, Do XV, et al. Prediction of complicated Clostridium difficile infection by pleural effusion and increased wall thickness on computed tomography. Clinic Infect Dis. Aug. 15. 2009;49(4):554-60. Not relevant to key questions.
815 van den Berg RJ, Kuijper EJ, van Coppenraet LE, et al. Rapid diagnosis of toxinogenic Clostridium difficile in faecal samples with internally controlled real-time PCR. Clinical Microbiology & Infection. Feb. 2006;12(2):184-6. Not relevant to key questions. [pmid: 16441459].
816 van Kraaij MG, Dekker AW, Verdonck LF, et al. Infectious gastro-enteritis: an uncommon cause of diarrhoea in adult allogeneic and autologous stem cell transplant recipients. Bone marrow transplantation. Aug. 2000;26(3):299-303. Not on topic. [pmid: 10967569].
817 van Nispen CH, Hoepelman AI, Rozenberg-Arska M, et al. A double-blind, placebo-controlled, parallel group study of oral trovafloxacin on bowel microflora in healthy male volunteers. American Journal of Surgery. Dec. 1998;176(6A Suppl):27S-31S. Not on topic. [pmid: 9935254].
818 Vanjak D, Girault G, Branger C, et al. Risk factors for Clostridium difficile infection in a hepatology ward. Infect Control Hosp Epidemiol. Feb. 2007;28(2):202-4. Not included study design. [pmid: 17265403].
819 Vasaly FW, Reines D. A quality committee's evaluation of surgical intervention for Clostridium difficile infection. AORN Journal. quiz 201-4. Aug. 2009;90(2):192-200. Not relevant to key questions. [pmid: 19736671].
820 Veillard E, Guggenbuhl P, Bello S, et al. Reactive oligoarthritis in a patient with Clostridium difficile pseudomembranous colitis. Review of the literature. Revue du Rhumatisme (English Edition). Dec. 1998;65(12):795-8. Not included study design.
821 Verdoorn BP, Orenstein R, Rosenblatt JE, et al. High prevalence of tcdC deletion-carrying Clostridium difficile and lack of association with disease severity. Diagnostic Microbiology & Infectious Disease. Jan. 2010;66(1):24-8. Not relevant to key questions. [pmid: 19775847].
822 Vermaat JH, Rosebrugh E, Ford-Jones EL, et al. An epidemiologic study of nosocomial infections in a pediatric long-term care facility. Am J Infect Control. Aug. 1993;21(4):183-8. Not on topic. [pmid: 8239048].
823 Vermaat JH, Rosebrugh E, Ford-Jones EL, et al. An epidemiologic study of nosocomial infections in a pediatric long-term care facility. Am J Infect Control. Aug. 1993;21(4):183-8. Duplicate listing. [pmid: 8239048].
824 Veroux M, Puzzo L, Corona D, et al. Cytomegalovirus and Clostridium difficile ischemic colitis in a renal transplant recipient: a lethal complication of anti-rejection therapy?. Urologia internationalis. discussion 180. 2007;79(2):177-9. Not included study design. [pmid: 17851290].
825 Vesoulis Z, Lozanski G, Loiudice T. Synchronous occurrence of collagenous colitis and pseudomembranous colitis. Can J Gastroenterol. Apr. 2000;14(4):353-8. Not included study design. [pmid: 10799091].
826 Vesoulis Z, Williams G, Matthews B. Pseudomembranous enteritis after proctocolectomy: report of a case. Dis Colon Rectum. Apr. 2000;43(4):551-4. Not included study design. [pmid: 10789757].
827 Vesta KS, Wells PG, Gentry CA, et al. Specific risk factors for Clostridium difficile-associated diarrhea: a prospective, multicenter, case control evaluation. Am J Infect Control. Oct. 2005;33(8):469-72. Duplicate listing. [pmid: 16216661].
828 Viscidi R, Laughon BE, Yolken R, et al. Serum antibody response to toxins A and B of Clostridium difficile. J Infect Dis. Jul. 1983;148(1):93-100. Not relevant to key questions. [pmid: 6886489].
829 Viswanath YK, Griffiths CD. The role of surgery in pseudomembranous enterocolitis. Postgrad Med J. Apr. 1998;74(870):216-9. Not included study design. [pmid: 9683974].
830 Viswanath YK, Griffiths CD. The role of surgery in pseudomembranous enterocolitis. Postgrad Med J. Apr. 1998;74(870):216-9. Duplicate listing. [pmid: 9683974].
831 von Konow L, Kondell PA, Nord CE, et al. Clindamycin versus phenoxymethylpenicillin in the treatment of acute orofacial infections. Eur J Clin Microbiol Infect Dis. Dec. 1992;11(12):1129-35. Not relevant to key questions. [pmid: 1291309].
832 Vonberg RP, Reichardt C, Behnke M, et al. Costs of nosocomial Clostridium difficile-associated diarrhoea. J Hosp Infect. Sep. 2008;70(1):15-20. Not relevant to key questions. [pmid: 18602185].
833 Walker KJ, Gilliland SS, Vance-Bryan K, et al. Clostridium difficile colonization in residents of long-term care facilities: prevalence and risk factors. Journal of the American Geriatrics Society. Sep. 1993;41(9):940-6. Not relevant to key questions. [pmid: 8104968].
834 Walker RC, Ruane PJ, Rosenblatt JE, et al. Comparison of culture, cytotoxicity assays, and enzyme-linked immunosorbent assay for toxin A and toxin B in the diagnosis of Clostridium difficile-related enteric disease. Diagnostic Microbiology & Infectious Disease. May. 1986;5(1):61-9. Not relevant to key questions. [pmid: 3086027].
835 Wall R, Klenerman L, McCullough C, et al. A comparison of teicoplanin and cefuroxime as prophylaxis for orthopaedic implant surgery: a preliminary report. J Antimicrob Chemother. Jan. 1988;21(Suppl A):141-6. Not on topic. [pmid: 2965126].
836 Walters BA, Roberts R, Stafford R, et al. Relapse of antibiotic associated colitis: endogenous persistence of Clostridium difficile during vancomycin therapy. Gut. Mar. 1983;24(3):206-12. Not relevant to key questions. [pmid: 6826104].
837 Wanahita A, Goldsmith EA, Marino BJ, et al. Clostridium difficile infection in patients with unexplained leukocytosis. Am J Med. Nov. 2003;115(7):543-6. Not relevant to key questions. [pmid: 14599633].
838 Wanahita A, Goldsmith EA, Musher DM. Conditions associated with leukocytosis in a tertiary care hospital, with particular attention to the role of infection caused by clostridium difficile. Clinic Infect Dis. Jun. 15. 2002;34(12):1585-92. Not relevant to key questions.
839 Wang A, Takeshima F, Ikeda M, et al. Ulcerative colitis complicating pseudomembranous colitis of the right colon. Journal of gastroenterology. 2002;37(4):309-12. Not included study design. [pmid: 11993517].
840 Warny M, Vaerman JP, Avesani V, et al. Human antibody response to Clostridium difficile toxin A in relation to clinical course of infection. Infect Immun. Feb. 1994;62(2):384-9. Not relevant to key questions. [pmid: 8300199].
841 Wasserman E, Hidalgo M, Hornedo J, et al. Octreotide (SMS 201-995) for hematopoietic support-dependent high-dose chemotherapy (HSD-HDC)-related diarrhoea: dose finding study and evaluation of efficacy. Bone marrow transplantation. Nov. 1997;20(9):711-4. Not on topic. [pmid: 9384471].
842 Watanakunakorn PW, Watanakunakorn C, Hazy J. Risk factors associated with Clostridium difficile diarrhea in hospitalized adult patients: a case-control study--sucralfate ingestion is not a negative risk factor. Infect Control Hosp Epidemiol. Apr. 1996;17(4):232-5. Not relevant to key questions. [pmid: 8935731].
843 Watson B, Ellis M, Mandal B, et al. A comparison of the clinico-pathological features with stool pathogens in patients hospitalised with the symptom of diarrhoea. Scand J Infect Dis. 1986;18(6):553-9. Not on topic. [pmid: 3810049].
844 Waywa D, Kongkriengdaj S, Chaidatch S, et al. Protozoan enteric infection in AIDS related diarrhea in Thailand. Southeast Asian Journal of Tropical Medicine & Public Health. 2001;32(Suppl 2):151-5. Not on topic. [pmid: 12041580].
845 Weber P, Koch M, Heizmann WR, et al. Microbic superinfection in relapse of inflammatory bowel disease. J Clin Gastroenterol. Jun. 1992;14(4):302-8. Not on topic. [pmid: 1607606].
846 Wei SC, Wong JM, Hsueh PR, et al. Diagnostic role of endoscopy, stool culture, and toxin A in Clostridium difficile-associated disease. Journal of the Formosan Medical Association. Nov. 1997;96(11):879-83. Not relevant to key questions. [pmid: 9409120].
847 Weiss B, Kleinkauf N, Eckmanns T, et al. Risk factors related to a hospital-associated cluster of Clostridium difficile PCR ribotype 027 infections in Germany During 2007. Infect Control Hosp Epidemiol. Mar. 2009;30(3):282-4. Duplicate listing. [pmid: 19215194].
848 Weiss B, Kleinkauf N, Eckmanns T, et al. Risk factors related to a hospital-associated cluster of Clostridium difficile PCR ribotype 027 infections in Germany During 2007. Infect Control Hosp Epidemiol. Mar. 2009;30(3):282-4. Not relevant to key questions. [pmid: 19215194].
849 Welkon CJ, Long SS, Thompson CM Jr, et al. Clostridium difficile in patients with cystic fibrosis. American Journal of Diseases of Children. Aug. 1985;139(8):805-8. Not included study design. [pmid: 4025261].
850 West M, Pirenne J, Chavers B, et al. Clostridium difficile colitis after kidney and kidney-pancreas transplantation. Clinical transplantation. Aug. 1999;13(4):318-23. Not relevant to key questions. [pmid: 10485373].
851 Whittier S, Shapiro DS, Kelly WF, et al. Evaluation of four commercially available enzyme immunoassays for laboratory diagnosis of Clostridium difficile-associated diseases. J Clin Microbiol. Nov. 1993;31(11):2861-5. Not relevant to key questions. [pmid: 8263168].
852 Wilcox CM, Gryboski D, Fernandez M, et al. Computed tomographic findings in pseudomembranous colitis: an important clue to the diagnosis. Southern medical journal. Sep. 1995;88(9):929-33. Not relevant to key questions. [pmid: 7660210].
853 Wilcox CM, Martin T, Phadnis M, et al. Absence of gastrointestinal infections in a cohort of patients with Zollinger-Ellison syndrome and other acid hypersecretors receiving long-term acid suppression with lansoprazole. BMC Gastroenterology. 2008;8:18. Not relevant to key questions. [pmid: 18507843].
854 Wilcox MH, Cunniffe JG, Trundle C, et al. Financial burden of hospital-acquired Clostridium difficile infection. J Hosp Infect. Sep. 1996;34(1):23-30. Not relevant to key questions. [pmid: 8880547].
855 Wilcox MH, Fawley WN, Settle CD, et al. Recurrence of symptoms in Clostridium difficile infection--relapse or reinfection?. [see comment]. J Hosp Infect. Feb. 1998;38(2):93-100. Not relevant to key questions. [pmid: 9522287].
856 Wilcox MH, Fawley WN, Wigglesworth N, et al. Comparison of the effect of detergent versus hypochlorite cleaning on environmental contamination and incidence of Clostridium difficile infection. J Hosp Infect. Jun. 2003;54(2):109-14. Not relevant to key questions. [pmid: 12818583].
857 Wilcox MH, Howe R. Diarrhoea caused by Clostridium difficile: response time for treatment with metronidazole and vancomycin. J Antimicrob Chemother. Oct. 1995;36(4):673-9. Not relevant to key questions. [pmid: 8591942].
858 Wilcox MH, Mooney L, Bendall R, et al. A case-control study of community-associated Clostridium difficile infection. J Antimicrob Chemother. Aug. 2008;62(2):388-96. Not relevant to key questions. [pmid: 18434341].
859 Wilcox MH, Smyth ET. Incidence and impact of Clostridium difficile infection in the UK, 1993-1996. J Hosp Infect. Jul. 1998;39(3):181-7. Not relevant to key questions. [pmid: 9699137].
860 Wilkinson IJ, Rich G, Moore B, et al. Relapse of antibiotic-associated colitis after vancomycin therapy. Medical Journal of Australia. Apr. 5. 1980;1(7):321-3. Not relevant to key questions. [pmid: 7393060].
861 Williams RN, Hemingway D, Miller AS. Enteral Clostridium difficile, an emerging cause for high-output ileostomy. Journal of Clinical Pathology. Oct. 2009;62(10):951-3. Not relevant to key questions. [pmid: 19447832].
862 Willingham FF, Ticona Chavez E, Taylor DN, et al. Diarrhea and Clostridium difficile infection in Latin American patients with AIDS. Working Group on AIDS in Peru. Clinic Infect Dis. Sep. 1998;27(3):487-93. Not relevant to key questions.
863 Wistrom J, Norrby SR, Myhre EB, et al. Frequency of antibiotic-associated diarrhoea in 2462 antibiotic-treated hospitalized patients: a prospective study. J Antimicrob Chemother. Jan. 2001;47(1):43-50. Not relevant to key questions. [pmid: 11152430].
864 Wolf PL, Kasyan A. Images in clinical medicine. Pseudomembranous colitis associated with Clostridium difficile. New England Journal of Medicine. Dec. 8. 2005;353(23):2491. Not included study design. [pmid: 16339097].
865 Wong AS, Lam CS, Tambyah PA. Fatal chemotherapy associated Clostridium difficile infection--a case report. Singapore medical journal. May. 2001;42(5):214-6. Not included study design. [pmid: 11513059].
866 Wong NA, Bathgate AJ, Bellamy CO. Colorectal disease in liver allograft recipients -- a clinicopathological study with follow-up. European journal of gastroenterology & hepatology. Mar. 2002;14(3):231-6. Not on topic. [pmid: 11953686].
867 Wong NA, Bathgate AJ, Bellamy CO. Colorectal disease in liver allograft recipients -- a clinicopathological study with follow-up. European journal of gastroenterology & hepatology. Mar. 2002;14(3):231-6. Duplicate listing. [pmid: 11953686].
868 Wongwanich S, Rugdeekha S, Pongpech P, et al. Detection of Clostridium difficile toxin A and B genes from stool samples of Thai diarrheal patients by polymerase chain reaction technique. Journal of the Medical Association of Thailand. Oct. 2003;86(10):970-5. Not relevant to key questions. [pmid: 14650710].
869 Woodford HJ, George J. Diagnosis and management of urinary tract infection in hospitalized older people. Journal of the American Geriatrics Society. Jan. 2009;57(1):107-14. Not relevant to key questions. [pmid: 19054190].
870 Woodhead M, Macfarlane J, Bts Cap, Guidelines C. Local antibiotic guidelines for adult community-acquired pneumonia (CAP): a survey of UK hospital practice in 1999. J Antimicrob Chemother. Jul. 2000;46(1):141-3. Not relevant to key questions. [pmid: 10882705].
871 Wren SM, Ahmed N, Jamal A, et al. Preoperative oral antibiotics in colorectal surgery increase the rate of Clostridium difficile colitis. Archives of Surgery. Aug. 2005;140(8):752-6. Not relevant to key questions. [pmid: 16103284].
872 Wright JM, Adams SP, Gribble MJ, et al. Clostridium difficile in Crohn's disease. Canadian Journal of Surgery. Sep. 1984;27(5):435-7. Not on topic.
873 Wright TW, Linscheid RL, O'Duffy JD. Acute flexor tenosynovitis in association with Clostridium difficile infection: a case report. Journal of Hand Surgery - American Volume. Mar. 1996;21(2):304-6. Not included study design.
874 Wright TW, Linscheid RL, O'Duffy JD. Acute flexor tenosynovitis in association with Clostridium difficile infection: a case report. Journal of Hand Surgery - American Volume. Mar. 1996;21(2):304-6. Duplicate listing.
875 Wu A. Spontaneous persistent pseudomembranous colitis related to Clostridium difficile in ischaemic bowel disease. BMJ Clinical Research Ed. May. 29. 1982;284(6329):1606-7. Not included study design. [pmid: 6805624].
876 Wullt M, Laurell MH. Low prevalence of nosocomial Clostridium difficile transmission, as determined by comparison of arbitrarily primed PCR and epidemiological data. J Hosp Infect. Dec. 1999;43(4):265-73. Not relevant to key questions. [pmid: 10658802].
877 Wullt M, Odenholt I. A double-blind randomized controlled trial of fusidic acid and metronidazole for treatment of an initial episode of Clostridium difficile-associated diarrhoea. J Antimicrob Chemother. Jul. 2004;54(1):211-6. Not included treatment type. [pmid: 15163651].
878 Yablon SA, Krotenberg R, Fruhmann K. Diarrhea in hospitalized patients. American Journal of Physical Medicine & Rehabilitation. Apr. 1992;71(2):102-7. Not relevant to key questions. [pmid: 1558730].
879 Yadav Y, Garey KW, Dao-Tran TK, et al. Automated system to identify Clostridium difficile infection among hospitalised patients. J Hosp Infect. Aug. 2009;72(4):337-41. Background. [pmid: 19596490].
880 Yahav J, Samra Z, Blau H, et al. Helicobacter pylori and Clostridium difficile in cystic fibrosis patients. Dig Dis Sci. Dec. 2006;51(12):2274-9. Not included study design. [pmid: 17078007].
881 Yamashita M, Nomura K, Fujimoto Y, et al. Length of vancomycin administration for treatment of clostridium difficile-associated diarrhea may depend on presentation of colonic ulcer. Hepato-gastroenterology. Mar-Apr. 2009;56(90):313-6. Not relevant to key questions. [pmid: 19579589].
882 Yamazawa K, Kanno H, Seki K, et al. Life-threatening Clostridium difficile-associated diarrhea induced by paclitaxel-carboplatin combination chemotherapy. Acta Obstetricia et Gynecologica Scandinavica. Aug. 2001;80(8):768-9. Not included study design. [pmid: 11531624].
883 Yangco BG, Sher G, Bardin MC. Nitazoxanide and probiotics for the treatment of recurrent Clostridium difficile infection in a peritoneal dialysis patient. Southern medical journal. Jul. 2009;102(7):746-7. Not included study design. [pmid: 19488013].
884 Yapar N, Sener A, Karaca B, et al. Antibiotic-associated diarrhea in a Turkish outpatient population: investigation of 288 cases. Journal of Chemotherapy. Feb. 2005;17(1):77-81. Not on topic. [pmid: 15828448].
885 Yapar N, Sener A, Karaca B, et al. Antibiotic-associated diarrhea in a Turkish outpatient population: investigation of 288 cases. Journal of Chemotherapy. Feb. 2005;17(1):77-81. Duplicate listing. [pmid: 15828448].
886 Yarinsky S, Wheeler WE. Inappropriate antibiotic use and the development of Clostridium difficile colitis. West Virginia Medical Journal. Jun. 1990;86(6):239-42. Not relevant to key questions. [pmid: 2363281].
887 Yip C, Loeb M, Salama S, et al. Quinolone use as a risk factor for nosocomial Clostridium difficile-associated diarrhea. Infect Control Hosp Epidemiol. Sep. 2001;22(9):572-5. Not relevant to key questions. [pmid: 11732787].
888 Yokohama S, Aoshima M, Asama T, et al. Clostridium difficile-associated enteric disease after percutaneous endoscopic gastrostomy. Journal of gastroenterology. 2009;44(2):121-5. Not relevant to key questions. [pmid: 19214673].
889 Yokohama S, Aoshima M, Nakade Y, et al. Investigation and prediction of enteral nutrition problems after percutaneous endoscopic gastrostomy. World Journal of Gastroenterology. Mar. 21. 2009;15(11):1367-72. Not on topic. [pmid: 19294767].
890 Yolken RH, Bishop CA, Townsend TR, et al. Infectious gastroenteritis in bone-marrow-transplant recipients. New England Journal of Medicine. Apr. 29. 1982;306(17):1010-2. Not on topic. [pmid: 7038501].
891 Young GP, Bayley N, Ward P, et al. Antibiotic-associated colitis caused by Clostridium difficile: relapse and risk factors. Medical Journal of Australia. Mar. 17. 1986;144(6):303-6. Not relevant to key questions. [pmid: 3520264].
892 Young KW, Munro IC, Taylor SL, et al. The safety of whey protein concentrate derived from the milk of cows immunized against Clostridium difficile. Regulatory Toxicology & Pharmacology. Apr. 2007;47(3):317-26. Not on topic. [pmid: 17293018].
893 Yousuf K, Saklayen MG, Markert RJ, et al. Clostridium difficile-associated diarrhea and chronic renal insufficiency. Southern medical journal. Jul. 2002;95(7):681-3. Not relevant to key questions. [pmid: 12144071].
894 Yuen KY, Woo PC, Liang RH, et al. Clinical significance of alimentary tract microbes in bone marrow transplant recipients. Diagnostic Microbiology & Infectious Disease. Feb. 1998;30(2):75-81. Not on topic. [pmid: 9554172].
895 Zabolotny B, Meterissian SH. Pseudomembranous colitis. Journal of the American College of Surgeons. Jul. 2005;201(1):142. Not included study design. [pmid: 15978456].
896 Zajac BA, Fisher MA, Gibson GA, et al. Safety and efficacy of high-dose treatment with imipenem-cilastatin in seriously ill patients. Antimicrob Agents Chemother. May. 1985;27(5):745-8. Not on topic. [pmid: 3860187].
897 Zar FA, Bakkanagari SR, Moorthi KM, et al. A comparison of vancomycin and metronidazole for the treatment of Clostridium difficile-associated diarrhea, stratified by disease severity. Clinic Infect Dis. Aug. 1. 2007;45(3):302-7. Duplicate listing.
898 Zerey M, Paton BL, Lincourt AE, et al. The burden of Clostridium difficile in surgical patients in the United States. Surgical Infections. Dec. 2007;8(6):557-66. Not relevant to key questions. [pmid: 18171114].
899 Zetola-Burneo N, Brown C. Cases from the Osler Medical Service at Johns Hopkins University. Am J Med. Feb. 1. 2004;116(3):198-200. Not included study design. [pmid: 14749166].
900 Zilberberg MD, Nathanson BH, Sadigov S, et al. Epidemiology and outcomes of clostridium difficile-associated disease among patients on prolonged acute mechanical ventilation. Chest. Sep. 2009;136(3):752-8. Not relevant to key questions. [pmid: 19465510].
901 Zilberberg MD, Shorr AF, Micek ST, et al. Clostridium difficile-associated disease and mortality among the elderly critically ill. Critical care medicine. Sep. 2009;37(9):2583-9. Not relevant to key questions. [pmid: 19623053].
902 Zimmerman RK. Risk factors for Clostridium difficile cytotoxin-positive diarrhea after control for horizontal transmission. Infect Control Hosp Epidemiol. Feb. 1991;12(2):96-100. Not relevant to key questions. [pmid: 2016508].
903 Zirakzadeh A, Gastineau DA, Mandrekar JN, et al. Vancomycin-resistant enterococcal colonization appears associated with increased mortality among allogeneic hematopoietic stem cell transplant recipients. Bone marrow transplantation. Feb. 2008;41(4):385-92. Not relevant to key questions. [pmid: 18084341].
904 Ziring D, Tran R, Edelstein S, et al. Infectious enteritis after intestinal transplantation: incidence, timing, and outcome. Transplantation. Mar. 27. 2005;79(6):702-9. Not on topic. [pmid: 15785377].
905 Zollner-Schwetz I, Hogenauer C, Joainig M, et al. Role of Klebsiella oxytoca in antibiotic-associated diarrhea. Clinic Infect Dis. Nov. 1. 2008;47(9):e74-8. Not on topic.

## Excluded References – C Difficile (Diagnostics Search)

1 Aas J, Gessert CE, Bakken JS. Recurrent Clostridium difficile colitis: case series involving 18 patients treated with donor stool administered via a nasogastric tube. Clinic Infect Dis. Mar. 1. 2003;36(5):580-5. Not relevant to key question.
2 Abrahao C, Carman RJ, Hahn H, et al. Similar frequency of detection of Clostridium perfringens enterotoxin and Clostridium difficile toxins in patients with antibiotic-associated diarrhea. Eur J Clin Microbiol Infect Dis. Sep. 2001;20(9):676-7. Not relevant to key question. [pmid: 11714055].
3 Aichinger E, Schleck CD, Harmsen WS, et al. Nonutility of repeat laboratory testing for detection of Clostridium difficile by use of PCR or enzyme immunoassay. J Clin Microbiol. Nov. 2008;46(11):3795-7. Not relevant to key question. [pmid: 18784320].
4 Aichinger E, Schleck CD, Harmsen WS, et al. Nonutility of repeat laboratory testing for detection of Clostridium difficile by use of PCR or enzyme immunoassay. J Clin Microbiol. Nov. 2008;46(11):3795-7. Not relevant to key question. [pmid: 18784320].
5 Akerlund T, Persson I, Unemo M, et al. Increased sporulation rate of epidemic Clostridium difficile Type 027/NAP1. J Clin Microbiol. Apr. 2008;46(4):1530-3. Not relevant to key question. [pmid: 18287318].
6 Akerlund T, Svenungsson B, Lagergren A, et al. Correlation of disease severity with fecal toxin levels in patients with Clostridium difficile-associated diarrhea and distribution of PCR ribotypes and toxin yields in vitro of corresponding isolates. J Clin Microbiol. Feb. 2006;44(2):353-8. Not relevant to key question. [pmid: 16455883].
7 Albright JB, Bonatti H, Mendez J, et al. Early and late onset Clostridium difficile-associated colitis following liver transplantation. Transplant International. Oct. 2007;20(10):856-66. Not relevant to key question. [pmid: 17854444].
8 Alestig K, Carlberg H, Nord CE, et al. Effect of cefoperazone on faecal flora. J Antimicrob Chemother. Aug. 1983;12(2):163-7. Not relevant to key question. [pmid: 6619054].
9 Alfa MJ, Kabani A, Lyerly D, et al. Characterization of a toxin A-negative, toxin B-positive strain of Clostridium difficile responsible for a nosocomial outbreak of Clostridium difficile-associated diarrhea. J Clin Microbiol. Jul. 2000;38(7):2706-14. Not relevant to key question. [pmid: 10878068].
10 Al-Nassir WN, Sethi AK, Nerandzic MM, et al. Comparison of clinical and microbiological response to treatment of Clostridium difficile-associated disease with metronidazole and vancomycin. Clinic Infect Dis. Jul. 1. 2008;47(1):56-62. Not relevant to key question.
11 Altaie SS, Meyer P, Dryja D. Comparison of two commercially available enzyme immunoassays for detection of Clostridium difficile in stool specimens. J Clin Microbiol. Jan. 1994;32(1):51-3. Not relevant to key question. [pmid: 8126205].
12 Andrews CN, Raboud J, Kassen BO, et al. Clostridium difficile-associated diarrhea: predictors of severity in patients presenting to the emergency department. Can J Gastroenterol. Jun. 2003;17(6):369-73. Not relevant to key question. [pmid: 12813602].
13 Ang P, Cheong WK, Khoo KS. Pseudomembranous colitis in a patient treated with paclitaxel for carcinoma of the breast: a case report. Ann Acad Med Singapore. Jan. 2000;29(1):132-4. Not relevant to key question. [pmid: 10748982].
14 Aronsson B, Barany P, Nord CE, et al. Clostridium difficile-associated diarrhoea in uremic patients. European J Clin Microbiol. Jun. 1987;6(3):352-6. Not relevant to key question. [pmid: 3622506].
15 Aronsson B, Granstrom M, Mollby R, et al. Serum antibody response to Clostridium difficile toxins in patients with Clostridium difficile diarrhoea. Infection. May-Jun. 1985;13(3):97-101. Not relevant to key question. [pmid: 4030111].
16 Aronsson B, Mollby R, Nord CE. Antimicrobial agents and Clostridium difficile in acute enteric disease: epidemiological data from Sweden, 1980-1982. J Infect Dis. Mar. 1985;151(3):476-81. Not relevant to key question. [pmid: 3973405].
17 Arslan H, Inci EK, Azap OK, et al. Etiologic agents of diarrhea in solid organ recipients. Transplant Infectious Disease. Dec. 2007;9(4):270-5. Not relevant to key question. [pmid: 17511817].
18 Arsura EL, Fazio RA, Wickremesinghe PC. Pseudomembranous colitis following prophylactic antibiotic use in primary cesarean section. American Journal of Obstetrics & Gynecology. Jan. 1. 1985;151(1):87-9. Not relevant to key question. [pmid: 3966512].
19 Asha NJ, Tompkins D, Wilcox MH. Comparative analysis of prevalence, risk factors, and molecular epidemiology of antibiotic-associated diarrhea due to Clostridium difficile, Clostridium perfringens, and Staphylococcus aureus. J Clin Microbiol. Aug. 2006;44(8):2785-91. Not relevant to key question. [pmid: 16891493].
20 Ayyagari A, Sharma P, Venkateswarlu, et al. Prevalence of Clostridium difficile in pseudomembranous and antibiotic-associated colitis in north India. Journal of diarrhoeal diseases research. Sep. 1986;4(3):157-60. Not relevant to key question. [pmid: 3584906].
21 Bacon AE 3rd, Fekety R. Immunoglobulin G directed against toxins A and B of Clostridium difficile in the general population and patients with antibiotic-associated diarrhea. Diagnostic Microbiology & Infectious Disease. Apr. 1994;18(4):205-9. Not relevant to key question. [pmid: 7924215].
22 Balamurugan R, Balaji V, Ramakrishna BS. Estimation of faecal carriage of Clostridium difficile in patients with ulcerative colitis using real time polymerase chain reaction. Indian Journal of Medical Research. May. 2008;127(5):472-7. Not relevant to key question. [pmid: 18653911].
23 Balassiano IT, Miranda KR, Boente RF, et al. Characterization of Clostridium difficile strains isolated from immunosuppressed inpatients in a hospital in Rio de Janeiro, Brazil. Anaerobe. Jun. 2009;15(3):61-4. Not relevant to key question. [pmid: 19154793].
24 Barany P, Stenvinkel P, Nord CE, et al. Clostridium difficile infection--a poor prognostic sign in uremic patients?. Clinical nephrology. Jul. 1992;38(1):53-7. Not relevant to key question. [pmid: 1499170].
25 Barbut F, Beaugerie L, Delas N, et al. Comparative value of colonic biopsy and intraluminal fluid culture for diagnosis of bacterial acute colitis in immunocompetent patients. Infectious Colitis Study Group Clinic Infect Dis. Aug. 1999;29(2):356-60. Not relevant to key question.
26 Barbut F, Corthier G, Charpak Y, et al. Prevalence and pathogenicity of Clostridium difficile in hospitalized patients. A French multicenter study. Arch Intern Med. Jul. 8. 1996;156(13):1449-54. Not relevant to key question. [pmid: 8678714].
27 Barbut F, Decre D, Lalande V, et al. Clinical features of Clostridium difficile-associated diarrhoea due to binary toxin (actin-specific ADP-ribosyltransferase)-producing strains. Journal of medical microbiology. Feb. 2005;54(Pt 2):181-5. Not relevant to key question. [pmid: 15673514].
28 Barbut F, Gariazzo B, Bonne L, et al. Clinical features of Clostridium difficile-associated infections and molecular characterization of strains: results of a retrospective study, 2000-2004. Infect Control Hosp Epidemiol. Feb. 2007;28(2):131-9. Not relevant to key question. [pmid: 17265393].
29 Barbut F, Lalande V, Burghoffer B, et al. Prevalence and genetic characterization of toxin A variant strains of Clostridium difficile among adults and children with diarrhea in France. J Clin Microbiol. Jun. 2002;40(6):2079-83. Not relevant to key question. [pmid: 12037068].
30 Barbut F, Leluan P, Antoniotti G, et al. Value of routine stool cultures in hospitalized patients with diarrhea. Eur J Clin Microbiol Infect Dis. Apr. 1995;14(4):346-9. Not relevant to key question. [pmid: 7649200].
31 Barbut F, Meynard JL, Guiguet M, et al. Clostridium difficile-associated diarrhea in HIV-infected patients: epidemiology and risk factors. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. Nov. 1. 1997;16(3):176-81. Not relevant to key question. [pmid: 9390569].
32 Barbut F, Richard A, Hamadi K, et al. Epidemiology of recurrences or reinfections of Clostridium difficile-associated diarrhea. J Clin Microbiol. Jun. 2000;38(6):2386-8. Not relevant to key question. [pmid: 10835010].
33 Barbut F, Mastrantonio P, Delmée M, et al. Prospective study of Clostridium difficile infections in Europe with phenotypic and genotypic characterisation of the isolates. Clinical Microbiology & Infection. Nov. 2007;13(11):1048-57. Not relevant to key question. [pmid: 17850341].
34 Bartlett JG, Gerding DN. Clinical recognition and diagnosis of Clostridium difficile infection. Clinic Infect Dis. Jan. 15. 2008;46(Suppl 1):S12-8. Not relevant to key question.
35 Bate G. Comparison of Minitek Anaerobe II, API An-Ident, and RapID ANA systems for identification of Clostridium difficile. American Journal of Clinical Pathology. Jun. 1986;85(6):716-8. Not relevant to key question. [pmid: 3518405].
36 Bauer TM, Lalvani A, Fehrenbach J, et al. Derivation and validation of guidelines for stool cultures for enteropathogenic bacteria other than Clostridium difficile in hospitalized adults. JAMA. Jan. 17. 2001;285(3):313-9. Not relevant to key question. [pmid: 11176841].
37 Bender BS, Bennett R, Laughon BE, et al. Is Clostridium difficile endemic in chronic-care facilities?. Lancet. Jul. 5. 1986;2(8497):11-3. Not relevant to key question. [pmid: 2873315].
38 Bennett GC, Allen E, Millard PH. Clostridium difficile diarrhoea: a highly infectious organism. Age Ageing. Nov. 1984;13(6):363-6. Not relevant to key question. [pmid: 6516973].
39 Bennett RG, Greenough WB 3rd. C difficile diarrhea: a common--and overlooked--nursing home infection. Geriatrics. Sep. 1990;45(9):83-7. 77. 8. Not relevant to key question.
40 Bennett RG, Laughon BE, Mundy LM, et al. Evaluation of a latex agglutination test for Clostridium difficile in two nursing home outbreaks. J Clin Microbiol. May. 1989;27(5):889-93. Not relevant to key question. [pmid: 2745696].
41 Benno Y, Shiragami N, Uchida K, et al. Effect of moxalactam on human fecal microflora. Antimicrob Agents Chemother. Jan. 1986;29(1):175-8. Not relevant to key question. [pmid: 3729329].
42 Bergan T, Delin C, Johansen S, et al. Pharmacokinetics of ciprofloxacin and effect of repeated dosage on salivary and fecal microflora. Antimicrob Agents Chemother. Feb. 1986;29(2):298-302. Not relevant to key question. [pmid: 2940965].
43 Berman L, Carling T, Fitzgerald TN, et al. Defining surgical therapy for pseudomembranous colitis with toxic megacolon. J Clin Gastroenterol. May-Jun. 2008;42(5):476-80. Not relevant to key question. [pmid: 18277885].
44 Binkovitz LA, Allen E, Bloom D, et al. Atypical presentation of Clostridium difficile colitis in patients with cystic fibrosis. AJR.American Journal of Roentgenology. Feb. 1999;172(2):517-21. Not relevant to key question. [pmid: 9930816].
45 Bishara J, Bloch Y, Garty M, et al. Antimicrobial resistance of Clostridium difficile isolates in a tertiary medical center, Israel. Diagnostic Microbiology & Infectious Disease. Feb. 2006;54(2):141-4. Not relevant to key question. [pmid: 16406180].
46 Bishara J, Peled N, Pitlik S, et al. Mortality of patients with antibiotic-associated diarrhoea: the impact of Clostridium difficile. J Hosp Infect. Apr. 2008;68(4):308-14. Not relevant to key question. [pmid: 18353491].
47 Bishara J, Peled N, Pitlik S, et al. Mortality of patients with antibiotic-associated diarrhoea: the impact of Clostridium difficile. J Hosp Infect. Apr. 2008;68(4):308-14. Not relevant to key question. [pmid: 18353491].
48 Bliss DZ, Johnson S, Savik K, et al. Fecal incontinence in hospitalized patients who are acutely ill. Nursing research. Mar-Apr. 2000;49(2):101-8. Not relevant to key question. [pmid: 10768587].
49 Bloedt K, Riecker M, Poppert S, et al. Evaluation of new selective culture media and a rapid fluorescence in situ hybridization assay for identification of Clostridium difficile from stool samples. Journal of medical microbiology. Jul. 2009;58(Pt 7):874-7. Not relevant to key question. [pmid: 19502365].
50 Blot E, Escande MC, Besson D, et al. Outbreak of Clostridium difficile-related diarrhoea in an adult oncology unit: risk factors and microbiological characteristics. J Hosp Infect. Mar. 2003;53(3):187-92. Not relevant to key question. [pmid: 12623319].
51 Blum RN, Berry CD, Phillips MG, et al. Clinical illnesses associated with isolation of dysgonic fermenter 3 from stool samples. J Clin Microbiol. Feb. 1992;30(2):396-400. Not relevant to key question. [pmid: 1537908].
52 Bobulsky GS, Al-Nassir WN, Riggs MM, et al. Clostridium difficile skin contamination in patients with C. difficile-associated disease. Clinic Infect Dis. Feb. 1. 2008;46(3):447-50. Not relevant to key question.
53 Boland GW, Lee MJ, Cats AM, et al. Antibiotic-induced diarrhea: specificity of abdominal CT for the diagnosis of Clostridium difficile disease. Radiology. Apr. 1994;191(1):103-6. Not relevant to key question. [pmid: 8134552].
54 Bolton RP, Culshaw MA. Faecal metronidazole concentrations during oral and intravenous therapy for antibiotic associated colitis due to Clostridium difficile. Gut. Oct. 1986;27(10):1169-72. Not relevant to key question. [pmid: 3781329].
55 Bolton RP, Thomas DF. Pseudomembranous colitis in children and adults. British J Hosp Med. Jan. 1986;35(1):37-42. Not relevant to key question.
56 Bond F, Payne G, Borriello SP, et al. Usefulness of culture in the diagnosis of Clostridium difficile infection. Eur J Clin Microbiol Infect Dis. Mar. 1995;14(3):223-6. Not relevant to key question. [pmid: 7614964].
57 Borody TJ, Warren EF, Leis S, et al. Treatment of ulcerative colitis using fecal bacteriotherapy. J Clin Gastroenterol. Jul. 2003;37(1):42-7. Not relevant to key question. [pmid: 12811208].
58 Borriello SP, Barclay FE. Protection of hamsters against Clostridium difficile ileocaecitis by prior colonisation with non-pathogenic strains. Journal of medical microbiology. Jun. 1985;19(3):339-50. Not relevant to key question. [pmid: 4009689].
59 Borriello SP, Barclay FE. An in-vitro model of colonisation resistance to Clostridium difficile infection. Journal of medical microbiology. Jun. 1986;21(4):299-309. Not relevant to key question. [pmid: 3723582].
60 Borriello SP, Honour P. Concomitance of cytotoxigenic and non-cytotoxigenic Clostridium difficile in stool specimens. J Clin Microbiol. Oct. 1983;18(4):1006-7. Not relevant to key question. [pmid: 6630455].
61 Bouza E, Burillo A, Munoz P. Antimicrobial therapy of Clostridium difficile-associated diarrhea. Medical Clinics of North America. Nov. 2006;90(6):1141-63. Not relevant to key question. [pmid: 17116441].
62 Bowen KE, McFarland LV, Greenberg RN, et al. Isolation of Clostridium difficile at a university hospital: a two-year study. Clinic Infect Dis. Jun. 1995;20(Suppl 2):S261-2. Not relevant to key question.
63 Brazier JS, Borriello SP. Microbiology, epidemiology and diagnosis of Clostridium difficile infection. Current Topics in Microbiology & Immunology. 2000;250:1-33. Not relevant to key question. [pmid: 10981355].
64 Brettle RP, Poxton IR, Murdoch JM, et al. Clostridium difficile in association with sporadic diarrhoea. BMJ Clinical Research Ed. Jan. 23. 1982;284(6311):230-3. Not relevant to key question. [pmid: 6799113].
65 Brettle RP, Wallace E. Clostridium difficile-associated diarrhoea. Journal of Infection. Mar. 1984;8(2):123-8. Not relevant to key question. [pmid: 6725965].
66 Bricker E, Garg R, Nelson R, et al. Antibiotic treatment for Clostridium difficile-associated diarrhea in adults. [update in Cochrane Database Syst Rev. 2007;(3):CD004610; PMID:17636768]. Cochrane Database Syst Rev. 2005;(1):004610. Not relevant to key question.
67 Briggs S, Upton A, Bilkey M, et al. Vancomycin-resistant enterococcal colonisation of hospitalised patients in Auckland. New Zealand Medical Journal. Aug. 23. 2002;115(1160):U145. Not relevant to key question. [pmid: 12362202].
68 Brinson RR, Curtis WD, Singh M. Diarrhea in the intensive care unit: the role of hypoalbuminemia and the response to a chemically defined diet (case reports and review of the literature). Journal of the American College of Nutrition. Dec. 1987;6(6):517-23. Not relevant to key question. [pmid: 3121713].
69 Brismar B, Edlund C, Nord CE. Effect of ceftibuten on the normal intestinal microflora. Infection. Nov-Dec. 1993;21(6):373-5. Not relevant to key question. [pmid: 8132366].
70 Brismar B, Edlund C, Nord CE. Impact of cefpodoxime proxetil and amoxicillin on the normal oral and intestinal microflora. Eur J Clin Microbiol Infect Dis. Sep. 1993;12(9):714-9. Not relevant to key question. [pmid: 8243490].
71 Brooks JB, Nunez-Montiel OL, Basta MT, et al. Studies of stools from pseudomembranous colitis, rotaviral, and other diarrheal syndromes by frequency-pulsed electron capture gas-liquid chromatography. J Clin Microbiol. Sep. 1984;20(3):549-60. Not relevant to key question. [pmid: 6490836].
72 Bruce D, Ritchie C, Jennings LC, et al. Clostridium difficile-associated colitis: cross infection in predisposed patients with renal failure. New Zealand Medical Journal. Apr. 28. 1982;95(706):265-7. Not relevant to key question. [pmid: 6953368].
73 Burke DA, Axon AT. Clostridium difficile, sulphasalazine, and ulcerative colitis. Postgrad Med J. Nov. 1987;63(745):955-7. Not relevant to key question. [pmid: 2897683].
74 Burke DA, Axon AT. Clostridium difficile, sulphasalazine, and ulcerative colitis. Postgrad Med J. Nov. 1987;63(745):955-7. Not relevant to key question. [pmid: 2897683].
75 Byrn JC, Maun DC, Gingold DS, et al. Predictors of mortality after colectomy for fulminant Clostridium difficile colitis. Archives of Surgery. discussion 155. Feb. 2008;143(2):150-4. Not relevant to key question. [pmid: 18283139].
76 Calame W, Weseler AR, Viebke C, et al. Gum arabic establishes prebiotic functionality in healthy human volunteers in a dose-dependent manner. British Journal of Nutrition. Dec. 2008;100(6):1269-75. Not relevant to key question. [pmid: 18466655].
77 Calame W, Weseler AR, Viebke C, et al. Gum arabic establishes prebiotic functionality in healthy human volunteers in a dose-dependent manner. British Journal of Nutrition. Dec. 2008;100(6):1269-75. Not relevant to key question. [pmid: 18466655].
78 Campbell RR, Beere D, Wilcock GK, et al. Clostridium difficile in acute and long-stay elderly patients. Age Ageing. Sep. 1988;17(5):333-6. Not relevant to key question. [pmid: 3232587].
79 Can M, Besirbellioglu BA, Avci IY, et al. Prophylactic Saccharomyces boulardii in the prevention of antibiotic-associated diarrhea: a prospective study. Medical Science Monitor. Apr. 2006;12(4):P19-22. Not relevant to key question.
80 Carmeli Y, Venkataraman L, DeGirolami PC, et al. Stool colonization of healthcare workers with selected resistant bacteria. Infect Control Hosp Epidemiol. Jan. 1998;19(1):38-40. Not relevant to key question. [pmid: 9475348].
81 Cartmill TD, Shrimpton SB, Panigrahi H, et al. Nosocomial diarrhoea due to a single strain of Clostridium difficile: a prolonged outbreak in elderly patients. Age Ageing. Jul. 1992;21(4):245-9. Not relevant to key question. [pmid: 1514452].
82 Cascinu S, Catalano G. Have enteric infections a role in 5-fluorouracil-associated diarrhea?. Supportive Care in Cancer. Sep. 1995;3(5):322-3. Not relevant to key question. [pmid: 8520881].
83 Cefai C, Elliott TS, Woodhouse KW. Gastrointestinal carriage rate of Clostridium difficile in elderly, chronic care hospital patients. J Hosp Infect. May. 1988;11(4):335-9. Not relevant to key question. [pmid: 2899585].
84 Chachaty E, Bourneix C, Renard S, et al. Shedding of Clostridium difficile, fecal beta-lactamase activity, and gastrointestinal symptoms in 51 volunteers treated with oral cefixime. Antimicrob Agents Chemother. Jul. 1993;37(7):1432-5. Not relevant to key question. [pmid: 8363371].
85 Chachaty E, Depitre C, Mario N, et al. Presence of Clostridium difficile and antibiotic and beta-lactamase activities in feces of volunteers treated with oral cefixime, oral cefpodoxime proxetil, or placebo. Antimicrob Agents Chemother. Sep. 1992;36(9):2009-13. Not relevant to key question. [pmid: 1416894].
86 Chancellor AM, Ellis-Pegler RB. A clinical and aetiological study of adult patients hospitalised for acute diarrhoeal disease. New Zealand Medical Journal. Mar. 10. 1982;95(703):154-6. Not relevant to key question. [pmid: 6952128].
87 Chang TW, Gorbach SL, Bartlett JG, et al. Bacitracin treatment of antibiotic-associated colitis and diarrhea caused by Clostridium difficile toxin. Gastroenterol. Jun. 1980;78(6):1584-6. Not relevant to key question.
88 Chaudhry R, Joshy L, Kumar L, et al. Changing pattern of Clostridium difficile associated diarrhoea in a tertiary care hospital: a 5 year retrospective study. Indian Journal of Medical Research. Apr. 2008;127(4):377-82. Not relevant to key question. [pmid: 18577793].
89 Cheng SH, Lu JJ, Young TG, et al. Clostridium difficile--associated diseases: comparison of symptomatic infection versus carriage on the basis of risk factors, toxin production, and genotyping results. Clinic Infect Dis. Jul. 1997;25(1):157-8. Not relevant to key question.
90 Cherifi S, Delmee M, Van Broeck J, et al. Management of an outbreak of Clostridium difficile-associated disease among geriatric patients. Infect Control Hosp Epidemiol. Nov. 2006;27(11):1200-5. Not relevant to key question. [pmid: 17080377].
91 Chezmar JL, Nelson RC, Bernardino ME. Portal venous gas after hepatic transplantation: sonographic detection and clinical significance. AJR.American Journal of Roentgenology. Dec. 1989;153(6):1203-5. Not relevant to key question. [pmid: 2683676].
92 Church JM, Fazio VW. The significance of quantitative results of C. difficile cultures and toxin assays in patients with diarrhea. Dis Colon Rectum. Nov. 1985;28(11):765-9. Not relevant to key question. [pmid: 3902411].
93 Church JM, Fazio VW. A role for colonic stasis in the pathogenesis of disease related to Clostridium difficile. Dis Colon Rectum. Dec. 1986;29(12):804-9. Not relevant to key question. [pmid: 3792161].
94 Churchill DR, Lucas SB, Williams I, et al. Recurrent pseudomembranous colitis due to Clostridium difficile in AIDS. Genitourinary medicine. Feb. 1994;70(1):51-5. Not relevant to key question. [pmid: 8300102].
95 Clarke HJ, Jinnah RH, Byank RP, et al. Clostridium difficile infection in orthopaedic patients. Journal of Bone & Joint Surgery - American Volume. Aug. 1990;72(7):1056-9. Not relevant to key question.
96 Cloud J, Noddin L, Pressman A, et al. Clostridium difficile strain NAP-1 is not associated with severe disease in a nonepidemic setting. Clin Gastroenterol Hepatol. Aug. 2009;7(8):868-73.e2. Not relevant to key question. [pmid: 19465153].
97 Cohen SH, Tang YJ, Hansen B, et al. Isolation of a toxin B-deficient mutant strain of Clostridium difficile in a case of recurrent C. difficile-associated diarrhea. Clinic Infect Dis. Feb. 1998;26(2):410-2. Not relevant to key question.
98 Coignard B, Barbut F, Blanckaert K, et al. Emergence of Clostridium difficile toxinotype III, PCR-ribotype 027-associated disease, France, 2006. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2006;11(9):E060914.1. Not relevant to key question. [pmid: 17075146].
99 Cooper GS, Lederman MM, Salata RA. A predictive model to identify Clostridium difficile toxin in hospitalized patients with diarrhea. Am J Gastroenterol. Jan. 1996;91(1):80-4. Background. [pmid: 8561149].
100 Corrado OJ, Mascie-Taylor BH, Hall MJ, et al. Prevalence of Clostridium difficile on a mixed-function ward for the elderly. Journal of Infection. Nov. 1990;21(3):287-92. Not relevant to key question. [pmid: 2273275].
101 Corthier G, Dubos F, Raibaud P. Modulation of cytotoxin production by Clostridium difficile in the intestinal tracts of gnotobiotic mice inoculated with various human intestinal bacteria. Applied & Environmental Microbiology. Jan. 1985;49(1):250-2. Not relevant to key question. [pmid: 3977313].
102 Crogan NL, Evans BC. Clostridium difficile: an emerging epidemic in nursing homes. Geriatric nursing. May-Jun. 2007;28(3):161-4. Not relevant to key question. [pmid: 17642100].
103 Cunney RJ, Magee C, McNamara E, et al. Clostridium difficile colitis associated with chronic renal failure. Nephrology Dialysis Transplantation. Nov. 1998;13(11):2842-6. Not relevant to key question.
104 Cuzzolin L, Zambreri D, Donini M, et al. Influence of radiotherapy on intestinal microflora in cancer patients. Journal of Chemotherapy. Jun. 1992;4(3):176-9. Not relevant to key question. [pmid: 1517812].
105 Cuzzolin L, Zambreri D, Donini M, et al. Influence of radiotherapy on intestinal microflora in cancer patients. Journal of Chemotherapy. Jun. 1992;4(3):176-9. Not relevant to key question. [pmid: 1517812].
106 Danna PL, Urban C, Bellin E, et al. Role of candida in pathogenesis of antibiotic-associated diarrhoea in elderly inpatients. Lancet. Mar. 2. 1991;337(8740):511-4. Not relevant to key question. [pmid: 1671890].
107 Dansinger ML, Johnson S, Jansen PC, et al. Protein-losing enteropathy is associated with Clostridium difficile diarrhea but not with asymptomatic colonization: a prospective, case-control study. Clinic Infect Dis. Jun. 1996;22(6):932-7. Not relevant to key question.
108 Daw NC, Santana VM, Iacono LC, et al. Phase I and pharmacokinetic study of topotecan administered orally once daily for 5 days for 2 consecutive weeks to pediatric patients with refractory solid tumors. Journal of Clinical Oncology. Mar. 1. 2004;22(5):829-37. Not relevant to key question. [pmid: 14990638].
109 De La Cochetiere MF, Durand T, Lalande V, et al. Effect of antibiotic therapy on human fecal microbiota and the relation to the development of Clostridium difficile. Microbial ecology. Oct. 2008;56(3):395-402. Not relevant to key question. [pmid: 18209965].
110 de Lalla F, Nicolin R, Rinaldi E, et al. Prospective study of oral teicoplanin versus oral vancomycin for therapy of pseudomembranous colitis and Clostridium difficile-associated diarrhea. Antimicrob Agents Chemother. Oct. 1992;36(10):2192-6. Not relevant to key question. [pmid: 1444298].
111 Debast SB, Vaessen N, Choudry A, et al. Successful combat of an outbreak due to Clostridium difficile PCR ribotype 027 and recognition of specific risk factors. Clinical Microbiology & Infection. May. 2009;15(5):427-34. Not relevant to key question. [pmid: 19416295].
112 Delmee M, Ramboer I, Van Broeck J, et al. Epidemiology of Clostridium difficile toxinotype III, PCR-ribotype 027 associated disease in Belgium, 2006. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2006;11(9):E060914.2. Not relevant to key question. [pmid: 17075147].
113 Depitre C, Avesani V, Delmee M, et al. Detection of Clostridium difficile toxins in stools. Comparison between a new enzyme immunoassay for toxin A and other routine tests. Gastroenterologie clinique et biologique. 1993;17(4):283-6. Not relevant to key question. [pmid: 8339887].
114 Dhawan B, Chaudhry R, Sharma N. Incidence of Clostridium difficile infection: a prospective study in an Indian hospital. J Hosp Infect. Dec. 1999;43(4):275-80. Not relevant to key question. [pmid: 10658803].
115 Dickinson RJ, Rampling A, Wight DG. Spontaneous pseudomembranous colitis not associated with Clostridium difficile. Journal of Infection. May. 1985;10(3):252-5. Not relevant to key question. [pmid: 4031517].
116 Djuretic T, Wall PG, Brazier JS. Clostridium difficile: an update on its epidemiology and role in hospital outbreaks in England and Wales. J Hosp Infect. Mar. 1999;41(3):213-8. Not relevant to key question. [pmid: 10204123].
117 Dorman SA, Liggoria E, Winn WC Jr, et al. Isolation of Clostridium difficile from patients with inactive Crohn's disease. Gastroenterol. Jun. 1982;82(6):1348-51. Not relevant to key question.
118 Drees M, Snydman DR, O'Sullivan CE. Repeated enzyme immunoassays have limited utility in diagnosing Clostridium difficile. Eur J Clin Microbiol Infect Dis. May. 2008;27(5):397-9. Not relevant to key question. [pmid: 18189148].
119 Drudy D, Harnedy N, Fanning S, et al. Emergence and control of fluoroquinolone-resistant, toxin A-negative, toxin B-positive Clostridium difficile. Infect Control Hosp Epidemiol. Aug. 2007;28(8):932-40. Not relevant to key question. [pmid: 17620240].
120 Dubberke ER, Reske KA, McDonald LC, et al. ICD-9 codes and surveillance for Clostridium difficile-associated disease. Emerging Infectious Diseases. Oct. 2006;12(10):1576-9. Not relevant to key question. [pmid: 17176576].
121 Dudley MN, McLaughlin JC, Carrington G, et al. Oral bacitracin vs vancomycin therapy for Clostridium difficile-induced diarrhea. A randomized double-blind trial. Arch Intern Med. Jun. 1986;146(6):1101-4. Not relevant to key question. [pmid: 3521518].
122 Edlund C, Alvan G, Barkholt L, et al. Pharmacokinetics and comparative effects of telithromycin (HMR 3647) and clarithromycin on the oropharyngeal and intestinal microflora. J Antimicrob Chemother. Nov. 2000;46(5):741-9. Not relevant to key question. [pmid: 11062193].
123 Edlund C, Stark C, Nord CE. The relationship between an increase in beta-lactamase activity after oral administration of three new cephalosporins and protection against intestinal ecological disturbances. J Antimicrob Chemother. Jul. 1994;34(1):127-38. Not relevant to key question. [pmid: 7961199].
124 Eidhin DN, Ryan AW, Doyle RM, et al. Sequence and phylogenetic analysis of the gene for surface layer protein, slpA, from 14 PCR ribotypes of Clostridium difficile. Journal of medical microbiology. Jan. 2006;55(Pt 1):69-83. Not relevant to key question. [pmid: 16388033].
125 Elinav E, Planer D, Gatt ME. Prolonged ileus as a sole manifestation of pseudomembranous enterocolitis. International journal of colorectal disease. May. 2004;19(3):273-6. Not relevant to key question. [pmid: 14618347].
126 Elvy J, Riordan T, Sarsfield P, et al. A diarrhoeal illness with a difference?. BMJ. 2009;339:b2648. Not relevant to key question. [pmid: 19620222].
127 Enocksson A, Lundberg J, Weitzberg E, et al. Rectal nitric oxide gas and stool cytokine levels during the course of infectious gastroenteritis. Clinical & Diagnostic Laboratory Immunology. Mar. 2004;11(2):250-4. Not relevant to key question. [pmid: 15013971].
128 Enzensberger R, Shah PM, Knothe H. Impact of oral ciprofloxacin on the faecal flora of healthy volunteers. Infection. Nov-Dec. 1985;13(6):273-5. Not relevant to key question. [pmid: 2934338].
129 Ergen EK, Akalin H, Yilmaz E, et al. Nosocomial diarrhea and Clostridium Difficile associated diarrhea in a Turkish University Hospital. Medecine et Maladies Infectieuses. Jun. 2009;39(6):382-7. Not relevant to key question. [pmid: 19269761].
130 Falsen E, Kaijser B, Nehls L, et al. Clostridium difficile in relation to enteric bacterial pathogens. J Clin Microbiol. Sep. 1980;12(3):297-300. Not relevant to key question. [pmid: 7217331].
131 Fan YJ, Chen SJ, Yu YC, et al. A probiotic treatment containing Lactobacillus, Bifidobacterium and Enterococcus improves IBS symptoms in an open label trial. Journal of Zhejiang University.Science.B. Dec. 2006;7(12):987-91. Not relevant to key question. [pmid: 17111468].
132 Fawley WN, Parnell P, Verity P, et al. Molecular epidemiology of endemic Clostridium difficile infection and the significance of subtypes of the United Kingdom epidemic strain (PCR ribotype 1). J Clin Microbiol. Jun. 2005;43(6):2685-96. Not relevant to key question. [pmid: 15956384].
133 Fawley WN, Wilcox MH. Molecular epidemiology of endemic Clostridium difficile infection. Epidemiology & Infection. Jun. 2001;126(3):343-50. Not relevant to key question. [pmid: 11467790].
134 Fekety R, McFarland LV, Surawicz CM, et al. Recurrent Clostridium difficile diarrhea: characteristics of and risk factors for patients enrolled in a prospective, randomized, double-blinded trial. Clinic Infect Dis. Mar. 1997;24(3):324-33. Not relevant to key question.
135 Feldman RJ, Kallich M, Weinstein MP. Bacteremia due to Clostridium difficile: case report and review of extraintestinal C. difficile infections. Clinic Infect Dis. Jun. 1995;20(6):1560-2. Not relevant to key question.
136 Fenner L, Frei R, Gregory M, et al. Epidemiology of Clostridium difficile-associated disease at University Hospital Basel including molecular characterisation of the isolates 2006-2007. Eur J Clin Microbiol Infect Dis. Dec. 2008;27(12):1201-7. Not relevant to key question. [pmid: 18560909].
137 Fenner L, Widmer AF, Goy G, et al. Rapid and reliable diagnostic algorithm for detection of Clostridium difficile. J Clin Microbiol. Jan. 2008;46(1):328-30. Background. [pmid: 18032627].
138 Ferroni A, Merckx J, Ancelle T, et al. Nosocomial outbreak of Clostridium difficile diarrhea in a pediatric service. Eur J Clin Microbiol Infect Dis. Dec. 1997;16(12):928-33. Not relevant to key question. [pmid: 9495676].
139 Fille M, Larcher C, Dierich MP, et al. Evaluation of four methods for detection of Clostridium difficile or C. difficile toxin: cytotoxin assay, culture, latex agglutination, and a new rapid immunoassay (C. difficile toxin A test). Zeitschrift fur Gastroenterologie. Feb. 1998;36(2):143-9. Not relevant to key question. [pmid: 9544497].
140 Finegold SM. Clinical considerations in the diagnosis of antimicrobial agent-associated gastroenteritis. Diagnostic Microbiology & Infectious Disease. Mar. 1986;4(3 Suppl):87S-91S. Not relevant to key question. [pmid: 3698542].
141 Forward LJ, Tompkins DS, Brett MM. Detection of Clostridium difficile cytotoxin and Clostridium perfringens enterotoxin in cases of diarrhoea in the community. Journal of medical microbiology. Sep. 2003;52(Pt 9):753-7. Not relevant to key question. [pmid: 12909650].
142 Foulke GE, Silva J Jr. Clostridium difficile in the intensive care unit: management problems and prevention issues. Critical care medicine. Aug. 1989;17(8):822-6. Not relevant to key question. [pmid: 2752778].
143 Freeman J, Baines SD, Saxton K, et al. Effect of metronidazole on growth and toxin production by epidemic Clostridium difficile PCR ribotypes 001 and 027 in a human gut model. J Antimicrob Chemother. Jul. 2007;60(1):83-91. Not relevant to key question. [pmid: 17483547].
144 Freeman J, Wilcox MH. The effects of storage conditions on viability of Clostridium difficile vegetative cells and spores and toxin activity in human faeces. Journal of clinical pathology. Feb. 2003;56(2):126-8. Not relevant to key question. [pmid: 12560391].
145 Frenz MB, McIntyre AS. Reducing delays in the diagnosis and treatment of Clostridium difficile diarrhoea. QJM. Aug. 2003;96(8):579-82. Not relevant to key question. [pmid: 12897343].
146 Garbutt JM, Littenberg B, Evanoff BA, et al. Enteric carriage of vancomycin-resistant Enterococcus faecium in patients tested for Clostridium difficile. Infect Control Hosp Epidemiol. Oct. 1999;20(10):664-70. Not relevant to key question. [pmid: 10530643].
147 Garcia C, Samalvides F, Vidal M, et al. Epidemiology of Clostridium difficile-associated diarrhea in a Peruvian tertiary care hospital. American Journal of Tropical Medicine & Hygiene. Nov. 2007;77(5):802-5. Not relevant to key question. [pmid: 17984329].
148 Garner CE, Smith S, de Lacy Costello B, et al. Volatile organic compounds from feces and their potential for diagnosis of gastrointestinal disease. FASEB Journal. Jun. 2007;21(8):1675-88. Not relevant to key question. [pmid: 17314143].
149 Gebhard RL, Gerding DN, Olson MM, et al. Clinical and endoscopic findings in patients early in the course of clostridium difficile-associated pseudomembranous colitis. Am J Med. Jan. 1985;78(1):45-8. Not relevant to key question. [pmid: 3966488].
150 George WL, Rolfe RD, Harding GK, et al. Clostridium difficile and cytotoxin in feces of patients with antimicrobial agent-associated pseudomembranous colitis. Infection. 1982;10(4):205-8. Not relevant to key question. [pmid: 7129642].
151 George WL, Sutter VL, Goldstein EJ, et al. Aetiology of antimicrobial-agent-associated colitis. Lancet. Apr. 15. 1978;1(8068):802-3. Not relevant to key question. [pmid: 85818].
152 Gerding DN, Olson MM, Peterson LR, et al. Clostridium difficile-associated diarrhea and colitis in adults. A prospective case-controlled epidemiologic study. Arch Intern Med. Jan. 1986;146(1):95-100. Not relevant to key question. [pmid: 3942469].
153 Germani Y, Morillon M, Begaud E, et al. Two-year study of endemic enteric pathogens associated with acute diarrhea in New Caledonia. J Clin Microbiol. Jun. 1994;32(6):1532-6. Not relevant to key question. [pmid: 8077399].
154 Gilbride SJ, Lee BE, Taylor GD, et al. Successful containment of a norovirus outreak in an acute adult psychiatric area. Infect Control Hosp Epidemiol. Mar. 2009;30(3):289-91. Not relevant to key question. [pmid: 19193019].
155 Gill VJ, Travis LB, Williams DY. Clinical and microbiological observations on CDC group DF-3, a gram-negative coccobacillus. J Clin Microbiol. Aug. 1991;29(8):1589-92. Not relevant to key question. [pmid: 1761678].
156 Gilligan PH, McCarthy LR, Genta VM. Relative frequency of Clostridium difficile in patients with diarrheal disease. J Clin Microbiol. Jul. 1981;14(1):26-31. Not relevant to key question. [pmid: 7263852].
157 Goodman JL, Jurkovich P, Kramber JM, et al. Molecular detection of persistent Borrelia burgdorferi in the urine of patients with active Lyme disease. Infect Immun. Jan. 1991;59(1):269-78. Not relevant to key question. [pmid: 1987041].
158 Goorhuis A, Bakker D, Corver J, et al. Emergence of Clostridium difficile infection due to a new hypervirulent strain, polymerase chain reaction ribotype 078. Clinic Infect Dis. Nov. 1. 2008;47(9):1162-70. Not relevant to key question.
159 Goorhuis A, Van der Kooi T, Vaessen N, et al. Spread and epidemiology of Clostridium difficile polymerase chain reaction ribotype 027/toxinotype III in The Netherlands. Clinic Infect Dis. Sep. 15. 2007;45(6):695-703. Not relevant to key question.
160 Gorbach SL, Cornick NA, Silva M. Effect of bismuth subsalicylate on fecal microflora. Reviews of infectious diseases. Jan-Feb. 1990;12(Suppl 1):S21-3. Not relevant to key question. [pmid: 2305174].
161 Gorenek L, Dizer U, Besirbellioglu B, et al. The diagnosis and treatment of Clostridium difficile in antibiotic-associated diarrhea. Hepato-gastroenterology. Jan-Feb. 1999;46(25):343-8. Not relevant to key question. [pmid: 10228818].
162 Gravet A, Rondeau M, Harf-Monteil C, et al. Predominant Staphylococcus aureus isolated from antibiotic-associated diarrhea is clinically relevant and produces enterotoxin A and the bicomponent toxin LukE-lukD. J Clin Microbiol. Dec. 1999;37(12):4012-9. Not relevant to key question. [pmid: 10565923].
163 Greenfield C, Burroughs A, Szawathowski M, et al. Is pseudomembranous colitis infectious?. Lancet. Feb. 14. 1981;1(8216):371-2. Not relevant to key question. [pmid: 6109999].
164 Grundfest-Broniatowski S, Quader M, Alexander F, et al. Clostridium difficile colitis in the critically ill. Dis Colon Rectum. Jun. 1996;39(6):619-23. Not relevant to key question. [pmid: 8646945].
165 Guenter PA, Settle RG, Perlmutter S, et al. Tube feeding-related diarrhea in acutely Ill patients. Jpen: Journal of Parenteral & Enteral Nutrition. May-Jun. 1991;15(3):277-80. Not relevant to key question. [pmid: 1650854].
166 Gujja D, Friedenberg FK. Predictors of serious complications due to Clostridium difficile infection. Aliment Pharmacol Ther. Mar. 15. 2009;29(6):635-42. Not relevant to key question. [pmid: 19077106].
167 Gurian L, Klein K, Ward TT. Role of Clostridium difficile and Campylobacter jejuni in relapses of inflammatory bowel disease. Western Journal of Medicine. Mar. 1983;138(3):359-60. Not relevant to key question. [pmid: 6858121].
168 Haberberger RL Jr, Mikhail IA, Burans JP, et al. Travelers' diarrhea among United States military personnel during joint American-Egyptian armed forces exercises in Cairo, Egypt. Military medicine. Jan. 1991;156(1):27-30. Not relevant to key question. [pmid: 1900113].
169 Hall SM, Calver GP, Williams M. A hospital outbreak of Clostridium difficile?. J Hosp Infect. Sep. 1985;6(3):312-22. Not relevant to key question. [pmid: 2865298].
170 Harris JP, Edmunds WJ, Pebody R, et al. Deaths from norovirus among the elderly, England and Wales. Emerging Infectious Diseases. Oct. 2008;14(10):1546-52. Not relevant to key question. [pmid: 18826817].
171 Harris JP, Edmunds WJ, Pebody R, et al. Deaths from norovirus among the elderly, England and Wales. Emerging Infectious Diseases. Oct. 2008;14(10):1546-52. Not relevant to key question. [pmid: 18826817].
172 Harter C, Schulze B, Goldschmidt H, et al. Piperacillin/tazobactam vs ceftazidime in the treatment of neutropenic fever in patients with acute leukemia or following autologous peripheral blood stem cell transplantation: a prospective randomized trial. Bone marrow transplantation. Feb. 2006;37(4):373-9. Not relevant to key question. [pmid: 16400334].
173 Hassoun A, Ibrahim F. Use of intravenous immunoglobulin for the treatment of severe Clostridium difficile colitis. Am J Geriatr Pharmacother. Mar. 2007;5(1):48-51. Not relevant to key question. [pmid: 17608247].
174 Hayakawa T, Imaeda H, Nakamura M, et al. Association of pseudomembranous colitis with Henoch-Schonlein purpura. Journal of gastroenterology. Jun. 2005;40(6):641-5. Not relevant to key question. [pmid: 16007399].
175 Heard SR, Wren B, Barnett MJ, et al. Clostridium difficile infection in patients with haematological malignant disease. Risk factors, faecal toxins and pathogenic strains. Epidemiology & Infection. Feb. 1988;100(1):63-72. Not relevant to key question. [pmid: 3123260].
176 Heimdahl A, Nord CE. Effect of phenoxymethylpenicillin and clindamycin on the oral, throat and faecal microflora of man. Scand J Infect Dis. 1979;11(3):233-42. Not relevant to key question. [pmid: 118526].
177 Heizmann W, Ehninger G, Vallbracht A, et al. Surveillance cultures and benefit of laminar airflow units in patients undergoing bone marrow transplantation. Infection. 1987;15(5):337-43. Not relevant to key question. [pmid: 3121516].
178 Helgason KO, Raby SJ, Kamel HM, et al. Cytomegalovirus colitis in a critically ill patient following elective repair of an abdominal aortic aneurysm. Anaesthesia & Intensive Care. Jan. 2008;36(1):107-9. Not relevant to key question. [pmid: 18326142].
179 Henrich TJ, Krakower D, Bitton A, et al. Clinical risk factors for severe Clostridium difficile-associated disease. Emerging Infectious Diseases. Mar. 2009;15(3):415-22. Not relevant to key question. [pmid: 19239754].
180 Hogenauer C, Langner C, Beubler E, et al. Klebsiella oxytoca as a causative organism of antibiotic-associated hemorrhagic colitis. New England Journal of Medicine. Dec. 7. 2006;355(23):2418-26. Not relevant to key question. [pmid: 17151365].
181 Holt HA, Lewis DA, White LO, et al. Effect of oral ciprofloxacin on the faecal flora of healthy volunteers. European J Clin Microbiol. Apr. 1986;5(2):201-5. Not relevant to key question. [pmid: 2941281].
182 Hooker M. Clostridium difficile. Clinical journal of oncology nursing. Dec. 2007;11(6):801-4. Not relevant to key question. [pmid: 18063537].
183 Hopkins MJ, Macfarlane GT. Changes in predominant bacterial populations in human faeces with age and with Clostridium difficile infection. Journal of medical microbiology. May. 2002;51(5):448-54. Not relevant to key question. [pmid: 11990498].
184 Hopkins MJ, Sharp R, Macfarlane GT. Age and disease related changes in intestinal bacterial populations assessed by cell culture, 16S rRNA abundance, and community cellular fatty acid profiles. Gut. Feb. 2001;48(2):198-205. Not relevant to key question. [pmid: 11156640].
185 Hopkins MJ, Sharp R, Macfarlane GT. Variation in human intestinal microbiota with age. Digestive & Liver Disease. Sep. 2002;34(Suppl 2):S12-8. Not relevant to key question. [pmid: 12408433].
186 Hossain M, Crook TJ, Keoghane SR. Clostridium difficile in urology. Annals of the Royal College of Surgeons of England. Jan. 2008;90(1):36-9. Not relevant to key question. [pmid: 18201498].
187 Hossain M, Crook TJ, Keoghane SR. Clostridium difficile in urology. Annals of the Royal College of Surgeons of England. Jan. 2008;90(1):36-9. Not relevant to key question. [pmid: 18201498].
188 Howitt JR, Grace JW, Schaefer MG, et al. Clostridium difficile-positive stools: a retrospective identification of risk factors. Am J Infect Control. Sep. 2008;36(7):488-91. Not relevant to key question. [pmid: 18786452].
189 Howitt JR, Grace JW, Schaefer MG, et al. Clostridium difficile-positive stools: a retrospective identification of risk factors. Am J Infect Control. Sep. 2008;36(7):488-91. Not relevant to key question. [pmid: 18786452].
190 Hsu MS, Wang JT, Huang WK, et al. Prevalence and clinical features of Clostridium difficile-associated diarrhea in a tertiary hospital in northern Taiwan. Journal of Microbiology, Immunology & Infection. Jun. 2006;39(3):242-8. Not relevant to key question.
191 Hu MY, Katchar K, Kyne L, et al. Prospective derivation and validation of a clinical prediction rule for recurrent Clostridium difficile infection. Gastroenterol. Apr. 2009;136(4):1206-14. Not relevant to key question.
192 Huhulescu S, Kiss R, Brettlecker M, et al. Etiology of acute gastroenteritis in three sentinel general practices, Austria 2007. Infection. Apr. 2009;37(2):103-8. Not relevant to key question. [pmid: 19148576].
193 Hutin Y, Casin I, Lesprit P, et al. Prevalence of and risk factors for Clostridium difficile colonization at admission to an infectious diseases ward. Clinic Infect Dis. May. 1997;24(5):920-4. Not relevant to key question.
194 Hutin Y, Molina JM, Casin I, et al. Risk factors for Clostridium difficile-associated diarrhoea in HIV-infected patients. AIDS. Nov. 1993;7(11):1441-7. Not relevant to key question. [pmid: 8280409].
195 Iizuka M, Itou H, Konno S, et al. Elemental diet modulates the growth of Clostridium difficile in the gut flora. Aliment Pharmacol Ther. Jul. 2004;20(Suppl 1):151-7. Not relevant to key question. [pmid: 15298621].
196 Iizuka M, Konno S, Itou H, et al. Novel evidence suggesting Clostridium difficile is present in human gut microbiota more frequently than previously suspected. Microbiology & Immunology. 2004;48(11):889-92. Not relevant to key question. [pmid: 15557747].
197 Imase K, Takahashi M, Tanaka A, et al. Efficacy of Clostridium butyricum preparation concomitantly with Helicobacter pylori eradication therapy in relation to changes in the intestinal microbiota. Microbiology & Immunology. Mar. 2008;52(3):156-61. Not relevant to key question. [pmid: 18402597].
198 Inagaki Y, Nakaya R, Chida T, et al. The effect of levofloxacin, an optically-active isomer of ofloxacin, on fecal microflora in human volunteers. Japanese Journal of Antibiotics. Mar. 1992;45(3):241-52. Not relevant to key question. [pmid: 1512920].
199 Inagaki Y, Yamamoto N, Chida T, et al. The effect of DU-6859a, a new potent fluoroquinolone, on fecal microflora in human volunteers. Japanese Journal of Antibiotics. Mar. 1995;48(3):368-79. Not relevant to key question. [pmid: 7752450].
200 Indra A, Huhulescu S, Hasenberger P, et al. First isolation of Clostridium difficile PCR ribotype 027 in Austria. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2006;11(9):E060914.3. Not relevant to key question. [pmid: 17075148].
201 Indra A, Huhulescu S, Kernbichler S, et al. First cases of Clostridium difficile PCR ribotype 027 acquired in Austria. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. May. 15. 2008;13(20). Not relevant to key question.
202 Indra A, Schmid D, Huhulescu S, et al. Characterization of clinical Clostridium difficile isolates by PCR ribotyping and detection of toxin genes in Austria, 2006-2007. Journal of medical microbiology. Jun. 2008;57(Pt 6):702-8. Not relevant to key question. [pmid: 18480326].
203 Ingebretsen A, Hansen G, Harmanus C, et al. First confirmed cases of Clostridium difficile PCR ribotype 027 in Norway. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Jan. 10. 2008;13(2). Not relevant to key question.
204 Issa M, Vijayapal A, Graham MB, et al. Impact of Clostridium difficile on inflammatory bowel disease. Clin Gastroenterol Hepatol. Mar. 2007;5(3):345-51. Not relevant to key question. [pmid: 17368234].
205 Ito Y, Moriwaki H, Muto Y, et al. Effect of lactulose on short-chain fatty acids and lactate production and on the growth of faecal flora, with special reference to Clostridium difficile. Journal of medical microbiology. Jan. 1997;46(1):80-4. Not relevant to key question. [pmid: 9003750].
206 Jarvis W, Nunez-Montiel O, Thompson F, et al. Comparison of bacterial isolation, cytotoxicity assay, and counterimmunoelectrophoresis for the detection of Clostridium difficile and its toxin. J Infect Dis. Apr. 1983;147(4):778. Not relevant to key question. [pmid: 6842010].
207 Jawa P, Conlin F. Pseudomembranes on colostomy. May Clinic Proc. Mar. 2009;84(3):214. Not relevant to key question.
208 Jawa P, Conlin F. Pseudomembranes on colostomy. May Clinic Proc. Mar. 2009;84(3):214. Not relevant to key question.
209 Jensen GL, Bross JE, Bourbeau PP, et al. Risk factors for Clostridium difficile stool cytotoxin b among critically ill patients: role of sucralfate. J Infect Dis. Jul. 1994;170(1):227-30. Not relevant to key question. [pmid: 8014506].
210 Jiang ZD, DuPont HL, Garey K, et al. A common polymorphism in the interleukin 8 gene promoter is associated with Clostridium difficile diarrhea. Am J Gastroenterol. May. 2006;101(5):1112-6. Not relevant to key question. [pmid: 16573784].
211 Jiang ZD, Garey KW, Price M, et al. Association of interleukin-8 polymorphism and immunoglobulin G anti-toxin A in patients with Clostridium difficile-associated diarrhea. Clin Gastroenterol Hepatol. Aug. 2007;5(8):964-8. Not relevant to key question. [pmid: 17618838].
212 Johal SS, Hammond J, Solomon K, et al. Clostridium difficile associated diarrhoea in hospitalised patients: onset in the community and hospital and role of flexible sigmoidoscopy. Gut. May. 2004;53(5):673-7. Not relevant to key question. [pmid: 15082585].
213 Johnson LL, McFarland LV, Dearing P, et al. Identification of Clostridium difficile in stool specimens by culture-enhanced gas-liquid chromatography. J Clin Microbiol. Oct. 1989;27(10):2218-21. Not relevant to key question. [pmid: 2685021].
214 Johnson S, Gerding DN, Janoff EN. Systemic and mucosal antibody responses to toxin A in patients infected with Clostridium difficile. J Infect Dis. Dec. 1992;166(6):1287-94. Not relevant to key question. [pmid: 1431247].
215 Johnson S, Homann SR, Bettin KM, et al. Treatment of asymptomatic Clostridium difficile carriers (fecal excretors) with vancomycin or metronidazole. A randomized, placebo-controlled trial. Annals of Internal Medicine. Aug. 15. 1992;117(4):297-302. Not relevant to key question. [pmid: 1322075].
216 Johnson S, Sambol SP, Brazier JS, et al. International typing study of toxin A-negative, toxin B-positive Clostridium difficile variants. J Clin Microbiol. Apr. 2003;41(4):1543-7. Not relevant to key question. [pmid: 12682143].
217 Joseph R, Demeyer D, Vanrenterghem D, et al. First isolation of Clostridium difficile PCR ribotype 027, toxinotype III in Belgium. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Oct. 2005;10(10):E051020.4. Not relevant to key question. [pmid: 16790888].
218 Jung K, Aronsson B. Rapid diagnosis of Clostridium difficile-associated diarrhoea using a latex agglutination test. APMIS. Jul. 1990;98(7):652-4. Not relevant to key question. [pmid: 2397115].
219 Kaatz GW, Gitlin SD, Schaberg DR, et al. Acquisition of Clostridium difficile from the hospital environment. American Journal of Epidemiology. Jun. 1988;127(6):1289-94. Not relevant to key question. [pmid: 2835900].
220 Kamboj M, Mihu CN, Sepkowitz K, et al. Work-up for infectious diarrhea after allogeneic hematopoietic stem cell transplantation: single specimen testing results in cost savings without compromising diagnostic yield. Transplant Infectious Disease. Dec. 2007;9(4):265-9. Not relevant to key question. [pmid: 17511822].
221 Kamthan AG, Bruckner HW, Hirschman SZ, et al. Clostridium difficile diarrhea induced by cancer chemotherapy. Arch Intern Med. Aug. 1992;152(8):1715-7. Not relevant to key question. [pmid: 1497405].
222 Karasawa T, Nojiri T, Hayashi Y, et al. Laboratory diagnosis of toxigenic Clostridium difficile by polymerase chain reaction: presence of toxin genes and their stable expression in toxigenic isolates from Japanese individuals. Journal of gastroenterology. Feb. 1999;34(1):41-5. Not relevant to key question. [pmid: 10204609].
223 Katchar K, Taylor CP, Tummala S, et al. Association between IgG2 and IgG3 subclass responses to toxin A and recurrent Clostridium difficile-associated disease. Clin Gastroenterol Hepatol. Jun. 2007;5(6):707-13. Not relevant to key question. [pmid: 17544998].
224 Kato H, Kato H, Nakamura M, et al. Rapid analysis of Clostridium difficile strains recovered from hospitalized patients by using the slpA sequence typing system. Journal of Infection & Chemotherapy. Jun. 2009;15(3):199-202. Not relevant to key question. [pmid: 19554407].
225 Kato H, Kato N, Katow S, et al. Deletions in the repeating sequences of the toxin A gene of toxin A-negative, toxin B-positive Clostridium difficile strains. FEMS microbiology letters. Jun. 15. 1999;175(2):197-203. Not relevant to key question. [pmid: 10386368].
226 Kato H, Kato N, Watanabe K, et al. Identification of toxin A-negative, toxin B-positive Clostridium difficile by PCR. J Clin Microbiol. Aug. 1998;36(8):2178-82. Not relevant to key question. [pmid: 9665986].
227 Kato H, Kita H, Karasawa T, et al. Colonisation and transmission of Clostridium difficile in healthy individuals examined by PCR ribotyping and pulsed-field gel electrophoresis. Journal of medical microbiology. Aug. 2001;50(8):720-7. Not relevant to key question. [pmid: 11478676].
228 Katz DA, Bates DW, Rittenberg E, et al. Predicting Clostridium difficile stool cytotoxin results in hospitalized patients with diarrhea. J Gen Intern Med. Jan. 1997;12(1):57-62. Not relevant to key question. [pmid: 9034947].
229 Katz DA, Bates DW, Rittenberg E, et al. Predicting Clostridium difficile stool cytotoxin results in hospitalized patients with diarrhea. J Gen Intern Med. Jan. 1997;12(1):57-62. Not relevant to key question. [pmid: 9034947].
230 Katz DA, Lynch ME, Littenberg B. Clinical prediction rules to optimize cytotoxin testing for Clostridium difficile in hospitalized patients with diarrhea. Am J Med. May. 1996;100(5):487-95. Not relevant to key question. [pmid: 8644759].
231 Kaukoranta-Tolvanen SS, Renkonen OV, Gordin A, et al. Effect of erythromycin acistrate and erythromycin stearate on human colonic microflora. Scand J Infect Dis. 1989;21(6):717-20. Not relevant to key question. [pmid: 2617212].
232 Kawecki D, Chmura A, Pacholczyk M, et al. Detection of Clostridium difficile in stool samples from patients in the early period after liver transplantation. Transplantation proceedings. Nov. 2007;39(9):2812-5. Not relevant to key question. [pmid: 18021993].
233 Keighley MR, Youngs D, Johnson M, et al. Clostridium difficile toxin in acute diarrhoea complicating inflammatory bowel disease. Gut. May. 1982;23(5):410-4. Not relevant to key question. [pmid: 7076018].
234 Kelly CP, Chetham S, Keates S, et al. Survival of anti-Clostridium difficile bovine immunoglobulin concentrate in the human gastrointestinal tract. Antimicrob Agents Chemother. Feb. 1997;41(2):236-41. Not relevant to key question. [pmid: 9021173].
235 Kelly CP, Pothoulakis C, Orellana J, et al. Human colonic aspirates containing immunoglobulin A antibody to Clostridium difficile toxin A inhibit toxin A-receptor binding. Gastroenterol. Jan. 1992;102(1):35-40. Not relevant to key question.
236 Kelly MT, Champagne SG, Sherlock CH, et al. Commercial latex agglutination test for detection of Clostridium difficile-associated diarrhea. J Clin Microbiol. Jul. 1987;25(7):1244-7. Not relevant to key question. [pmid: 3611316].
237 Kenneally C, Rosini JM, Skrupky LP, et al. Analysis of 30-day mortality for clostridium difficile-associated disease in the ICU setting. Chest. Aug. 2007;132(2):418-24. Not relevant to key question. [pmid: 17573523].
238 Kim SW, Peck KR, Jung SI, et al. Pseudomonas aeruginosa as a potential cause of antibiotic-associated diarrhea. Journal of Korean medical science. Dec. 2001;16(6):742-4. Not relevant to key question. [pmid: 11748355].
239 Kirkpatrick ID, Greenberg HM. Evaluating the CT diagnosis of Clostridium difficile colitis: should CT guide therapy?. AJR.American Journal of Roentgenology. Mar. 2001;176(3):635-9. Not relevant to key question. [pmid: 11222194].
240 Klarin B, Wullt M, Palmquist I, et al. Lactobacillus plantarum 299v reduces colonisation of Clostridium difficile in critically ill patients treated with antibiotics. Acta Anaesthesiologica Scandinavica. Sep. 2008;52(8):1096-102. Not relevant to key question. [pmid: 18840110].
241 Kleinkauf N, Weiss B, Jansen A, et al. Confirmed cases and report of clusters of severe infections due to Clostridium difficile PCR ribotype 027 in Germany. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Nov. 2007;12(11):E071115.2. Not relevant to key question. [pmid: 18005642].
242 Knothe H, Schafer V, Sammann A, et al. Influence of cefpirome on pharyngeal and faecal flora after single and multiple intravenous administrations of cefpirome to healthy volunteers. J Antimicrob Chemother. Apr. 1992;29(Suppl A):81-6. Not relevant to key question. [pmid: 1601763].
243 Knothe H, Schafer V, Sammann A, et al. Influence of fosfomycin on the intestinal and pharyngeal flora of man. Infection. Jan-Feb. 1991;19(1):18-20. Not relevant to key question. [pmid: 2013503].
244 Knudsen JD, Tvede M. Demonstration of toxin A and B by polymerase chain reaction and McCoy cell assay in clinical isolates of Clostridium difficile from Denmark. APMIS. Jan. 1993;101(1):18-22. Not relevant to key question. [pmid: 8457321].
245 Kocar IH, Caliskaner Z, Pay S, et al. Clostridium difficile infection in patients with reactive arthritis of undetermined etiology. Scandinavian journal of rheumatology. 1998;27(5):357-62. Not relevant to key question. [pmid: 9808399].
246 Koh TH, Tan AL, Tan ML, et al. Epidemiology of Clostridium difficile infection in a large teaching hospital in Singapore. Pathology. Aug. 2007;39(4):438-42. Not relevant to key question. [pmid: 17676487].
247 Kotloff KL, Wasserman SS, Losonsky GA, et al. Safety and immunogenicity of increasing doses of a Clostridium difficile toxoid vaccine administered to healthy adults. Infect Immun. Feb. 2001;69(2):988-95. Not relevant to key question. [pmid: 11159994].
248 Kuhl SJ, Tang YJ, Navarro L, et al. Diagnosis and monitoring of Clostridium difficile infections with the polymerase chain reaction. Clinic Infect Dis. Jun. 1993;16(Suppl 4):S234-8. Not relevant to key question.
249 Kuijper EJ, de Weerdt J, Kato H, et al. Nosocomial outbreak of Clostridium difficile-associated diarrhoea due to a clindamycin-resistant enterotoxin A-negative strain. Eur J Clin Microbiol Infect Dis. Aug. 2001;20(8):528-34. Not relevant to key question. [pmid: 11681431].
250 Kumar B, Vaishnavi C, Sandhu K, et al. Clostridium difficile toxin assay in psoriatic patients. Tropical Gastroenterology. Oct-Dec. 2004;25(4):164-7. Not relevant to key question. [pmid: 15912974].
251 Kurzynski TA, Cembrowski GS, Kimball JL. The use of CIE for the detection of Clostridium difficile toxin in stool filtrates: laboratory and clinical correlation. American Journal of Clinical Pathology. Mar. 1983;79(3):370-4. Not relevant to key question. [pmid: 6829506].
252 Kyne L, Sougioultzis S, McFarland LV, et al. Underlying disease severity as a major risk factor for nosocomial Clostridium difficile diarrhea. Infect Control Hosp Epidemiol. Nov. 2002;23(11):653-9. Not relevant to key question. [pmid: 12452292].
253 Kyne L, Warny M, Qamar A, et al. Asymptomatic carriage of Clostridium difficile and serum levels of IgG antibody against toxin A. New England Journal of Medicine. Feb. 10. 2000;342(6):390-7. Not relevant to key question. [pmid: 10666429].
254 Laffan AM, Bellantoni MF, Greenough WB 3rd, et al. Burden of Clostridium difficile-associated diarrhea in a long-term care facility. Journal of the American Geriatrics Society. Jul. 2006;54(7):1068-73. Not relevant to key question. [pmid: 16866677].
255 Lahn M, Tyler G, Daubener W, et al. Improvement of Clostridium difficile isolation by heat-shock and typing of the isolated strains by SDS-PAGE. European journal of epidemiology. May. 1993;9(3):327-34. Not relevant to key question. [pmid: 8405320].
256 Lam S, Singer C, Tucci V, et al. The challenge of vancomycin-resistant enterococci: a clinical and epidemiologic study. Am J Infect Control. Jun. 1995;23(3):170-80. Not relevant to key question. [pmid: 7677262].
257 Lam S, Singer C, Tucci V, et al. The challenge of vancomycin-resistant enterococci: a clinical and epidemiologic study. Am J Infect Control. Jun. 1995;23(3):170-80. Not relevant to key question. [pmid: 7677262].
258 LaMont JT, Trnka YM. Therapeutic implications of Clostridium difficile toxin during relapse of chronic inflammatory bowel disease. Lancet. Feb. 23. 1980;1(8165):381-3. Not relevant to key question. [pmid: 6101841].
259 Lau SK, Woo PC, Chan BY, et al. Haemophilus segnis polymicrobial and monomicrobial bacteraemia identified by 16S ribosomal RNA gene sequencing. Journal of medical microbiology. Aug. 2002;51(8):635-40. Not relevant to key question. [pmid: 12171293].
260 Lau SK, Woo PC, Leung KW, et al. Emergence of cotrimoxazole- and quinolone-resistant Campylobacter infections in bone marrow transplant recipients. Eur J Clin Microbiol Infect Dis. Feb. 2002;21(2):127-9. Not relevant to key question. [pmid: 11939393].
261 Lee SD, Turgeon DK, Ko CW, et al. Clinical correlation of toxin and common antigen enzyme immunoassay testing in patients with Clostridium difficile disease. Am J Gastroenterol. Jul. 2003;98(7):1569-72. Not relevant to key question. [pmid: 12873579].
262 Lejko-Zupanc T, Zakelj J, Strle F, et al. Influence of ceftriaxone on emergence of Clostridium difficile. Antimicrob Agents Chemother. Dec. 1992;36(12):2850-1. Not relevant to key question. [pmid: 1482159].
263 Lemann F, Chambon C, Barbut F, et al. Arbitrary primed PCR rules out Clostridium difficile cross-infection among patients in a haematology unit. J Hosp Infect. Feb. 1997;35(2):107-15. Not relevant to key question. [pmid: 9049815].
264 Levett PN. Clostridium difficile in habitats other than the human gastro-intestinal tract. Journal of Infection. May. 1986;12(3):253-63. Not relevant to key question. [pmid: 3522751].
265 Lewis R. Investigation of Clostridium difficile diarrhoea in a district general hospital: room for improvement?. J Hosp Infect. Nov. 1987;10(3):243-7. Not relevant to key question. [pmid: 2891751].
266 Lewis S, Burmeister S, Brazier J. Effect of the prebiotic oligofructose on relapse of Clostridium difficile-associated diarrhea: a randomized, controlled study. Clin Gastroenterol Hepatol. May. 2005;3(5):442-8. Not relevant to key question. [pmid: 15880313].
267 Lewis S, Burmeister S, Cohen S, et al. Failure of dietary oligofructose to prevent antibiotic-associated diarrhoea. Aliment Pharmacol Ther. Feb. 15. 2005;21(4):469-77. Not relevant to key question. [pmid: 15709999].
268 Lewis SJ, Potts LF, Barry RE. The lack of therapeutic effect of Saccharomyces boulardii in the prevention of antibiotic-related diarrhoea in elderly patients. Journal of Infection. Mar. 1998;36(2):171-4. Not relevant to key question. [pmid: 9570649].
269 Lishman AH, Al-Jumaili IJ, Record CO. Antitoxin production in antibiotic-associated colitis?. Journal of clinical pathology. Apr. 1981;34(4):414-5. Not relevant to key question. [pmid: 7240430].
270 Lode H, Von der Hoh N, Ziege S, et al. Ecological effects of linezolid versus amoxicillin/clavulanic acid on the normal intestinal microflora. Scand J Infect Dis. 2001;33(12):899-903. Not relevant to key question. [pmid: 11868762].
271 Long S, Fenelon L, Fitzgerald S, et al. First isolation and report of clusters of Clostridium difficile PCR 027 cases in Ireland. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Apr. 2007;12(4):E070426.3. Not relevant to key question. [pmid: 17868610].
272 Loosli J, Gyr K, Stalder H, et al. Etiology of acute infectious diarrhea in a highly industrialized area of Switzerland. Gastroenterol. Jan. 1985;88(1 Pt 1):75-9. Not relevant to key question.
273 Louie T, Miller M, Donskey C, et al. Clinical outcomes, safety, and pharmacokinetics of OPT-80 in a phase 2 trial with patients with Clostridium difficile infection. Antimicrob Agents Chemother. Jan. 2009;53(1):223-8. Not relevant to key question. [pmid: 18955525].
274 Louie T, Miller M, Donskey C, et al. Clinical outcomes, safety, and pharmacokinetics of OPT-80 in a phase 2 trial with patients with Clostridium difficile infection. Antimicrob Agents Chemother. Jan. 2009;53(1):223-8. Not relevant to key question. [pmid: 18955525].
275 Louther J. Enteric precautions for Clostridium difficile. American Journal of Nursing. Apr. 1996;96(4):19. Not relevant to key question. [pmid: 8600710].
276 Lyytikainen O, Mentula S, Kononen E, et al. First isolation of Clostridium difficile PCR ribotype 027 in Finland. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Nov. 2007;12(11):E071108.2. Not relevant to key question. [pmid: 18005648].
277 MacCannell DR, Louie TJ, Gregson DB, et al. Molecular analysis of Clostridium difficile PCR ribotype 027 isolates from Eastern and Western Canada. J Clin Microbiol. Jun. 2006;44(6):2147-52. Not relevant to key question. [pmid: 16757612].
278 Magee JT, Brazier JS, Hosein IK, et al. An investigation of a nosocomial outbreak of Clostridium difficile by pyrolysis mass spectrometry. Journal of medical microbiology. Nov. 1993;39(5):345-51. Not relevant to key question. [pmid: 8246251].
279 Malinen E, Rinttila T, Kajander K, et al. Analysis of the fecal microbiota of irritable bowel syndrome patients and healthy controls with real-time PCR. Am J Gastroenterol. Feb. 2005;100(2):373-82. Not relevant to key question. [pmid: 15667495].
280 Manabe YC, Vinetz JM, Moore RD, et al. Clostridium difficile colitis: an efficient clinical approach to diagnosis. Annals of Internal Medicine. Dec. 1. 1995;123(11):835-40. Not relevant to key question. [pmid: 7486465].
281 Marcon AP, Gamba MA, Vianna LA. Nosocomial diarrhea in the intensive care unit. Brazilian Journal of Infectious Diseases. Dec. 2006;10(6):384-9. Not relevant to key question. [pmid: 17420910].
282 Marinella MA, Burdette SD, Bedimo R, et al. Leukemoid reactions complicating colitis due to Clostridium difficile. Southern medical journal. Oct. 2004;97(10):959-63. Not relevant to key question. [pmid: 15558922].
283 Marrie TJ, Faulkner RS, Badley BW, et al. Pseudomembranous colitis: isolation of two species of cytotoxic clostridia and successful treatment with vancomycin. CMAJ. Nov. 4. 1978;119(9):1058-60. Not relevant to key question. [pmid: 743667].
284 Marrie TJ, Furlong M, Faulkner RS, et al. Clostridium difficile: epidemiology and clinical features. Canadian Journal of Surgery. Jul. 1982;25(4):438-42. Not relevant to key question.
285 Martin H, Willey B, Low DE, et al. Characterization of Clostridium difficile strains isolated from patients in Ontario, Canada, from 2004 to 2006. J Clin Microbiol. Sep. 2008;46(9):2999-3004. Not relevant to key question. [pmid: 18650360].
286 Martirosian G, Bulanda M, Wojcik-Stojek B, et al. Acute appendicitis: the role of enterotoxigenic strains of Bacteroides fragilis and Clostridium difficile. Medical Science Monitor. May-Jun. 2001;7(3):382-6. Not relevant to key question. [pmid: 11386013].
287 Martirosian G, Polanski JA, Szubert A, et al. Clostridium difficile in a department of surgery. Materia Medica Polona. Jul-Dec. 1993;25(3-4):145-7. Not relevant to key question. [pmid: 8072320].
288 Marts BC, Longo WE, Vernava AM 3rd, et al. Patterns and prognosis of Clostridium difficile colitis. Dis Colon Rectum. Aug. 1994;37(8):837-45. Not relevant to key question. [pmid: 8055732].
289 Marx CE, Morris A, Wilson ML, et al. Fecal leukocytes in stool specimens submitted for Clostridium difficile toxin assay. Diagnostic Microbiology & Infectious Disease. May-Jun. 1993;16(4):313-5. Not relevant to key question. [pmid: 8495586].
290 Mathai MG, Shanthaveerapa HN, Byrd RP Jr, et al. Fatal pseudomembranous colitis in a continent urinary neobladder. Journal of the Kentucky Medical Association. Jun. 2002;100(6):234-7. Not relevant to key question. [pmid: 12101580].
291 Matute AJ, Schurink CA, Krijnen RM, et al. Double-blind, placebo-controlled study comparing the effect of azithromycin with clarithromycin on oropharyngeal and bowel microflora in volunteers. Eur J Clin Microbiol Infect Dis. Jun. 2002;21(6):427-31. Not relevant to key question. [pmid: 12111597].
292 Mayumi T, Takezawa J, Takahashi H, et al. IL-15 is elevated in the patients of postoperative enterocolitis. Cytokine. Nov. 1999;11(11):888-93. Not relevant to key question. [pmid: 10547278].
293 Mbonu CC, Davison DL, El-Jazzar KM, et al. Clostridium difficile colitis associated with hemolytic-uremic syndrome. American Journal of Kidney Diseases. May. 2003;41(5):E14. Not relevant to key question. [pmid: 12778432].
294 McCluskey J, Riley TV, Owen ET, et al. Reactive arthritis associated with Clostridium difficile. Australian & New Zealand Journal of Medicine. Oct. 1982;12(5):535-7. Not relevant to key question. [pmid: 6960877].
295 McDonald M, Ward P, Harvey K. Antibiotic-associated diarrhoea and methicillin-resistant Staphylococcus aureus. Medical Journal of Australia. May. 29. 1982;1(11):462-4. Not relevant to key question. [pmid: 7048039].
296 McFarland LV, Surawicz CM, Greenberg RN, et al. Possible role of cross-transmission between neonates and mothers with recurrent Clostridium difficile infections. Am J Infect Control. Jun. 1999;27(3):301-3. Not relevant to key question. [pmid: 10358237].
297 McFarland LV, Surawicz CM, Greenberg RN, et al. Possible role of cross-transmission between neonates and mothers with recurrent Clostridium difficile infections. Am J Infect Control. Jun. 1999;27(3):301-3. Not relevant to key question. [pmid: 10358237].
298 Meijer-Severs GJ, van Santen E. Variations in the anaerobic faecal flora of ten healthy human volunteers with special reference to the Bacteroides fragilis-group and Clostridium difficile. Zentralblatt fur Bakteriologie, Mikrobiologie, und Hygiene - Series A, Medical Microbiology, Infectious Diseases, Virology, Parasitology. Feb. 1986;261(1):43-52. Not relevant to key question.
299 Meijer-Severs GJ, van Santen E. Variations in the anaerobic faecal flora of ten healthy human volunteers with special reference to the Bacteroides fragilis-group and Clostridium difficile. Zentralblatt fur Bakteriologie, Mikrobiologie, und Hygiene - Series A, Medical Microbiology, Infectious Diseases, Virology, Parasitology. Feb. 1986;261(1):43-52. Not relevant to key question.
300 Meijer-Severs GJ, Van Santen E, Meijer BC. Short-chain fatty acid and organic acid concentrations in feces of healthy human volunteers and their correlations with anaerobe cultural counts during systemic ceftriaxone administration. Scandinavian journal of gastroenterology. Jul. 1990;25(7):698-704. Not relevant to key question. [pmid: 2396083].
301 Meijer-Severs GJ, van Santen E, Puister SM, et al. The effect of FCE 22891, a new oral penem, on faecal flora anaerobes and their fermentation end products in patients with chronic obstructive pulmonary disease. Infection. Sep-Oct. 1993;21(5):311-7. Not relevant to key question. [pmid: 8300248].
302 Methe H, Kim JO, Kofler S, et al. Statins decrease Toll-like receptor 4 expression and downstream signaling in human CD14+ monocytes. Arteriosclerosis, Thrombosis & Vascular Biology. Jul. 2005;25(7):1439-45. Not relevant to key question.
303 Meyer AM, Ramzan NN, Loftus EV Jr, et al. The diagnostic yield of stool pathogen studies during relapses of inflammatory bowel disease. J Clin Gastroenterol. Oct. 2004;38(9):772-5. Not relevant to key question. [pmid: 15365403].
304 Mody LR, Smith SM, Dever LL. Clostridium difficile-associated diarrhea in a VA medical center: clustering of cases, association with antibiotic usage, and impact on HIV-infected patients. Infect Control Hosp Epidemiol. Jan. 2001;22(1):42-5. Not relevant to key question. [pmid: 11198022].
305 Mogg GA, Keighley MR, Burdon DW, et al. Antibiotic-associated colitis--a review of 66 cases. Br J Surg. Oct. 1979;66(10):738-42. Not relevant to key question. [pmid: 509051].
306 Mollby R, Aronsson B, Nord CE. Pathogenesis and diagnosis of clostridium difficile enterocolitis. Scand J Infect Dis Supplement. 1985;46:47-56. Not relevant to key question.
307 Mollby R, Nord CE, Aronsson B. Diagnosis of Clostridium difficile-associated enterocolitis in Sweden. Laboratory and epidemiological aspects. Scand J Infect Dis Supplement. 1980;(Suppl 22):30-6. Not relevant to key question.
308 Morelli MS, Rouster SD, Giannella RA, et al. Clinical application of polymerase chain reaction to diagnose Clostridium difficile in hospitalized patients with diarrhea. Clin Gastroenterol Hepatol. Aug. 2004;2(8):669-74. Not relevant to key question. [pmid: 15290659].
309 Morgan OW, Rodrigues B, Elston T, et al. Clinical severity of Clostridium difficile PCR ribotype 027: a case-case study. PLoS ONE. [Electronic Resource]. 2008;3(3):e1812. Not relevant to key question. [pmid: 18350149].
310 Morgan OW, Rodrigues B, Elston T, et al. Clinical severity of Clostridium difficile PCR ribotype 027: a case-case study. PLoS ONE. [Electronic Resource]. 2008;3(3):e1812. Not relevant to key question. [pmid: 18350149].
311 Morgan RJ, Gemmell CG, Lee FD, et al. Clostridium difficile isolated from the stool of a patient with pseudomembranous colits following ampicillin plus flucloxacillin (Magnapen) therapy. Postgrad Med J. Jan. 1980;56(651):65-6. Not relevant to key question. [pmid: 7383956].
312 Morgan RJ, Gemmell CG, Lee FD, et al. Clostridium difficile isolated from the stool of a patient with pseudomembranous colits following ampicillin plus flucloxacillin (Magnapen) therapy. Postgrad Med J. Jan. 1980;56(651):65-6. Not relevant to key question. [pmid: 7383956].
313 Morris JG Jr, Jarvis WR, Nunez-Montiel OL, et al. Clostridium difficile. Colonization and toxin production in a cohort of patients with malignant hematologic disorders. Arch Intern Med. May. 1984;144(5):967-9. Not relevant to key question. [pmid: 6370168].
314 Moskovitz M, Bartlett JG. Recurrent pseudomembranous colitis unassociated with prior antibiotic therapy. Arch Intern Med. Apr. 1981;141(5):663-4. Not relevant to key question. [pmid: 7224749].
315 Mulligan ME, Citron D, Gabay E, et al. Alterations in human fecal flora, including ingrowth of Clostridium difficile, related to cefoxitin therapy. Antimicrob Agents Chemother. Sep. 1984;26(3):343-6. Not relevant to key question. [pmid: 6508264].
316 Munoz P, Palomo J, Yanez J, et al. Clinical microbiological case: a heart transplant recipient with diarrhea and abdominal pain. Recurring C. difficile infection. Clinical Microbiology & Infection. Aug. 2001;7(8):458-9. 451. 2. Not relevant to key question.
317 Munro R, Foldes M, Morris G. An evaluation of a rapid latex test for the diagnosis of Clostridium difficile-associated diarrhea. Pathology. Oct. 1988;20(4):349-52. Not relevant to key question. [pmid: 3241736].
318 Mwachari C, Batchelor BI, Paul J, et al. Chronic diarrhoea among HIV-infected adult patients in Nairobi, Kenya. Journal of Infection. Jul. 1998;37(1):48-53. Not relevant to key question. [pmid: 9733379].
319 Mwachari C, Batchelor BI, Paul J, et al. Chronic diarrhoea among HIV-infected adult patients in Nairobi, Kenya. Journal of Infection. Jul. 1998;37(1):48-53. Not relevant to key question. [pmid: 9733379].
320 Mylonaki M, Langmead L, Pantes A, et al. Enteric infection in relapse of inflammatory bowel disease: importance of microbiological examination of stool. European journal of gastroenterology & hepatology. Aug. 2004;16(8):775-8. Not relevant to key question. [pmid: 15256979].
321 Mylonaki M, Langmead L, Pantes A, et al. Enteric infection in relapse of inflammatory bowel disease: importance of microbiological examination of stool. European journal of gastroenterology & hepatology. Aug. 2004;16(8):775-8. Not relevant to key question. [pmid: 15256979].
322 Nakamura S, Mikawa M, Nakashio S, et al. Isolation of Clostridium difficile from the feces and the antibody in sera of young and elderly adults. Microbiology & Immunology. 1981;25(4):345-51. Not relevant to key question. [pmid: 7253967].
323 Nakamura S, Nakashio S, Inamatsu T, et al. Toxigenicity of Clostridium difficile isolates from patients and healthy adults. Microbiology & Immunology. 1980;24(10):995-7. Not relevant to key question. [pmid: 7464571].
324 Nash JQ, Chattopadhyay B, Honeycombe J, et al. Clostridium difficile and cytotoxin in routine faecal specimens. Journal of clinical pathology. May. 1982;35(5):561-5. Not relevant to key question. [pmid: 7085901].
325 Nathan MA, Seabold JE, Brown BP, et al. Colonic localization of labeled leukocytes in critically ill patients. Scintigraphic detection of pseudomembranous colitis. Clinical nuclear medicine. Feb. 1995;20(2):99-106. Not relevant to key question. [pmid: 7720321].
326 Nelson R. Antibiotic treatment for Clostridium difficile-associated diarrhea in adults. [update of Cochrane Database Syst Rev.2005;(1):CD004610; PMID:15674956]. Cochrane Database Syst Rev. 2007;(3):004610. Not relevant to key question.
327 Nemat H, Khan R, Ashraf MS, et al. Diagnostic value of repeated enzyme immunoassays in Clostridium difficile infection. Am J Gastroenterol. Aug. 2009;104(8):2035-41. Not relevant to key question. [pmid: 19367273].
328 Nomura K, Fujimoto Y, Yamashita M, et al. Absence of pseudomembranes in Clostridium difficile-associated diarrhea in patients using immunosuppression agents. Scandinavian journal of gastroenterology. 2009;44(1):74-8. Not relevant to key question. [pmid: 18781540].
329 Nonhoff C, Struelens MJ, Serruys E. Evaluation of gas-liquid chromatography (GLC) for rapid detection of Clostridium difficile in fecal specimens. Acta Clinica Belgica. 1995;50(2):76-80. Not relevant to key question. [pmid: 7597879].
330 Nord CE, Brismar B, Kasholm-Tengve B, et al. Effect of piperacillin/tazobactam therapy on intestinal microflora. Scand J Infect Dis. 1992;24(2):209-13. Not relevant to key question. [pmid: 1322559].
331 Nord CE, Kager L, Philipson A, et al. Impact of imipenem/cilastatin therapy on faecal flora. European J Clin Microbiol. Oct. 1984;3(5):475-7. Not relevant to key question. [pmid: 6594237].
332 Nord CE, Kager L, Philipson A, et al. Effect of imipenem/cilastatin on the colonic microflora. Reviews of infectious diseases. Jul-Aug. 1985;7(Suppl 3):S432-4. Not relevant to key question. [pmid: 3863218].
333 Nord CE, Movin G, Stalberg D. Impact of cefixime on the normal intestinal microflora. Scand J Infect Dis. 1988;20(5):547-52. Not relevant to key question. [pmid: 3222669].
334 Nord CE, Rasmanis G, Wahlund E. Effect of dalbavancin on the normal intestinal microflora. J Antimicrob Chemother. Sep. 2006;58(3):627-31. Not relevant to key question. [pmid: 16840427].
335 Nord CE, Sillerstrom E, Wahlund E. Effect of tigecycline on normal oropharyngeal and intestinal microflora. Antimicrob Agents Chemother. Oct. 2006;50(10):3375-80. Not relevant to key question. [pmid: 17005820].
336 Noren T, Tang-Feldman YJ, Cohen SH, et al. Clindamycin resistant strains of Clostridium difficile isolated from cases of C. difficile associated diarrhea (CDAD) in a hospital in Sweden. Diagnostic Microbiology & Infectious Disease. Feb. 2002;42(2):149-51. Not relevant to key question. [pmid: 11858913].
337 Novak E, Paxton LM, Bye A, et al. Human safety and pharmacokinetics of a single intramuscular dose of a novel spectinomycin analog, trospectomycin (U-63,366F). Antimicrob Agents Chemother. Dec. 1990;34(12):2342-7. Not relevant to key question. [pmid: 2150907].
338 Novak-Weekley SM, Hollingsworth MH. Comparison of the premier toxin A and B assay and the TOX A/B II assay for diagnosis of Clostridium difficile infection. Clinical & Vaccine Immunology: CVI. Mar. 2008;15(3):575-8. Not relevant to key question. [pmid: 18175802].
339 Novelli A, Mazzei T, Fallani S, et al. Betalactam therapy and intestinal flora. Journal of Chemotherapy. May. 1995;7(Suppl 1):25-31. Not relevant to key question. [pmid: 8618110].
340 Novelli A, Mazzei T, Fallani S, et al. Betalactam therapy and intestinal flora. Journal of Chemotherapy. May. 1995;7(Suppl 1):25-31. Not relevant to key question. [pmid: 8618110].
341 Orrhage K, Sjostedt S, Nord CE. Effect of supplements with lactic acid bacteria and oligofructose on the intestinal microflora during administration of cefpodoxime proxetil. J Antimicrob Chemother. Oct. 2000;46(4):603-12. Not relevant to key question. [pmid: 11020259].
342 Ozaki E, Kato H, Kita H, et al. Clostridium difficile colonization in healthy adults: transient colonization and correlation with enterococcal colonization. Journal of medical microbiology. Feb. 2004;53(Pt 2):167-72. Not relevant to key question. [pmid: 14729940].
343 Ozawa TT, Valadez T. Clostridium difficile infection associated with levofloxacin treatment. Tennessee Medicine. Mar. 2002;95(3):113-5. Not relevant to key question. [pmid: 11898264].
344 Paltansing S, van den Berg RJ, Guseinova RA, et al. Characteristics and incidence of Clostridium difficile-associated disease in The Netherlands, 2005. Clinical Microbiology & Infection. Nov. 2007;13(11):1058-64. Not relevant to key question. [pmid: 17922780].
345 Panichi G, Pantosti A, Gentile G, et al. Clostridium difficile colitis in leukemia patients. European journal of cancer & clinical oncology. Oct. 1985;21(10):1159-63. Not relevant to key question.
346 Peach SL, Borriello SP, Gaya H, et al. Asymptomatic carriage of Clostridium difficile in patients with cystic fibrosis. Journal of clinical pathology. Sep. 1986;39(9):1013-8. Not relevant to key question. [pmid: 3093537].
347 Peach SL, Gaya H, Borriello SP. Faecal carriage of Clostridium difficile in cystic fibrosis patients. Annali dell'Istituto Superiore di Sanita. 1986;22(3):953-7. Not relevant to key question.
348 Pechine S, Gleizes A, Janoir C, et al. Immunological properties of surface proteins of Clostridium difficile. Journal of medical microbiology. Feb. 2005;54(Pt 2):193-6. Not relevant to key question. [pmid: 15673516].
349 Pecquet S, Ravoire S, Andremont A. Faecal excretion of ciprofloxacin after a single oral dose and its effect on faecal bacteria in healthy volunteers. J Antimicrob Chemother. Jul. 1990;26(1):125-9. Not relevant to key question. [pmid: 2211433].
350 Peikin SR, Galdibini J, Bartlett JG. Role of Clostridium difficile in a case of nonantibiotic-associated pseudomembranous colitis. Gastroenterol. Nov. 1980;79(5 Pt 1):948-51. Not relevant to key question.
351 Peled N, Pitlik S, Samra Z, et al. Predicting Clostridium difficile toxin in hospitalized patients with antibiotic-associated diarrhea. Infect Control Hosp Epidemiol. Apr. 2007;28(4):377-81. Not relevant to key question. [pmid: 17385141].
352 Penders J, Thijs C, Vink C, et al. Factors influencing the composition of the intestinal microbiota in early infancy. Pediatrics. Aug. 2006;118(2):511-21. Not relevant to key question. [pmid: 16882802].
353 Persky SE, Brandt LJ. Treatment of recurrent Clostridium difficile-associated diarrhea by administration of donated stool directly through a colonoscope. Am J Gastroenterol. Nov. 2000;95(11):3283-5. Not relevant to key question. [pmid: 11095355].
354 Phillips C. Serum antibody responses to Clostridium difficile toxin A: predictive and protective?. Gut. Aug. 2001;49(2):167-8. Not relevant to key question. [pmid: 11454789].
355 Phillips KD, Rogers PA. Rapid detection and presumptive identification of Clostridium difficile by p-cresol production on a selective medium. Journal of clinical pathology. Jun. 1981;34(6):642-4. Not relevant to key question. [pmid: 7019263].
356 Piche T, Vanbiervliet G, Pipau FG, et al. Low risk of irritable bowel syndrome after Clostridium difficile infection. Can J Gastroenterol. Nov. 2007;21(11):727-31. Not relevant to key question. [pmid: 18026576].
357 Piche T, Vanbiervliet G, Pipau FG, et al. Low risk of irritable bowel syndrome after Clostridium difficile infection. Can J Gastroenterol. Nov. 2007;21(11):727-31. Not relevant to key question. [pmid: 18026576].
358 Pituch H, Bakker D, Kuijper E, et al. First isolation of Clostridium difficile PCR-ribotype 027/toxinotype III in Poland. Polish Journal of Microbiology/Polskie Towarzystwo Mikrobiologow/The Polish Society of Microbiologists. 2008;57(3):267-8. Not relevant to key question.
359 Pituch H, Kreft D, Obuch-Woszczatynski P, et al. Clonal spread of a Clostridium difficile strain with a complete set of toxin A, toxin B, and binary toxin genes among Polish patients with Clostridium difficile-associated diarrhea. J Clin Microbiol. Jan. 2005;43(1):472-5. Not relevant to key question. [pmid: 15635019].
360 Pituch H, Rupnik M, Obuch-Woszczatynski P, et al. Detection of binary-toxin genes (cdtA and cdtB) among Clostridium difficile strains isolated from patients with C. difficile-associated diarrhoea (CDAD) in Poland. Journal of medical microbiology. Feb. 2005;54(Pt 2):143-7. Not relevant to key question. [pmid: 15673507].
361 Pituch H, van Leeuwen W, Maquelin K, et al. Toxin profiles and resistances to macrolides and newer fluoroquinolones as epidemicity determinants of clinical isolates of Clostridium difficile from Warsaw, Poland. J Clin Microbiol. May. 2007;45(5):1607-10. Not relevant to key question. [pmid: 17314219].
362 Pokorny CS, Bye PT, MacLeod C, et al. Antibiotic-associated colitis and cystic fibrosis. Dig Dis Sci. Sep. 1992;37(9):1464-8. Not relevant to key question. [pmid: 1505297].
363 Porco FV, Visconte EB. Pseudomonas aeruginosa as a cause of infectious diarrhea successfully treated with oral ciprofloxacin. Ann Pharmacother. Nov. 1995;29(11):1122-3. Not relevant to key question. [pmid: 8573957].
364 Probert CS, Jones PR, Ratcliffe NM. A novel method for rapidly diagnosing the causes of diarrhoea. Gut. Jan. 2004;53(1):58-61. Not relevant to key question. [pmid: 14684577].
365 Pryor WM, Bye WA, Curran DH, et al. Acute diarrhoea in adults: a prospective study. Medical Journal of Australia. Nov. 16. 1987;147(10):490-3. Not relevant to key question. [pmid: 3683260].
366 Rafferty ME, Baltch AL, Smith RP, et al. Comparison of restriction enzyme analysis, arbitrarily primed PCR, and protein profile analysis typing for epidemiologic investigation of an ongoing Clostridium difficile outbreak. J Clin Microbiol. Oct. 1998;36(10):2957-63. Not relevant to key question. [pmid: 9738050].
367 Raibaud P, Ducluzeau R, Dubos F, et al. Implantation of bacteria from the digestive tract of man and various animals into gnotobiotic mice. American Journal of Clinical Nutrition. Nov. 1980;33(11 Suppl):2440-7. Not relevant to key question. [pmid: 7001883].
368 Rampling A, Warren RE, Bevan PC, et al. Clostridium difficile in haematological malignancy. Journal of clinical pathology. Apr. 1985;38(4):445-51. Not relevant to key question. [pmid: 3857233].
369 Raveh D, Rabinowitz B, Breuer GS, et al. Risk factors for Clostridium difficile toxin-positive nosocomial diarrhoea. International journal of antimicrobial agents. Sep. 2006;28(3):231-7. Not relevant to key question. [pmid: 16908119].
370 Razzaq R, Sukumar SA. Ultrasound diagnosis of clinically undetected Clostridium difficile toxin colitis. Clinical radiology. May. 2006;61(5):446-52. Not relevant to key question. [pmid: 16679120].
371 Rea MC, Clayton E, O'Connor PM, et al. Antimicrobial activity of lacticin 3,147 against clinical Clostridium difficile strains. Journal of medical microbiology. Jul. 2007;56(Pt 7):940-6. Not relevant to key question. [pmid: 17577060].
372 Riggs MM, Sethi AK, Zabarsky TF, et al. Asymptomatic carriers are a potential source for transmission of epidemic and nonepidemic Clostridium difficile strains among long-term care facility residents. Clinic Infect Dis. Oct. 15. 2007;45(8):992-8. Not relevant to key question.
373 Riley TV, Cooper M, Bell B, et al. Community-acquired Clostridium difficile-associated diarrhea. Clinic Infect Dis. Jun. 1995;20(Suppl 2):S263-5. Not relevant to key question.
374 Riley TV, O'Neill GL, Bowman RA, et al. Clostridium difficile-associated diarrhoea: epidemiological data from Western Australia. Epidemiology & Infection. Aug. 1994;113(1):13-20. Not relevant to key question. [pmid: 8062869].
375 Riley TV, Thean S, Hool G, et al. First Australian isolation of epidemic Clostridium difficile PCR ribotype 027. Medical Journal of Australia. Jun. 15. 2009;190(12):706-8. Not relevant to key question. [pmid: 19527210].
376 Riley TV, Wetherall F, Bowman J, et al. Diarrheal disease due to Clostridium difficile in general practice. Pathology. Oct. 1991;23(4):346-9. Not relevant to key question. [pmid: 1784528].
377 Rinttila T, Kassinen A, Malinen E, et al. Development of an extensive set of 16S rDNA-targeted primers for quantification of pathogenic and indigenous bacteria in faecal samples by real-time PCR. Journal of applied microbiology. 2004;97(6):1166-77. Not relevant to key question. [pmid: 15546407].
378 Roberts K, Smith CF, Snelling AM, et al. Aerial dissemination of Clostridium difficile spores. BMC Infectious Diseases. 2008;8:7. Background. [pmid: 18218089].
379 Rohner P, Pittet D, Pepey B, et al. Etiological agents of infectious diarrhea: implications for requests for microbial culture. J Clin Microbiol. Jun. 1997;35(6):1427-32. Not relevant to key question. [pmid: 9163457].
380 Rolny P, Jarnerot G, Mollby R. Occurrence of Clostridium difficile toxin in inflammatory bowel disease. Scandinavian journal of gastroenterology. Jan. 1983;18(1):61-4. Not relevant to key question. [pmid: 6144171].
381 Rossel P, Sortsoe Jensen H, Qvist P, et al. Prognosis of adult-onset idiopathic bile acid malabsorption. Scandinavian journal of gastroenterology. Jun. 1999;34(6):587-90. Not relevant to key question. [pmid: 10440608].
382 Rotimi VO, Akindutire D. Clostridium difficile in the normal adult faecal flora. African Journal of Medicine & Medical Sciences. Sep-Oct. 1986;15(3-4):73-7. Not relevant to key question. [pmid: 3031964].
383 Rotimi VO, Akindutire D. Feacal carriage of cytotoxigenic strains of Clostridium difficile by adult Nigerians. East African medical journal. May. 1989;66(5):319-23. Not relevant to key question. [pmid: 2791928].
384 Rotimi VO, Mokaddas EM, Jamal WY, et al. Hospital-acquired Clostridium difficile infection amongst ICU and burn patients in Kuwait. Medical Principles & Practice. Jan-Mar. 2002;11(1):23-8. Not relevant to key question. [pmid: 12116691].
385 Rutgeerts L, Ghillebert G, Drognee W, et al. Ischemic colitis in a patient with Crohn's disease taking an oral contraceptive and an ergotamine alkaloid. Acta Clinica Belgica. 1993;48(1):48-51. Not relevant to key question. [pmid: 8388603].
386 Rybolt AH, Bennett RG, Laughon BE, et al. Protein-losing enteropathy associated with Clostridium difficile infection. Lancet. Jun. 17. 1989;1(8651):1353-5. Not relevant to key question. [pmid: 2567373].
387 Sailhamer EA, Carson K, Chang Y, et al. Fulminant Clostridium difficile colitis: patterns of care and predictors of mortality. Archives of Surgery. discussion 439-40. May. 2009;144(5):433-9. Not relevant to key question. [pmid: 19451485].
388 Salcedo J, Keates S, Pothoulakis C, et al. Intravenous immunoglobulin therapy for severe Clostridium difficile colitis. Gut. Sep. 1997;41(3):366-70. Not relevant to key question. [pmid: 9378393].
389 Sambol SP, Merrigan MM, Lyerly D, et al. Toxin gene analysis of a variant strain of Clostridium difficile that causes human clinical disease. Infect Immun. Oct. 2000;68(10):5480-7. Not relevant to key question. [pmid: 10992443].
390 Samore MH, Bettin KM, DeGirolami PC, et al. Wide diversity of Clostridium difficile types at a tertiary referral hospital. J Infect Dis. Sep. 1994;170(3):615-21. Not relevant to key question. [pmid: 8077719].
391 Samore MH, DeGirolami PC, Tlucko A, et al. Clostridium difficile colonization and diarrhea at a tertiary care hospital. Clinic Infect Dis. Feb. 1994;18(2):181-7. Not relevant to key question.
392 Samuel SC, Hancock P, Leigh DA. An investigation into Clostridium perfringens enterotoxin-associated diarrhoea. J Hosp Infect. Jul. 1991;18(3):219-30. Not relevant to key question. [pmid: 1680904].
393 Sanchez-Hurtado K, Corretge M, Mutlu E, et al. Systemic antibody response to Clostridium difficile in colonized patients with and without symptoms and matched controls. Journal of medical microbiology. Jun. 2008;57(Pt 6):717-24. Not relevant to key question. [pmid: 18480328].
394 Savage AM, Alford RH. Nosocomial spread of Clostridium difficile. Infection Control. Jan-Feb. 1983;4(1):31-3. Not relevant to key question. [pmid: 6550579].
395 Savariau-Lacomme MP, Lebarbier C, Karjalainen T, et al. Transcription and analysis of polymorphism in a cluster of genes encoding surface-associated proteins of Clostridium difficile. Journal of Bacteriology. Aug. 2003;185(15):4461-70. Not relevant to key question. [pmid: 12867455].
396 Scanvic-Hameg A, Chachaty E, Rey J, et al. Impact of quinupristin/dalfopristin (RP59500) on the faecal microflora in healthy volunteers. J Antimicrob Chemother. Jan. 2002;49(1):135-9. Not relevant to key question. [pmid: 11751777].
397 Scheurer DB, Hicks LS, Cook EF, et al. Accuracy of ICD-9 coding for Clostridium difficile infections: a retrospective cohort. Epidemiology & Infection. Aug. 2007;135(6):1010-3. Not relevant to key question. [pmid: 17156501].
398 Schmidt NJ, Ho HH, Dondero ME. Clostridium difficile toxin as a confounding factor in enterovirus isolation. J Clin Microbiol. Dec. 1980;12(6):796-8. Not relevant to key question. [pmid: 6273451].
399 Schmitt-Grohe S, Wiggert E, Steffan J, et al. Severe antibiotic-associated colitis in a patient with cystic fibrosis and colonic wall thickening. Journal of Pediatric Gastroenterology & Nutrition. Feb. 2002;34(2):224-6. Not relevant to key question. [pmid: 11840045].
400 Schroeder MS. Clostridium difficile--associated diarrhea. American Family Physician. Mar. 1. 2005;71(5):921-8. Not relevant to key question. [pmid: 15768622].
401 Schwaber MJ, Simhon A, Block C, et al. Factors associated with nosocomial diarrhea and Clostridium difficile-associated disease on the adult wards of an urban tertiary care hospital. Eur J Clin Microbiol Infect Dis. Jan. 2000;19(1):9-15. Not relevant to key question.
402 Schwaber MJ, Simhon A, Block C, et al. Factors associated with nosocomial diarrhea and Clostridium difficile-associated disease on the adult wards of an urban tertiary care hospital. Eur J Clin Microbiol Infect Dis. Jan. 2000;19(1):9-15. Not relevant to key question.
403 Schwan A, Sjolin S, Trottestam U, et al. Relapsing Clostridium difficile enterocolitis cured by rectal infusion of normal faeces. Scand J Infect Dis. 1984;16(2):211-5. Not relevant to key question. [pmid: 6740251].
404 Schweitzer MA, Sweiss I, Silver DL, et al. The clinical spectrum of Clostridium difficile colitis in immunocompromised patients. American Surgeon. discussion 607-8. Jul. 1996;62(7):603-7. Not relevant to key question. [pmid: 8651560].
405 Sethi AK, Al-Nassir WN, Nerandzic MM, et al. Skin and environmental contamination with vancomycin-resistant Enterococci in patients receiving oral metronidazole or oral vancomycin treatment for Clostridium difficile-associated disease. Infect Control Hosp Epidemiol. Jan. 2009;30(1):13-7. Not relevant to key question. [pmid: 19046063].
406 Seyler L, Lalvani A, Collins L, et al. Safety and cost savings of an improved three-day rule for stool culture in hospitalised children and adults. J Hosp Infect. Oct. 2007;67(2):121-6. Not relevant to key question. [pmid: 17900758].
407 Shadel BN, Puzniak LA, Gillespie KN, et al. Surveillance for vancomycin-resistant enterococci: type, rates, costs, and implications. Infect Control Hosp Epidemiol. Oct. 2006;27(10):1068-75. Not relevant to key question. [pmid: 17006814].
408 Shastri S, Doane AM, Gonzales J, et al. Prevalence of astroviruses in a children's hospital. J Clin Microbiol. Sep. 1998;36(9):2571-4. Not relevant to key question. [pmid: 9705394].
409 Shastri YM, Bergis D, Povse N, et al. Prospective multicenter study evaluating fecal calprotectin in adult acute bacterial diarrhea. Am J Med. Dec. 2008;121(12):1099-106. Not relevant to key question. [pmid: 19028207].
410 Shehabi AA, Abu-Ragheb HA, Allaham NA. Prevalence of Clostridium difficile-associated diarrhoea among hospitalized Jordanian patients. Eastern Mediterranean Health Journal. Jul-Sep. 2001;7(4-5):750-5. Not relevant to key question. [pmid: 15332775].
411 Shen B, Remzi FH, Fazio VW. Fulminant Clostridium difficile-associated pouchitis with a fatal outcome. Nature Reviews Gastroenterology & Hepatology. Aug. 2009;6(8):492-5. Not relevant to key question.
412 Shen BO, Jiang ZD, Fazio VW, et al. Clostridium difficile infection in patients with ileal pouch-anal anastomosis. Clin Gastroenterol Hepatol. Jul. 2008;6(7):782-8. Not relevant to key question. [pmid: 18467184].
413 Shim JK, Johnson S, Samore MH, et al. Primary symptomless colonisation by Clostridium difficile and decreased risk of subsequent diarrhoea. Lancet. Feb. 28. 1998;351(9103):633-6. Not relevant to key question. [pmid: 9500319].
414 Shin JW, Yong D, Kim MS, et al. Sudden increase of vancomycin-resistant enterococcal infections in a Korean tertiary care hospital: possible consequences of increased use of oral vancomycin. Journal of Infection & Chemotherapy. discussion 104-5. Mar. 2003;9(1):62-7. Not relevant to key question. [pmid: 12673410].
415 Shuttleworth R, Taylor M, Jones DM. Antimicrobial susceptibilities of Clostridium difficile. Journal of clinical pathology. Oct. 1980;33(10):1002-5. Not relevant to key question. [pmid: 7430354].
416 Si JM, Yu YC, Fan YJ, et al. Intestinal microecology and quality of life in irritable bowel syndrome patients. World Journal of Gastroenterology. Jun. 15. 2004;10(12):1802-5. Not relevant to key question. [pmid: 15188510].
417 Siegel DL, Edelstein PH, Nachamkin I. Inappropriate testing for diarrheal diseases in the hospital. JAMA. Feb. 16. 1990;263(7):979-82. Not relevant to key question. [pmid: 2299766].
418 Siegle RJ, Fekety R, Sarbone PD, et al. Effects of topical clindamycin on intestinal microflora in patients with acne. Journal of the American Academy of Dermatology. Aug. 1986;15(2 Pt 1):180-5. Not relevant to key question. [pmid: 2943760].
419 Siemann M, Koch-Dorfler M, Rabenhorst G. Clostridium difficile-associated diseases. The clinical courses of 18 fatal cases. Intensive care medicine. Apr. 2000;26(4):416-21. Not relevant to key question. [pmid: 10872133].
420 Silva J Jr, Batts DH, Fekety R, et al. Treatment of Clostridium difficile colitis and diarrhea with vancomycin. Am J Med. Nov. 1981;71(5):815-22. Not relevant to key question. [pmid: 7304654].
421 Simmonds SD, Noble MA, Freeman HJ. Gastrointestinal features of culture-positive Yersinia enterocolitica infection. Gastroenterol. Jan. 1987;92(1):112-7. Not relevant to key question.
422 Simor AE, Yake SL, Tsimidis K. Infection due to Clostridium difficile among elderly residents of a long-term-care facility. Clinic Infect Dis. Oct. 1993;17(4):672-8. Not relevant to key question.
423 Sims RV, Hauser RJ, Adewale AO, et al. Acute gastroenteritis in three community-based nursing homes. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Sep. 1995;50(5):M252-6. Not relevant to key question.
424 Sobko T, Reinders CI, Jansson E, et al. Gastrointestinal bacteria generate nitric oxide from nitrate and nitrite. Nitric Oxide. Dec. 2005;13(4):272-8. Not relevant to key question. [pmid: 16183308].
425 Solaymani-Mohammadi S, Coyle CM, Factor SM, et al. Amebic colitis in an antigenically and serologically negative patient: usefulness of a small-subunit ribosomal RNA gene-based polymerase chain reaction in diagnosis. Diagnostic Microbiology & Infectious Disease. Nov. 2008;62(3):333-5. Not relevant to key question. [pmid: 18691843].
426 Song HJ, Shim KN, Jung SA, et al. Antibiotic-associated diarrhea: candidate organisms other than Clostridium difficile. Korean Journal of Internal Medicine. Mar. 2008;23(1):9-15. Not relevant to key question. [pmid: 18363274].
427 Song HJ, Shim KN, Jung SA, et al. Antibiotic-associated diarrhea: candidate organisms other than Clostridium difficile. Korean Journal of Internal Medicine. Mar. 2008;23(1):9-15. Not relevant to key question. [pmid: 18363274].
428 Soyletir G, Eskiturk A, Kilic G, et al. Clostridium difficile acquisition rate and its role in nosocomial diarrhoea at a university hospital in Turkey. European journal of epidemiology. Aug. 1996;12(4):391-4. Not relevant to key question. [pmid: 8891544].
429 Sriuranpong V, Voravud N. Antineoplastic-associated colitis in Chulalongkorn University Hospital. Journal of the Medical Association of Thailand. Aug. 1995;78(8):424-30. Not relevant to key question. [pmid: 7561566].
430 Stamper PD, Alcabasa R, Aird D, et al. Comparison of a commercial real-time PCR assay for tcdB detection to a cell culture cytotoxicity assay and toxigenic culture for direct detection of toxin-producing Clostridium difficile in clinical samples. J Clin Microbiol. Feb. 2009;47(2):373-8. Not relevant to key question. [pmid: 19073875].
431 Stamper PD, Alcabasa R, Aird D, et al. Comparison of a commercial real-time PCR assay for tcdB detection to a cell culture cytotoxicity assay and toxigenic culture for direct detection of toxin-producing Clostridium difficile in clinical samples. J Clin Microbiol. Feb. 2009;47(2):373-8. Not relevant to key question. [pmid: 19073875].
432 Starr JM, Martin H, McCoubrey J, et al. Risk factors for Clostridium difficile colonisation and toxin production. Age Ageing. Nov. 2003;32(6):657-60. Not relevant to key question. [pmid: 14600008].
433 Steiner TS, Flores CA, Pizarro TT, et al. Fecal lactoferrin, interleukin-1beta, and interleukin-8 are elevated in patients with severe Clostridium difficile colitis. Clinical & Diagnostic Laboratory Immunology. Nov. 1997;4(6):719-22. Not relevant to key question. [pmid: 9384296].
434 Stella PA. Evaluation of a commercial latex agglutination assay for screening for Clostridium difficile-associated disease. Clinical Laboratory Science. Sep-Oct. 1994;7(5):311-3. Not relevant to key question. [pmid: 10150387].
435 Stelzmueller I, Goegele H, Biebl M, et al. Clostridium difficile colitis in solid organ transplantation--a single-center experience. Dig Dis Sci. Nov. 2007;52(11):3231-6. Not relevant to key question. [pmid: 17406820].
436 Stelzmueller I, Wiesmayr S, Eller M, et al. Enterocolitis due to simultaneous infection with rotavirus and Clostridium difficile in adult and pediatric solid organ transplantation. Journal of Gastrointestinal Surgery. Jul. 2007;11(7):911-7. Not relevant to key question. [pmid: 17440792].
437 Strada M, Meregaglia D, Donzelli R. Double-contrast enema in antibiotic-related pseudomembranous colitis. Gastrointestinal radiology. 1983;8(1):67-9. Not relevant to key question. [pmid: 6832539].
438 Sultana Q, Chaudhry NA, Munir M, et al. Diagnosis of Clostridium difficile antibiotic associated diarrhoea culture versus toxin assay. JPMA - Journal of the Pakistan Medical Association. Aug. 2000;50(8):246-9. Not relevant to key question.
439 Sundram F, Guyot A, Carboo I, et al. Clostridium difficile ribotypes 027 and 106: clinical outcomes and risk factors. J Hosp Infect. Jun. 2009;72(2):111-8. Not relevant to key question. [pmid: 19386381].
440 Surawicz CM. Treatment of recurrent Clostridium difficile-associated disease. Nature Clinical Practice Gastroenterology & Hepatology. Nov. 2004;1(1):32-8. Not relevant to key question.
441 Surawicz CM, Elmer GW, Speelman P, et al. Prevention of antibiotic-associated diarrhea by Saccharomyces boulardii: a prospective study. Gastroenterol. Apr. 1989;96(4):981-8. Not relevant to key question.
442 Surawicz CM, McFarland LV, Greenberg RN, et al. The search for a better treatment for recurrent Clostridium difficile disease: use of high-dose vancomycin combined with Saccharomyces boulardii. Clinic Infect Dis. Oct. 2000;31(4):1012-7. Not relevant to key question.
443 Svanteson B, Thoren A, Castor B, et al. Acute diarrhoea in adults: aetiology, clinical appearance and therapeutic aspects. Scand J Infect Dis. 1988;20(3):303-14. Not relevant to key question. [pmid: 3406670].
444 Svenungsson B, Burman LG, Jalakas-Pornull K, et al. Epidemiology and molecular characterization of Clostridium difficile strains from patients with diarrhea: low disease incidence and evidence of limited cross-infection in a Swedish teaching hospital. J Clin Microbiol. Sep. 2003;41(9):4031-7. Not relevant to key question. [pmid: 12958221].
445 Svenungsson B, Lagergren A, Ekwall E, et al. Enteropathogens in adult patients with diarrhea and healthy control subjects: a 1-year prospective study in a Swedish clinic for infectious diseases. Clinic Infect Dis. May. 2000;30(5):770-8. Not relevant to key question.
446 Svenungsson B, Lagergren A, Lundberg A. Clostridium difficile cytotoxin B in adults with diarrhea: a comparison of patients treated or not treated with antibiotics prior to infection. Clinical Microbiology & Infection. Aug. 2001;7(8):447-50. Not relevant to key question. [pmid: 11591210].
447 Tabaqchali S, O'Farrell S, Holland D, et al. Method for the typing of Clostridium difficile based on polyacrylamide gel electrophoresis of [35S]methionine-labeled proteins. J Clin Microbiol. Jan. 1986;23(1):197-8. Not relevant to key question. [pmid: 3700603].
448 Tachon M, Cattoen C, Blanckaert K, et al. First cluster of C. difficile toxinotype III, PCR-ribotype 027 associated disease in France: preliminary report. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2006;11(5):E060504.1. Not relevant to key question. [pmid: 16816455].
449 Tae CH, Jung SA, Song HJ, et al. The first case of antibiotic-associated colitis by Clostridium difficile PCR ribotype 027 in Korea. Journal of Korean medical science. Jun. 2009;24(3):520-4. Not relevant to key question. [pmid: 19543521].
450 Tal S, Gurevich A, Guller V, et al. Risk factors for recurrence of Clostridium difficile-associated diarrhea in the elderly. Scand J Infect Dis. 2002;34(8):594-7. Not relevant to key question. [pmid: 12238576].
451 Tay JK, Bodle EE, Fisher DA, et al. Screening for vancomycin-resistant enterococci using stools sent for Clostridium difficile cytotoxin assay is effective: results of a survey of 300 Patients in a large Singapore Teaching Hospital. Ann Acad Med Singapore. Nov. 2007;36(11):926-9. Not relevant to key question. [pmid: 18071603].
452 Tayek JA, Bistrian BR, Blackburn GL. The effects of acute clostridium difficile diarrhea on fecal nitrogen content in adult hospitalized patients. Journal of the American College of Nutrition. Jun. 1987;6(3):255-9. Not relevant to key question. [pmid: 3598023].
453 Taylor CP, Tummala S, Molrine D, et al. Open-label, dose escalation phase I study in healthy volunteers to evaluate the safety and pharmacokinetics of a human monoclonal antibody to Clostridium difficile toxin A. Vaccine. Jun. 25. 2008;26(27-28):3404-9. Not relevant to key question. [pmid: 18502001].
454 Taylor CP, Tummala S, Molrine D, et al. Open-label, dose escalation phase I study in healthy volunteers to evaluate the safety and pharmacokinetics of a human monoclonal antibody to Clostridium difficile toxin A. Vaccine. Jun. 25. 2008;26(27-28):3404-9. Not relevant to key question. [pmid: 18502001].
455 Taylor ME, Oppenheim BA, Chadwick PR, et al. Detection of glycopeptide-resistant enterococci in routine diagnostic faeces specimens. J Hosp Infect. Sep. 1999;43(1):25-32. Not relevant to key question. [pmid: 10462636].
456 Terhes G, Brazier JS, Urban E, et al. Distribution of Clostridium difficile PCR ribotypes in regions of Hungary. Journal of medical microbiology. Mar. 2006;55(Pt 3):279-82. Not relevant to key question. [pmid: 16476791].
457 Testore GP, Pantosti A, Cerquetti M, et al. Evidence for cross-infection in an outbreak of Clostridium difficile-associated diarrhoea in a surgical unit. Journal of medical microbiology. Jun. 1988;26(2):125-8. Not relevant to key question. [pmid: 3385765].
458 Thamlikitkul V, Danpakdi K, Chokloikaew S. Incidence of diarrhea and Clostridium difficile toxin in stools from hospitalized patients receiving clindamycin, beta-lactams, or nonantibiotic medications. J Clin Gastroenterol. Mar. 1996;22(2):161-3. Not relevant to key question. [pmid: 8742665].
459 Thibault A, Miller MA, Gaese C. Risk factors for the development of Clostridium difficile-associated diarrhea during a hospital outbreak. Infect Control Hosp Epidemiol. Jun. 1991;12(6):345-8. Not relevant to key question. [pmid: 2071877].
460 Thomas DR, Bennett RG, Laughon BE, et al. Postantibiotic colonization with Clostridium difficile in nursing home patients. Journal of the American Geriatrics Society. Apr. 1990;38(4):415-20. Not relevant to key question. [pmid: 2329250].
461 Titov L, Lebedkova N, Shabanov A, et al. Isolation and molecular characterization of Clostridium difficile strains from patients and the hospital environment in Belarus. J Clin Microbiol. Mar. 2000;38(3):1200-2. Not relevant to key question. [pmid: 10699022].
462 Toyokawa M, Ueda A, Tsukamoto H, et al. Pseudomembranous colitis caused by toxin A-negative/toxin B-positive variant strain of Clostridium difficile. Journal of Infection & Chemotherapy. Dec. 2003;9(4):351-4. Not relevant to key question. [pmid: 14691659].
463 Trnka YM, Lamont JT. Clostridium difficile colitis. Advances in Internal Medicine. 1984;29:85-107. Not relevant to key question. [pmid: 6369936].
464 Turner RJ. Pseudomembranous enterocolitis after gynecologic endoscopy. Journal of the American Association of Gynecologic Laparoscopists. Feb. 1994;1(2):168-70. Not relevant to key question. [pmid: 9138866].
465 Tvede M, Rask-Madsen J. Bacteriotherapy for chronic relapsing Clostridium difficile diarrhoea in six patients. Lancet. May. 27. 1989;1(8648):1156-60. Not relevant to key question. [pmid: 2566734].
466 Uhnoo I, Wadell G, Svensson L, et al. Aetiology and epidemiology of acute gastro-enteritis in Swedish children. Journal of Infection. Jul. 1986;13(1):73-89. Not relevant to key question. [pmid: 3734469].
467 Urban E, Tusnadi A, Terhes G, et al. Prevalence of gastrointestinal disease caused by Clostridium difficile in a university hospital in Hungary. J Hosp Infect. Jul. 2002;51(3):175-8. Not relevant to key question. [pmid: 12144795].
468 Vaishnavi C, Bhasin D, Kochhar R, et al. Clostridium difficile toxin and faecal lactoferrin assays in adult patients. Microbes & Infection. Dec. 2000;2(15):1827-30. Not relevant to key question. [pmid: 11165926].
469 Vaishnavi C, Kaur S. Clostridium perfringens enterotoxin in antibiotic-associated diarrhea. Indian journal of pathology & microbiology. Apr-Jun. 2008;51(2):198-9. Not relevant to key question.
470 Vaishnavi C, Kaur S, Prakash S. Speciation of fecal Candida isolates in antibiotic-associated diarrhea in non-HIV patients. Japanese journal of infectious diseases. Jan. 2008;61(1):1-4. Not relevant to key question. [pmid: 18219125].
471 Vaishnavi C, Kaur S, Prakash S. Speciation of fecal Candida isolates in antibiotic-associated diarrhea in non-HIV patients. Japanese journal of infectious diseases. Jan. 2008;61(1):1-4. Not relevant to key question. [pmid: 18219125].
472 Vaishnavi C, Kaur S, Singh K. Clostridium perfringens type A & antibiotic associated diarrhoea. Indian Journal of Medical Research. Jul. 2005;122(1):52-6. Not relevant to key question. [pmid: 16106091].
473 Vaishnavi C, Kochhar R, Bhasin D, et al. Simultaneous assays for Clostridium difficile and faecal lactoferrin in ulcerative colitis. Tropical Gastroenterology. Jan-Mar. 2003;24(1):13-6. Not relevant to key question. [pmid: 12974208].
474 Valiquette L, Pepin J, Do XV, et al. Prediction of complicated Clostridium difficile infection by pleural effusion and increased wall thickness on computed tomography. Clinic Infect Dis. Aug. 15. 2009;49(4):554-60. Not relevant to key question.
475 van den Berg RJ, Kuijper EJ, van Coppenraet LE, et al. Rapid diagnosis of toxinogenic Clostridium difficile in faecal samples with internally controlled real-time PCR. Clinical Microbiology & Infection. Feb. 2006;12(2):184-6. Not relevant to key question. [pmid: 16441459].
476 van Kraaij MG, Dekker AW, Verdonck LF, et al. Infectious gastro-enteritis: an uncommon cause of diarrhoea in adult allogeneic and autologous stem cell transplant recipients. Bone marrow transplantation. Aug. 2000;26(3):299-303. Not relevant to key question. [pmid: 10967569].
477 van Nispen CH, Hoepelman AI, Rozenberg-Arska M, et al. A double-blind, placebo-controlled, parallel group study of oral trovafloxacin on bowel microflora in healthy male volunteers. American Journal of Surgery. Dec. 1998;176(6A Suppl):27S-31S. Not relevant to key question. [pmid: 9935254].
478 Varki NM, Aquino TI. Isolation of Clostridium difficile from hospitalized patients without antibiotic-associated diarrhea or colitis. J Clin Microbiol. Oct. 1982;16(4):659-62. Not relevant to key question. [pmid: 7153315].
479 Verity P, Wilcox MH, Fawley W, et al. Prospective evaluation of environmental contamination by Clostridium difficile in isolation side rooms. J Hosp Infect. Nov. 2001;49(3):204-9. Not relevant to key question. [pmid: 11716638].
480 Vesoulis Z, Williams G, Matthews B. Pseudomembranous enteritis after proctocolectomy: report of a case. Dis Colon Rectum. Apr. 2000;43(4):551-4. Not relevant to key question. [pmid: 10789757].
481 Viscidi R, Willey S, Bartlett JG. Isolation rates and toxigenic potential of Clostridium difficile isolates from various patient populations. Gastroenterol. Jul. 1981;81(1):5-9. Not relevant to key question.
482 Walker KJ, Gilliland SS, Vance-Bryan K, et al. Clostridium difficile colonization in residents of long-term care facilities: prevalence and risk factors. Journal of the American Geriatrics Society. Sep. 1993;41(9):940-6. Not relevant to key question. [pmid: 8104968].
483 Walker RC, Ruane PJ, Rosenblatt JE, et al. Comparison of culture, cytotoxicity assays, and enzyme-linked immunosorbent assay for toxin A and toxin B in the diagnosis of Clostridium difficile-related enteric disease. Diagnostic Microbiology & Infectious Disease. May. 1986;5(1):61-9. Not relevant to key question. [pmid: 3086027].
484 Walters BA, Roberts R, Stafford R, et al. Relapse of antibiotic associated colitis: endogenous persistence of Clostridium difficile during vancomycin therapy. Gut. Mar. 1983;24(3):206-12. Not relevant to key question. [pmid: 6826104].
485 Walters BA, Stafford R, Roberts RK, et al. Contamination and crossinfection with Clostridium difficile in an intensive care unit. Australian & New Zealand Journal of Medicine. Jun. 1982;12(3):255-8. Not relevant to key question. [pmid: 6956292].
486 Wanahita A, Goldsmith EA, Marino BJ, et al. Clostridium difficile infection in patients with unexplained leukocytosis. Am J Med. Nov. 2003;115(7):543-6. Not relevant to key question. [pmid: 14599633].
487 Warny M, Vaerman JP, Avesani V, et al. Human antibody response to Clostridium difficile toxin A in relation to clinical course of infection. Infect Immun. Feb. 1994;62(2):384-9. Not relevant to key question. [pmid: 8300199].
488 Wasserman E, Hidalgo M, Hornedo J, et al. Octreotide (SMS 201-995) for hematopoietic support-dependent high-dose chemotherapy (HSD-HDC)-related diarrhoea: dose finding study and evaluation of efficacy. Bone marrow transplantation. Nov. 1997;20(9):711-4. Not relevant to key question. [pmid: 9384471].
489 Watanakunakorn PW, Watanakunakorn C, Hazy J. Risk factors associated with Clostridium difficile diarrhea in hospitalized adult patients: a case-control study--sucralfate ingestion is not a negative risk factor. Infect Control Hosp Epidemiol. Apr. 1996;17(4):232-5. Not relevant to key question. [pmid: 8935731].
490 Watson B, Ellis M, Mandal B, et al. A comparison of the clinico-pathological features with stool pathogens in patients hospitalised with the symptom of diarrhoea. Scand J Infect Dis. 1986;18(6):553-9. Not relevant to key question. [pmid: 3810049].
491 Waywa D, Kongkriengdaj S, Chaidatch S, et al. Protozoan enteric infection in AIDS related diarrhea in Thailand. Southeast Asian Journal of Tropical Medicine & Public Health. 2001;32(Suppl 2):151-5. Not relevant to key question. [pmid: 12041580].
492 Wei SC, Wong JM, Hsueh PR, et al. Diagnostic role of endoscopy, stool culture, and toxin A in Clostridium difficile-associated disease. Journal of the Formosan Medical Association. Nov. 1997;96(11):879-83. Not relevant to key question. [pmid: 9409120].
493 Weiss B, Kleinkauf N, Eckmanns T, et al. Risk factors related to a hospital-associated cluster of Clostridium difficile PCR ribotype 027 infections in Germany During 2007. Infect Control Hosp Epidemiol. Mar. 2009;30(3):282-4. Not relevant to key question. [pmid: 19215194].
494 Weiss B, Kleinkauf N, Eckmanns T, et al. Risk factors related to a hospital-associated cluster of Clostridium difficile PCR ribotype 027 infections in Germany During 2007. Infect Control Hosp Epidemiol. Mar. 2009;30(3):282-4. Not relevant to key question. [pmid: 19215194].
495 Welkon CJ, Long SS, Thompson CM Jr, et al. Clostridium difficile in patients with cystic fibrosis. American Journal of Diseases of Children. Aug. 1985;139(8):805-8. Not relevant to key question. [pmid: 4025261].
496 Whelan K, Judd PA, Preedy VR, et al. Covert assessment of concurrent and construct validity of a chart to characterize fecal output and diarrhea in patients receiving enteral nutrition. Jpen: Journal of Parenteral & Enteral Nutrition. Mar-Apr. 2008;32(2):160-8. Not relevant to key question. [pmid: 18407909].
497 Whittier S, Shapiro DS, Kelly WF, et al. Evaluation of four commercially available enzyme immunoassays for laboratory diagnosis of Clostridium difficile-associated diseases. J Clin Microbiol. Nov. 1993;31(11):2861-5. Not relevant to key question. [pmid: 8263168].
498 Wilcox MH, Mooney L, Bendall R, et al. A case-control study of community-associated Clostridium difficile infection. J Antimicrob Chemother. Aug. 2008;62(2):388-96. Not relevant to key question. [pmid: 18434341].
499 Wongwanich S, Pongpech P, Dhiraputra C, et al. Characteristics of Clostridium difficile strains isolated from asymptomatic individuals and from diarrheal patients. Clinical Microbiology & Infection. Aug. 2001;7(8):438-41. Not relevant to key question. [pmid: 11591208].
500 Wongwanich S, Ramsiri S, Vanasin B, et al. Clostridium difficile associated disease in Thailand. Southeast Asian Journal of Tropical Medicine & Public Health. Sep. 1990;21(3):367-72. Not relevant to key question. [pmid: 2075479].
501 Wongwanich S, Rugdeekha S, Pongpech P, et al. Detection of Clostridium difficile toxin A and B genes from stool samples of Thai diarrheal patients by polymerase chain reaction technique. Journal of the Medical Association of Thailand. Oct. 2003;86(10):970-5. Not relevant to key question. [pmid: 14650710].
502 Wright JM, Adams SP, Gribble MJ, et al. Clostridium difficile in Crohn's disease. Canadian Journal of Surgery. Sep. 1984;27(5):435-7. Not relevant to key question.
503 Wullt M, Laurell MH. Low prevalence of nosocomial Clostridium difficile transmission, as determined by comparison of arbitrarily primed PCR and epidemiological data. J Hosp Infect. Dec. 1999;43(4):265-73. Not relevant to key question. [pmid: 10658802].
504 Yablon SA, Krotenberg R, Fruhmann K. Diarrhea in hospitalized patients. American Journal of Physical Medicine & Rehabilitation. Apr. 1992;71(2):102-7. Not relevant to key question. [pmid: 1558730].
505 Yadav Y, Garey KW, Dao-Tran TK, et al. Automated system to identify Clostridium difficile infection among hospitalised patients. J Hosp Infect. Aug. 2009;72(4):337-41. Not relevant to key question. [pmid: 19596490].
506 Yapar N, Sener A, Karaca B, et al. Antibiotic-associated diarrhea in a Turkish outpatient population: investigation of 288 cases. Journal of Chemotherapy. Feb. 2005;17(1):77-81. Not relevant to key question. [pmid: 15828448].
507 Yapar N, Sener A, Karaca B, et al. Antibiotic-associated diarrhea in a Turkish outpatient population: investigation of 288 cases. Journal of Chemotherapy. Feb. 2005;17(1):77-81. Not relevant to key question. [pmid: 15828448].
508 Yokohama S, Aoshima M, Nakade Y, et al. Investigation and prediction of enteral nutrition problems after percutaneous endoscopic gastrostomy. World Journal of Gastroenterology. Mar. 21. 2009;15(11):1367-72. Not relevant to key question. [pmid: 19294767].
509 Yolken RH, Bishop CA, Townsend TR, et al. Infectious gastroenteritis in bone-marrow-transplant recipients. New England Journal of Medicine. Apr. 29. 1982;306(17):1010-2. Not relevant to key question. [pmid: 7038501].
510 Young GP, Bayley N, Ward P, et al. Antibiotic-associated colitis caused by Clostridium difficile: relapse and risk factors. Medical Journal of Australia. Mar. 17. 1986;144(6):303-6. Not relevant to key question. [pmid: 3520264].
511 Young GP, Ward PB, Bayley N, et al. Antibiotic-associated colitis due to Clostridium difficile: double-blind comparison of vancomycin with bacitracin. Gastroenterol. Nov. 1985;89(5):1038-45. Not relevant to key question.
512 Younus F, Steigbigel RT. Images in clinical medicine. Nodular Clostridium difficile colitis. New England Journal of Medicine. Mar. 4. 2004;350(10):e9. Not relevant to key question. [pmid: 14999125].
513 Zaiss NH, Weile J, Ackermann G, et al. A case of Clostridium difficile-associated disease due to the highly virulent clone of Clostridium difficile PCR ribotype 027, March 2007 in Germany. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. Nov. 2007;12(11):E071115.1. Not relevant to key question. [pmid: 18005641].
514 Zedd AJ, Sell TL, Schaberg DR, et al. Nosocomial Clostridium difficile reservoir in a neonatal intensive care unit. Pediatric infectious disease. Sep-Oct. 1984;3(5):429-32. Not relevant to key question. [pmid: 6494014].
515 Zilberberg MD, Nathanson BH, Sadigov S, et al. Epidemiology and outcomes of clostridium difficile-associated disease among patients on prolonged acute mechanical ventilation. Chest. Sep. 2009;136(3):752-8. Not relevant to key question. [pmid: 19465510].
516 Zumbado-Salas R, Gamboa-Coronado Mdel M, Rodriguez-Cavallini E, et al. Clostridium difficile in adult patients with nosocomial diarrhea in a Costa Rican hospital. American Journal of Tropical Medicine & Hygiene. Aug. 2008;79(2):164-5. Not relevant to key question. [pmid: 18689617].