# Evidence Tables

Appendix Table C1 Summary of matched comparisons of select assays for C. difficile toxins

Appendix Table C2 Grade of evidence for comparisons of diagnostic tests for toxigenic C. difficile

Appendix Table C3 Description of studies evaluating risk factors for CDI

Appendix Table C4 Evidence table for standard antibiotic treatments

Appendix Table C5 Assessment of study quality of individual metronidazole trials

Appendix Table C6 Assessment of study quality of individual vancomycin trials

Appendix Table C7 Summary of strength of evidence for CDI—Key Question 3c: vancomycin studies

Appendix Table C8 Summary of strength of evidence for CDI—Key Question 3c: metronidazole studies

Appendix Table C9 Assessment of study quality of individual nonstandard treatment trials

Appendix Table C10 Summary of evidence for CDI—Key Question 4

Appendix Table C11 Case studies/series and potential harms of nonstandard interventions for CDI

Appendix Table C12 Reviews and meta-analyses

## References for Appendix Tables

Note that reference numbers for evidence tables in this appendix are different from those in the body of the report.

1 Swindells J, Brenwald N, Reading N, et al. Evaluation of diagnostic tests for Clostridium difficile infection. J Clin Microbiol. Feb. 2010;48(2):606-8. [pmid: 20032256].
2 Kvach EJ, Ferguson D, Riska PF, et al. Comparison of BD GeneOhm Cdiff real-time PCR assay with a two-step algorithm and a toxin A/B enzyme-linked immunosorbent assay for diagnosis of toxigenic Clostridium difficile infection. J Clin Microbiol. Jan. 2010;48(1):109-14. [pmid: 19864479].
3 Alcala L, Marin M, Madrid M, et al. Comparison of ImmunoCard Toxins A&B and the new semiautomated Vidas Clostridium difficile Toxin A&B tests for diagnosis of C. difficile infection. J Clin Microbiol. Mar. 2010;48(3):1014-5. [pmid: 20071550].
4 Eastwood K, Else P, Charlett A, et al. Comparison of nine commercially available Clostridium difficile toxin detection assays, a real-time PCR assay for C. difficile tcdB, and a glutamate dehydrogenase detection assay to cytotoxin testing and cytotoxigenic culture methods. J Clin Microbiol. Oct. 2009;47(10):3211-7. [pmid: 19710274].
5 Novak-Weekley SM, Marlowe EM, Miller JM, et al. Clostridium difficile testing in the clinical laboratory by use of multiple testing algorithms. J Clin Microbiol. Mar. 2010;48(3):889-93. [pmid: 20071552].
6 Alcala L, Sanchez-Cambronero L, Catalan MP, et al. Comparison of three commercial methods for rapid detection of Clostridium difficile toxins A and B from fecal specimens. J Clin Microbiol. Nov. 2008;46(11):3833-5. [pmid: 18784313].
7 Miendje Deyi VY, Vandenberg O, Mascart G, et al. Diagnostic value of five commercial tests for the rapid diagnosis of Clostridium difficile-associated disease. Clin Lab. 2008;54(1-2):9-13. [pmid: 18510038].
8 Samra Z, Luzon A, Bishara J. Evaluation of two rapid immunochromatography tests for the detection of Clostridium difficile toxins. Dig Dis Sci. Jul. 2008;53(7):1876-9. [pmid: 17990108].
9 Sloan LM, Duresko BJ, Gustafson DR, et al. Comparison of real-time PCR for detection of the tcdC gene with four toxin immunoassays and culture in diagnosis of Clostridium difficile infection. J Clin Microbiol. Jun. 2008;46(6):1996-2001. [pmid: 18434563].
10 Musher DM, Manhas A, Jain P, et al. Detection of Clostridium difficile toxin: comparison of enzyme immunoassay results with results obtained by cytotoxicity assay. J Clin Microbiol. Aug. 2007;45(8):2737-9. [pmid: 17567791].
11 van den Berg RJ, Vaessen N, Endtz HP, et al. Evaluation of real-time PCR and conventional diagnostic methods for the detection of Clostridium difficile-associated diarrhoea in a prospective multicentre study. J Med Microbiol. Jan. 2007;56(Pt 1):36-42. [pmid: 17172514].
12 Turgeon DK, Novicki TJ, Quick J, et al. Six rapid tests for direct detection of Clostridium difficile and its toxins in fecal samples compared with the fibroblast cytotoxicity assay. J Clin Microbiol. Feb. 2003;41(2):667-70. [pmid: 12574264].
13 O'Connor D, Hynes P, Cormican M, et al. Evaluation of methods for detection of toxins in specimens of feces submitted for diagnosis of Clostridium difficile-associated diarrhea. J Clin Microbiol. Aug. 2001;39(8):2846-9. [pmid: 11474001].
14 Peled N, Pitlik S, Samra Z, et al. Predicting Clostridium difficile toxin in hospitalized patients with antibiotic-associated diarrhea. Infect Control Hosp Epidemiol. Apr. 2007;28(4):377-81. [pmid: 17385141].
15 Samore MH, Venkataraman L, DeGirolami PC, et al. Genotypic and phenotypic analysis of Clostridium difficile correlated with previous antibiotic exposure. Microb Drug Resist. 2006;12(1):23-8. [pmid: 16584304].
16 Yearsley KA, Gilby LJ, Ramadas AV, et al. Proton pump inhibitor therapy is a risk factor for Clostridium difficile-associated diarrhoea. Aliment Pharmacol Ther. Aug. 15. 2006;24(4):613-9. [pmid: 16907893].
17 Vesta KS, Wells PG, Gentry CA, et al. Specific risk factors for Clostridium difficile-associated diarrhea: a prospective, multicenter, case control evaluation. Am J Infect Control. Oct. 2005;33(8):469-72. [pmid: 16216661].
18 Kyne L, Sougioultzis S, McFarland LV, et al. Underlying disease severity as a major risk factor for nosocomial Clostridium difficile diarrhea. Infect Control Hosp Epidemiol. Nov. 2002;23(11):653-9. [pmid: 12452292].
19 Mody LR, Smith SM, Dever LL. Clostridium difficile-associated diarrhea in a VA medical center: clustering of cases, association with antibiotic usage, and impact on HIV-infected patients. Infect Control Hosp Epidemiol. Jan. 2001;22(1):42-5. [pmid: 11198022].
20 Schwaber MJ, Simhon A, Block C, et al. Factors associated with nosocomial diarrhea and Clostridium difficile-associated disease on the adult wards of an urban tertiary care hospital. Eur J Clin Microbiol Infect Dis. Jan. 2000;19(1):9-15.
21 Katz DA, Bates DW, Rittenberg E, et al. Predicting Clostridium difficile stool cytotoxin results in hospitalized patients with diarrhea. J Gen Intern Med. Jan. 1997;12(1):57-62. [pmid: 9034947].
22 Louie TJ, Miller MA, Mullane KM, et al. Fidaxomicin versus vancomycin for Clostridium difficile infection. N Engl J Med. Feb. 3. 2011;364(5):422-31. [pmid: 21288078].
23 Musher DM, Logan N, Bressler AM, et al. Nitazoxanide versus vancomycin in Clostridium difficile infection: a randomized, double-blind study. Clinic Infect Dis. Feb. 15. 2009;48(4):e41-6.
24 Zar FA, Bakkanagari SR, Moorthi KM, et al. A comparison of vancomycin and metronidazole for the treatment of Clostridium difficile-associated diarrhea, stratified by disease severity. Clinic Infect Dis. Aug. 1. 2007;45(3):302-7.
25 Nelson R. Antibiotic treatment for Clostridium difficile-associated diarrhea in adults. [update of Cochrane Database Syst Rev 2005;(1):CD004610; PMID: 15674956]. Cochrane Database Syst Rev. 2007;(3):004610.
26 Lagrotteria D, Holmes S, Smieja M, et al. Prospective, randomized inpatient study of oral metronidazole versus oral metronidazole and rifampin for treatment of primary episode of Clostridium difficile-associated diarrhea. Clinic Infect Dis. Sep. 1. 2006;43(5):547-52.
27 Musher DM, Logan N, Hamill RJ, et al. Nitazoxanide for the treatment of Clostridium difficile colitis. Clinic Infect Dis. Aug. 15. 2006;43(4):421-7.
28 Wullt M, Odenholt I. A double-blind randomized controlled trial of fusidic acid and metronidazole for treatment of an initial episode of Clostridium difficile-associated diarrhoea. J Antimicrob Chemother. Jul. 2004;54(1):211-6. [pmid: 15163651].
29 Noren T, Wullt M, Akerlund T, et al. Frequent emergence of resistance in Clostridium difficile during treatment of C. difficile-associated diarrhea with fusidic acid. Antimicrob Agents Chemother. Sep. 2006;50(9):3028-32. [pmid: 16940098].
30 Wenisch C, Parschalk B, Hasenhundl M, et al. Comparison of vancomycin, teicoplanin, metronidazole, and fusidic acid for the treatment of Clostridium difficile-associated diarrhea. Clinic Infect Dis. May. 1996;22(5):813-8.
31 de Lalla F, Nicolin R, Rinaldi E, et al. Prospective study of oral teicoplanin versus oral vancomycin for therapy of pseudomembranous colitis and Clostridium difficile-associated diarrhea. Antimicrob Agents Chemother. Oct. 1992;36(10):2192-6. [pmid: 1444298].
32 Fekety R, Silva J, Kauffman C, et al. Treatment of antibiotic-associated Clostridium difficile colitis with oral vancomycin: comparison of two dosage regimens. Am J Med. Jan. 1989;86(1):15-9. [pmid: 2910090].
33 Dudley MN, McLaughlin JC, Carrington G, et al. Oral bacitracin vs vancomycin therapy for Clostridium difficile-induced diarrhea. A randomized double-blind trial. Arch Intern Med. Jun. 1986;146(6):1101-4. [pmid: 3521518].
34 Young GP, Ward PB, Bayley N, et al. Antibiotic-associated colitis due to Clostridium difficile: double-blind comparison of vancomycin with bacitracin. Gastroenterol. Nov. 1985;89(5):1038-45.
35 Teasley DG, Gerding DN, Olson MM, et al. Prospective randomised trial of metronidazole versus vancomycin for Clostridium-difficile-associated diarrhoea and colitis. Lancet. Nov. 5. 1983;2(8358):1043-6. [pmid: 6138597].
36 Keighley MR, Burdon DW, Arabi Y, et al. Randomised controlled trial of vancomycin for pseudomembranous colitis and postoperative diarrhoea. BMJ. Dec. 16. 1978;2(6153):1667-9. [pmid: 367509].
37 Wullt M, Hagslatt ML, Odenholt I. Lactobacillus plantarum 299v for the treatment of recurrent Clostridium difficile-associated diarrhoea: a double-blind, placebo-controlled trial. Scand J Infect Dis. 2003;35(6-7):365-7. [pmid: 12953945].
38 Surawicz CM, McFarland LV, Greenberg RN, et al. The search for a better treatment for recurrent Clostridium difficile disease: use of high-dose vancomycin combined with Saccharomyces boulardii. Clinic Infect Dis. Oct. 2000;31(4):1012-7.
39 McFarland LV, Surawicz CM, Greenberg RN, et al. A randomized placebo-controlled trial of Saccharomyces boulardii in combination with standard antibiotics for Clostridium difficile disease. JAMA. Jun. 22-29. 1994;271(24):1913-8. [pmid: 8201735].
40 Mattila E, Anttila VJ, Broas M, et al. A randomized, double-blind study comparing Clostridium difficile immune whey and metronidazole for recurrent Clostridium difficile-associated diarrhoea: efficacy and safety data of a prematurely interrupted trial. Scand J Infect Dis. 2008;40(9):702-8. [pmid: 19086244].
41 Mogg GA, George RH, Youngs D, et al. Randomized controlled trial of colestipol in antibiotic-associated colitis. Br J Surg. Mar. 1982;69(3):137-9. [pmid: 7039758].
42 McDonald GB, Vracko R. Systemic absorption of oral cholestyramine. Gastroenterol. Jul. 1984;87(1):213-5.
43 Kunimoto D, Thomson AB. Recurrent Clostridium difficile-associated colitis responding to cholestyramine. Digestion. 1986;33(4):225-8. [pmid: 3956890].
44 Kimura Y, Sato K, Tokuda H, et al. Effects of combination therapy with direct hemoperfusion using polymyxin B-immobilized fiber and oral vancomycin on fulminant pseudomembranous colitis with septic shock. Dig Dis Sci. Mar. 2007;52(3):675-8. [pmid: 17273924].
45 Tvede M, Rask-Madsen J. Bacteriotherapy for chronic relapsing Clostridium difficile diarrhoea in six patients. Lancet. May. 27. 1989;1(8648):1156-60. [pmid: 2566734].
46 Persky SE, Brandt LJ. Treatment of recurrent Clostridium difficile-associated diarrhea by administration of donated stool directly through a colonoscope. Am J Gastroenterol. Nov. 2000;95(11):3283-5. [pmid: 11095355].
47 MacConnachie AA, Fox R, Kennedy DR, et al. Faecal transplant for recurrent Clostridium difficile-associated diarrhoea: a UK case series. QJM. Nov. 2009;102(11):781-4. [pmid: 19726581].
48 Rohlke F, Surawicz C, Stollman N. Fecal flora reconstitution for recurrent clostridium difficile infection: results and methodology. Journal of Clinical Gastroenterol. 2010;44(8):567-70.
49 Yoon S, Brandt L. Treatment of refractory/recurrent C. difficile-associated disease by donated stool transplanted via colonoscopy: a case series of 12 patients. J Clin Gastroenterol. 2010;44(8):562-6. [pmid: 20463588].
50 Silverman MS, Davis I, Pillai DR. Success of self-administered home fecal transplantation for chronic Clostridium difficile infection. Clin Gastroenterol Hepatol. May. 2010;8(5):471-3. [pmid: 20117243].
51 MacGregor G, Smith AJ, Thakker B, et al. Yoghurt biotherapy: contraindicated in immunosuppressed patients?. Postgrad Med J. Jun. 2002;78(920):366-7. [pmid: 12151695].
52 Pakyz A. A case of recurrent Clostridium difficile diarrhea. Consult Pharm. Mar. 2007;22(3):249-53. [pmid: 17658971].
53 Munoz P, Bouza E, Cuenca-Estrella M, et al. Saccharomyces cerevisiae fungemia: an emerging infectious disease. [see comment]. Clinic Infect Dis. Jun. 1. 2005;40(11):1625-34.
54 Seal D, Borriello SP, Barclay F, et al. Treatment of relapsing Clostridium difficile diarrhoea by administration of a non-toxigenic strain. Eur J Clin Microbiol. Feb. 1987;6(1):51-3. [pmid: 3569251].
55 Taylor CP, Tummala S, Molrine D, et al. Open-label, dose escalation phase I study in healthy volunteers to evaluate the safety and pharmacokinetics of a human monoclonal antibody to Clostridium difficile toxin A. Vaccine. Jun. 25. 2008;26(27-28):3404-9. [pmid: 18502001].
56 Herpers BL, Vlaminckx B, Burkhardt O, et al. Intravenous tigecycline as adjunctive or alternative therapy for severe refractory Clostridium difficile infection. Clinic Infect Dis. Jun. 15. 2009;48(12):1732-5.
57 Sougioultzis S, Kyne L, Drudy D, et al. Clostridium difficile toxoid vaccine in recurrent C. difficile-associated diarrhea. Gastroenterol. Mar. 2005;128(3):764-70.
58 Kotloff KL, Wasserman SS, Losonsky GA, et al. Safety and immunogenicity of increasing doses of a Clostridium difficile toxoid vaccine administered to healthy adults. Infect Immun. Feb. 2001;69(2):988-95. [pmid: 11159994].
59 McPherson S, Rees CJ, Ellis R, et al. Intravenous immunoglobulin for the treatment of severe, refractory, and recurrent Clostridium difficile diarrhea. Dis Colon Rectum. May. 2006;49(5):640-5. [pmid: 16525744].
60 Murphy C, Vernon M, Cullen M. Intravenous immunoglobulin for resistant Clostridium difficile infection. Age Ageing. Jan. 2006;35(1):85-6. [pmid: 16303776].
61 Hassoun A, Ibrahim F. Use of intravenous immunoglobulin for the treatment of severe Clostridium difficile colitis. Am J Geriatr Pharmacother. Mar. 2007;5(1):48-51. [pmid: 17608247].
62 Abougergi MS, Broor A, Cui W, et al. Intravenous immunoglobulin for the treatment of severe Clostridium difficile colitis: an observational study and review of the literature. J Hosp Med (Online). Jan. 2010;5(1):E1-9.
63 Planche T, Aghaizu A, Holliman R, et al. Diagnosis of Clostridium difficile infection by toxin detection kits: a systematic review. Lancet Infect Dis. Dec. 2008;8(12):777-84. [pmid: 18977696].
64 Garey KW, Sethi S, Yadav Y, et al. Meta-analysis to assess risk factors for recurrent Clostridium difficile infection. J Hosp Infect. Dec. 2008;70(4):298-304. [pmid: 18951661].
65 Bignardi GE. Risk factors for Clostridium difficile infection. J Hosp Infect. Sep. 1998;40(1):1-15. [pmid: 9777516].
66 Leonard J, Marshall JK, Moayyedi P. Systematic review of the risk of enteric infection in patients taking acid suppression. Am J Gastroenterol. Sep. 2007;102(9):2047-56. quiz 57. [pmid: 17509031].
67 Kramer A, Schwebke I, Kampf G. How long do nosocomial pathogens persist on inanimate surfaces? A systematic review. BMC Infect Dis. 2006;6:130. [pmid: 16914034].
68 Thomas MR, Litin SC, Osmon DR, et al. Lack of effect of Lactobacillus GG on antibiotic-associated diarrhea: a randomized, placebo-controlled trial. May Clinic Proc. Sep. 2001;76(9):883-9.
69 Davey P, Brown E, Fenelon L, et al. Interventions to improve antibiotic prescribing practices for hospital inpatients. Cochrane Database Syst Rev. 2005;(4):CD003543. [pmid: 16235326].
70 Koo HL, Koo DC, Musher DM, et al. Antimotility agents for the treatment of Clostridium difficile diarrhea and colitis. Clinic Infect Dis. Mar. 1. 2009;48(5):598-605.
71 Pillai A, Nelson R. Probiotics for treatment of Clostridium difficile-associated colitis in adults. Cochrane Database Syst Rev. 2008;(1):CD004611. [pmid: 18254055].
72 Eddins C, Gray M. Are probiotic or synbiotic preparations effective for the management of clostridium difficile-associated or radiation-induced diarrhea?. J Wound Ostomy Continence Nurs. Jan-Feb. 2008;35(1):50-8. [pmid: 18199939].
73 Segarra-Newnham M. Probiotics for Clostridium difficile-associated diarrhea: focus on Lactobacillus rhamnosus GG and Saccharomyces boulardii. Ann Pharmacother. Jul. 2007;41(7):1212-21. [pmid: 17595306].
74 McFarland LV. Meta-analysis of probiotics for the prevention of antibiotic associated diarrhea and the treatment of Clostridium difficile disease. Am J Gastroenterol. Apr. 2006;101(4):812-22. [pmid: 16635227].
75 Dendukuri N, Costa V, McGregor M, et al. Probiotic therapy for the prevention and treatment of Clostridium difficile-associated diarrhea: a systematic review. CMAJ. Jul. 19. 2005;173(2):167-70. [pmid: 16027434].
76 Zimmerman MJ, Bak A, Sutherland LR. Review article: treatment of Clostridium difficile infection. Aliment Pharmacol Ther. Dec. 1997;11(6):1003-12. [pmid: 9663822].