# Search Strategies

## Search string for C Difficile (general)

Database: Ovid MEDLINE

Search Strategy:

--------------------------------------------------------------------------------

1. difficile.mp.
2. limit 1 to (english language and humans)
3. limit 2 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)
4. randomized controlled trial.pt.
5. controlled clinical trial.pt.
6. randomized.ab.
7. placebo.ab.
8. drug therapy.fs.
9. randomly.ab.
10. trial.ab.
11. groups.ab.
12. or/4-11
13. (animals not (humans and animals)).sh.
14. 12 not 13
15. 3 and 14
16. limit 15 to (addresses or bibliography or biography or dictionary or directory or duplicate publication or editorial or interview or introductory journal article or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or portraits)
17. 15 not 16
18. Cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or risk factors/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
19. limit 18 to (comment or editorial or historical article or interview or letter)
20. 18 not 19
21. 3 and 20
22. 17 or 21

## Search string for C Difficile (Diagnostic)

Database: Ovid MEDLINE

Search Strategy:

--------------------------------------------------------------------------------

1. difficile.mp.
2. diagnostic accuracy.mp.
3. (enzyme adj2 immunoassay$).mp.
4. Immunoenzyme techniques/
5. enzyme linked immunosorbent assay/
6. feces/
7. faeces analysis.mp.
8. fecal.mp.
9. stool culture.mp.
10. exp “Sensitivity and Specificity”/
11. cytotoxicity test, immunologic/
12. cell cytotoxicity assay.mp.
13. pcr.mp. or polymerase chain reaction/
14. immunochromatography.mp.
15. or/2-14
16. 1 and 15
17. limit 16 to (english language and humans and (“young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”))
18. limit 17 to (addresses or bibliography or biography or dictionary or directory or duplicate publication or editorial or interactive tutorial or interview or introductory journal article or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or portraits)
19. limit 17 to in vitro
20. 17 not (18 or 19)