# Technical Expert Panel Members and Affiliation

Marcel Salive, M.D., M.P.H. | Division of Medical and Surgical Services Centers for Medicare and Medicaid Services Baltimore, Maryland
Erik Dubberke, M.D., SHEA | School of Medicine Washington University St. Louis, Missouri
Christina Surawicz, M.D. | Professor of Medicine University of Washington School of Medicine Seattle, Washington
Dale Gerding, M.D. | Associate Chief of Staff Hines VA Hospital Hines, Illinois
Michael Wilson, M.D. | Department of Pathology & Laboratory Services Denver Health Medical Center Denver, Colorado