# Appendixes

Appendix A Technical Expert Panel Members and Affiliation

Appendix B Search Strategies

Appendix C Evidence Tables

Appendix D Excluded Studies