# Acknowledgments

We sincerely thank all peer and public reviewers and David Samson for their comments and suggestions. The report is better because of their contributions.

We would like to thank Christa Prodzinski, Maureen Carlyle, and especially Marilyn Eells, for editing support. We would also like to thank Michelle Brasure, Jim Tacklind, and Indy Rutks, for their librarian expertise, database management, abstracting skills, and all-around general support.