# Abbreviations

AAD: Antibiotic-associated disease
AE: Adverse effects
AHRQ: Agency for Healthcare Research and Quality
AMED: Allied and Complementary Medicine
CDI: Clostridium difficile infection
CI: Confidence interval
GDH: Glutamate dehydrogenase enzyme
GI: Gastrointestinal
GRADE: Grading of Recommendations, Assessment, Development, and Evaluation
ICU: Intensive care unit
MeSH: Medical Subject Headings
MRSA: Methicillin-resistant Staphylococcus aureus
PCR: Polymerase chain reaction
RCT: Randomized controlled trial
RR: Relative risk
TEP: Technical expert panel
VRE: Vancomycin-resistant enterococci
WMD: Weighted mean differences