# References and Included Studies

1 Brainsky A, Glick H, Lydick E, et al. The economic cost of hip fractures in community–dwelling older adults: a prospective study. J Am Geriatr Soc. 1997;45(3):281-7. [pmid: 9063272].
2 Cooper C, Campion G, Melton LJ. Hip fractures in the elderly: a world–wide projection. Osteoporos Int. 1992;2(6):285-9. [pmid: 1421796].
3 Gullberg B, Johnell O, Kanis JA. World–wide projections for hip fracture. Osteoporos Int. 1997;7(5):407-13. [pmid: 9425497].
4 Maggi S, Kelsey JL, Litvak J, et al. Incidence of hip fractures in the elderly: a cross–national analysis. Osteoporos Int. 1991;1(4):232-41. [pmid: 1790410].
5 Kannegaard PN, van der MS, Eiken P, et al. Excess mortality in men compared with women following a hip fracture: national analysis of comedications, comorbidity and survival. Age Ageing. 2010;39(2):203-9. [pmid: 20075035].
6 Jette AM, Harris BA, Cleary PD, et al. Functional recovery after hip fracture. Arch Phys Med Rehabil. 1987;68(10):735-40. [pmid: 3662784].
7 Magaziner J, Simonsick EM, Kashner TM, et al. Predictors of functional recovery one year following hospital discharge for hip fracture: a prospective study. J Gerontol. 1990;45(3):M101-M107. [pmid: 2335719].
8 Mossey JM, Mutran E, Knott K, et al. Determinants of recovery 12 months after hip fracture: the importance of psychosocial factors. Am J Public Health. 1989;79(3):279-86. [pmid: 2916712].
9 Lyons AR, Karpf DB, Lips P, et al. Clinical outcomes and treatment of hip fractures. Am J Med. 1997;103(2 A).
10 Ronald LA, McGregor MJ, McGrail KM, et al. Hospitalization rates of nursing home residents and community–dwelling seniors in british columbia. Can J Aging. 2008;27(1):109-15. [pmid: 18492642].
11 Beaupre LA, Cinats JG, Jones CA, et al. Does functional recovery in elderly hip fracture patients differ between patients admitted from long–term care and the community?. J Gerontol A Biol Sci Med Sci. 2007;62(10):1127-33. [pmid: 17921426].
12 Donald IP, Bulpitt CJ. The prognosis of falls in elderly people living at home. Age Ageing. 1999;28(2):121-5. [pmid: 10350407].
13 Haentjens P, Autier P, Barette M, et al. The economic cost of hip fractures among elderly women: a one–year, prospective, observational cohort study with matched–pair analysis: Belgian Hip Fracture Study Group. J Bone Joint Surg Am. 2001;83–A(4):493-500.
14 Wiktorowicz ME, Goeree R, Papaioannou A, et al. Economic implications of hip fracture: health service use, institutional care and cost in Canada. Osteoporos Int. 2001;12(4):271-8. [pmid: 11420776].
15 The management of chronic pain in older persons: AGS panel on chronic pain in older persons: American geriatrics society. J Am Geriatr Soc. 1998;46(5):635-51. [pmid: 9588381].
16 Cleeland CS. Undertreatment of cancer pain in elderly patients. JAMA. 1998;279(23):1914-5. [pmid: 9634265].
17 Ferrell BA. Pain management in elderly people. J Am Geriatr Soc. 1991;39(1):64-73. [pmid: 1670940].
18 Nussenzveig TC. Pain management after total joint replacement and its impact on patient outcomes. AORN J. 1999;70(6):1060-2. [pmid: 10635429].
19 Pergolizzi J, Boger RH, Budd K, et al. Opioids and the management of chronic severe pain in the elderly: consensus statement of an International Expert Panel with focus on the six clinically most often used World Health Organization Step III opioids (buprenorphine, fentanyl, hydromorphone, methadone, morphine, oxycodone). Pain Pract. 2008;8(4):287-313. [pmid: 18503626].
20 Burke A, Emer S, FitzGerald GA. Analgesic, antipyretic and anti–inflamatory agents; pharmacotherapy of Goat. Brunton LL, Lazo JS, Parker KL, editors. Goodman & Gilman's The Pharmacological Basis of Therapeutics. 11 ed. The McGraw–Hill Companies. 2006.
21 National Center for Complementary and Alternative Medicine. What is complementary and alternative medicine?. Bethesda, MD. National Institutes of Health. http://nccam.nih.gov/health/whatiscam/. Accessed August 9, 2010.
22 Fassoulaki A, Paraskeva A, Kostopanagiotou G, et al. Acupressure on the extra 1 acupoint: the effect on bispectral index, serum melatonin, plasma {beta}–endorphin, and stress. Anesth Analg. 2007;104(2):312-7. [pmid: 17242086].
23 Parker MJ, Griffiths R, Appadu B. Nerve blocks (subcostal, lateral cutaneous, femoral, triple, psoas) for hip fractures. Cochrane Database Syst Rev. 2002.
24 Congedo E, Sgreccia M, De CG. New drugs for epidural analgesia. Curr Drug Targets. 2009;10(8):696-706. [pmid: 19702518].
25 Parker MJ, Handoll HH. Pre–operative traction for fractures of the proximal femur in adults. Cochrane Database Syst Rev. 2006;3:CD000168. [pmid: 16855952].
26 Resch S, Bjarnetoft B, Thorngren K–G. Preoperative skin traction or pillow nursing in hip fractures: a prospective, randomized study in 123 patients. Disabil Rehabil. 2005;27(18–19):1191-5. [pmid: 16278188].
27 Poitras S, Brosseau L. Evidence–informed management of chronic low back pain with transcutaneous electrical nerve stimulation, interferential current, electrical muscle stimulation, ultrasound, and thermotherapy. Spine J. 2008;8(1):226-33. [pmid: 18164470].
28 Milisen K, Abraham IL, Broos PLO. Postoperative variation in neurocognitive and functional status in elderly hip fracture patients. J Adv Nurs. 1998;27(1):59-67. [pmid: 9515609].
29 Goldstein FC, Strasser DC, Woodard JL, et al. Functional outcome of cognitively impaired hip fracture patients on a geriatric rehabilitation unit. J Am Geriatr Soc. 1997;45(1):35-42. [pmid: 8994485].
30 Francis J. Delirium in older patients. J Am Geriatr Soc. 1992;40(8):829-38. [pmid: 1634729].
31 Williams MA, Campbell EB, Raynor WJ, et al. Reducing acute confusional states in elderly patients with hip fractures. Res Nurs Health. 1985;8(4):329-37. [pmid: 3853245].
32 Wallerstein SL. Scaling clinical pain and pain relief. Bromm B, editor. Pain measurement in man: neurophysiological correlates of pain. New York. Elsevier. 1984.
33 Todd KH. Clinical versus statistical significance in the assessment of pain relief. Ann Emerg Med. 1996;27(4):439-41. [pmid: 8604855].
34 Kelly AM. The minimum clinically significant difference in visual analogue scale pain score does not differ with severity of pain. EMERG MED J. 2001;18(3):205-7. [pmid: 11354213].
35 Breivik EKP, Bjornsson GAD, Skovlund EP. A comparison of pain rating scales by sampling from clinical trial data. Clin J Pain. 2000;16(1):22-8. [pmid: 10741815].
36 Grilo RM, Treves R, Preux PM, et al. Clinically relevant VAS pain score change in patients with acute rheumatic conditions. Joint Bone Spine. 2007;74(4):358-61. [pmid: 17591454].
37 Stott DJ, Langhorne P, Knight PV. Multidisciplinary care for elderly people in the community. Lancet. 2008;371(9614):699-700. [pmid: 18313484].
38 Berlin JA. Does blinding of readers affect the results of meta–analyses? University of Pennsylvania Meta–analysis Blinding Study Group. Lancet. Jul. 19. 1997;350(9072):185-6.
39 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.1. The Cochrane Collaboration. 2008.
40 Wells G, Shea B, O'Connell D, Peterson J, et al. The Newcastle–Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta–analyses. Ottawa, Canada. Department of Epidemiology & Community Medicine, University of Ottawa. 2009. Available at: http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm.
41 Apostolopoulos A. Parecoxib as a post surgical analgesic drug in fractures of the hip joint in comparison with diclofenac–pethidine. J Bone Joint Surg Br. Suppl 1. 2006;88–B:186.
42 Baker A, Klimscha W, Eisenach JC, et al. Intrathecal clonidine for postoperative analgesia in elderly patients: the influence of baricity on hemodynamic and analgesic effects. Anesth Analg. 2004;99(1):128-34. [pmid: 15281518].
43 Barker R, Kober A, Hoerauf K, et al. Out–of–hospital auricular acupressure in elder patients with hip fracture: a randomized double–blinded trial. Acad Emerg Med. 2006;13(1):19-23. [pmid: 16365322].
44 Vickers AJ. The use of percentage change from baseline as an outcome in a controlled trial is statistically inefficient: a simulation study. BMC Med Res Methodol. 2001;1:6. [pmid: 11459516].
45 DerSimonian R, Laird N. Meta–analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
46 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta–analytical methods with rare events. Stat Med. 2007;26(1):53-77. [pmid: 16596572].
47 Lau J, Ioannidis JP, Schmid CH. Summing up evidence: one answer is not always enough. Lancet. 1998;351(9096):123-7. [pmid: 9439507].
48 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta–analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
49 Hayashino Y, Noguchi Y, Fukui T. Systematic evaluation and comparison of statistical tests for publication bias. J Epidemiol. 2005;15(6):235-43. [pmid: 16276033].
50 Gartlehner G, Hansen RA, Nissman D, Lohr KN, et al. Criteria for Distinguishing Effectiveness From Efficacy Trials in Systematic Reviews: Technical Review 12 (Prepared by the RTI–International–University of North Carolina Evidence–based Practice Center under Contract No. 290–02–0016). Rockville, MD. Agency for Healthcare Research and Quality. April. 2006. [publisher-id: AHRQ Publication No. 06-0046].
51 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. May. [pmid: 19595577].
52 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. Apr. 2008;336(7650):924-6. [pmid: 18436948].
53 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta–analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
54 Martin KR. Relaxation as a postoperative comfort measure in elderly patients with fractured hips [dissertation]. Louisville, KY. Bellarmine College. 1991.
55 Poitevin LA, Pellegrini H, Alvarez CA, et al. Preoperative control in patients with femoral fractures. Prensa Med Argent. 1999;86(9):913-9. (Spa).
56 Adams HA, Wolf C, Michaelis G, et al. Postoperative course and endocrine stress reaction of geriatric patients with para–articular hip fractures: prospective randomized study comparing spinal anesthesia and halothane intubation narcosis. Anasth Intensivther Notfallmed. 1990;25(4):263-70. (Ger). [pmid: 2171375].
57 Alonso Chico A, Cruz Pardos P, Alvarez Grau J, et al. Comparison of the hemodynamic response in subarachnoid anesthesia with bupivacaine versus bupivacaine with fentanyl in traumatology surgery in elderly patients. Rev Esp Anestesiol Reanim. 2003;50(1):17-22. (Spa). [pmid: 12701260].
58 Ben–David B, Frankel R, Arzumonov T, et al. Minidose bupivacaine–fentanyl spinal anesthesia for surgical repair of hip fracture in the aged. Anesthesiology. 2000;92(1):6-10. [pmid: 10638892].
59 Bredahl C, Hindsholm KB, Frandsen PC. Changes in body heat during hip fracture surgery: a comparison of spinal analgesia and general anaesthesia. Acta Anaesthesiol Scand. 1991;35(6):548-52. [pmid: 1897353].
60 Casati A, Aldegheri G, Vinciguerra E, et al. Randomized comparison between sevoflurane anaesthesia and unilateral spinal anaesthesia in elderly patients undergoing orthopaedic surgery. Eur J Anaesthesiol. 2003;20(8):640-6. [pmid: 12932066].
61 Danelli G, Baciarello M, Di Cianni S, et al. Effects of baricity of 0.5% or 0.75% levobupivacaine on the onset time of spinal anesthesia: a randomized trial. Can J Anaesth. 2008;55(8):501-6. [pmid: 18676384].
62 Favarel–Garrigues JF, Sztark F, Petitjean ME, et al. Hemodynamic effects of spinal anesthesia in the elderly: single dose versus titration through a catheter. Anesth Analg. 1996;82(2):312-6. [pmid: 8561333].
63 Hooda S, Malhotra N, Kumar L. Evaluation of three doses of intrathecal bupivacaine with fentanyl in geriatric patients undergoing hip surgery. J Anaesth Clin Pharmacol. 2006;22(3):267-72.
64 Juelsgaard P, Sand NP, Felsby S, et al. Perioperative myocardial ischaemia in patients undergoing surgery for fractured hip randomized to incremental spinal, single–dose spinal or general anaesthesia. Eur J Anaesthesiol. 1998;15(6):656-63. [pmid: 9884850].
65 Klimscha W, Chiari A, Krafft P, et al. Hemodynamic and analgesic effects of clonidine added repetitively to continuous epidural and spinal blocks. Anesth Analg. 1995;80(2):322-7. [pmid: 7818120].
66 Kwan ASK, Lee BB, Brake T. Intrathecal morphine for post–operative analgesia in patients with fractured hips. Hong Kong Med J. 1997;3(3):250-5. [pmid: 11847368].
67 Malek J, Kurzova A. Intrathecal fentanyl and sufentanil added to bupivacaine augments analgesia after surgical repair of hip fracture. Acute Pain. 2004;6(2):53-6.
68 Martyr JW, Clark MX. Hypotension in elderly patients undergoing spinal anaesthesia for repair of fractured neck of femur: a comparison of two different spinal solutions. Anaesth Intensive Care. 2001;29(5):501-5. [pmid: 11669431].
69 Martyr JW, Stannard KJ, Gillespie G. Spinal–induced hypotension in elderly patients with hip fracture: a comparison of glucose–free bupivacaine with glucose–free bupivacaine and fentanyl. Anaesth Intensive Care. 2005;33(1):64-8. [pmid: 15957693].
70 Maurette P, Bonada G, Djiane V, et al. A comparison between lidocaine alone and lidocaine with meperidine for continuous spinal anesthesia. Reg Anesth. 1993;18(5):290-5. [pmid: 8268117].
71 Minville V, Fourcade O, Grousset D, et al. Spinal anesthesia using single injection small–dose bupivacaine versus continuous catheter injection techniques for surgical repair of hip fracture in elderly patients. Anesth Analg. 2006;102(5):1559-63. [pmid: 16632842].
72 Navas Martínez Á, Ortiz de la Tabla González R, Vazquez Gutierrez T, et al. Continuous subarachnoid blockade versus single shot technique for surgical treatment of the hip fracture [abstract]. Reg Anesth Pain Med. 5 Suppl 1. 2008;33:e30.
73 Olofsson C, Nygards EB, Bjersten AB, et al. Low–dose bupivacaine with sufentanil prevents hypotension after spinal anesthesia for hip repair in elderly patients. Acta Anaesthesiol Scand. 2004;48(10):1240-4. [pmid: 15504182].
74 Qamarul Hoda M. Efficacy and hemodynamic effects of three different dosages of bupivacaine with fentanyl in spinal anaesthesia for surgical reapir of hip fracture [abstract]. Reg Anesth Pain Med. Suppl 1. 2003;28:6.
75 Rais K, Jajjej Z, Rami O, et al. Comparative study of two doses of bupivacaine for contineous spinal anesthesia in elderly. European Society of Anaesthesiology. 2008.
76 Said–Ahmed HAE. Comparison of hypotension after spinal anesthesia in the elderly with either bupivacaine minidose plus fentanyl/sufentanil or bupivacaine conventional dose. Acta Anaesthesiol Ital. 2006;57(2–3):198-203.
77 Krobot R, Premuzic J, Bacak I. Levobupivacaine–fentanyl spinal anaesthesia for hip fracture repair in the elderly [abstract]. Reg Anesth Pain Med. 5 Suppl 1. 2006;31:33.
78 Koval KJ, Aharonoff GB, Rosenberg AD, et al. Hip fracture in the elderly: the effect of anesthetic technique. Orthopedics. 1999;22(1):31-4. [pmid: 9925195].
79 Labaille T, Benhamou D, Westermann J. Hemodynamic effects of continuous spinal anesthesia: a comparative study between low and high doses of bupivacaine. Reg Anesth. 1992;17(4):193-6. [pmid: 1515383].
80 Malcolmson SE, Freebairn R. Haemodynamic stability and vasopressor use during low–dose spinal anaesthesia in the high risk elderly with fractured neck of femur. Critical Care and Shock. 2009;12(4):144-56.
81 Miller K, Reichel M, Karlbauer R, et al. The choice of the method of anesthesia as a risk factor in the femoral fracture near the hip joint in elderly patients. Anaesthesist. 1990;39(2):83-7. (Ger). [pmid: 2310007].
82 Minville V, Asehnoune K, Delussy A, et al. Hypotension during surgery for femoral neck fracture in elderly patients: effect of anaesthetic techniques: a retrospective study. Minerva Anestesiol. 2008;74(12):691-6. [pmid: 19034248].
83 Sen S, Aydin K, Discigil G. Hypotension induced by lateral decubitus or supine spinal anaesthesia in elderly with low ejection fraction undergone hip surgery. J Clin Monit Comput. 2007;21(2):103-7. [pmid: 17216323].
84 Shih YJ, Hsieh CH, Kang TW, et al. General versus spinal anesthesia: which is a risk factor for octogenarian hip fracture repair patients?. Int J Gerontol. 2010;4(1):37-42.
85 Sutcliffe AJ, Parker M. Mortality after spinal and general anaesthesia for surgical fixation of hip fractures. Anaesthesia. 1994;49(3):237-40. [pmid: 8147519].
86 Milisen K, Foreman MD, Abraham IL, et al. A nurse–led interdisciplinary intervention program for delirium in elderly hip–fracture patients. J Am Geriatr Soc. 2001;49(5):523-32. [pmid: 11380743].
87 Ogilvie–Harris DJ, Botsford DJ, Hawker RW. Elderly patients with hip fractures: improved outcome with the use of care maps with high–quality medical and nursing protocols. J Orthop Trauma. 1993;7(5):428-37. [pmid: 8229379].
88 Antonopoulou E, Papaioannou K, Konstantinou G, et al. Continuous femoral block in elderly patients with hip fractures [abstract]. Reg Anesth Pain Med. 5 Suppl 1. 2006;31:92. [pmid: 16418040].
89 Chudinov A, Berkenstadt H, Salai M, et al. Continuous psoas compartment block for anesthesia and perioperative analgesia in patients with hip fractures. Reg Anesth Pain Med. 1999;24(6):563-8. [pmid: 10588563].
90 Coad NR. Post–operative analgesia following femoral–neck surgery: a comparison between 3 in 1 femoral nerve block and lateral cutaneous nerve block. Eur J Anaesthesiol. 1991;8(4):287-90. [pmid: 1874226].
91 Cuvillon P, Ripart J, Debureaux S, et al. Analgesia after hip fracture repair in elderly patients: the effect of a continuous femoral nerve block: a prospective and randomised study. Ann Fr Anesth Reanim. 2007;26(1):2-9. (Fre). [pmid: 17142005].
92 De Visme V, Picart F, Le Jouan R, et al. Combined lumbar and sacral plexus block compared with plain bupivacaine spinal anesthesia for hip fractures in the elderly. Reg Anesth Pain Med. 2000;25(2):158-62. [pmid: 10746528].
93 Eyrolle L. Regional anaesthesia for femoral neck fracture surgery: comparison of lumbar plexus block and spinal anaesthesia [abstract]. Br J Anaesth. Suppl 1. 1998;80:112.
94 Fletcher AK, Rigby AS, Heyes FL. Three–in–one femoral nerve block as analgesia for fractured neck of femur in the emergency department: a randomized, controlled trial. Ann Emerg Med. 2003;41(2):227-33. [pmid: 12548273].
95 Foss NB, Kristensen MT, Kristensen BB, et al. Effect of postoperative epidural analgesia on rehabilitation and pain after hip fracture surgery: a randomized, double–blind, placebo–controlled trial. Anesthesiology. 2005;102(6):1197-204. [pmid: 15915033].
96 Foss NB, Kristensen BB, Bundgaard M, et al. Fascia iliaca compartment blockade for acute pain control in hip fracture patients: a randomized, placebo–controlled trial. Anesthesiology. 2007;106(4):773-8. [pmid: 17413915].
97 Gille J, Gille M, Gahr R, et al. Acute pain management in proximal femoral fractures: femoral nerve block (catheter technique) vs. systemic pain therapy using a clinic internal organisation model. Anaesthesist. 2006;55(4):414-22. (Ger). [pmid: 16320011].
98 Graham CA, Baird K, McGuffie AC. A pilot randomised clinical trial of 3–in–1 femoral nerve block and intravenous morphine as primary analgesia for patients presenting to the emergency department with fractured hip. Hong Kong J Emerg Med. 2008;15(4):205-11.
99 Haddad FS, Williams RL. Femoral nerve block in extracapsular femoral neck fractures. J Bone Joint Surg Br. 1995;77(6):922-3. [pmid: 7593107].
100 Henderson K, Akhtar S, Sandoval M, et al. Femoral nerve block for pain management of hip fractures in the emergency department: preliminary results of a randomized, controlled trial [abstract]. Ann Emerg Med. 2008;52(4):S164.
101 Hood G, Edbrooke DL, Gerrish SP. Postoperative analgesia after triple nerve block for fractured neck of femur. Anaesthesia. 1991;46(2):138-40. [pmid: 1872429].
102 Mannion S, Hayes I, Loughnane F, et al. Intravenous but not perineural clonidine prolongs postoperative analgesia after psoas compartment block with 0.5% levobupivacaine for hip fracture surgery. Anesth Analg. 2005;100(3):873-8. [pmid: 15728081].
103 Marhofer P, Schrogendorfer K, Koinig H, et al. Ultrasonographic guidance improves sensory block and onset time of three–in–one blocks. Anesth Analg. 1997;85(4):854-7. [pmid: 9322469].
104 Marhofer P, Schrogendorfer K, Wallner T, et al. Ultrasonographic guidance reduces the amount of local anesthetic for 3–in–1 blocks. Reg Anesth Pain Med. 1998;23(6):584-8. [pmid: 9840855].
105 Marhofer P, Oismüller C, Faryniak B, et al. Three–in–one blocks with ropivacaine: evaluation of sensory onset time and quality of sensory block. Anesth Analg. 2000;90(1):125-8. [pmid: 10624992].
106 Matot I, Oppenheim–Eden A, Ratrot R, et al. Preoperative cardiac events in elderly patients with hip fracture randomized to epidural or conventional analgesia. Anesthesiology. 2003;98(1):156-63. [pmid: 12502992].
107 Monzon DG, Vazquez J, Jauregui JR, et al. Pain treatment in post–traumatic hip fracture in the elderly: regional block vs. systemic non–steroidal analgesics. Int J Emerg Med. 2010;3(4):321-5. [pmid: 21373300].
108 Mouzopoulos G, Vasiliadis G, Lasanianos N, et al. Fascia iliaca block prophylaxis for hip fracture patients at risk for delirium: a randomized placebo–controlled study. J Orthop Traumatol. 2009;10(3):127-33. [pmid: 19690943].
109 Murgue D, Ehret B, Massacrier–Imbert S, et al. Equimolar nitrous oxide/oxygen combined with femoral nerve block for emergency analgesia of femoral neck fractures. J Eur Urg. 2006;19(1):9-14. (Fre).
110 Scheinin H, Virtanen T, Kentala E, et al. Epidural infusion of bupivacaine and fentanyl reduces perioperative myocardial ischaemia in elderly patients with hip fracture–a randomized controlled trial. Acta Anaesthesiol Scand. 2000;44(9):1061-70. [pmid: 11028724].
111 Segado Jimenez MI, Bayon GM, Arias DJ, et al. [Efficacy of obturator and femoral cutaneous nerve blocks for postoperative analgesia in hip surgery]. Rev Esp Anestesiol Reanim. 2009;56(10):590-7. (Spa). [pmid: 20151520].
112 Segado Jimenez MI, Arias Delgado J, Casas Garca ML, et al. Post–surgical analgesia in hip surgery: a comparison of three techniques. Rev Soc Esp Dolor. 2010;17(6):259-67.
113 Spansberg NL, Anker–Moller E, Dahl JB, et al. The value of continuous blockade of the lumbar plexus as an adjunct to acetylsalicyclic acid for pain relief after surgery for femoral neck fractures. Eur J Anaesthesiol. 1996;13(4):410-2. [pmid: 8842667].
114 Tuncer S, Sert OA, Yosunkaya A, et al. Patient–controlled femoral nerve analgesia versus patient–controlled intravenous analgesia for postoperative analgesia after trochanteric fracture repair. Acute Pain. 2003;4(3–4):105-8.
115 Turker G, Uckunkaya N, Yavascaoglu B, et al. Comparison of the catheter–technique psoas compartment block and the epidural block for analgesia in partial hip replacement surgery. Acta Anaesthesiol Scand. 2003;47(1):30-6. [pmid: 12492794].
116 Yun MJ. Analgesia before a spinal block for femoral neck fracture: fascia iliaca compartment block. Acta Anaesthesiol Scand. 2009;2009(10):1282-7.
117 Del Rosario E, Esteve N, Sernandez MJ, et al. Does femoral nerve analgesia impact the development of postoperative delirium in the elderly?: a retrospective investigation. Acute Pain. 2008;10(2):59-64.
118 Kocum A, Turkoz A, Ulger H, et al. Ropivacaine 0.25% is as effective as bupivacaine 0.25% in providing surgical anaesthesia for lumbar plexus and sciatic nerve block in high–risk patients: preliminary report. Anaesth Intensive Care. 2007;35(4):510-4. [pmid: 18020068].
119 Pedersen SJ, Borgbjerg FM, Schousboe B, et al. A comprehensive hip fracture program reduces complication rates and mortality. J Am Geriatr Soc. 2008;56(10):1831-8. [pmid: 19054201].
120 Gorodetskyi IG, Gorodnichenko AI, Tursin PS, et al. Non–invasive interactive neurostimulation in the post–operative recovery of patients with a trochanteric fracture of the femur: a randomised, controlled trial. J Bone Joint Surg Br. 2007;89(11):1488-94. [pmid: 17998187].
121 Lang T, Barker R, Steinlechner B, et al. TENS relieves acute posttraumatic hip pain during emergency transport. J Trauma. 2007;62(1):184-8. [pmid: 17215752].
122 Di Lorenzo L, Forte A, Formisano R, et al. Low back pain after unstable extracapsular hip fractures: randomized control trial on a specific training. Eura Medicophys. 2007;43(3):349-57. [pmid: 17595600].
123 Finsen V, Borset M, Buvik GE, et al. Preoperative traction in patients with hip fractures. Injury. 1992;23(4):242-4. [pmid: 1618564].
124 Jerre R, Doshe A, Karlsson J. Preoperative skin traction in patients with hip fractures is not useful. Clin Orthop Relat Res. 2000;(378):169-73.
125 Needoff M, Radford P, Langstaff R. Preoperative traction for hip fractures in the elderly: a clinical trial. Injury. 1993;24(5):317-8. [pmid: 8349341].
126 Resch S, Thorngren KG. Preoperative traction for hip fracture: a randomized comparison between skin and skeletal traction in 78 patients. Acta Orthop Scand. 1998;69(3):277-9. [pmid: 9703402].
127 Rosen JE, Chen FS, Hiebert R, et al. Efficacy of preoperative skin traction in hip fracture patients: a prospective, randomized study. J Orthop Trauma. 2001;15(2):81-5. [pmid: 11232658].
128 Anderson GH, Harper WM, Connolly CD, et al. Preoperative skin traction for fractures of the proximal femur: a randomised prospective trial. J Bone Joint Surg Br. 1993;75(5):794-6. [pmid: 8376442].
129 Ghnaimat M, Aldweri M, Hijazi A, et al. Preoperative skin traction for fractures of the proximal femur. J Bahrain Med Soc. 2005;17(4):240-2.
130 Saygi B, Ozkan K, Eceviz E, et al. Skin traction and placebo effect in the preoperative pain control of patients with collum and intertrochanteric femur fractures. Bull NYU Hosp Jt Dis. 2010;68(1):15-7. [pmid: 20345356].
131 Yip DK, Chan CF, Chiu PK, et al. Why are we still using pre–operative skin traction for hip fractures?. Int Orthop. 2002;26(6):361-4. [pmid: 12466869].
132 Vermeiren J, Brabants K, Van HM. Paralysis of the peroneal nerve following hip fracture treatment. Acta Orthop Belg. 1995;61(2):122-5. [pmid: 7597887].
133 Anderson GH, Harper WM, Badham J, Goodrich N, et al. The effect of pre–operative skin traction on pain and morbidity following fracture of the proximal femur: a randomised prospective trial. J Bone Joint Surg Br. 1993:42.
134 Barlas P. Ear acupressure appears to be an effective anxiolytic and analgesic modality in elderly people with a broken hip. Focus Alternative Compl Ther. 2006;11(2):128-9.
135 Barnes P. Preoperative pillow placement under the injured extremity had better analgesic effects than skin traction for hip fracture. Evid Based Nurs. 2002;5(1):24. [pmid: 11915802].
136 Chudinov A, Berkenstadt H, Salai M, Cahana A, et al. Continuous psoas compartment block for anesthesia and perioperative analgesia in patients with hip fractures [abstract]. Br J Anaesth. 1999:111.
137 Cuvillon P, Debureau S, Boisson C, Viales N, et al. Femoral block does not improve postoperative rehabilitation after hip fracture. Annual Meeting of the American Society of Anesthesiologists. October 12-16, 2002. Orlando, FL, USA. Anesthesiology Abstracts of Scientific Papers Annual Meeting. 2002. 2002:A912.
138 Del Rosario E, Esteve N, Perelló J, et al. Impact of regional analgesia in patients outcomes after hip fracture repair surgery. Meeting of the European Society of Anaesthesiology. 3–5 Jun 2006. Madrid, Spain. 2006:121.
139 Finsen V, Borset M, Buvik GE, Hauke I. Preoperative traction in patients with hip fractures. Acta Orthop Scand Suppl. 1991;(243):21-22. [pmid: 2042482].
140 Jerre R, Doshe A, Karlsson J. Preoperative treatment in patients with hip fractures. Acta Orthop Scand Suppl. 1999;(284):40.
141 Koval KJ. Preoperative skin traction was not useful for hip fractures. J Bone Joint Surg Am. 2001;83–A(2):303.
142 Koval K. 3–in–1 femoral nerve block provided fast pain relief for femoral neck fracture. J Bone Joint Surg. 2004;86–A(2):441.
143 Marhofer P, Schrogendorfer C, Wallner T, Kapral S, et al. Ultrasonographic guidance reduces the amount of local anaesthetic for 3–in–1 blocks. Br J Anaesth. 1998:112-3.
144 Needoff M, Radford P, Langstaff R. Preoperative traction for femoral neck fractures. Injury. 1993;24(4):280-281.
145 Resch S, Thorngren KG. Preoperative skin vs. skeletal traction in patients with hip fractures: the effect on pain and on patient flow characteristics [abstract]. Acta Orthop Scand Suppl. 1996;(270):34-5.
146 Hoda MQ, Saeed S, Afshan G, et al. Haemodynamic effects of intrathecal bupivacaine for surgical repair of hip fracture. J Pak Med Assoc. 2007;57(5):245-8. [pmid: 17571481].
147 Morrison RS, Magaziner J, McLaughlin MA, et al. The impact of post–operative pain on outcomes following hip fracture. Pain. 2003;103(3):303-11. [pmid: 12791436].
148 Pasero CL, McCaffery M. Reluctance to order opioids in elders. Am J Nurs. 1997;97(9):20. 23.
149 Closs SJ. An exploratory analysis of nurses' provision of postoperative analgesic drugs. J Adv Nurs. 1990;15(1):42-9. [pmid: 2303614].
150 Bitsch MS, Foss NB, Kristensen BB, et al. Pathogenesis of and management strategies for postoperative delirium after hip fracture: a review. Acta Orthop Scand. 2004;75(4):378-89. [pmid: 15370579].
151 Roofthooft E, Van d V. Low–dose spinal anaesthesia for Caesarean section to prevent spinal–induced hypotension. Curr Opin Anaesthesiol. 2008;21(3):259-62. [pmid: 18458538].
152 Malchow RJ, Black IH. The evolution of pain management in the critically ill trauma patient: emerging concepts from the global war on terrorism. Crit Care Med. 7 Suppl. 2008;36:S346-S357. [pmid: 18594262].
153 Penrod JD, Boockvar KS, Litke A, et al. Physical therapy and mobility 2 and 6 months after hip fracture. J Am Geriatr Soc. 2004;52(7):1114-20. [pmid: 15209649].