# Introduction

## Background

Hip fractures are a source of significant morbidity and mortality. Incidence increases substantially with age, rising for men and women, respectively, from 22.5 and 23.9 per 100,000 population at age 50, to 630.2 and 1,289.3 per 100,000 population by age 80.^1-4^ The impact of hip fractures is far reaching. Short-term mortality rates are high and range from 25 percent for women to 37 percent for men in the first year following a hip fracture.5 Furthermore, a large proportion of those patients who survive never recover to their prefracture level of function,6-8 and approximately 25 to 50 percent of elderly patients with hip fractures have not returned home by 1 year postfracture.9 Up to 25 percent of hip fractures occur in continuing care facilities (long-term residential care for dependent people).10, 11 Because of poor functional recovery, health service utilization associated with recovery is substantially increased for at least 1 year, with much of the health care cost attributable to subsequent long-term care.1, 12-14

Pain following hip fracture has been associated with delirium, depression, sleep disturbance, and decreased response to interventions for other disease states.15-17 Therefore, it is important to treat and manage complaints of pain adequately during acute treatment for hip fracture. Furthermore, poorly managed postoperative pain is associated with delayed ambulation, pulmonary complications, and delayed transition to lower levels of care.18

Hip fracture patients require a continuum of pain management from the time of prehospital admission through the completion of final rehabilitation. Therefore the interventions administered to relieve pain in this population can be divided according to both the timing of the intervention (e.g., pre-, peri-, and postoperative) and according to their classification (e.g., systemic analgesia, nerve blocks, etc.).

According to the timing of the intervention, preoperative pain management has traditionally been achieved using systemic analgesia and in some cases, lower limb traction. Recently, nerve blocks, which block the nerve impulses from reaching the sensory cortex, have been introduced.

Intra-operative pain management has also traditionally been achieved with systemic analgesia in association with general anesthesia. Even so, neuraxial anesthesia is gaining momentum as a replacement for general anesthesia.

Postoperative pain management is usually accomplished by a more diverse array of interventions including systemic analgesia, nerve blocks, physical therapy, and transcutaneous electrical nerve stimulation (TENS).

## Interventions

Pain management interventions can be divided into pharmacological and nonpharmacological interventions. Pharmacological interventions include systemic analgesia and medications used in nerve blocks and neuraxial anesthesia (e.g., bupivacaine). Nonpharmacological interventions include TENS, acupressure, or stabilization of the fracture using traction. The following broad categories represent the interventions covered by this report.

### Systemic Analgesia

This classification of intervention is broad and encompasses both narcotic and non-narcotic medications. The general goal is to provide pharmacologic analgesia although some also have anti-inflammatory properties.

Opiates (e.g., morphine) can be used at all stages of pain management to treat mild to severe pain.19 Fentanyl, primarily targets the mu receptors in the brain and spinal cord and, is used in the treatment of severe pain. Sufentanil is 5–10 times more potent than fentanyl and, due to its immediate onset of action and its limited accumulation, it is ideal for short, quick action.

Nonsteroidal anti-inflammatory drugs (NSAIDs) (e.g., diclofenac) are used for their analgesic properties and act by inhibiting both cyclooxygenase (COX) isoenzymes (COX-1 and COX-2).20 Acetaminophen, a commonly used analgesic, has minimal inhibition of COX-1 and COX-2, with appreciable inhibition of central COX-3, but its precise mechanism for analgesia has not been confirmed. The use of COX-II selective inhibitors (coxibs) has fluctuated since their introduction on the U.S. market in the 1990s with the current use of coxibs in decline.

### Anesthesia

Anesthesia can generally be divided into general and neuraxial, with the latter constituting spinal and epidural anesthesia. Pain management during general anesthesia is usually accomplished by the use of pharmacological systemic analgesia (e.g., opioids). During neuraxial anesthesia, injection of a local anesthetic into the epidural or subarachnoid space (e.g., spinal anesthesia) causes pain relief and often does not require additional pain medications.

### Complementary and Alternative Medicine (CAM)

Complementary and alternative medicine (CAM) has been defined as a group of diverse medical and health care systems, practices, and products that are not generally considered part of conventional medicine (i.e., medicine as practiced by holders of M.D. (medical doctor) and D.O. (doctor of osteopathy) degrees and by allied health professionals, such as physical therapists, psychologists, and registered nurses).21 CAM practices are often grouped into broad categories, such as natural products, mind-body medicine, and manipulative and body-based practices. In this report, two CAM practices were identified as having been used with hip fracture patients: acupressure and the Jacobson relaxation technique.

According to traditional Chinese acupuncture, auricular acupressure involves the placing of tiny beads onto the outer ear at acupuncture points, thereby stimulating the corresponding acupuncture points. Bilateral auricular acupressure can be performed at sites known to decrease pain and anxiety (e.g., shenmen, hip, valium point).22 Using these body points, areas can be stimulated to direct energy flow.

Another CAM procedure used for hip fracture patients is the Jacobson relaxation technique. This involves a two-step process of contracting and relaxing specific muscles. With practice the patient learns which muscles are related to pain and relaxes them.

### Multimodal Pain Management

Multimodal pain management is the use of multiple pain management strategies (consecutively or in parallel) as part of the clinical pathway for patients with hip fractures. The goal is to decrease pain to a greater extent than with one intervention alone.

### Nerve Blocks

Nerve blocks include the lateral cutaneous nerve of the thigh, femoral nerve, sciatic nerve, 3-in-1 nerve block (femoral, obturator, and sciatic nerves), psoas (lumbar plexus), or continuous epidural block.23 Local anesthetics (e.g., bupivacine) are used in regional nerve blocks to prevent the generation and conduction of nerve impulses to the spinal column and brain.24 Additional medications used with nerve blocks include clonidine, morphine, fentanyl, and sulfetanil.

### Rehabilitation

Rehabilitation is a standard part of postoperative care in patients with hip fractures to increase mobility and reduce pain. The goal is to increase muscle strength and range of motion as soon as possible following hip fracture. One of the major factors that can limit patient participation in rehabilitation is the degree of delirium and pain that the patient may be experiencing.

### Traction

Preoperative skin or skeletal traction was traditionally standard care in this patient population. The theory is that by maintaining the lower limb stretched, using 5 to 10 pounds, intracapsular pressure and pain is decreased, and fracture reduction is made easier. However, a recent Cochrane systematic review of 10 randomized controlled trials (1,546 participants) reported no benefits for traction use.25

Skin traction is used to stabilize a fractured leg and to decrease pain and the risk of surgical complications prior to any operation. Skin traction is applied by using adhesive tape, bandaging the limb, and placing it on a traction sled with an appropriate weight hung from it.20, 26 Foam boot traction, a form of skin traction, uses a foam boot strapped around the leg and placed on a traction sled with an appropriate weight attached.26 Skeletal traction involves passing a metal pin through the proximal tibia or distal femur, under local anesthesia. Traction is applied using ropes and weights attached to the end of the pin.20

### Transcutaneous Electrical Nerve Stimulation (TENS)

TENS uses electrodes to apply electrical energy to peripheral nerves to treat acute and chronic musculoskeletal pain. Electrical stimulation can be administered at varying amplitudes and frequencies, depending on the indication.27

## Outcomes

The patient’s self-report of pain is the gold standard for evaluating its character and intensity.15 However, those with dementia or acute delirium may have difficulty reporting pain levels. Acute delirium, or confusion, following hip fracture may be a complication of the fracture, the resulting pain due to tissue trauma and/or the pain management interventions used. The potential for underreporting of pain has direct ramifications for the hip fracture population, as many patients are frail older people with postoperative confusion and an impaired ability to communicate.28-31

The most commonly used measure of pain in clinical settings is the visual analogue scale (VAS).32 It consists of a 100mm unmarked line printed where the patients are instructed to point to the position on the line to indicate how much pain they are currently feeling. The far left end of the line indicates “No pain” and the far right end of the line indicates “Worst pain ever.” Its ease of use, especially with older patients, reproducible results and extensive use in clinical practice makes it one of the first choices among pain measurement scales.33 Additionally, it has been shown not to be biased by the severity of pain.34

Other commonly used scales include numerical, verbal, and facial pain scales. The numerical scales usually consist of a number between zero and 10, and the patients are instructed to give a number relating to how much pain they are currently feeling, with the higher numbers indicating greater pain intensity. Many variations of this scale exist including a numerical scale of zero to three, one to five, etc. Numerical scales have been shown to have a linear correlation with the VAS and don’t require the use of any printed material.35, 36

With regard to clinically important effect size differences for pain measurements, no exact cutoff has been defined in the medical literature; however, it has been widely accepted as ranging from 20 to 30 percent absolute pain reduction. This would reflect an additional 30mm of absolute difference on the VAS.

Most research to date has focused on the management of acute pain, the expected sensory and emotional response to injury, which lasts for the duration of the injury and healing (i.e., up to 30 days post hip fracture). It is possible that pain following a hip fracture has longer-term effects on recovery as has been seen in recovery from hip replacement surgery.

The need to improve recovery after hip fracture, particularly among frail elderly patients, is a pressing worldwide problem that will only increase in the future as the population ages.37 Synthesized data are lacking regarding pain management after hip fracture; therefore, our review will be of interest to patients and families, the medical community and health care decisionmakers. The review will also elucidate evidence on important subgroups of patients and interventions for which further research is needed.

## Scope and Key Questions

We have focused the key questions using the PICOTS framework (population, intervention, comparison, outcome, timing, and setting) as follows:

### Key Question 1

In older adults (≥50 years) admitted to the hospital following acute hip fracture, what is the effectiveness of pharmacologic and/or nonpharmacologic pain management interventions for controlling acute (up to 30 days postfracture) and chronic pain (up to 1 year postfracture) compared with usual care or other interventions in all settings?

### Key Question 2

In older adults (≥50 years) admitted to the hospital following acute hip fracture, what is the effectiveness of pharmacologic and/or nonpharmacologic pain management interventions on other outcomes up to 1 year postfracture compared with usual care or other interventions in all settings? Other outcomes include:

a. Mortality (30-day and up to 1 year postfracture)
b. Functional status
c. Pain medication use; change in type and quantity
d. Mental status
e. Health-related quality of life
f. Quality of sleep in the hospital
g. Ability to participate in rehabilitation
h. Return to prefracture living arrangements
i. Health services utilization

### Key Question 3

In older adults (≥50 years) admitted to the hospital following acute hip fracture, what is the nature and frequency of adverse effects that are directly or indirectly associated with pharmacologic and nonpharmacologic pain management interventions up to 1 year postfracture compared with usual care or other interventions in all settings?

### Key Question 4

In older adults (≥50 years) admitted to the hospital following acute hip fracture, how do the effectiveness and safety of pharmacologic and nonpharmacologic pain management interventions vary in differing subpopulations following acute hip fracture up to 1 year after fracture compared with usual care or other interventions in all settings?

Important refinement points regarding the key questions:

- Population(s):
  Older adults of either sex who were diagnosed as having an acute hip fracture resulting from low-energy trauma (e.g., slip and fall) were included. This includes patients with intracapsular (e.g., subcapital and femoral neck) and extracapsular (e.g., basal, trochanteric, intertrochanteric, and subtrochanteric) fractures regardless of whether surgical repair was performed. There were no restrictions on comorbidities or baseline functionality.
  Patients with hip fracture due to the following etiologies were not considered: pathologic hip fractures (e.g., metastatic fractures, Paget’s disease); femoral head fractures; periprosthetic fractures (i.e., post-hip replacement fractures/arthroplasty population); fractures resulting from high energy trauma (e.g., motor vehicle crashes, falls from heights, etc.).
- Interventions:
  We considered all interventions, alone or in combination, with various methods of administration and modes of delivery, and at various time points during the care pathway (e.g., preoperative, intra-operative, postoperative, rehabilitation, and following discharge from acute care). The same intervention may be administered at different time points (e.g., epidural block for preoperative analgesia and intra-operatively for anesthesia). Interventions included traditional and nontraditional medications/interventions (e.g., natural health products). Interventions that were directly related to surgical/nonsurgical treatment of the hip fracture (e.g., reduction, fixation, hemiarthroplasty, total hip replacement) were not considered.
- Comparators:
  Comparators of interest were defined in the primary studies. This included, but was not limited to, opioid, nonopioid, or NSAIDS, and nonpharmacological comparators.
- Outcomes for each question:
  For KQ1, pain had to be assessed using a validated pain measurement tool—either patient defined or proxy reported.
  For KQ2, all reported outcomes that were directly or indirectly related to the intervention for pain management were investigated.
  For KQ3, all reported adverse effects that were directly or indirectly associated to the intervention for pain management (e.g., medication complications such as constipation or gastrointestinal bleeding; pain interventions (e.g., femoral blocks) that may delay ambulation) were investigated. Adverse effects of interventions directly related to surgical/nonsurgical/medical treatment of the hip fracture (e.g., wound infection, etc.) were not investigated.
  For KQ4: Subgroups to be investigated included sex, age, race, marital status, comorbidities, body mass index, prefracture functional status, and family distress.
- Timing:
  We included all followup time points from the time of the trauma leading to the hip fracture and thereafter.
- Settings:
  Settings included, but were not limited to, emergency department, hospital, rehabilitation facilities, skilled nursing facility, subacute care facility, and place of residence.

Figure 1 provides an analytic framework to illustrate the population, interventions, and outcomes that guided the literature search and synthesis. The figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates how pharmacologic and nonpharmacologic pain management interventions, alone or in combination, may result in (1) intermediate outcomes such as control of acute pain, pain medication use, the ability to participate in rehabilitation, the quality of sleep in hospital, and length of stay, and (2) long-term outcomes such as chronic pain, changes in the mental status, the functional status (e.g., activities of daily living), the ability to return to prefracture place of residence, health-related quality of life, health service utilization, and mortality. Also, adverse effects may occur at any point after the treatment is received (e.g., medication adverse effects such as constipation, gastrointestinal irritation, rash).

Figure 1 Analytic framework for pain management interventions

Analytic framework illustrating the population, interventions, and outcomes that guided the literature search and synthesis. The figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates how pharmacologic and nonpharmacologic pain management interventions, alone or in combination, may result in (1) intermediate outcomes such as control of acute pain, pain medication use, the ability to participate in rehabilitation, the quality of sleep in hospital, and length of stay, and (2) long-term outcomes such as chronic pain, changes in the mental status, the functional status (e.g., activities of daily living), the ability to return to prefracture place of residence, health-related quality of life, health service utilization, and mortality. Also, adverse effects may occur at any point after the treatment is received (e.g., medication adverse effects such as constipation, gastrointestinal irritation, rash).