# Discussion

## Overview

Hip fracture due to low-energy trauma (e.g., slip and fall) is a common condition in the geriatric population. Today, nearly all hip fractures in the developed world are surgically treated and represent one of the most common emergency orthopedic procedures. Even so, the associated morbidity and mortality of hip fracture are significant. One year mortality for hip fracture is estimated to be up to 37 percent, and a large proportion of those patients who do survive will never recover to their prefracture level of function.5

Hip fractures are frequently characterized by acute pre-, peri- and postoperative pain; with pain manifesting on a number of fronts. Preoperative pain arises from injury to the muscles and joint capsule from the serrated edges of broken bone and the associated release of local inflammatory factors. Immediate postoperative pain is attributed to the procedures required for the surgical fixation of the femur (e.g., skin incision, femur stabilization). Patients with greater postoperative pain are slower to mobilize and have longer hospital stays.147 Additionally, pain at all stages is aggravated by psychological stress and anxiety.

Pain that is not properly managed in geriatric patients can have deleterious effects in terms of increased risk of cardiovascular adverse effects and postoperative delirium. While little is known about the impact of postoperative pain in older adults, physicians are hesitant to prescribe opioid analgesics for fear of adverse effects such as delirium, nausea, respiratory depression, drowsiness, hypotension, and constipation as these events have been demonstrated to occur more frequently in the geriatric population.147, 148 Others have reported that postoperative pain management in older adults is more commonly undertreated and untreated than in younger patients.149 This may reflect a belief among patients and health professionals that pain in the elderly is a natural phenomenon that is self-limiting and should be left to take its course without any intervention.19

This comparative effectiveness review (CER) identified, summarized, critically appraised, and compared the evidence on pain management interventions following hip fracture. We conducted a comprehensive search of over 25 electronic databases for published studies and ongoing trials. In addition, we hand searched major conference proceedings in order to identify additional relevant studies. Finally, we did not exclude studies on the basis of their published language. All these safeguards were implemented to help identify the evidence and limit the possibility of publication bias. To reduce the possibility of selection bias, we performed duplicate, independent study selection, and all data were independently extracted by two reviewers.

## Summary of Findings

Table 22 summarizes the findings for key outcomes for each intervention. Many studies within this review included small numbers of participants and reported only a small number of outcome measures. Several studies had a poor level of methodological rigor, in particular regarding their inherent risk of bias. Of the 65 included trials, the majority were assessed with an unclear risk for bias. Twenty-eight trials were considered to be at high risk of bias while only two were considered to be of low risk of bias. The strength of the evidence for most outcomes was considered insufficient or low. This is a reflection of the general poor methodological quality, lack of study power, and number of studies investigating each intervention in this population.

Table 22 Summary of evidence for key outcomes for pain management following hip fracture

Outcome | Comparison (# studies) | Strength of evidence | Summary
Systemic analgesia
Acute pain | Parecoxib IV vs. diclofenac ± meperidine IM (1 RCT) Intrathecal isotonic clonidine vs. intrathecal hypertonic clonidine (1 RCT) Lysine clonixinate vs. metamizole (1 RCT) | Insufficient | Significant effect in favor of parecoxib IV (MD = -0.70; 95% CI -1.04, -0.36) Significant effect in favor of intrathecal isotonic clonidine (MD = -1.69; 95% CI -2.01, -1.37) No significant difference
Acute pain at rest | Lysine clonixinate vs. metamizole (1 RCT) | Insufficient | No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | Lysine clonixinate vs. metamizole (1 RCT) | Insufficient | No significant difference
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Anesthesia: spinal vs. general anesthesia
Acute pain | Spinal vs. general anesthesia (1 RCT) | Insufficient | Significant effect in favor of spinal anesthesia (MD = -0.86; 95% CI -1.30, -0.42)
Chronic pain | None | Insufficient | No data
30-day mortality | Spinal vs. general anesthesia (2 RCTs, 2 cohort studies) | Low | No significant difference
Delirium | Spinal vs. general anesthesia (1 RCT) | Insufficient | No significant difference
Myocardial infarction | Spinal vs. general anesthesia (2 RCT) | Insufficient | No significant difference
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Anesthesia: spinal – continuous vs. single administration
Acute pain | None | Insufficient | No data
Chronic pain | None | Insufficient | No data
30-day mortality | Continuous vs. single administration (3 RCTs, 1 cohort study) | Low | No significant difference
Delirium | Continuous vs. single administration (2 RCTs) | Low | No significant difference
Myocardial infarction | Continuous vs. single administration (1 RCT) | Insufficient | No significant difference
Renal failure | None | Insufficient | No data
Stroke | Continuous vs. single administration (1 RCT) | Insufficient | No significant difference
Anesthesia: spinal – addition of other medications
Acute pain | Addition of fentanyl vs. standard spinal anesthesia (1 RCT) Addition of morphine vs. standard spinal anesthesia (1 RCT) Addition of sufentanil vs. standard spinal anesthesia (1 RCT) | Insufficient Insufficient Insufficient | No significant difference No significant difference No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | Addition of morphine vs. standard spinal anesthesia (1 RCT) | Insufficient | No significant difference
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Anesthesia: spinal – different doses
Acute pain | Bupivacaine 2.5mg vs. 5mg (1 cohort study) | Insufficient | No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | Bupivacaine 4mg vs. 12mg (1 cohort study) | Insufficient | No significant difference
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Complementary and alternative medicine
Acute pain | Acupressure vs. standard care (1 RCT) Relaxation vs. standard care (1 RCT) | Insufficient Insufficient | No significant difference No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | None | Insufficient | No data
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Multimodal pain management
Acute pain | None | Insufficient | No data
Chronic pain | None | Insufficient | No data
30-day mortality | Multimodal pain management vs. standard care (1 cohort study) | Insufficient | No significant difference
Delirium | Multimodal pain management vs. standard care (1 cohort study) | Insufficient | No significant difference
Myocardial infarction | Multimodal pain management vs. standard care (1 cohort study) | Insufficient | No significant difference
Renal failure | None | Insufficient | No data
Stroke | Multimodal pain management vs. standard care (1 cohort study) | Insufficient | No significant difference
Nerve blockade
Acute pain | Nerve block vs. no nerve block (11 RCTs) | Moderate | Significant effect in favor of nerve block in subgroup analyses
Pain on movement | Nerve block vs. no nerve block (4 RCTs) | Low | Significant effect in favor of nerve block in subgroup analyses
Pain at rest | Nerve block vs. no nerve block (3 RCTs) | Low | Data inconsistent for conclusions to be made
Day 1 pain | Nerve block vs. no nerve block (1 RCTs) | Insufficient | No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | Nerve block vs. no nerve block (4 RCTs) | Low | No significant difference
Delirium | Nerve block vs. no nerve block (3 RCTs, 2 cohort studies) | Moderate | Significant effect in favor of nerve block (OR_RCT_ = 0.36; 95% CI 0.17, 0.74) (OR_Cohort_ = 0.24; 95% CI 0.08, 0.72)
Myocardial infarction | Nerve block vs. no nerve block (2 RCTs, 1 cohort study) | Insufficient | No significant difference
Stroke | Nerve block vs. no nerve block (1 RCT, 1 cohort study) | Insufficient | No significant difference
Renal failure | None | Insufficient | No data
Nerve blockade vs. regional anesthesia
Acute pain | Nerve block vs. regional anesthesia (3 RCTs) | Low | No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | Nerve block vs. regional anesthesia (1 RCT) | Insufficient | No significant difference
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Nerve Blocks: ropivacaine vs. bupivacaine
Acute pain | None | Insufficient | No data
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | Ropivacaine vs. bupivacaine (1 cohort study) | Insufficient | No significant difference
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Neurostimulation
Acute pain | Neurostimulation vs. standard care (2 RCTs) | Insufficient | Significant effect in favor of neurostimulation (MD = -2.79; 95% CI -4.95, -0.64)
Pain on movement | Neurostimulation vs. standard care (1 RCT) | Insufficient | Significant effect in favor of neurostimulation (MD = -3.90; 95% CI -6.22, -1.58)
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | None | Insufficient | No data
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Rehabilitation
Acute pain | Physical therapy vs. standard care (1 RCT) | Insufficient | Significant effect in favor of physical therapy (MD = -1.39; 95% CI -2.27, -0.51)
Chronic pain | None | Insufficient | No data
30-day mortality | None | Insufficient | No data
Delirium | None | Insufficient | No data
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data
Traction
Acute pain | Skin traction vs. no traction (7 RCTs) Skin traction vs. skeletal traction (1 RCT) | Low Insufficient | No significant difference No significant difference
Chronic pain | None | Insufficient | No data
30-day mortality | Skin traction vs. no traction (1 RCT) Skeletal traction vs. no traction (1 RCT) | Insufficient Insufficient | No significant difference No significant difference
Delirium | None | Insufficient | No data
Myocardial infarction | None | Insufficient | No data
Renal failure | None | Insufficient | No data
Stroke | None | Insufficient | No data

CI = confidence interval; IM = intramuscular; IV = intravenous; MD = mean difference; OR = odds ratio; RCT = randomized controlled trial; SMD = standardized mean difference

The majority of studies included in this review fell into the categories of nerve blocks (n = 30),88-106, 108-111, 113-119 and anesthesia (n = 26),56-58, 60-73, 75-77, 79-83, 145 while fewer studies dealt with traction (n = 11),26, 123-132 systemic analgesia (n = 3),41, 42, 55 complementary and alternative medicine (n = 2),43, 54 multimodal pain management (n = 2),86, 87 neurostimulation (n = 2),120, 121 and rehabilitation (n = 1).122 Although we restricted the publication of studies from 1990, there appears to be a trend for more recent studies to examine pain management following hip fracture (median publication date = 2003; IQR: 1998 to 2007). Most studies included in this review were RCTs conducted in single university settings in Europe with few studies included from North American sites.

Most studies examined the pharmaceutical management of peri- and postoperative pain in this patient population. Short-term (in hospital) postoperative pain was the most frequent pain examined. None of the studies examined the longer-term pain associated with hip fracture; that is pain extending beyond the initial 30 days of hip fracture. Management of pain was often evaluated from few perspectives such as reported pain, mortality and adverse effects. The ramifications of pain were infrequently examined in terms of functional recovery, HRQOL, and health services utilization.

Although the majority of hip fracture patients are elderly women, this patient population consists of subgroups that warrant further investigation. For instance, almost half of the studies (n = 31) reported excluding patients with any cognitive impairment, or inability to cooperate. Researchers have reported that approximately 35 percent of the elderly hip fracture population includes patients with some degree of cognitive impairment, be it, dementia, delirium, or acute confusion.150 None of the included studies in this CER exclusively examined participants from institutional settings or with cognitive impairment, which reduces the external validity or generalizability of our findings to the overall hip fracture patient population.

Regardless of these limitations, some general consensus can be made from this review.

Key Questions 1 and 2: Pain management and other outcomes. The available evidence suggests that, in general, the nerve blockade is effective for the relief of the acute pain of hip fracture compared with standard care alone. Nerve blockade also reduces the need for supplemental systemic analgesia and may reduce the risk of delirium, a common and dangerous complication of hip fracture. However, most studies were limited to either assessing acute pain or examining use of additional analgesia and did not report on how nerve blockades may affect rehabilitation such as ambulation or mobility if the blockade has both sensory and motor effects. Furthermore, our decision to extract followup data demonstrating the greatest improvement for the intervention arm may have introduced a bias favoring the intervention. However, we do not expect this to have had a major impact because most studies presented data for only one time point. Nerve blockade of the types described in this CER are within the repertoire of most practicing anesthesiologists, but many institutions are deterred from providing them due to the additional time, effort, and supervision they require if they are to work well.

This review also calls into question some commonly held beliefs about the care of those with hip fracture. Preoperative traction, for instance, does not appear to reduce pain or complications in any demonstrable way compared with no traction. These results are consistent with those of the previously published Cochrane review on this topic.25 While the strength of evidence is insufficient to make firm conclusions, spinal anesthesia used during the operation to fix the fracture, while effective and safe, does not demonstrably differ in rates of mortality, delirium, or other medical complications of the fracture as compared with general anesthesia. Adding other agents to plain local anesthetic for spinal anesthesia does not seem to make any difference to outcomes outside the operating room. Furthermore, bigger doses of spinal anesthetic may cause more hypotension issues without improving pain control or outcome.151

The evidence guiding the selection of systemic drugs for hip fracture analgesia is very scant and warrants further study.

This review also finds that acupressure, relaxation therapy, and transcutaneous electrical neurostimulation are safe interventions that may be associated with potentially clinically meaningful reductions in pain after hip fracture, but further evidence is warranted before any firm conclusions are reached. The obvious drawback of these is the amount of skilled health provider time that must be used to apply and/or teach these modalities correctly. Physical therapy regimens may potentially improve pain control in the postoperative period, but there is insufficient evidence to draw firm conclusions.

No evidence could be found that any analgesic intervention attenuated the progression of acute to chronic pain. Furthermore, there was insufficient evidence to show that multimodal analgesia (combinations of analgesic interventions) yields improvements over single modalities. Further research in this area might profitably focus on combinations of interventions that are known to be effective in isolation.

Key Question 3: Adverse effects. Although most studies reported on adverse effects associated with the specific interventions being evaluated, the included studies were small; thus most studies reported few, if any, adverse effects. Moreover, the horizon for adverse effects was over a short period of time, usually within the acute care setting, and did not examine the development of adverse effects outside of the acute care setting.

Key Question 4: Effectiveness and safety of pain management in differing subpopulations. This question was addressed by limited data from two RCTs of nerve blocks—one was restricted participants with heart disease and to participants who were independent prior to the hip fracture. The only significant difference reported was a reduction in acute pain in participants with heart disease who received a nerve block.

## Applicability

The study populations in this body of evidence were relatively homogeneous. Studies included patients with all types of hip fractures due to low energy trauma. All participants were over 50 years of age; the mean age in most studies clustered between 77 and 82 years. Most patients were female. Studies generally included a mixture of hip fracture types and minimal data for specific fracture types were available. A majority of studies excluded patients on the basis of mental status (i.e., patients with dementia or other cognitive disorders). Studies did not generally provide information of the pre-fracture dwelling (i.e., community vs. institution) or social status/support of participants (e.g., married, living with relatives). Interventions were provided across the spectrum of the care pathway from preoperative to postoperative; however, no studies provided data on long-term followup for this patient population.

The other issue regarding applicability for this body of evidence relates to the practitioners administering the interventions (e.g., anesthetists, surgeons, physical therapists, or other health care providers). Outcome effects may differ between the trials and real life practice based on practitioners’ skills and experience, volume of surgery, and variations or rigor surrounding cointerventions or procedural protocols.

## Limitations of Existing Evidence

To our knowledge, no specific evidence-based guidelines for pain management in hip fracture are available; however, this may be indirectly related to the fact that to the best of our knowledge there currently are no committees or task force groups for pain management in hip fracture. Further, there are no recommended standardized outcomes for assessing pain specific to this patient population. This patient population is different from other surgical patients in that they are older and predominantly women with a significant number of coexisting conditions, commonly including altered cognition.

Evaluations of common subpopulations found within the overall hip fracture patient populations were infrequent. A large proportion of the included studies excluded patients with altered cognition due to delirium or dementia, despite the high prevalence of dementia in the hip fracture population. Further, most studies performed limited assessment of either delirium or dementia in their participants using broad cognitive assessment tools (e.g., Mini-Mental State Examination) that were unable to distinguish between onset of dementia or acute delirium. In addition, although multiple comorbidities are common in patients who experience a hip fracture, risk adjustments for illness/health severity were not reported, nor were most of the subpopulations that we intended to investigate (e.g., prefracture functional status). These are all factors that could potentially affect reported pain levels.

Included studies were primarily pharmacologic interventions and represented evaluation by a single discipline (e.g., anesthesiology) despite evidence in other clinical areas that optimal chronic pain management is multidisciplinary.19, 152 In addition studies were primarily conducted in single centers in Europe or Asia with small samples sizes; minimal evidence was available from centers in North America. Study quality was low and thus, clear evidence to support clinical decision making for interventions is limited. Also the choice to limit the search to 1990 might have led to missing some earlier studies on pain management in this population, but its effect is not expected to change the conclusions of this report.

In addition, lack of standardized outcome reporting or use of standardized measures limits the interpretation and applicability of the results. Although pain and function are correlated,147 most outcomes focused on pain relief and did not evaluate if the intervention had any positive or negative effects on the patients’ ability to mobilize postoperatively, a factor that is linked to recovery levels following hip fracture.153 There was no evidence about managing pain after hospital discharge or examining the long-term effects of early postoperative pain management on subsequent recovery.

Finally, because of the low incidence of complications following surgery, no individual included study had adequate numbers to detect associated adverse effects with the interventions. For example, the rationale for using a nerve block for pain management following a hip fracture is primarily to enable pain to be controlled with lower doses of systemic analgesia. Although the studies demonstrated a reduced requirement for systemic analgesics, this is only clinically useful if it associated with a reduction in the adverse effects of such analgesic use.

## Recommendations for Future Research

Multicenter research studies. Adequately powered multi-center research studies are needed to provide a comprehensive assessment of safe, effective, and appropriate pain management following a hip fracture. Studies need to be large enough to allow subgroup analyses by age, gender, comorbidities, functional groups (e.g., independent vs. dependent in ambulation), or multiple complex interventions (e.g. 3-in-1 vs. femoral block only). In addition, researchers need to consider inclusion of common subpopulations of hip fracture patients. In particular, those with altered cognition who make up a substantial proportion of the overall hip fracture patient population should be included in future studies of pain management following hip fracture.

Outcomes. Standardization of outcomes and outcome measures will allow easier and meaningful comparisons across different interventions and among studies. The types of outcomes reported do not reflect the multidimensional nature of pain. Relevant outcomes should include validated pain scores, prescription of opiates and other agents, adverse effects or complications attributable or related to the intervention. There should also be consideration for use of nonverbal pain assessment scales to allow assessment of pain in patients with communication issues such as delirium and/or dementia. Associated outcomes of pain such as function, quality of life, and time to recovery should also be evaluated.

The evaluation of pain should include preoperative assessment, daily assessments while in hospital, as well as regular and longer term followup of pain beyond the acute hospital setting. Researchers should consider pain outcomes up to 6 months post-hip fracture to determine the pattern of pain recovery and whether early effective pain management techniques affects ultimate recovery levels.

Methods. Investigators should consider including patients with cognitive impairment in future studies as this group represents a substantial proportion of the hip fracture patient population. Better cognitive screening and assessment tools are needed to determine the presence of delirium and to be able to distinguish between acute delirium and chronic underlying or new onset dementia. Future research should seek to minimize bias by blinding outcome assessors, use of validated and standardized outcome assessment instruments, adequate allocation concealment (where applicable), and appropriate handling and reporting of missing data.

## Conclusions

For the majority of interventions, there are only sparse data available, which precludes firm conclusions for any single approach or for the optimal overall pain management following nonpathological hip fracture due to low energy trauma. The paucity of evidence related to long-term outcomes and the fact that the majority of the data is derived from studies of low methodological quality or from study designs associated with higher risk of bias (i.e., cohort studies). Overall, the evidence shows that most interventions result in improvements in short-term pain scores; however, few differences of long-term clinical importance are evident when comparisons between interventions are available. The rates of complications were generally low and the majority of complications were not significantly different among the interventions. Well-designed and -powered, long-term trials are needed in order to determine the relative effectiveness of pain interventions for hip fracture patients. Until then, pain management in this population will rely heavily on availability of the interventions, staff skills and training and pre-existing patient comorbidities.