# GRADE Tables: Assessing the Strength of Evidence

Each major outcome was provided a summary of the body of evidence (e.g., number of studies, study designs), the quality of the evidence, the results of pooling (if performed), and an overall grade for the quality of evidence for each outcome using the AHRQ GRADE approach. Randomized trials were considered to high quality unless downgraded as a result of concerns of important limitations (e.g., high risk of bias, inconsistent results, etc.). Cohorts were considered to be lower quality unless upgraded as a result of both confidence in the lack of any major limitations and characterized by having special strengths (e.g., large effect size).

Table J-1 Analgesia for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) - IM Analgesia (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Precise | Publication bias: Not investigated | 35 | 55 | - | MD 0.7 lower (1.04 to 0.36 lower) | INSUFFICIENT
Acute pain (post-treatment means) - Oral analgesia (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 48 | 46 | - | MD 0.43 lower (1.3 lower to 0.44 higher) | INSUFFICIENT
Acute pain (post-treatment means) - Intrathecal analgesia (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Precise | Publication bias: Not investigated | 15 | 15 | - | MD 1.69 lower (2.01 to 1.37 lower) | INSUFFICIENT
Acute pain (rest) - Oral analgesia (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 48 | 46 | - | MD 0.43 lower (1.3 lower to 0.44 higher) | INSUFFICIENT
Delirium - Oral analgesia
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 1/48 (2.1%) | 1/46 (2.2%) | OR 0.96 (0.06 to 15.77) | 1 fewer per 1,000 (from 20 fewer to 238 more) | INSUFFICIENT

RCT = randomized controlled trial; IM = intramuscular; MD = mean difference; OR = odds ratio

Table J-2 Spinal versus general anesthesia for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) - Spinal anesthesia (single) (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 15 | 15 | - | MD 0.86 lower (1.3 to 0.42 lower) | INSUFFICIENT
Delirium - Spinal anesthesia (single)
3 | 1 RCT; 2 Cohorts | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 8/15 (53.3%) | 9/15 (60%) | OR 0.76 (0.18 to 3.24) | 67 fewer per 1,000 (from 387 fewer to 229 more) | INSUFFICIENT
Mortality 30 days
4 | 2 RCTs; 5 Cohorts | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 10/53 (18.9%) | 5/46 (10.9%) | OR 1.73 (0.53 to 5.68) | 66 more per 1,000 (from 48 fewer to 301 more) | LOW
Myocardial Infarction
2 | 1 RCT; 1 Cohort | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 1/29 (3.4%) | 0/14 (0%) | OR 1.55 (0.06 to 42.91) | 0 more per 1,000 (from 0 fewer to 0 more) | INSUFFICIENT
Renal failure
1 | Cohort | High | Unkown | Direct | Imprecise | Publication bias: Not investigated | 1/168 (0.6%) | 2/167 (1.2%) | OR 0.49 (0.04 to 5.5) | 6 fewer per 1,000 (from 11 fewer to 51 more) | INSUFFICIENT
Stroke
2 | Cohorts | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 3/448 (0.7%) | 4/529 (0.8%) | 3/448 (0.7%) | 0 fewer per 1,000 (from 6 fewer to 23 more) | INSUFFICIENT

Table J-3 Spinal anesthesia (continuous vs. single administration) for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Delirium
2 | RCTs | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 5/67 (7.5%) | 4/67 (6%) | OR 1.27 (0.32 to 4.99) | 15 more per 1,000 (from 40 fewer to 181 more) | LOW
Mortality 30 days
4 | 3 RCTs; 1 Cohort | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 2/81 (2.5%) | 4/82 (4.9%) | OR 0.46 (0.07 to 3.02) | 26 fewer per 1,000 (from 45 fewer to 85 more) | INSUFFICIENT
Myocardial Infarction
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 0/14 (0%) | 1/15 (6.7%) | OR 0.33 (0.01 to 8.88) | 44 fewer per 1,000 (from 66 fewer to 321 more) | INSUFFICIENT
Stroke
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 0/37 (0%) | 0/37 (0%) | not pooled | not pooled | INSUFFICIENT

Table J-4 Spinal anesthesia (single): addition of fentanyl for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 20 | 20 | - | not pooled | INSUFFICIENT
Day 1 pain
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 6/40 (15%) | 5/40 (12.5%) | OR 1.24 (0.34 to 4.48) | not pooled | INSUFFICIENT

Table J-5 Spinal anesthesia (single): addition of morphine for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (Better indicated by lower values)
1 | RCTs | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 20 | 20 | - | MD 0.36 lower (1.11 lower to 0.39 higher) | INSUFFICIENT
Delirium
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 1/20 (5%) | 0/20 (0%) | OR 3.15 (0.12 to 82.16) | 0 more per 1,000 (from 0 fewer to 0 more) | INSUFFICIENT

Table J-6 Spinal anesthesia (single): addition of sufentanil for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 25 | 25 | - | not pooled | INSUFFICIENT

Table J-7 Spinal anesthesia: Different doses (Bupivacaine 2.5 mg vs. 5mg) for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Mortality 30 days
1 | Cohort | Low | Unknown | Direct | Imprecise | Publication bias: Not investigated | 4/121 (3.3%) | 4/61 (6.6%) | OR 0.49 (0.12 to 2.02) | 32 fewer per 1,000 (from 57 fewer to 59 more) | INSUFFICIENT

Table J-8 Spinal anesthesia: Different doses (Bupivacaine 2.5 mg vs. 5mg) for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Mortality 30 days
1 | Cohort | Low | Unknown | Direct | Imprecise | Publication bias: Not investigated | 2/30 (6.7%) | 4/30 (13.3%) | OR 0.46 (0.08 to 2.75) | 67 fewer per 1,000 (from 1,000 fewer to 164 more) | INSUFFICIENT

Table J-9 Comparative alternative medicine for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) - Acupressure (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 18 | 20 | - | MD 3.01 lower (4.53 to 1.49 lower) | INSUFFICIENT
Acute pain (post-treatment means) - Relaxation (better indicated by lower values)
1 | RCT | High | Unknown | Direct | Precise | Publication bias: Not investigated | 30 | 30 | - | MD 1.1 lower (1.43 to 0.77 lower) | INSUFFICIENT

Table J-10 Multimodal pain management

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Delirium - Protocol #1
1 | Cohort | Medium | Unknown | Direct | Imprecise | Publication bias: Not investigated | 12/60 (20%) | 14/60 (23.3%) | OR 0.82 (0.34 to 1.96) | 34 fewer per 1,000 (from 140 fewer to 140 more) | INSUFFICIENT
Delirium - Protocol #2
1 | Cohort | Medium | Unknown | Direct | Imprecise | Publication bias: Not investigated | 1/55 (1.8%) | 2/51 (3.9%) | OR 0.45 (0.04 to 5.16) | 21 fewer per 1,000 (from 38 fewer to 135 more) | INSUFFICIENT
Mortality 30 days - Protocol #2
1 | Cohort | Medium | Unknown | Direct | Imprecise | Publication bias: Not investigated | 5/55 (9.1%) | 8/51 (15.7%) | OR 0.54 (0.16 to 1.77) | 66 fewer per 1,000 (from 128 fewer to 91 more) | INSUFFICIENT
Myocardial Infarction - Protocol #2
1 | Cohort | Medium | Unknown | Direct | Imprecise | Publication bias: Not investigated | 1/55 (1.8%) | 2/51 (3.9%) | OR 0.45 (0.04 to 5.16) | 21 fewer per 1,000 (from 38 fewer to 135 more) | INSUFFICIENT
Stroke - Protocol #2
1 | Cohort | Medium | Unknown | Direct | Imprecise | Publication bias: Not investigated | 0/55 (0%) | 1/51 (2%) | OR 0.13 (0.00 to 6.32) | 17 fewer per 1,000 (from 20 to 93 more) | INSUFFICIENT

Table J-11 Nerve blocks vs. no block for hip fracture

Quality assessment | | | | | | | | | | Summary of findings
Quality assessment | | | | | | | | | | No of patients | | | | Effect | | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | | Precision | | Other considerations | | Analgesia | | control | | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (better indicated by lower values)
13 | RCTs | High | Consistent | Direct | | Precise | | Publication bias: Unlikely | | 508 | | 492 | | - | Not pooled | | MODERATE
Pain on movement (post-treatment) (better indicated by lower values)
4 | RCTs | High | Inconsistent | Direct | Imprecise | | Publication bias: Not investigated | | 128 | | 130 | | - | | | Not pooled | LOW
Pain on rest (post-treatment) (better indicated by lower values)
3 | RCTs | High | Inconsistent | Direct | Imprecise | | Publication bias: Not investigated | | 104 | | 104 | | - | | | Not pooled | LOW
Day 1 Pain
1 | RCT | High | Unknown | Direct | Precise | | Publication bias: Not investigated | | 7/25 (28%) | | 20/25 (80%) | | OR 0.1 (0.03 to 0.36) | | | 514 fewer per 1,000 (from 210 fewer to 693 fewer) | INSUFFICIENT
Delirium
6 | 4 RCTs; 2 Cohorts | Medium | Consistent | Direct | Precise | | Publication bias: Not investigated | | 11/242 (4.5%) | | 33/219 (7.9%) | | OR 0.33 (0.16 to 0.66) | | | 95 fewer per 1,000 (from 46 fewer to 123 fewer) | MODERATE
Mortality 30 days
4 | RCTs | HIGH | Consistent | Direct | Imprecise | | Publication bias: Not investigated | | 2/114 (1.8%) | | 10/114 (8.8%) | | OR 0.28 (0.07 to 1.12) | | | 62 fewer per 1,000 (from 81 fewer to 10 more) | LOW
Myocardial Infarction
3 | 2 RCTs; 1 Cohort | High | Consistent | Direct | Imprecise | | Publication bias: Not investigated | | 1/72 (1.4%) | | 1/73 (1.4%) | | OR 1 (0.06 to 16.67) | | | 0 fewer per 1,000 (from 13 fewer to 174 more) | INSUFFICIENT
Stroke
2 | 1 RCT; 1 Cohort | High | Consistent | Direct | Imprecise | | Publication bias: Not investigated | | 1/25 (4%) | | 0/25 (0%) | | OR 3.12 (0.12 to 80.39) | | | 0 more per 1,000 (from 0 fewer to 0 more) | INSUFFICIENT

Table J-12 Nerve blocks vs. regional anesthesia for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (Better indicated by lower values)
3 | RCTs | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 55 | 54 | - | MD 0.35 lower (1.1 lower to 0.39 higher) | LOW
Delirium
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 6/15 (40%) | 5/14 (35.7%) | OR 1.2 (0.27 to 5.4) | 43 more per 1,000 (from 227 fewer to 393 more) | INSUFFICIENT

Table J-13 Nerve Blocks: Ropivacaine vs. Bupivacaine for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Delirium
1 | Cohort | Low | Unknown | Direct | Imprecise | Publication bias: Not investigated | 2/32 (6.3%) | 1/30 (3.3%) | OR 1.93 (0.17 to 22.5) | 29 more per 1,000 (from 28 fewer to 404 more) | INSUFFICIENT

Table J-14 Neurostimulation for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (Better indicated by lower values)
2 | RCTs | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 60 | 63 | - | MD 2.79 lower (4.95 to 0.64 lower) | INSUFFICIENT
Pain on movement (post-treatment) (Better indicated by lower values)
1 | RCT | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 30 | 30 | - | MD 3.9 lower (6.22 to 1.58 lower) | INSUFFICIENT

Table J-15 Rehabilitation for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) (Better indicated by lower values)
1 | RCTs | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 18 | 19 | - | MD 1.39 lower (2.27 to 0.51 lower) | INSUFFICIENT

Table J-16 Traction for hip fracture

Quality assessment | | | | | | | Summary of findings
Quality assessment | | | | | | | No of patients | | Effect | | Quality
No of studies | Design | Risk of Bias | Consistency | Directness | Precision | Other considerations | Analgesia | control | Relative (95% CI) | Absolute
Acute pain (post-treatment means) - Skin traction versus no traction (Better indicated by lower values)
8 | RCTs | High | Consistent | Direct | Imprecise | Publication bias: Not investigated | 498 | 594 | - | MD 0.20 higher (0.24 lower to 0.65 higher) | MODERATE
Mortality 30 days (traction vs. no traction)
2 | RCTs | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 0/55 (0%) | 2/25 (8%) | OR 0.14 (0.01 to 1.44) | 65 fewer per 1,000 (from 78 fewer to 35 more) | INSUFFICIENT
Mortality 30 days (skin vs. skeletal) - Skin traction versus skeletal traction
1 | RCTs | High | Unknown | Direct | Imprecise | Publication bias: Not investigated | 0/26 (0%) | 0/29 (0%) | not pooled | not pooled | INSUFFICIENT