# Newcastle-Ottawa Scale Assessment of Cohort Studies

NEWCASTLE - OTTAWA QUALITY ASSESSMENT SCALE CASE CONTROL STUDIES

Note: A study can be awarded a maximum of one star for each numbered item within the Selection and Exposure categories. A maximum of two stars can be given for Comparability.

NEWCASTLE - OTTAWA QUALITY ASSESSMENT SCALE COHORT STUDIES

Note: A study can be awarded a maximum of one star for each numbered item within the Selection and Outcome categories. A maximum of two stars can be given for Comparability

Table I-1 Anesthesia

| | Selection | | | | Comparability | Outcome | | | Total stars
Author, year | Study design | Representativeness of cohort | Selection of nonexposed cohort | Ascertainment of exposure | Outcome of interest | Comparability of cohorts | Assessment of outcome | Adequate duration of followup | Adequate followup of cohort | Total stars
Koval 1999^78^ | Prospective cohort study | B (1*) | A (1*) | D (0) | A (1*) | B (1*) | D (0) | A (1*) | C (0) | 5
Labaille 1992^79^ | Prospective cohort study | B (1*) | A (1*) | B (1*) | A (1*) | A (1*) | B (1*) | A (1*) | A (1*) | 8
Miller 1990^81^ | Retrospective cohort study | A (1*) | A (1*) | D (0) | A (1*) | A (1*) | B (1*) | A (1*) | A (1*) | 7
Minville 2008^71^ | Retrospective cohort study | B (1*) | A (1*) | A (1*) | A (1*) | B (1*) | B (1*) | A (1*) | A (1*) | 8
Sen 2007^83^ | Retrospective cohort study | B (1*) | A (1*) | A (1*) | B (0) | A (1*) | B (1*) | A (1*) | A (1*) | 7
Shih 2010^84^ | Retrospective cohort study | B (1*) | A (1*) | A (1*) | A (1*) | B (1*) | B (1*) | A (1*) | A (1*) | 8
Sutcliffe 1994^85^ | Prospective cohort study | B (1*) | B (0) | D (0) | A (1*) | B (1*) | D (0) | A (1*) | A (1*) | 5

Table I-2 Multimodal pain management

| | Selection | | | | Comparability | Outcome | | | Total stars
Author, year | Study design | Representativeness of cohort | Selection of nonexposed cohort | Ascertainment of exposure | Outcome of interest | Comparability of cohorts | Assessment of outcome | Adequate duration of followup | Adequate followup of cohort | Total stars
Milisen 2001^86^ | Prospective cohort study | B (1*) | A (1*) | A (1*) | A (1*) | A,B (2*) | C (0) | A (1*) | A (1*) | 8
Ogilvie-Harris 1993^87^ | Prospective cohort study | D (0) | C (0) | A (1*) | A (1*) | B (1*) | B (1*) | A (1*) | D (0) | 5

Table I-3 Nerve blocks

| | Selection | | | | Comparability | Outcome | | | Total stars
Author, year | Study design | Representativeness of cohort | Selection of nonexposed cohort | Ascertainment of exposure | Outcome of interest | Comparability of cohorts | Assessment of outcome | Adequate duration of followup | Adequate followup of cohort | Total stars
Del Rosario 2008^117^ | Retrospective cohort study | B (1*) | A (1*) | A (1*) | B (0) | B (1*) | B (1*) | A (1*) | A (1*) | 7
Kocum 2007^118^ | Retrospective cohort study | B (1*) | A (1*) | A (1*) | A (1*) | A (1*) | B (1*) | A (1*) | B (1*) | 8
Pedersen 2008^119^ | Retrospective cohort study | A (1*) | A (1*) | A (1*) | A (1*) | A,B (2*) | B (1*) | A (1*) | A (1*) | 9

Table I-4 Traction

| | Selection | | | | Comparability | Outcome | | | Total stars
Author, year | Study design | Representativeness of cohort | Selection of nonexposed cohort | Ascertainment of exposure | Outcome of interest | Comparability of cohorts | Assessment of outcome | Adequate duration of followup | Adequate followup of cohort | Total stars
Vermeiren 1995^132^ | Prospective cohort study | A (1*) | A (1*) | A (1*) | A (1*) | (0) | B (1*) | A (1*) | B (1*) | 7