# Summary Risk of Bias Assessments

Table H-1 Pharmacological analgesia

Domain | High | Unclear | Low
Adequate sequence generation | 0 (0%) | 3 (100%) | 0 (0%)
Allocation concealment | 0 (0%) | 3 (100%) | 0 (0%)
Blinding | 0 (0%) | 1 (33.33%) | 2 (66.67%)
Incomplete outcome data addressed | 0 (0%) | 1 (33.33%) | 2 (66.67%)
Free of selective reporting | 0 (0%) | 1 (33.33%) | 2 (66.67%)
Free of other bias | 0 (0%) | 2 (66.67%) | 1 (33.33%)

Table H-2 Anesthesia

Domain | High | Unclear | Low
Adequate sequence generation | 2 (9.09%) | 17 (77.27%) | 3 (13.64%)
Allocation concealment | 1 (4.55%) | 17 (77.27%) | 4 (18.18%)
Blinding | 1 (4.55%) | 10 (45.45%) | 11 (50.00%)
Incomplete outcome data addressed | 2 (9.09%) | 3 (13.64%) | 17 (77.27%)
Free of selective reporting | 0 (0%) | 0 (0%) | 22 (100%)
Free of other bias | 0 (0%) | 19 (86.36%) | 3 (13.64%)

Table H-3 Complementary and alternative medicine (CAM)

Domain | High | Unclear | Low
Adequate sequence generation | 0 (0%) | 1 (50%) | 1 (50%)
Allocation concealment | 0 (0%) | 2 (100%) | 0 (0%)
Blinding | 1 (50%) | 0 (0%) | 1 (50%)
Incomplete outcome data addressed | 0 (0%) | 0 (0%) | 2 (100%)
Free of selective reporting | 0 (0%) | 0 (0%) | 2 (100%)
Free of other bias | 0 (0%) | 2 (100%) | 0 (0%)

Table H-4 Nerve blocks

Domain | High | Unclear | Low
Adequate sequence generation | 0 (0%) | 19 (65.52%) | 10 (34.48%)
Allocation concealment | 0 (0%) | 23 (79.31%) | 6 (20.69%)
Blinding | 7 (24.14%) | 13 (44.83%) | 9 (31.03%)
Incomplete outcome data addressed | 3 (10.35%) | 3 (10.35%) | 23 (79.31%)
Free of selective reporting | 4 (13.79%) | 0 (0%) | 25 (86.21%)
Free of other bias | 1 (3.45%) | 21 (72.41%) | 7 (24.14%)

Table H-5 Neurostimulation

Domain | High | Unclear | Low
Adequate sequence generation | 0 (0%) | 1 (50%) | 1 (50%)
Allocation concealment | 0 (0%) | 1 (50%) | 1 (50%)
Blinding | 0 (0%) | 0 (0%) | 2 (100%)
Incomplete outcome data addressed | 1 (50%) | 0 (0%) | 1 (50%)
Free of selective reporting | 0 (0%) | 0 (0%) | 2 (100%)
Free of other bias | 1 (50%) | 1 (50%) | 0 (0%)

Table H-6 Rehabilitation

Domain | High | Unclear | Low
Adequate sequence generation | 0 (0%) | 0 (0%) | 1 (100%)
Allocation concealment | 0 (0%) | 1 (100%) | 0 (0%)
Blinding | 1 (100%) | 0 (0%) | 0 (0%)
Incomplete outcome data addressed | 0 (0%) | 0 (0%) | 1 (100%)
Free of selective reporting | 0 (0%) | 0 (0%) | 1 (100%)
Free of other bias | 0 (0%) | 1 (100%) | 0 (0%)

Table H-7 Traction

Domain | High | Unclear | Low
Adequate sequence generation | 4 (40.00%) | 4 (40.00%) | 2 (20.00%)
Allocation concealment | 4 (40.00%) | 6 (60.00%) | 0 (0%)
Blinding | 10 (100%) | 0 (0%) | 0 (0%)
Incomplete outcome data addressed | 1 (10.00%) | 0 (0%) | 9 (90.00%)
Free of selective reporting | 1 (10.00%) | 0 (0%) | 9 (90.00%)
Free of other bias | 0 (0.00%) | 5 (50.00%) | 5 (50.00%)