# Risk of Bias Assessment for Randomized Controlled Trials and Nonrandomized Controlled Trials

## Guidelines and Decision Rules for Risk of Bias Assessments

### Sequence Generation

- If computer-generated, random number list, flipping coins, randomly picking envelopes, etc. is specified → YES
- If the description only includes ‘random,’ ‘randomly generated,’ ‘randomized,’ etc., do not assume additional details → UNCLEAR
- If the description is quasi-randomized (e.g. alternate randomization, day of the year, day of the month, birth date, birth month, beginning letter of last name, availability of investigator or specialist, etc.) → NO

### Allocation Concealment

- If the assignment is conducted by central telephone, pharmacy, etc. → YES
- If dark (or opaque), sealed, sequentially numbered envelopes are used → YES
- If the envelopes are not stated to dark and sealed, or sequentially numbered → UNCLEAR

[underlined: Note:] sequential numbering of the envelopes is only required for adequate allocation concealment if the method of randomization was anything other than randomly picking envelopes (i.e., the envelopes were only used for allocation concealment and not as part of the randomization process).

### Blinding

- If the study was stated to be blinded (masked) and the blinding is considered to be possible, and not likely to be broken → YES
- If the study is only stated to be blinded, double-blinded, double-dummy, etc. without any further details → UNCLEAR
- If the study states the use of a placebo (dummy) but with no further details → UNCLEAR
- If no mention of blinding → NO

### Incomplete Outcome Data

- Look for intention-to-treat analysis (all randomized pts. are analyzed) → YES
- If all participants were accounted for (i.e. no drop-outs or censored analysis conducted) → YES
- If the numbers and reasons for withdrawal/dropouts were described and comparable across groups (and ≤ approximately 10 percent) → YES
- If there is between 10 percent and 30 percent dropout and no ITT analysis → UNCLEAR
- If there is greater 30 percent dropout and no ITT analysis → NO

### Selective Outcome Reporting

- If the study protocol is available (referenced in the manuscript), compare the outcomes reported in the publication to those specified in the protocol. If they match → YES
- If the study protocol is available (referenced in the manuscript), compare the outcomes reported in the publication to those specified in the protocol. If they do not match, but there is reference to another publication with this information presented → YES
- If the study protocol is not available, compare the outcomes reported in the Methods and Results sections. If they match → YES

### Other Sources of Bias

- Assess for baseline imbalances that could have biased the results (or were not accounted for).
- Assess for early stopping for benefit.
- Assess for appropriateness of cross-over design (e.g., inadequate washout period).
- Assess for inappropriate influence of funders that could have biased the results:
  ○ If sponsor is acknowledged and there is a clear statement regarding no involvement of sponsor in trial conduct or data management/analysis, or coauthorship → YES
  ○ If sponsor is acknowledged with no further information provided or (co)author works for a pharmaceutical company → NO
  ○ If there is no mention of funding source → UNCLEAR
- Note any “other” sources of bias.

## Risk of Bias (RoB) Assessments

Table G-1 Pharmacologic Analgesia

Study | Item | Judgment | Description
Apostolopoulos 2006^41^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Apostolopoulos 2006^41^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Apostolopoulos 2006^41^ | Blinding? | UNCLEAR | NR
Apostolopoulos 2006^41^ | Incomplete outcome data addressed? | UNCLEAR | Not enough information provided in the text to make a precise decision
Apostolopoulos 2006^41^ | Free of selective reporting? | UNCLEAR | Not enough information provided in the text to make a precise decision
Apostolopoulos 2006^41^ | Free of other bias? | UNCLEAR | No information on baseline characteristics or any information on financial support.
Baker 2004^42^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Baker 2004^42^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Baker 2004^42^ | Blinding? | YES | Reported as a double-blind trial and that the study solutions were freshly prepared by an anesthesiologist who had no further part in the study. Also reported that the anesthesiologist who injected the study solution and the investigator were blinded to the baricity of the clonidine solution administered
Baker 2004^42^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Baker 2004^42^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Baker 2004^42^ | Free of other bias? | YES | Baseline characteristics were balanced and the source of funding was declared to be institutional
Poitevin 1999^55^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Poitevin 1999^55^ | Allocation concealment? | UNCLEAR | NR
Poitevin 1999^55^ | Blinding? | YES | Reported as a double-blind study using identical matching placebos
Poitevin 1999^55^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Poitevin 1999^55^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Poitevin 1999^55^ | Free of other bias? | UNCLEAR | Baseline characteristics are balanced but there is no source of funding declared

Table G-2 Anesthesia

Study | Item | Judgment | Description
Adams 1990^56^ | Adequate sequence generation? | NO | Quasi-randomization based on the date of admission
Adams 1990^56^ | Allocation concealment? | NO | Based on even or odd calendar dates of admission
Adams 1990^56^ | Blinding? | UNCLEAR | NR
Adams 1990^56^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Adams 1990^56^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Adams 1990^56^ | Free of other bias? | UNCLEAR | Baseline characteristics are balanced but there is no source of funding declared
Alonso Chico 2003^57^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Alonso Chico 2003^57^ | Allocation concealment? | UNCLEAR | NR
Alonso Chico 2003^57^ | Blinding? | UNCLEAR | NR
Alonso Chico 2003^57^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Alonso Chico 2003^57^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Alonso Chico 2003^57^ | Free of other bias? | UNCLEAR | Baseline characteristics are balanced but there is no source of funding declared
Ben-David 2000^58^ | Adequate sequence generation? | UNCLEAR | Reported the use of a sealed-envelope technique with no further details
Ben-David 2000^58^ | Allocation concealment? | UNCLEAR | Reported the use of sealed-envelope technique with no further details
Ben-David 2000^58^ | Blinding? | YES | Reported that all pts received the same injectate volume. Additionally the syringes were prepared by one researcher and administered by a second who remained blinded to its contents. Patient assessment and care were conducted and study data were recorded by the second blinded researcher. Finally, the protocol allowed for conversion to general anesthesia as deemed necessary by the blinded anesthesiologist. No mention of patient blinding was reported.
Ben-David 2000^58^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Ben-David 2000^58^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Ben-David 2000^58^ | Free of other bias? | YES | Baseline characteristics were balanced and the source of funding was declared to be institutional
Bredahl 1991^59^ | Adequate sequence generation? | Unclear | Reported as a randomized trial without any further details
Bredahl 1991^59^ | Allocation concealment? | Unclear | No description of allocation concealment reported
Bredahl 1991^59^ | Blinding? | Unclear | NR
Bredahl 1991^59^ | Incomplete outcome data addressed? | Unclear | No ITT. 13.3% exclusion in general a. group due to the incomplete data and sampling.
Bredahl 1991^59^ | Free of selective reporting? | Yes | Protocol not available, but the outcomes in the methods match those in the results.
Bredahl 1991^59^ | Free of other bias? | Unclear | Baseline characteristics are balanced but there is no source of funding declared.
Casati 2003^60^ | Adequate sequence generation? | UNCLEAR | Reported the use of a sealed-envelope technique with no further details
Casati 2003^60^ | Allocation concealment? | UNCLEAR | Reported that Allocation concealment was via a sealed-envelope technique with no further details
Casati 2003^60^ | Blinding? | NO | Reported that the orthopedic and rehabilitation staff who assessed the clinical criteria prior to discharge from hospital were blinded to the anesthesia technique used during surgery. There is no mention of clinicians or patients being blinded. Additionally since pts in the spinal group were awake, while the pts in the general anesthesia group were unconscious, pt blinding was not possible. Finally, no mention of any procedure to blind the clinicians performing the surgery or anesthesia.
Casati 2003^60^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Casati 2003^60^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Casati 2003^60^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Danelli 2008^61^ | Adequate sequence generation? | YES | Reported that randomization was performed using a computer-generated sequence of random numbers
Danelli 2008^61^ | Allocation concealment? | YES | Reported that allocation concealment was ensured using sequentially numbered, sealed opaque envelopes
Danelli 2008^61^ | Blinding? | YES | Reported as a double-blind study with an independent observer, who was blinded to group allocation, recording the observations.
Danelli 2008^61^ | Incomplete outcome data addressed? | YES | Principle of Intention-to-treat not used in the analyses with 9% of randomized pts were excluded with reasons provided
Danelli 2008^61^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Danelli 2008^61^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Favarel-Garrigues 1996^62^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Favarel-Garrigues 1996^62^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Favarel-Garrigues 1996^62^ | Blinding? | UNCLEAR | NR
Favarel-Garrigues 1996^62^ | Incomplete outcome data addressed? | YES | All patient completed the study and followed up for one month post-operatively (intention-to-treat)
Favarel-Garrigues 1996^62^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Favarel-Garrigues 1996^62^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Hooda 2006^63^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Hooda 2006^63^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Hooda 2006^63^ | Blinding? | YES | Reported as a double-blind trial and that In order to facilitate blinding; spinal anesthesia was administered by a fellow colleague and observer did not know the amount of drug received by the patient
Hooda 2006^63^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Hooda 2006^63^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Hooda 2006^63^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Juelsgaard 1998^64^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Juelsgaard 1998^64^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Juelsgaard 1998^64^ | Blinding? | YES | Reported that the investigator was blinded to the randomization
Juelsgaard 1998^64^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 11/54 (%) of randomized pts excluded from the analyses with reasons provided
Juelsgaard 1998^64^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Juelsgaard 1998^64^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Klimscha 1995^65^ | Adequate sequence generation? | YES | Reported that randomization was performed by having an assistant blindly pick from an envelope a piece of paper with the name of the study solution and route of administration written on it
Klimscha 1995^65^ | Allocation concealment? | UNCLEAR | Reported as using envelopes with no further details
Klimscha 1995^65^ | Blinding? | YES | Reported that an assisting anesthesiologist inserted the catheters, prepared the fresh study solution, injected it, and covered the injection port with a cotton towel to blind the other anesthesiologist to the group assignment.
Klimscha 1995^65^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Klimscha 1995^65^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Klimscha 1995^65^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared. There was mention of 'valuable support' from an employee of a pharmaceutical company with no further explanation
Krobot 2006^77^ | Adequate sequence generation? | NO | NR to be a randomized trial
Krobot 2006^77^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Krobot 2006^77^ | Blinding? | UNCLEAR | NR
Krobot 2006^77^ | Incomplete outcome data addressed? | UNCLEAR | Not enough information provided in the text to make a precise decision
Krobot 2006^77^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Krobot 2006^77^ | Free of other bias? | UNCLEAR | Baseline characteristics not provided nor any disclosure on sources of funding
Kwan 1997^66^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Kwan 1997^66^ | Allocation concealment? | YES | Injections were prepared by another investigator who was not performing the block.
Kwan 1997^66^ | Blinding? | YES | Reported as double-blind design. Two different investigators prepared the solutions and administered them. An assessment of pain level conducted by investigator who was unaware of the constituents of the allocation
Kwan 1997^66^ | Incomplete outcome data addressed? | YES | Intention-to-treat analysis was not used with 10% of participants dropped-out of the trial with reasons provided
Kwan 1997^66^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Kwan 1997^66^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Malek 2004^67^ | Adequate sequence generation? | UNCLEAR | Reported the use of a sealed-envelope technique with no further details
Malek 2004^67^ | Allocation concealment? | UNCLEAR | Reported the use of sealed-envelope technique with no further details
Malek 2004^67^ | Blinding? | UNCLEAR | Reported that only the anesthesiologist and anesthetic nurse were aware of the allocation, but there is no reporting on how was in charge of monitoring the patients and recording the outcomes
Malek 2004^67^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Malek 2004^67^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Malek 2004^67^ | Free of other bias? | YES | Baseline characteristics were balanced and the source of funding was declared to be institutional
Martyr 2001^68^ | Adequate sequence generation? | UNCLEAR | Reported that for each patient a numbered syringe was chosen at random from the supply kept in the Pharmacy Department with no further details
Martyr 2001^68^ | Allocation concealment? | YES | Reported that the coded syringes were chosen at random
Martyr 2001^68^ | Blinding? | YES | Reported that the syringes were prepared by Baxter Healthcare and the study solution syringes were the same volume as the standard solution syringes and were all numbered and coded such that the administering anesthetist was blinded to their contents.
Martyr 2001^68^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 6/48 (12.50%) of randomized pts excluded from the analyses with reasons provided
Martyr 2001^68^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Martyr 2001^68^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Martyr 2005^69^ | Adequate sequence generation? | YES | Reported that randomization was performed using a computer-generated randomization
Martyr 2005^69^ | Allocation concealment? | YES | Reported that randomization was performed by a third-party and syringes were sequentially numbered and administered
Martyr 2005^69^ | Blinding? | YES | Reported that the syringes were prepared by a third party and stored in the hospital pharmacy, and that the anesthesiologists and nurses that administered and monitored the patients were not aware of the allocation
Martyr 2005^69^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Martyr 2005^69^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Martyr 2005^69^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced, and disclosure of institutional financial support is provided, but the interventions were provided by Baxter Healthcare and it is not clear if they were provided as a type of financial support for the trial or were co
Maurette 1993^70^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Maurette 1993^70^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Maurette 1993^70^ | Blinding? | YES | Reported as double-blind, and that the investigator that administered the medications was different from the one that prepared them
Maurette 1993^70^ | Incomplete outcome data addressed? | YES | Intention-to-treat principle was not used with 1/35 (2.86%) of randomized pts were excluded with reasons provided
Maurette 1993^70^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Maurette 1993^70^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Minville 2006^71^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Minville 2006^71^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Minville 2006^71^ | Blinding? | UNCLEAR | Reported that a blinded observer assessed the dermatome level of sensory blockade, but no details of who assessed the outcome measures
Minville 2006^71^ | Incomplete outcome data addressed? | YES | Intention-to-treat principle was not used in the analyses with one pt not completing the investigation and not included in the analyses
Minville 2006^71^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Minville 2006^71^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Navas 2008^72^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Navas 2008^72^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Navas 2008^72^ | Blinding? | UNCLEAR | NR
Navas 2008^72^ | Incomplete outcome data addressed? | UNCLEAR | Not enough information provided in the text to make a precise decision
Navas 2008^72^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Navas 2008^72^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Olofsson 2004^73^ | Adequate sequence generation? | UNCLEAR | Reported the use of a sealed-envelope technique with no further details
Olofsson 2004^73^ | Allocation concealment? | UNCLEAR | Reported the use of sealed-envelope technique with no further details
Olofsson 2004^73^ | Blinding? | YES | Reported that the study was double-blind and that all pts received the same injectate volume which was prepared by a nurse not involved in the study
Olofsson 2004^73^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Olofsson 2004^73^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Olofsson 2004^73^ | Free of other bias? | YES | Baseline characteristics were balanced and the source of funding was declared to be institutional
Qamarul Hoda 2007^146^ | Adequate sequence generation? | UNCLEAR | Reported that randomization was performed using the sealed envelope technique with no further details
Qamarul Hoda 2007^146^ | Allocation concealment? | UNCLEAR | Reported the use of sealed envelopes with no further details
Qamarul Hoda 2007^146^ | Blinding? | UNCLEAR | NR
Qamarul Hoda 2007^146^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Qamarul Hoda 2007^146^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Qamarul Hoda 2007^146^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Rais 2008^75^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Rais 2008^75^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Rais 2008^75^ | Blinding? | UNCLEAR | NR
Rais 2008^75^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Rais 2008^75^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Rais 2008^75^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Said-Ahmed 2006^76^ | Adequate sequence generation? | UNCLEAR | Reported the use of randomization using sealed envelopes with no further details
Said-Ahmed 2006^76^ | Allocation concealment? | UNCLEAR | Reported the use of sealed envelopes with no further details
Said-Ahmed 2006^76^ | Blinding? | YES | Reported that the syringes were prepared by a researcher and passed to a second investigator who was blinded to its content. The second investigator was reported to have administered the drug and collected the study data.
Said-Ahmed 2006^76^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Said-Ahmed 2006^76^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Said-Ahmed 2006^76^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared

Table G-3 Complementary and alternative medicine (CAM)

Study | Item | Judgment | Description
Barker 2006^43^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Barker 2006^43^ | Allocation concealment? | UNCLEAR | Reported using a sealed envelope to determine the patient’s group assignment without any further details
Barker 2006^43^ | Blinding? | YES | Reported that the trial was double-blind and that following the administration of the intervention, one paramedic covered the ears of all subjects with ear patches to assure blinding of the other paramedic, who was involved in the outcome assessment
Barker 2006^43^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Barker 2006^43^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Barker 2006^43^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Martin 1991^54^ | Adequate sequence generation? | YES | Reported that randomization was performed using a table of random numbers coding system
Martin 1991^54^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Martin 1991^54^ | Blinding? | NO | Reported that the researcher that was instructing the patients on the use of the intervention was also the one measuring outcomes; including subjective assessments of pain.
Martin 1991^54^ | Incomplete outcome data addressed? | UNCLEAR | Pts were randomized before receiving confirmation of inclusion in the study with no mention of the number excluded after randomization
Martin 1991^54^ | Free of selective reporting? | NO | Protocol not available, but methods section numerates differing outcomes than were presented in the results
Martin 1991^54^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared

Table G-4 Nerve blocks

Study | Item | Judgment | Description
Antonopoulou 2006^88^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Antonopoulou 2006^88^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Antonopoulou 2006^88^ | Blinding? | UNCLEAR | NR
Antonopoulou 2006^88^ | Incomplete outcome data addressed? | UNCLEAR | Not enough information provided in the text to make a precise decision
Antonopoulou 2006^88^ | Free of selective reporting? | NO | Protocol not available, but methods section numerates differing outcomes than were presented in the results
Antonopoulou 2006^88^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Chudinov 1999^89^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Chudinov 1999^89^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Chudinov 1999^89^ | Blinding? | UNCLEAR | NR
Chudinov 1999^89^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Chudinov 1999^89^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Chudinov 1999^89^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Coad 1991^90^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Coad 1991^90^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Coad 1991^90^ | Blinding? | YES | Reported that the nurses who prescribed rescue analgesia were unaware of the patients' allocation
Coad 1991^90^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Coad 1991^90^ | Free of selective reporting? | NO | Protocol not available, but it was noted that the authors abandoned a pilot study for measuring pain score using VAS due to unsatisfactory results.
Coad 1991^90^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Cuvillon 2007^91^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Cuvillon 2007^91^ | Allocation concealment? | UNCLEAR | Reported the use of sealed, numbered envelopes with no further details
Cuvillon 2007^91^ | Blinding? | UNCLEAR | NR
Cuvillon 2007^91^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Cuvillon 2007^91^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Cuvillon 2007^91^ | Free of other bias? | YES | Baseline characteristics are balanced and the source of funding was declared to be institutional
de Visme 2000^92^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
de Visme 2000^92^ | Allocation concealment? | YES | Randomization was performed in the hospital pharmacy (third party)
de Visme 2000^92^ | Blinding? | NO | NR, but also not possible with the study design
de Visme 2000^92^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 11/29 (37.93%) of randomized pts excluded from analysis
de Visme 2000^92^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
de Visme 2000^92^ | Free of other bias? | YES | Baseline characteristics were balanced and the source of funding was declared to be institutional
Eyrolle 1998^93^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Eyrolle 1998^93^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Eyrolle 1998^93^ | Blinding? | UNCLEAR | NR
Eyrolle 1998^93^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Eyrolle 1998^93^ | Free of selective reporting? | NO | Protocol is not available and the intended outcomes were not clearly described in the methods section
Eyrolle 1998^93^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Fletcher 2003^94^ | Adequate sequence generation? | YES | Reported that randomization was performed using a random number generator
Fletcher 2003^94^ | Allocation concealment? | YES | Reported the use of sealed opaque envelopes
Fletcher 2003^94^ | Blinding? | NO | Reported that data collectors and outcome assessors were blinded but patients were not blinded to group allocation
Fletcher 2003^94^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Fletcher 2003^94^ | Free of selective reporting? | NO | Protocol not available, but one of the outcomes in the methods is not presented in the results (i.e., time to discharge)
Fletcher 2003^94^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Foss 2005^95^ | Adequate sequence generation? | YES | Reported that randomization was performed using a computer-generated randomization list
Foss 2005^95^ | Allocation concealment? | YES | Reported that randomization was performed by a third party
Foss 2005^95^ | Blinding? | YES | Reported that it was a double-blind trials and that the epidural cassettes were packed by the local pharmacy and blinded and supplied with a randomization number by a person not affiliated with the project
Foss 2005^95^ | Incomplete outcome data addressed? | YES | Intention-to-treat principle was not used in the analyses with 5/60 (8.33%) pts excluded from the analyses with reasons given
Foss 2005^95^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Foss 2005^95^ | Free of other bias? | YES | Baseline characteristics were balanced and source of funding declared as governmental
Foss 2007^96^ | Adequate sequence generation? | YES | Reported that randomization was performed using computer-generated list
Foss 2007^96^ | Allocation concealment? | YES | Reported that the medicine used for each individual patient was prepared by a nurse not otherwise involved with the collection of patient data
Foss 2007^96^ | Blinding? | YES | Reported that the study was double blind with placebo injections given along with the intervention studied in each group
Foss 2007^96^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Foss 2007^96^ | Free of selective reporting? | YES | The outcomes reported in the publication match those in the protocol (NCT00162630)
Foss 2007^96^ | Free of other bias? | YES | Gender is imbalanced between the groups but this is unlikely to introduce bias; Funding provided by IMK Almene Fond, a private research fund
Gille 2006^97^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Gille 2006^97^ | Allocation concealment? | UNCLEAR | NR
Gille 2006^97^ | Blinding? | UNCLEAR | NR
Gille 2006^97^ | Incomplete outcome data addressed? | UNCLEAR | Not clear if all pts completed the trial and were included in the analyses
Gille 2006^97^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Gille 2006^97^ | Free of other bias? | YES | Baseline characteristics are balanced and the source of funding was declared to be institutional
Graham 2008^98^ | Adequate sequence generation? | UNCLEAR | Reported the use of numbered, sequential, sealed opaque envelopes with no further details
Graham 2008^98^ | Allocation concealment? | YES | Reported that allocation concealment was ensured using numbered, sequential, sealed opaque envelopes
Graham 2008^98^ | Blinding? | NO | Reported as an 'open-label' trial
Graham 2008^98^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 7/40 (17.50%) of randomized pts excluded from analyses with reasons provided
Graham 2008^98^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Graham 2008^98^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Haddad 1995^99^ | Adequate sequence generation? | UNCLEAR | Reported as randomized by using sealed envelopes with no further details
Haddad 1995^99^ | Allocation concealment? | UNCLEAR | Reported the use of sealed-envelope technique with no further details
Haddad 1995^99^ | Blinding? | YES | Reported that the staff that monitored the patients and provided rescue analgesia were unaware of the patients' allocation
Haddad 1995^99^ | Incomplete outcome data addressed? | YES | Intention-to-treat principle was not used with 5/50 (10%) of randomized pts were excluded with reasons provided
Haddad 1995^99^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Haddad 1995^99^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Henderson 2008^100^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Henderson 2008^100^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Henderson 2008^100^ | Blinding? | UNCLEAR | NR
Henderson 2008^100^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Henderson 2008^100^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Henderson 2008^100^ | Free of other bias? | UNCLEAR | No information on baseline characteristics or any information on financial support.
Hood 1991^101^ | Adequate sequence generation? | UNCLEAR | Reported the use of unmarked envelopes with no further details
Hood 1991^101^ | Allocation concealment? | UNCLEAR | Reported the use of sealed-envelope technique with no further details
Hood 1991^101^ | Blinding? | YES | Reported that all the patients had their skin prepared and an elastoplast placed over the possible injection site to minimize bias, while staff providing rescue analgesia administration and assessing the quality of analgesia after operation were blinded to the patients' allocation
Hood 1991^101^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Hood 1991^101^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Hood 1991^101^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Mannion 2005^102^ | Adequate sequence generation? | YES | Reported that randomization was performed using a randomization table restricted to blocks of 12 (block randomization)
Mannion 2005^102^ | Allocation concealment? | UNCLEAR | Reported as using sealed envelopes without any further details
Mannion 2005^102^ | Blinding? | YES | Reported as a double-blind trial and that the drug solutions to be administered were prepared by an anesthesiologist not involved in block performance, patient care, or data collection.
Mannion 2005^102^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Mannion 2005^102^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Mannion 2005^102^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Marhofer 1997^103^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Marhofer 1997^103^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Marhofer 1997^103^ | Blinding? | UNCLEAR | NR
Marhofer 1997^103^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Marhofer 1997^103^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Marhofer 1997^103^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Marhofer 1998^104^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Marhofer 1998^104^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Marhofer 1998^104^ | Blinding? | YES | Reported that all blocks were performed by one anesthesiologist while another anesthesiologist unaware of the group assignment performed the monitoring
Marhofer 1998^104^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Marhofer 1998^104^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Marhofer 1998^104^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Marhofer 2000^105^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Marhofer 2000^105^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Marhofer 2000^105^ | Blinding? | UNCLEAR | Reported as a double-blind trial without any further details
Marhofer 2000^105^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Marhofer 2000^105^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Marhofer 2000^105^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Matot 2003^106^ | Adequate sequence generation? | YES | Reported that randomization was performed using random numbers
Matot 2003^106^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Matot 2003^106^ | Blinding? | NO | NR, but also not possible with the study design
Matot 2003^106^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Matot 2003^106^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Matot 2003^106^ | Free of other bias? | YES | Baseline characteristics were balanced and the source of funding was declared to be institutional
Monzon 2010^107^ | Adequate sequence generation? | Yes | Computer-generated
Monzon 2010^107^ | Allocation concealment? | Yes | The randomization list was kept by one of the authors who did not interact with the patients. He gave instructions to the patient’s ED nurse about which treatment should be administered.
Monzon 2010^107^ | Blinding? | Unclear | NR
Monzon 2010^107^ | Incomplete outcome data addressed? | Unclear | No ITT, and 13.6 exclusion.
Monzon 2010^107^ | Free of selective reporting? | Yes | Protocol not available, but the outcomes in the methods match those in the results.
Monzon 2010^107^ | Free of other bias? | Yes | Baseline characteristics are balanced; no funding
Mouzopoulos 2009^108^ | Adequate sequence generation? | YES | Reported that randomization was performed using a computer-generated randomization code
Mouzopoulos 2009^108^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Mouzopoulos 2009^108^ | Blinding? | YES | Reported that patients were blinded to the treatment using a placebo with identical appearance and route of administration to the study medication
Mouzopoulos 2009^108^ | Incomplete outcome data addressed? | YES | Intention-to-treat principle was not used in the analyses with 12/219 (5.48%) of randomized pts not included in the analyses
Mouzopoulos 2009^108^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Mouzopoulos 2009^108^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Murgue 2006^109^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Murgue 2006^109^ | Allocation concealment? | UNCLEAR | NR
Murgue 2006^109^ | Blinding? | UNCLEAR | NR
Murgue 2006^109^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Murgue 2006^109^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Murgue 2006^109^ | Free of other bias? | UNCLEAR | Baseline characteristics are balanced but there is no source of funding declared
Scheinin 2000^110^ | Adequate sequence generation? | YES | Reported that randomization was performed using permuted blocks with strata
Scheinin 2000^110^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Scheinin 2000^110^ | Blinding? | NO | Reported as an “open-label” trial
Scheinin 2000^110^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 18/77 (23.38%) of randomized pts excluded from the analyses
Scheinin 2000^110^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Scheinin 2000^110^ | Free of other bias? | NO | Baseline characteristics were unbalanced with more males allocated to the parenteral analgesia group, but the source of funding is declared to be governmental and institutional.
Segado Jiménez 2009^111^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Segado Jiménez 2009^111^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Segado Jiménez 2009^111^ | Blinding? | UNCLEAR | Reported as double-blind without any further details
Segado Jiménez 2009^111^ | Incomplete outcome data addressed? | UNCLEAR | Not enough information provided in the text to make a precise decision
Segado Jiménez 2009^111^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Segado Jiménez 2009^111^ | Free of other bias? | UNCLEAR | Baseline characteristics were not presented and there is no source of funding declared
Segado Jimenez 2010^112^ | Adequate sequence generation? | Unclear | Reported as a randomized trial without any further details
Segado Jimenez 2010^112^ | Allocation concealment? | Unclear | NR
Segado Jimenez 2010^112^ | Blinding? | No | Surgeons and evaluators were independants. nothing is reported about patients.
Segado Jimenez 2010^112^ | Incomplete outcome data addressed? | Yes | All patients completed the study and were included in the analyses (intention-to-treat)
Segado Jimenez 2010^112^ | Free of selective reporting? | Yes | Protocol not available, but the outcomes in the methods match those in the results.
Segado Jimenez 2010^112^ | Free of other bias? | Unclear | Baseline characteristics are balanced. No conflict of interest for funding.
Spansberg 1996^113^ | Adequate sequence generation? | YES | Reported that randomization was performed using a computer-generated randomization.
Spansberg 1996^113^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Spansberg 1996^113^ | Blinding? | YES | Reported as a double-blind trial and reported the use of a placebo (saline) to blind patients, recovery staff and observers.
Spansberg 1996^113^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Spansberg 1996^113^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Spansberg 1996^113^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Tuncer 2003^114^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Tuncer 2003^114^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Tuncer 2003^114^ | Blinding? | NO | NR, but also not possible with the study design
Tuncer 2003^114^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Tuncer 2003^114^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Tuncer 2003^114^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Turker 2003^115^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Turker 2003^115^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Turker 2003^115^ | Blinding? | UNCLEAR | Reported that the outcomes assessment was blinded (single-blind)
Turker 2003^115^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Turker 2003^115^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Turker 2003^115^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Yun 2009^116^ | Adequate sequence generation? | YES | 'using an allocation sequence (which was generated by Y.H. Kim using a computer)'
Yun 2009^116^ | Allocation concealment? | UNCLEAR | 'The random allocation sequence was concealed until group was assigned' - no further details.
Yun 2009^116^ | Blinding? | NO | Although the anaesthesiologist who performed the spinal block and reocrded the UAS scores during patient positioning was unaware of group assignments the clinical effects of i.v. alfentanil were evident in most patients which may have introduced a bias'
Yun 2009^116^ | Incomplete outcome data addressed? | YES | All the patients in both groups were included in the statistical analysis'
Yun 2009^116^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Yun 2009^116^ | Free of other bias? | UNCLEAR | Baseline characteristics are balanced but source of funding is not declared

Table G-5 Neurostimulation

Study | Item | Judgment | Description
Gorodetskyi 2007^120^ | Adequate sequence generation? | UNCLEAR | Reported as randomized using a fixed randomization scheme with sealed envelopes with no further details.
Gorodetskyi 2007^120^ | Allocation concealment? | UNCLEAR | Reported as using sealed envelopes with no further details
Gorodetskyi 2007^120^ | Blinding? | YES | Reported that all the assessing surgeons, patients and research personnel involved in determining and recording outcome measurements were blinded. Additionally reported that the sham device had an identical appearance and application to the active device, but did not produce interactive neurostimulation
Gorodetskyi 2007^120^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Gorodetskyi 2007^120^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Gorodetskyi 2007^120^ | Free of other bias? | NO | Baseline characteristics were balanced but there is financial support from a commercial party
Lang 2007^121^ | Adequate sequence generation? | YES | Reported that randomization was performed using computer-generated codes
Lang 2007^121^ | Allocation concealment? | YES | Reported that they used sealed, sequentially-numbered, opaque envelopes
Lang 2007^121^ | Blinding? | YES | Reported that the investigator that recorded the data was not aware of the allocation, neither was the patient (use of a sham procedure)
Lang 2007^121^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 9/72 (12.50%) of randomized pts excluded from analyses with reasons provided
Lang 2007^121^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Lang 2007^121^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared

Table G-6 Rehabilitation

Study | Item | Judgment | Description
Di Lorenzo 2007^122^ | Adequate sequence generation? | YES | Reported that randomization was performed using a random numerical table (simple dichotomized admission table)
Di Lorenzo 2007^122^ | Allocation concealment? | UNCLEAR | Reported that the allocation was performed by a 'blinded' nurse but without any further details
Di Lorenzo 2007^122^ | Blinding? | NO | Reported as an 'open' trail.
Di Lorenzo 2007^122^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Di Lorenzo 2007^122^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Di Lorenzo 2007^122^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared

Table G-7 Traction

Study | Item | Judgment | Description
Finsen 1992^123^ | Adequate sequence generation? | YES | Reported that randomization was performed using random numbers
Finsen 1992^123^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Finsen 1992^123^ | Blinding? | NO | NR, but also not possible with the study design
Finsen 1992^123^ | Incomplete outcome data addressed? | NO | Intention-to-treat principle was not used in the analyses with 38/118 (32.20%) of randomized pts excluded with reasons provided
Finsen 1992^123^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Finsen 1992^123^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Jerre 2000^124^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Jerre 2000^124^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Jerre 2000^124^ | Blinding? | NO | NR, but also not possible with the study design
Jerre 2000^124^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Jerre 2000^124^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Jerre 2000^124^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Needoff 1993^125^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Needoff 1993^125^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Needoff 1993^125^ | Blinding? | NO | NR, but also not possible with the study design
Needoff 1993^125^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Needoff 1993^125^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Needoff 1993^125^ | Free of other bias? | UNCLEAR | Baseline characteristics were balanced but there is no source of funding declared
Resch 1998^126^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Resch 1998^126^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Resch 1998^126^ | Blinding? | NO | NR, but also not possible with the study design
Resch 1998^126^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Resch 1998^126^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Resch 1998^126^ | Free of other bias? | YES | Baseline characteristics were balanced and source of funding declared as governmental
Resch 2005^26^ | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial without any further details
Resch 2005^26^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Resch 2005^26^ | Blinding? | NO | NR, but also not possible with the study design
Resch 2005^26^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Resch 2005^26^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Resch 2005^26^ | Free of other bias? | UNCLEAR | Baseline characteristics were not described for the groups, but the source of funding was declared to be institutional. Additionally, reasons for the 1:2:1 randomization scheme was not provided
Rosen 2001^127^ | Adequate sequence generation? | YES | Reported that randomization was performed using computer-generated randomization
Rosen 2001^127^ | Allocation concealment? | UNCLEAR | No description of allocation concealment reported
Rosen 2001^127^ | Blinding? | NO | NR, but also not possible with the study design
Rosen 2001^127^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Rosen 2001^127^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Rosen 2001^127^ | Free of other bias? | YES | Baseline characteristics were balanced and declaration made of no external funding
Saygi 2010^130^ | Adequate sequence generation? | NO | Reported as allocation according to the order of adminission to the hospital
Saygi 2010^130^ | Allocation concealment? | NO | Quasi-randomization
Saygi 2010^130^ | Blinding? | NO | NR, but also not possible with the study design
Saygi 2010^130^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Saygi 2010^130^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Saygi 2010^130^ | Free of other bias? | YES | Baseline characteristics were balanced and declaration made of no external funding
Yip 2002^131^ | Adequate sequence generation? | NO | Patients were randomised into the two study arms depending on whether their hospital admission number was an even or an odd number.
Yip 2002^131^ | Allocation concealment? | NO | Patients were randomised into the two study arms depending on whether their hospital admission number was an even or an odd number.
Yip 2002^131^ | Blinding? | NO | There was no blinding.
Yip 2002^131^ | Incomplete outcome data addressed? | YES | All pts completed the study and were included in the analyses (intention-to-treat)
Yip 2002^131^ | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods match those in the results
Yip 2002^131^ | Free of other bias? | YES | Baseline characteristics are balanced and declaration of a noncomercial source of funding is provided