# Characteristics of Interventions

Table F-1 Systemic analgesia

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Apostolopoulos 2006^41^ | Classification | IV analgesia | IM analgesia | NA | NA
Apostolopoulos 2006^41^ | Type of intervention | Parecoxib IV | Diclofenac IM; Pethidine IM
Apostolopoulos 2006^41^ | Dosage | 40mg | 75mg; NR
Apostolopoulos 2006^41^ | Dosage Intervals | Every 12hrs | Every 12hrs; on demand
Apostolopoulos 2006^41^ | Timing of intervention | Postoperative | Postoperative
Apostolopoulos 2006^41^ | Type of intervention | Clonidine (Isotonic) | Clonidine (Hypertonic)
Apostolopoulos 2006^41^ | Dosage | 150 ug | 150 ug
Apostolopoulos 2006^41^ | Dosage Intervals | Single administration | Single administration
Apostolopoulos 2006^41^ | Timing of intervention | Postoperative | Postoperative
Apostolopoulos 2006^41^ | Baseline pain score (VAS) Mean ± SD (n) | 6.51 ± 0.63 (15) | 7.18 ± 0.37 (15)
Poitevin 1999^55^ | Classification | Analgesia | Analgesia | NA | NA
Poitevin 1999^55^ | Type of intervention | Lysine clonixinate | Metamizole
Poitevin 1999^55^ | Dosage | 125mg | 400mg
Poitevin 1999^55^ | Dosage Intervals | every 8 hr | every 8 hr
Poitevin 1999^55^ | Age (yr) Mean ± SD | 76.91 ± 6.00 | 77.60 ± 6.10
Poitevin 1999^55^ | Gender
Poitevin 1999^55^ | Females: n (%) | 35/48 (72.92%) | 35/46 (76.09%)
Poitevin 1999^55^ | Males: n (%) | 13/48 (27.08%) | 9/46 (19.57%)

IM = intramuscular; IV = intravenous; NA = not applicable; NR = not reported; VAS = visual analogue scale

Table F-2 Anesthesia

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Adams 1990^56^ | Classification | Spinal anesthesia | General anesthesia | NA | NA
Adams 1990^56^ | Type of intervention | Bupivacaine 0.5%/Mepivacaine 4% | NR
Adams 1990^56^ | Dosage | NR | NR
Adams 1990^56^ | Dosage Intervals | NR | NR
Adams 1990^56^ | Age (yr) Mean Range | 81 (70 – 88) | 79 (63 – 96)
Adams 1990^56^ | Body weight (Kg) Mean Range | 63 (45 – 100) | 58 (40 – 80)
Adams 1990^56^ | Height (cm) Mean ± SD Range | 161.00 ± 178 (150 –182) | 161.00 ± 178 (150 – 178)
Adams 1990^56^ | BMI (Kg/m^2^) Mean Gender Females: n (%) Males: n (%) Type of fractures Femoral neck: n (%) Intertrochanteric: n (%) Proximal femur: n (%) | 24.3 18/24 (75.00%) 6/24 (25.00%) 24/24 (100.00%) 0/24 (0.00%) 0/24 (0.00%) | 22.4 28/32 (87.50%) 4/32 (12.50%) 32/32 (100.00%) 0/32 (0.00%) 0/32 (0.00%)
Ben-David 2000^58^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Ben-David 2000^58^ | Type of intervention | Bupivacaine/Fentanyl | Bupivacaine
Ben-David 2000^58^ | Dosage | 4mg/20ug | 10mg
Ben-David 2000^58^ | Dosage Intervals | Single administration | Single administration
Ben-David 2000^58^ | Timing of intervention | Intra-operative | Intra-operative
Ben-David 2000^58^ | Type of surgery | Richard’s platescrew internal fixation of femoral neck fx in 8/10 ; Austin–Moore hemiarthroplasty for subcapital fx of femoral neck in 2/10 | Richard’s platescrew internal fixation of femoral neck fx and Austin–Moore hemiarthroplasty for subcapital fx of femoral neck in all
Ben-David 2000^58^ | Type of anesthesia Epidural Spinal General | 0/10 (0%) 10/10 (100%) 0/10 (0%) | 0/10 (0%) 10/10 (100%) 0/10 (0%)
Bredahl 1991^59^ | Classification | Spinal anaesthesia | General anaesthesia | NA | NA
Bredahl 1991^59^ | Type of intervention | Bupivacainc 0.5% | Thiopentone
Bredahl 1991^59^ | Dosage | 2.5-3 ml | 2-4 mg/kg
Bredahl 1991^59^ | Dosage Intervals | NR | Once
Bredahl 1991^59^ | Timing of intervention | Intra-operative | Intra-operative
Bredahl 1991^59^ | Type of surgery | internal fixation/hemiarthroplasty | internal fixation/hemiarthroplasty
Bredahl 1991^59^ | Type of anesthesia Epidural Spinal General | 0/15 (0%) 15/15 (100%) 0/15(0%) | 0/15 (0%) 0/15(0%) 13/13(100%)
Bredahl 1991^59^ | Duration of surgery (hr) Mean ± SD (Range) | 1.00 ± 0.40 (0.50 –2.00) | 1.10 ± 0.40 (0.60 –1.75)
Bredahl 1991^59^ | Age (yr) Mean ± SD (Range) | 80.00± 5.81 (72 – 93) | 79.00 ± 7.93 (60 – 90)
Bredahl 1991^59^ | Body weight (Kg) Mean ± SD Range | 56.00 ± 6.97 (40 – 65) | 56.00 ± 7.93 (45 – 70)
Bredahl 1991^59^ | Gender Females: n (%) Males: n (%) | 15/15 (100%) 0/15 (0%) | 13/13 (100%) 0/13 (0%)
Bredahl 1991^59^ | Type of fractures Femoral neck: n (%) Intertrochanteric: n (%) Proximal femur: n (%) | 12/15 (80%) 3/15 (20%) 0/15 (0%) | 8/13 (61.50%) 5/13 (38.50%) 0/13 (0%)
Casati 2003^60^ | Classification | Spinal anesthesia (single) | General anesthesia | NA | NA
Casati 2003^60^ | Type of intervention | Bupivacaine 0.5% | None
Casati 2003^60^ | Dosage | 7.5mg | NA
Casati 2003^60^ | Dosage Intervals | Single administration | NA
Casati 2003^60^ | Timing of intervention | Intra-operative | Intra-operative
Casati 2003^60^ | Type of anesthesia Epidural Spinal General | 0/15 (0%) 15/15 (100%) 0/15 (0%) | 0/15 (0%) 0/15 (0%) 15/15 (100%)
Casati 2003^60^ | Duration of surgery (hr) Range | (0.75 –1.83) | (0.83 –1.67)
Casati 2003^60^ | Baseline pain score Mean ± SD (n) (Range) | Scale name [NRS (1-5)] 1.67 ± 0.49 (15) (1.00 – 2.00) | 2.13 ± 0.74 (15) (1.00 – 3.00)
Danelli 2008^61^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Danelli 2008^61^ | Type of intervention | Levobupivacaine 0.5% | Levobupivacaine 0.75%
Danelli 2008^61^ | Dosage | 15mg | 15mg
Danelli 2008^61^ | Dosage Intervals | Single administration | Single administration
Danelli 2008^61^ | Timing of intervention | Intra-operative | Intra-operative
Danelli 2008^61^ | Type of surgery | Gamma-nail fixation or hip hemiarthroplasty in all | Gamma-nail fixation or hip hemiarthroplasty in all
Danelli 2008^61^ | Type of anesthesia Epidural Spinal General | 0/29 (0%) 29/29 (100%) 0/29 (0%) | 0/31 (0%) 31/31 (100%) 0/31 (0%)
Favarel-Garrigues 1996^62^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (single) | NA | NA
Favarel-Garrigues 1996^62^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5%
Favarel-Garrigues 1996^62^ | Dosage | Bolus: Bupivacaine 5mg (1ml); Manintainence: Bupivacaine 2.5mg (0.5ml) | Based on age and ht: 15mg 70-79 yr or >170 cm;12.5mg 80-90 yr or 150-170 cm; 10mg >90 yr or <150 cm
Favarel-Garrigues 1996^62^ | Dosage Intervals | Single administration; Continuous administration on demand | Single administration
Favarel-Garrigues 1996^62^ | Timing of intervention | Intra-operative | Intra-operative
Favarel-Garrigues 1996^62^ | Type of anesthesia Epidural Spinal General Duration of surgery (hr) Mean ± SD | 0/30 (0%) 30/30 (100%) 0/30 (0%) 1.42 ± 0.71 | 0/30 (0%) 30/30 (100%) 0/30 (0%) 1.38 ± 0.55
Hooda 2006^63^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | Spinal anesthesia (single)
Hooda 2006^63^ | Type of intervention | Bupivacaine 0.5%/Fentanyl | Bupivacaine 0.5%/Fentanyl | Bupivacaine 0.5%/Fentanyl
Hooda 2006^63^ | Dosage | 4mg (0.8ml)/20mg (0.4ml) | 5mg (1.0ml)/20mg (0.4ml) | 6mg (1.2ml)/20mg (0.4ml)
Hooda 2006^63^ | Dosage Intervals | Single administration | Single administration | Single administration
Hooda 2006^63^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Hooda 2006^63^ | Type of anesthesia Epidural Spinal General | 0/30 (0%) 30/30 (100%) 0/30 (0%) | 0/30 (0%) 30/30 (100%) 0/30 (0%) | 0/30 (0%) 30/30 (100%) 0/30 (0%)
Hooda 2006^63^ | Duration of surgery (hr) Mean ± SD (Range) | 0.98 ± 0.27 (0.42 –1.42) | 1.00 ± 0.41 (0.50 –2.67) | 1.03 ± 0.21 (0.67 –1.50)
Juelsgaard 1998^64^ | Classification | Spinal anesthesia (incremental) | Spinal anesthesia (single) | General anesthesia
Juelsgaard 1998^64^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5% | Fentanyl
Juelsgaard 1998^64^ | Dosage | 1.6ml | 2.5ml | Bolus: 1-2ug/kg/Maintainence: 25-50ug
Juelsgaard 1998^64^ | Dosage Intervals | Incremental dosage | Single administration | Single administration/Continuous administration (on demand)
Juelsgaard 1998^64^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Juelsgaard 1998^64^ | Type of surgery | Internal fixation in 4/14; hemiarthroplasty in 10/14 | Internal fixation in 5/15; hemiarthroplasty in 10/15 | Internal fixation in 3/14; hemiarthroplasty in 11/14
Juelsgaard 1998^64^ | Type of anesthesia Epidural Spinal General | 0/14 (0%) 14/14 (100%) 0/14 (0%) | 0/15 (0%) 15/15 (100%) 0/15 (0%) | 0/14 (0%) 0/14 (0%) 14/14 (100%)
Juelsgaard 1998^64^ | Duration of surgery (hr) Mean (Range) | 1.09 (0.45 –2.00) | 1.17 (0.45 –2.40) | 1.13 (0.45 –1.20)
Klimscha 1995^65^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (continuous) | Epidural anesthesia (continuous) | Epidural anesthesia (continuous)
Klimscha 1995^65^ | Type of intervention | Bupivacaine 0.5% plus clonidine | Bupivacaine 0.5% | Bupivacaine 0.5%/clonidine | Bupivacaine 0.5%
Klimscha 1995^65^ | Dosage | 1ml bupivacaine/1ml Clonidine | 10ml bupivacaine | 10ml bupivacaine/1ml Clonidine | 10ml bupivacaine
Klimscha 1995^65^ | Dosage Intervals | Continuous administration (3 repetitive doses) | Continuous administration (3 repetitive doses) | Continuous administration (3 repetitive doses) | Continuous administration (3 repetitive doses)
Klimscha 1995^65^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative | Intra-operative
Klimscha 1995^65^ | Type of anesthesia Epidural Spinal General | 0/10 (0%) 10/10 (100%) 0/10 (0%) | 0/10 (0%) 10/10 (100%) 0/10 (0%) | 10/10 (100%) 0/10 (0%) 0/10 (0%) | 10/10 (100%) 0/10 (0%) 0/10 (0%)
Koval 1999^78^ | Classification | Spinal anaesthesia | General anaesthesia | NA | NA
Koval 1999^78^ | Type of intervention | NR | NR
Koval 1999^78^ | Dosage | NR | NR
Koval 1999^78^ | Dosage Intervals | NR | NR
Koval 1999^78^ | Timing of intervention | Intra-operative | Intra-operative
Koval 1999^78^ | Type of surgery | Internal fixation, Prosthetic replacement | Internal fixation, Prosthetic replacement
Koval 1999^78^ | Type of anesthesia Epidural Spinal General | 0/280 (0%) 143/280 (51.07%) 137/280 (48.93%) | 0/362 (0%) 196/362 (54.14%) 166/362 (48.86%)
Koval 1999^78^ | Age (yr) Mean ± SD (Range) | 81.00 (65 – 105) | 78.50 (65 – 104)
Koval 1999^78^ | Gender Females: n (%) Males: n (%) | 213/280 (76.07%) 67/280 (23.93%) | 62/362 (17.13%) 300/362 (82.87%)
Koval 1999^78^ | Type of fractures Femoral neck: n (%) Intertrochanteric: n (%) Proximal femur: n (%) | 143/280(51.07%) 137/280(48.93%) 0/280(0%) | 196/362(54.14%) 166/362(45.86%) 0/362(0%)
Krobot 2006^77^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Krobot 2006^77^ | Type of intervention | Levobupivacaine/Fentanyl | Levobupivacaine
Krobot 2006^77^ | Dosage | 7.5mg/0.01mg | 10mg
Krobot 2006^77^ | Dosage Intervals | Single administration | Single administration
Krobot 2006^77^ | Timing of intervention | Intra-operative | Intra-operative
Kwan 1997^66^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Kwan 1997^66^ | Type of intervention | Bupivacaine 0.5%/Morphine | Bupivacaine 0.5%
Kwan 1997^66^ | Dosage | 2.2ml/0.2mg | 2.2ml
Kwan 1997^66^ | Dosage Intervals | Single administration | Single administration
Kwan 1997^66^ | Timing of intervention | Intra-operative | Intra-operative
Kwan 1997^66^ | Type of surgery | Austin Moore arthroplasty or compression hip screw | Austin Moore arthroplasty or compression hip screw
Kwan 1997^66^ | Baseline pain score Mean ± SD (n) | Scale name [VAS] 4.68 ± 2.14 (20) | 5.40 ± 2.76 (20)
Labaille 1992^79^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (continuous) | NA | NA
Labaille 1992^79^ | Type of intervention | Bupivacaine 0.125%/Bupivacaine 0.125% | Bupivacaine 0.5%/Bupivacaine 0.5%
Labaille 1992^79^ | Dosage | Bolus: 3ml/Maintaninence: 1ml | Bolus: 3ml/Maintaninence: 1ml
Labaille 1992^79^ | Dosage Intervals | Single administration/Continuous administration (on demand) | Single administration/Continuous administration (on demand)
Labaille 1992^79^ | Timing of intervention | Intra-operative | Intra-operative
Malek 2004^67^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | Spinal anesthesia (single) | NA
Malek 2004^67^ | Type of intervention | Bupivacaine 0.5%/Fentanyl | Bupivacaine 0.5%/Sufentanil | Bupivacaine 0.5%
Malek 2004^67^ | Dosage | 3ml/50ug | 3ml/5ug | 3ml
Malek 2004^67^ | Dosage Intervals | Single administration | Single administration | Single administration
Malek 2004^67^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Malek 2004^67^ | Type of anesthesia Epidural Spinal General | 0/21 (0%) 21/21 (100%) 0/21 (0%) | 0/21 (0%) 21/21 (100%) 0/21 (0%) | 0/21 (0%) 21/21 (100%) 0/21 (0%)
Malek 2004^67^ | Duration of surgery (hr) Mean ± SD | 1.57 ± 0.43 | 1.75 ± 0.33 | 1.60 ± 0.50
Martyr 2001^68^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Martyr 2001^68^ | Type of intervention | Bupivaciane/Fentanyl | Bupivacaine
Martyr 2001^68^ | Dosage | 7.5mg/20ug | 12.5mg
Martyr 2001^68^ | Dosage Intervals | Single administration | Single administration
Martyr 2001^68^ | Timing of intervention | Intra-operative | Intra-operative
Martyr 2001^68^ | Type of surgery | Richards pin and plate in all | Richards pin and plate in all
Martyr 2001^68^ | Type of anesthesia Epidural Spinal General | 0/20 (0%) 20/20 (100%) 0/20 (0%) | 0/22 (0%) 22/22 (100%) 0/22 (0%)
Martyr 2001^68^ | Duration of surgery (hr) Mean ± SD | 1.27 ± 0.50 | 1.10 ± 0.24
Martyr 2005^69^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Martyr 2005^69^ | Type of intervention | Bupivacaine/Fentanyl | Bupivacaine
Martyr 2005^69^ | Dosage | 9.0mg/20ug | 11.0mg
Martyr 2005^69^ | Dosage Intervals | Single administration | Single administration
Martyr 2005^69^ | Timing of intervention | Intra-operative | Intra-operative
Martyr 2005^69^ | Type of surgery | DHS in 13/20 pts; hemianhroplasty in 7/20 pts | DHS in 11/20 pts; hemianhroplasty in 9/20 pts
Martyr 2005^69^ | Type of anesthesia Epidural Spinal General | 0/20 (0%) 20/20 (100%) 0/20 (0%) | 0/20 (0%) 20/20 (100%) 0/20 (0%)
Martyr 2005^69^ | Duration of surgery (hr) Mean ± SD | 0.85 ± 0.40 | 0.78 ± 0.33
Maurette 1993^70^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (continuous) | NA | NA
Maurette 1993^70^ | Type of intervention | Bolus: lidocaine 1.6%/meperidine 1%; Maintainence: lidocaine 1.6% | Bolus: lidocaine 1.6%; Maintainence: lidocaine 1.6%
Maurette 1993^70^ | Dosage | NA/4ml (200mg); NA | NA
Maurette 1993^70^ | Dosage Intervals | Continuous administration | Continuous administration
Maurette 1993^70^ | Timing of intervention | Intra-operative | Intra-operative
Maurette 1993^70^ | Type of anesthesia Epidural Spinal General | 0/19 (0%) 19/19 (100%) 0/19 (0%) | 0/15 (0%) 15/15 (100%) 0/15 (0%)
Maurette 1993^70^ | Duration of surgery (hr) Mean ± SD | 1.33 ± 0.60 | 1.35 ± 0.40
Miller 1990^81^ | Classification | Spinal anesthesia | General anesthesia
Miller 1990^81^ | Type of intervention | Mepivacaine 4 % | Fentanyl
Miller 1990^81^ | Dosage | 2ml (80 mg) | 3-5mg per kg
Miller 1990^81^ | Dosage Intervals | NR | NR
Miller 1990^81^ | Age (yr) Mean | 79.8 | 80.5
Miller 1990^81^ | Type of fractures Femoral neck: n (%) Intertrochanteric: n (%) Proximal femur: n (%) | 0/180 (0.00%) 0/180 (0.00%) 180/180 (100.00%) | 0/137 (0.00%) 0/137 (0.00%) 137/137 (100.00%)
Minville 2006^71^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (single) | NA | NA
Minville 2006^71^ | Type of intervention | Bupivacaine | Bupivacaine
Minville 2006^71^ | Dosage | 2.5mg | 7.5mg
Minville 2006^71^ | Dosage Intervals | Continuous administration | Single administration
Minville 2006^71^ | Timing of intervention | Intra-operative | Intra-operative
Minville 2006^71^ | Type of surgery | DHS in 12/36 pts; Austin-Moore arthroplasty in 18/36; hip hemiarthroplasty in 6/36 | DHS in 10/37 pts; Austin-Moore arthroplasty in 22/37; hip hemiarthroplasty in 5/37
Minville 2006^71^ | Type of anesthesia Epidural Spinal General | 0/36 (0%) 36/36 (100%) 0/36 (0%) | 0/37 (0%) 37/37 (100%) 0/37 (0%)
Minville 2006^71^ | Duration of surgery (hr) Mean ± SD | 0.87 ± 0.30 | 0.85 ± 0.28
Minville 2008^82^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (continuous) | Spinal anesthesia (single) | General anesthesia
Minville 2008^82^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5% | Bupivacaine 0.5% | Sulfentanil
Minville 2008^82^ | Dosage | 2.5mg | 5mg | NR | NR
Minville 2008^82^ | Dosage Intervals | Continuous administration | Continuous administration | Single administration | NR
Minville 2008^82^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative | Intra-operative
Minville 2008^82^ | Time from ED arrival to surgery (hr) Mean ± SD | 24.00 ± 10.00 | 17.00 ± 12.00 | 18.00 ± 10.00 | 23.00 ± 7.00
Minville 2008^82^ | Type of surgery | Ostheosynthesis in 76/121; intermediate prosthesis in 33/12; total hip replacement in 12/121 | ostheosynthesis 34/61; intermediate prosthesis 19/61; total hip replacement 8/61 | ostheosynthesis 52/109; intermediate prosthesis 41/109; total hip replacement 16/109 | ostheosynthesis 20/42; intermediate prosthesis 8/42; total hip replacement 14/42
Minville 2008^82^ | Type of anesthesia Epidural Spinal General | 0/121 (0%) 121/121 (100%) 0/121 (0%) | 0/61 (0%) 61/61 (100%) 0/61 (0%) | 0/109 (0%) 109/109 (100%) 0/109 (0%) | 0/42 (0%) 0/42 (0%) 42/42 (100%)
Minville 2008^82^ | Duration of surgery (hr) Mean ± SD | 1.00 ± 0.33 | 1.03 ± 0.32 | 1.10 ± 0.48 | 1.30 ± 0.48
Navas 2008^72^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (single) | NA | NA
Navas 2008^72^ | Type of intervention | Bupivacaine 0.15-0.25% | Bupivacaine 0.5%
Navas 2008^72^ | Dosage | NR | NR
Navas 2008^72^ | Dosage Intervals | Continuous administration | Single administration
Navas 2008^72^ | Timing of intervention | Intra-operative | Intra-operative
Olofsson 2004^73^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | NA | NA
Olofsson 2004^73^ | Type of intervention | Bupivacaine/sufentanil | Bupivacaine
Olofsson 2004^73^ | Dosage | 7.5mg/5mg | 15mg
Olofsson 2004^73^ | Dosage Intervals | Single administration | Single administration
Olofsson 2004^73^ | Timing of intervention | Intra-operative | Intra-operative
Olofsson 2004^73^ | Type of surgery | internal fixation of femoral neck fractures with two parallel screws or DHS for subcapital fractures of the femoral neck in all pts | internal fixation of femoral neck fractures with two parallel screws or DHS for subcapital fractures of the femoral neck in all
Olofsson 2004^73^ | Type of anesthesia Epidural Spinal General | 0/25 (0%) 25/25 (100%) 0/25 (0%) | 0/25 (0%) 25/25 (100%) 0/25 (0%)
Olofsson 2004^73^ | Duration of surgery (hr) Mean ± SD | 0.82 ± 0.13 | 0.65 ± 0.08
Qamarul Hoda 2007^146^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | Spinal anesthesia (single) | NA
Qamarul Hoda 2007^146^ | Type of intervention | Bupivacaine/Fentanyl | Bupivacaine/Fentanyl | Bupivacaine
Qamarul Hoda 2007^146^ | Dosage | 6mg/20ug | 8mg/20ug | 10mg
Qamarul Hoda 2007^146^ | Dosage Intervals | Single administration | Single administration | Single administration
Qamarul Hoda 2007^146^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Rais 2008^75^ | Classification | Spinal anesthesia (continuous) | Spinal anesthesia (continuous) | NA | NA
Rais 2008^75^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5%
Rais 2008^75^ | Dosage | 2.5mg | 5mg
Rais 2008^75^ | Dosage Intervals | Single administration | Single administration
Rais 2008^75^ | Timing of intervention | Intra-operative | Intra-operative
Said-Ahmed 2006^76^ | Classification | Spinal anesthesia (single) | Spinal anesthesia (single) | Spinal anesthesia (single) | NA
Said-Ahmed 2006^76^ | Type of intervention | Bupivacaine 0.5%/Fentanyl | Bupivacaine 0.5%/Sufentanil | Bupivacaine 0.5%
Said-Ahmed 2006^76^ | Dosage | 5mg/20mcg | 5mg/5mcg | 10mg
Said-Ahmed 2006^76^ | Dosage Intervals | Single administration | Single administration | Single administration
Said-Ahmed 2006^76^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Said-Ahmed 2006^76^ | Type of surgery | Austin-Moore prosthesis in 14/20 pts; DHS in 6/20 pts | Austin-Moore prosthesis in 14/20; DHS in 6/20 | Austin-Moore prosthesis 14/20; DHS 6/20
Said-Ahmed 2006^76^ | Type of anesthesia Epidural Spinal General | 0/20 (0%) 20/20 (100%) 0/20 (0%) | 0/20 (0%) 20/20 (100%) 0/20 (0%)
Sen 2007^83^ | Classification | Spinal anesthesia (single - lateral) | Spinal anesthesia (single - supine) | NA | NA
Sen 2007^83^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5%
Sen 2007^83^ | Dosage | 10mg | 10mg
Sen 2007^83^ | Dosage Intervals | Single administration | Single administration
Sen 2007^83^ | Timing of intervention | Intra-operative | Intra-operative
Sen 2007^83^ | Type of anesthesia Epidural Spinal General | 0/23 (0%) 23/23 (100%) 0/23 (0%) | 0/18 (0%) 18/18 (100%) 0/18 (0%)
Shih 2010^84^ | Classification | Spinal anaesthesia | General anaesthesia | NA | NA
Shih 2010^84^ | Type of intervention | Bupivacaine | Thiopental
Shih 2010^84^ | Dosage | 8-15 mg | NR
Shih 2010^84^ | Dosage Intervals | NR | NR
Shih 2010^84^ | Timing of intervention | Intra-operative | Intra-operative
Shih 2010^84^ | Type of surgery | NR | NR
Shih 2010^84^ | Type of anesthesia Epidural Spinal General | 0/168 (0%) 168/168 (100%) 0/168 (0%) | 0/167 (0%) 0/167 (0%) 167/167(100%)
Shih 2010^84^ | Duration of surgery (hr) Mean ± SD Range | NR (1.33 –4.92) | NR (1.42 –8.53)
Shih 2010^84^ | Age (yr) Mean ± SD (Range) | 84.93 ± 4.04 (80 – 99) | 83.96 ± 3.71 (80 – 99)
Shih 2010^84^ | Gender Females: n (%) Males: n (%) | 74/168 (44.05%) 94/168 (55.95%) | 72/167 (43.11%) 95/167 (56.89%)
Shih 2010^84^ | ASA Class ASA I (%) ASA II (%) ASA III (%) ASA IV (%) | 0/168 (0%) 45/168 (26.79%) 120/168 (71.43%) 2/168 (1.19%) | 0/167 (0%) 47/167 (28.14%) 115/167 (68.86%) 1/167 (0.60%)
Sutcliffe 1994^85^ | Classification | Spinal anaesthesia | General anaesthesia | NA | NA
Sutcliffe 1994^85^ | Type of intervention | Bupivacaine | NR
Sutcliffe 1994^85^ | Dosage | NR | NR
Sutcliffe 1994^85^ | Dosage Intervals | NR | NR
Sutcliffe 1994^85^ | Timing of intervention | Intra-operative | Intra-operative
Sutcliffe 1994^85^ | Time from fall to surgery (hr) Mean ± SD | 57.00 ± NR | 56.00 ± NR
Sutcliffe 1994^85^ | Type of surgery | internal fixation, hemiarthroplasty, dynamic hip screw or nail plate fixation, other fixation devices | internal fixation, hemiarthroplasty, dynamic hip screw or nail plate fixation, other fixation devices
Sutcliffe 1994^85^ | Type of anesthesia Epidural Spinal General | 0/383 (0%) 383/383 (100%) 0/383 (0%) | 0/950 (0%) 0/950 (100%) 950/950 (0%)
Sutcliffe 1994^85^ | Age (yr) Mean ± SD | 80.00 ± NR | 79.00 ± NR
Sutcliffe 1994^85^ | Gender Females: n (%) Males: n (%) | 303/383 (79.11%) 80/383 (20.89%) | 788/950 (82.95%) 162/950 (17.05%)
Sutcliffe 1994^85^ | Pre-fracture residence Community: n (%) Institutional: n (%) | 92/383 (24.00) 291/383 (76.00) | 266/950 (28.00) 684/950 (72.00)

NA = not applicable; NR = not reported; NRS = numeric rating scale; VAS = visual analogue scale

Table F-3 Complementary and alternative medicine (CAM)

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Barker 2006^43^ | Classification | Auricular acupressure | Sham Control | NA | NA
Barker 2006^43^ | Type of intervention | 1-mm plastic acupressure beads | 1-mm acupressure plastic beads
Barker 2006^43^ | Dosage | 3 true auricular acupressure points | 3 sham auricular acupressure points
Barker 2006^43^ | Dosage Intervals | Single administration | Single administration
Barker 2006^43^ | Timing of intervention | Pre-operative | Pre-operative
Barker 2006^43^ | Time from fall to ED arrival (hr) Mean ± SD | 0.48 ± 0.20 | 0.53 ± 0.25
Barker 2006^43^ | Baseline pain score Mean ± SD (n) | Scale name [VAS] 6.39 ± NR (18) | 6.56 ± NR (20)
Martin 1991^54^ | Classification | Relaxation | Analgesia | NA | NA
Martin 1991^54^ | Type of intervention | Jacobson relaxation technique/Meperidine/Morphine | Meperidine/Morphine
Martin 1991^54^ | Dosage | NA | NR
Martin 1991^54^ | Dosage Intervals | Instruction given prior to surgery | NR
Martin 1991^54^ | Timing of intervention | Pre-operative | Pre-operative

NA = not applicable; NR = not reported; VAS = Visual analogue scale

Table F-4 Multimodal pain management

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Milisen 2001^86^ | Classification | Multimodal pain management | Standard care | NA | NA
Milisen 2001^86^ | Type of intervention | Bolus: Tramadol IV; Maintainence (48hrs): Tramdol IV + propacetamol IV; Maintainence (Day 3-5): oral tramadol + oral paracetamol | NR
Milisen 2001^86^ | Dosage | 3mg/ kg; 6mg/ kg/ 24hrs; 120mg/ kg/ 24hours/NA | NR
Milisen 2001^86^ | Dosage Intervals | Continuous administration | NR
Milisen 2001^86^ | Timing of intervention | Postoperative | Postoperative
Ogilvie-Harris 1993^87^ | Classification | Mutlimodal pain management | Standard care | NA | NA
Ogilvie-Harris 1993^87^ | Type of intervention | Skin Traction/Morphine/Acetaminophen | NR
Ogilvie-Harris 1993^87^ | Dosage | NA/2.5-5mg/1000mg | NR
Ogilvie-Harris 1993^87^ | Dosage Intervals | Rewrap every 8hrs/every 4hrs/every 4hrs | NR
Ogilvie-Harris 1993^87^ | Timing of intervention | Preoperative | Preoperative

IV = intravenous; NA = not applicable; NR = not reported

Table F-5 Nerve blocks

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Antonopoulou 2006^88^ | Classification | Femoral nerve block | Analgesia | NA | NA
Antonopoulou 2006^88^ | Type of intervention | Bolus: Levobupivacaine 0.25%; Maintanence: Levobupivacaine 0.12% | Paracetamol; Pethidine
Antonopoulou 2006^88^ | Dosage | 18ml | 500mg; NR
Antonopoulou 2006^88^ | Dosage Intervals | Single administration; Continuous administration | Every 8hrs; on demand
Antonopoulou 2006^88^ | Timing of intervention | Postoperative | Postoperative
Antonopoulou 2006^88^ | Type of anesthesia Epidural Spinal General | 0/49 (0%) 49/49 (100%) 0/49 (0%) | 0/35 (0%) 35/35 (100%) 0/35 (0%)
Chudinov 1999^89^ | Classification | Psoas Compartment Block (continuous) | IM analgesia | NA | NA
Chudinov 1999^89^ | Type of intervention | Bupivacaine 0.25% | Meperidine IM
Chudinov 1999^89^ | Dosage | Bolus: 2mg/kg; Maintainence: 2mg/kg | 1mg/kg
Chudinov 1999^89^ | Dosage Intervals | Single administration/Maintainence: every 12hrs | On demand (max every 5hrs)
Chudinov 1999^89^ | Timing of intervention | Preoperative | Preoperative
Chudinov 1999^89^ | Type of anesthesia Epidural Spinal General | 0/20 (0%) 11/20 (55%) 1/20 (5%) | 0/20 (0%) 19/20 (95%) 1/20 (5%)
Chudinov 1999^89^ | Baseline pain score Mean ± SD (n) | Scale name [VAS]
Chudinov 1999^89^ | Baseline pain score Mean ± SD (n) | 4.30 ± 0.60 (20) | 4.30 ± 0.70 (20)
Coad 1991^90^ | Classification | 3-in-1 nerve block | Lateral cutaneous nerve block | Standard care | NA
Coad 1991^90^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5% | NR
Coad 1991^90^ | Dosage | 15ml | 15ml | NR
Coad 1991^90^ | Dosage Intervals | Single administration | Single administration | NR
Coad 1991^90^ | Timing of intervention | Postoperative | Postoperative | Postoperative
Coad 1991^90^ | Type of surgery | Compresion screw 12/17 pts; pin and plate 5/17 | Compresion screw 13/17 pts; pin and plate 4/17 | Compresion screw 11/17; pin and plate 5/17
Coad 1991^90^ | Type of anesthesia Epidural Spinal General | 0/17 (0%) 0/17 (0%) 17/17 (100%) | 0/17 (0%) 0/17 (0%) 17/17 (100%) | 0/16 (0%) 0/16 (0%) 16/16 (100%)
Cuvillon 2007^91^ | Classification | 3-in-1 nerve block (NS) | Analgesia | Analgesia
Cuvillon 2007^91^ | Type of intervention | Ropivacaine | Paracetamol | Morphine
Cuvillon 2007^91^ | Dosage | Catheter attached to pump allowing continuous ropivacaine 0.2% at 10 mL/hr × 48 hr | 1st dose 2g then 2g | 2 mg q5min in post-op until VAS <30 then 0.1 mg/kg q4 hr; if VAS >30 dosage increased by 50%
Cuvillon 2007^91^ | Dosage Intervals | Continuous | Every 6 hours
Cuvillon 2007^91^ | Age (yr) Mean ± SD | 83 ± 5.00 | 83 ± 7.00 | 81.00 ± 8.00
Cuvillon 2007^91^ | Body weight (Kg) Mean ± SD | 60.00 ± 11.00 | 57.00 ± 10.00 | 59.00 ± 13.00
Cuvillon 2007^91^ | Height (cm) Mean ± SD | 159.00 ± 10.00 | 158.00 ± 10.00 | 159.00 ± 10.00
Cuvillon 2007^91^ | Gender Females: n (%) Males: n (%) | 18/21 (85.71%) 3/21 (14.29%) | 19/21 (90.48%) 2/21 (9.52%) | 16/20 (80.00%) 4/20 (20.00%)
de Visme 2000^92^ | Classification | Combined lumbar/sacral plexus block (NS) | Spinal anesthesia (single) | NA | NA
de Visme 2000^92^ | Type of intervention | Lidocaine 1.33% | Bupivacaine 0.5%
de Visme 2000^92^ | Dosage | 45mL | 3mL
de Visme 2000^92^ | Dosage Intervals | Single administration | Single administration
de Visme 2000^92^ | Timing of intervention | Intra-operative | Intra-operative
de Visme 2000^92^ | Type of surgery | Gamma nail osteosynthesis 9/15; Moore prosthesis 2/15; intermediary prosthesis 0/15; pinnings 4/15 | Gamma nail osteosynthesis 11/14; Moore prosthesis 1/14; intermediary prosthesis 2/14; pinnings 0/14
de Visme 2000^92^ | Type of anesthesia Epidural Spinal General | 0/15 (0%) 0/15 (0%) 0/15 (0%) | 0/14 (0%) 14/14 (100%) 0/14 (0%)
de Visme 2000^92^ | Duration of surgery (hr) Mean ± SD (Range) | 0.73 ± NR (0.32 –1.30) | 1.02 ± NR (0.53 –2.67)
Del Rosario 2008^117^ | Classification | Femoral nerve block (NS)/IV analgesia | IV analgesia | NA | NA
Del Rosario 2008^117^ | Type of intervention | Bolus: Bupivacaine 0.25%; Maintainence: bupivaine 0.1%; PCA: Paracetamol IV/metamizol IV | Paracetamol IV; metamizol IV
Del Rosario 2008^117^ | Dosage | 30ml/5ml/1g/2g | 1g; 2g
Del Rosario 2008^117^ | Dosage Intervals | Single administration; Maintainence: every hour; Patient controlled bolus: every 6hrs/every 8hrs | Every 6hrs; every 8hrs
Del Rosario 2008^117^ | Timing of intervention | Postoperative | Postoperative
Del Rosario 2008^117^ | Type of anesthesia Epidural Spinal General | 0/49 (0%) 49/49 (100%) 0/49 (0%) | 0/50 (0%) 50/50 (100%) 0/50 (0%)
Eyrolle 1998^93^ | Classification | Posterior lumbar plexus block | Spinal anesthesia (single) | NA | NA
Eyrolle 1998^93^ | Type of intervention | Lidocaine 2%/Bupivacaine 0.5% | Bupivacaine 0.5%
Eyrolle 1998^93^ | Dosage | NR | NR
Eyrolle 1998^93^ | Dosage Intervals | NR | Single administration
Eyrolle 1998^93^ | Timing of intervention | Intra-operative | Intra-operative
Eyrolle 1998^93^ | Type of anesthesia Epidural Spinal General | 0/25 (0%) 0/25 (0%) 0/25 (0%) | 0/25 (0%) 25/25 (100%) 0/25 (0%)
Fletcher 2003^94^ | Classification | 3-in-1 nerve block (NS) | IV analgesia | NA | NA
Fletcher 2003^94^ | Type of intervention | Bupivacaine 0.5% | Morphine IV
Fletcher 2003^94^ | Dosage | 20mL | 5-10mg
Fletcher 2003^94^ | Dosage Intervals | Single administration | On demand
Fletcher 2003^94^ | Timing of intervention | Preoperative | Preoperative
Fletcher 2003^94^ | Time from fall to ED arrival (hr) Mean ± SD | 29.30 ± 20.80 | 27.40 ± 16.50
Fletcher 2003^94^ | Baseline pain score Mean ± SD (n) | Scale name [NRS (0-3)]
Fletcher 2003^94^ | Baseline pain score Mean ± SD (n) | 2.80 ± 0.40 (24) | 2.70 ± 0.60 (26)
Foss 2005^95^ | Classification | Epidural analgesia (continuous) | Placebo | NA | NA
Foss 2005^95^ | Type of intervention | Bupivacaine 0.125%/morphine | Saline
Foss 2005^95^ | Dosage | 4ml of 50ug per ml per hr | NA
Foss 2005^95^ | Dosage Intervals | Continuous infusion (four days) | Continuous inusion (four days)
Foss 2005^95^ | Timing of intervention | Postoperative | Postoperative
Foss 2005^95^ | Type of surgery | Arthroplasty 10/28; intramedullar nailing 0/28; partial screws 6/28; sliding screws 12/28 | Arthroplasty 8/2; intramedullar nailing 4/27; partial screws 4/27; sliding screws 11/27
Foss 2005^95^ | Type of anesthesia Epidural Spinal General | 28/28 (100%) 0/28 (0%) 0/28 (0%) | 27/27 (100%) 0/27 (0%) 0/27 (0%)
Foss 2007^96^ | Classification | Fascia iliaca compartment nerve block (CT) | Analgesia | NA | NA
Foss 2007^96^ | Type of intervention | 1.0% mepivacaine | Morphine
Foss 2007^96^ | Dosage | 40 mL 1.0% mepivacaine with 1:200 000 epinephrine; 0.02 mL/kg placebo IM injection of 0.9% saline | 40 mL placebo FICB with 0.9% saline; 0.02 mL/kg 5.0 mg/mL morphine
Foss 2007^96^ | Dosage Intervals | Single dose | Single dose
Foss 2007^96^ | Age (yr) Mean Range | 83 (75 – 88) | 77 (69 – 88)
Foss 2007^96^ | Body weight (Kg) Mean Range | 60.00 (50 – 80) | 60.00 (50 – 65)
Foss 2007^96^ | BMI (Kg/m^2^) Mean Range | 22.80 (20 – 28) | 21.30 (19 – 21)
Foss 2007^96^ | Gender Females: n (%) Males: n (%) | 14/24 (58.33%) 10/24 (41.67%) | 21/24 (87.50%) 3/24 (12.50%)
Foss 2007^96^ | ASA Class ASA I (%) ASA II (%) ASA III (%) ASA IV (%) | 0/24 (0.00%) 13/24 (54.17%) 11/24 (45.83%) 0/24 (0.00%) | 3/24 (12.50%) 15/24 (62.50%) 6/24(25.00%) 0/24 (0.00%)
Gille 2006^97^ | Classification | Femoral nerve block | Analgesia | NA | NA
Gille 2006^97^ | Type of intervention | Prilocaine 1%/Ropivacaine 0.2% | Metamizol/Tilidine; Ibuprofen
Gille 2006^97^ | Dosage | 40ml/30ml | 1g /100mg; 400mg
Gille 2006^97^ | Dosage Intervals | Single administration/Continuous (every 6hrs) | Single administration/single administration; every 8hrs
Gille 2006^97^ | Age (yr) Mean ± SD Range | 82 ± 8.85 (61 – 103) | 78 ± 13.16 (35 – 93)
Gille 2006^97^ | Body weight (Kg) Mean ± SD | 64.00 ± 13.41 | 67.00 ± 14.54
Gille 2006^97^ | Height (cm) Mean | 163.00 | 165.00
Gille 2006^97^ | BMI (Kg/m^2^) Mean | 24.10 | 24.60
Gille 2006^97^ | Gender Females: n (%) Males: n (%) | 39/50 (78.00%) 11/50 (22.00%) | 38/50 (76.00%) 12/50 (24.00%)
Gille 2006^97^ | Type of fractures Femoral neck: n (%) Intertrochanteric: n (%) Proximal femur: n (%) | 0/50 (0.00%) 0/50 (0.00%) 50/50 (100.00%) | 0/50 (0.00%) 0/50 (0.00%) 50/50 (100.00%)
Graham 2008^98^ | Classification | 3-in-1 nerve block (NS) | IV analgesia | NA | NA
Graham 2008^98^ | Type of intervention | Bupivacaine 0.5% | Morphine IV
Graham 2008^98^ | Dosage | 30ml | 0.1mg per kg
Graham 2008^98^ | Dosage Intervals | Single administration | Single administration
Graham 2008^98^ | Timing of intervention | Preoperative | Preoperative
Haddad 1995^99^ | Classification | Femoral nerve block CT) | Standard care | NA | NA
Haddad 1995^99^ | Type of intervention | Bupivacaine 0.25% | NR
Haddad 1995^99^ | Dosage | 0.3ml per kg | NR
Haddad 1995^99^ | Dosage Intervals | Single administration | NR
Haddad 1995^99^ | Timing of intervention | Preoperative | Preoperative
Haddad 1995^99^ | Type of surgery | Internal fixation with DHS in all pts | Internal fixation with DHS in all pts
Haddad 1995^99^ | Baseline pain score Mean (n) (Range) | Scale name [VAS]
Haddad 1995^99^ | Baseline pain score Mean (n) (Range) | 7.40 (25) (2.00 – 10.00) | 7.10 (25) (3.00 – 10.00)
Henderson 2008^100^ | Classification | Femoral nerve block/Opioids | Standard care | NA | NA
Henderson 2008^100^ | Type of intervention | Bupivacaine 0.5% | Opioids
Henderson 2008^100^ | Dosage | NR/NR | NR
Henderson 2008^100^ | Dosage Intervals | Continuous/On demand | Intermittent
Henderson 2008^100^ | Timing of intervention | Preoperative | Preoperative
Hood 1991^101^ | Classification | 3-in-1 nerve block | Standard care | NA | NA
Hood 1991^101^ | Type of intervention | Prilocaine 0.75% | NR
Hood 1991^101^ | Dosage | 43ml | NR
Hood 1991^101^ | Dosage Intervals | Single administration | NR
Hood 1991^101^ | Timing of intervention | Intra-operative | Intra-operative
Hood 1991^101^ | Type of surgery | Compression screw or pin and plate device | Compression screw or pin and plate device
Hood 1991^101^ | Type of anesthesia General | 25/25 (100%) | 25/25 (100%)
Kocum 2007^118^ | Classification | Lumbar plexus plus sciatic block (NS) | Lumbar plexus plus sciatic block (NS) | NA | NA
Kocum 2007^118^ | Type of intervention | Ropivacaine 0.25% | Bupivacaine 0.25%
Kocum 2007^118^ | Dosage | 60ml | 60ml
Kocum 2007^118^ | Dosage Intervals | Single administration | Single administration
Kocum 2007^118^ | Timing of intervention | Intra-operative | Intra-operative
Kocum 2007^118^ | Duration of surgery (hr) Mean ± SD | 1.05 ± 0.39 | 1.03 ± 0.29
Mannion 2005^102^ | Classification | Psoas compartment block (NS) | Psoas compartment block (NS) | Psoas compartment block (NS) | NA
Mannion 2005^102^ | Type of intervention | Levobupivacaine 0.5%/Clonidine IV | Levobupivacaine 0.5%/Clonidine (peripheral) | Levobupivacaine 0.5%
Mannion 2005^102^ | Dosage | 0.4mL per kg/1ug per kg | 0.4mL per kg/1ug/kg | 0.4mL/kg
Mannion 2005^102^ | Dosage Intervals | Single administration | Single administration | Single administration
Mannion 2005^102^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Mannion 2005^102^ | Type of surgery | Hemiarthroplasty in 6/12 pts; DHS in 6/12 pts | Hemiarthroplasty in 7/12 pts; DHS in 5/12 pts | Hemiarthroplasty in 5/12 pts; DHS in 7/12 pts
Mannion 2005^102^ | Type of anesthesia General | 12/12 (100%) | 12/12 (100%) | 12/12 (100%)
Marhofer 1997^103^ | Classification | 3-in-1 nerve block (US) | 3-in-1 nerve block (NS) | NA | NA
Marhofer 1997^103^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5%
Marhofer 1997^103^ | Dosage | 20ml | 20ml
Marhofer 1997^103^ | Dosage Intervals | Single administration | Single administration
Marhofer 1997^103^ | Timing of intervention | Preoperative | Preoperative
Marhofer 1997^103^ | Type of anesthesia Epidural Spinal General | 0/20 (0%) 20/20 (100%) 0/20 (0%) | 0/20 (0%) 20/20 (100%) 0/20 (0%)
Marhofer 1998^104^ | Classification | 3-in-1 nerve block (US) | 3-in-1 nerve block (NS) | 3-in-1 nerve block (NS) | NA
Marhofer 1998^104^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5% | Bupivacaine 0.5%
Marhofer 1998^104^ | Dosage | 20ml | 20ml | 30ml
Marhofer 1998^104^ | Dosage Intervals | Single administration | Single administration | Single administration
Marhofer 1998^104^ | Timing of intervention | Pre-operative | Pre-operative | Pre-operative
Marhofer 2000^105^ | Classification | 3-in-1 nerve block (NS) | 3-in-1 nerve block (NS) | NA | NA
Marhofer 2000^105^ | Type of intervention | Ropivacaine 0.5% | Bupivacaine 0.5%
Marhofer 2000^105^ | Dosage | 20ml | 20ml
Marhofer 2000^105^ | Dosage Intervals | Single administration | Single administration
Marhofer 2000^105^ | Timing of intervention | Preoperative | Preoperative
Matot 2003^106^ | Classification | Epidural analgesia (continuous) | IM analgesia | NA | NA
Matot 2003^106^ | Type of intervention | Bolus: Bupivacaine 0.25%/Methadone; Maintainence: Bupivacaine 0.5%/Methadone | Meperidine IM
Matot 2003^106^ | Dosage | 7-10mL/4mg; 45mg/16mg | 1mg/kg
Matot 2003^106^ | Dosage Intervals | Continous (24hrs) | Every 6hrs
Matot 2003^106^ | Timing of intervention | Preoperative | Preoperative
Matot 2003^106^ | Time from fall to ED arrival (hr) Mean ± SD | 4.38 ± 2.50 | 4.18 ± 2.21
Matot 2003^106^ | Time from ED arrival to surgery (hr) Mean ± SD | 25.90 ± 16.70 | 28.60 ± 18.20
Matot 2003^106^ | Type of surgery | DHS and plate fixation 20/34; hemiarthroplasty 12/34; cannulated hip screw 2/34 | DHS and plate fixation 17/34; hemiarthroplasty 11/34; cannulated hip screw 2/34
Matot 2003^106^ | Type of anesthesia Epidural Spinal General | 30/34 (88.24%) 0/34 (0%) 4/34 (11.76%) | 0/34 (0%) 27/34 (79.41%) 3/34 (8.82%)
Matot 2003^106^ | Baseline pain score Mean ± SD (n) | Scale name [VAS]
Matot 2003^106^ | Baseline pain score Mean ± SD (n) | 5.16 ± 1.74 (34) | 4.91 ± 2.03 (34)
Monzon 2010^107^ | Classification | Fascia iliaca compartment block | General anaethesia | NA | NA
Monzon 2010^107^ | Type of intervention | 0.25% bupivacaine | IV NSAID analgesics
Monzon 2010^107^ | Dosage | 0.3 ml/kg | NR
Monzon 2010^107^ | Dosage Intervals | NR | NR
Monzon 2010^107^ | Timing of intervention | Intra-operative | Intra-operative
Monzon 2010^107^ | Type of surgery | NR | NR
Monzon 2010^107^ | Type of anesthesia Epidural Spinal General | 0/92 (0%) 92/92 (100%) 0/92 (0%) | 0/62 (0%) 0/62 (0%) 62/62 (100%)
Monzon 2010^107^ | Baseline pain score Scale name [VAS] Mean ± SD (n) | 8.50 ± 0.72 (n = 92) | 7.60 ± 0.22 (n = 62)
Monzon 2010^107^ | Gender Females: n (%) Males: n (%) | 59/92 (64.13%) 33/92 (35.87%) | 37/62 (59.68%) 25/62 (40.32%)
Mouzopoulos 2009^108^ | Classification | Fascia iliaca compartment nerve block (CT) | Placebo | NA | NA
Mouzopoulos 2009^108^ | Type of intervention | Bupivacaine | Saline
Mouzopoulos 2009^108^ | Dosage | 0.25mg dose of 0.3mL/kg | NA
Mouzopoulos 2009^108^ | Dosage Intervals | every 24h pre-/post surgery | Every 24h pre-/post surgery
Mouzopoulos 2009^108^ | Timing of intervention | Preoperative | Preoperative
Mouzopoulos 2009^108^ | Baseline pain score Mean ± SD (n) | Scale name [Visual analogue scale]
Mouzopoulos 2009^108^ | Baseline pain score Mean ± SD (n) | 6.14 ± NR (102) | 6.82 ± NR (105)
Murgue 2006^109^ | Classification | Femoral nerve block | Analgesia | Analgesia | NA
Murgue 2006^109^ | Type of intervention | Mepivacaine | IV morphine | IV paracetamol + ketoprofen
Murgue 2006^109^ | Dosage | 20 cc | 2 mg | 1 g P + 100 mg K
Murgue 2006^109^ | Dosage Intervals | | 1 mg q5 min until p<=4
Murgue 2006^109^ | Age (yr) Mean ± SD Range | 85.90 ± 6.60 (70 – 96) | 85.90 ± 6.60 (70 – 96) | 85.90 ± 6.60 (70 – 96)
Pedersen 2008^119^ | Classification | 3-in-1 nerve block | Analgesia | NA | NA
Pedersen 2008^119^ | Type of intervention | Bupivacaine | Preoperative: Morphine SC or tablets; Postoperative: Morphine SR tablets/acetaminophen/ibuprofen
Pedersen 2008^119^ | Dosage | Bolus: 100mg; Maintainence: 50mg | 2.5-5mg/10-20mg; 1g/or 400mg
Pedersen 2008^119^ | Dosage Intervals | Single administration; continuous (every 8hrs) | Every 12hrs; every 8hr/or every 12hrs
Pedersen 2008^119^ | Timing of intervention | Preoperative | Preoperative
Pedersen 2008^119^ | Time from ED arrival to surgery (hr) Mean ± SD | 26.40 ± 19.30 | 27.60 ± 29.10
Pedersen 2008^119^ | Type of surgery | Screws 39/178; DHS 50/178; intramedullary hip screw 43/178; Hemialloplasty 44/178; total hip arthroplasty 2/178 | Screws 66/357; DHS 109/357; intramedullary hip screw 81/357; hemialloplasty 101/357; total hip arthroplasty 0/357
Pedersen 2008^119^ | Type of anesthesia Epidural Spinal General | 0/178 (0%) 42/178 (23.60%) 136/178 (76.40%) | 0/357 (0%) 48/357 (13.45%) 309/357 (86.55%)
Scheinin 2000^110^ | Classification | Epidural analgesia (continuous) | IM analgesia | NA | NA
Scheinin 2000^110^ | Type of intervention | Bupivacaine/Fentanyl | Oxycodone IM
Scheinin 2000^110^ | Dosage | 1mg per ml + 10ug/ml | 0.1-0.15mg/kg
Scheinin 2000^110^ | Dosage Intervals | Continuous administration | On demand (max every 6hrs)
Scheinin 2000^110^ | Timing of intervention | Preoperative | Preoperative
Scheinin 2000^110^ | Type of surgery | Screw, lamina or prothesis in all pts | Screw, lamina or prothesis in all pts
Scheinin 2000^110^ | Type of anesthesia Epidural Spinal General | 0/38 (0%) 38/38 (100%) 0/38 (0%) | 0/39 (0%) 39/39 (100%) 0/39 (0%)
Scheinin 2000^110^ | Baseline pain score Mean ± SD (n) | Scale name [VAS] 3.40 ± 2.40 (38) | 4.20 ± 2.90 (39)
Segado Jiménez 2009^111^ | Classification | Obturator/Femoral cutaneous nerve block | Obturator nerve block | IV analgesia
Segado Jiménez 2009^111^ | Type of intervention | NR | NR | Opioid analgesia
Segado Jiménez 2009^111^ | Dosage | NR | NR | NR
Segado Jiménez 2009^111^ | Dosage Intervals | NR | NR | NR
Segado Jiménez 2009^111^ | Timing of intervention | Postoperative | Postoperative | Postoperative
Segado Jiménez 2010^112^ | Classification | Fascia iliaca compartment block | Obturator/femoralcutaneous nerves block | General anaesthesia | NA
Segado Jiménez 2010^112^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5% | NR
Segado Jiménez 2010^112^ | Dosage | 30 ml | 15ml / 5 ml | NR
Segado Jiménez 2010^112^ | Dosage Intervals | NR | NR | NR
Segado Jiménez 2010^112^ | Timing of intervention | Intra-operative | Intra-operative | Intra-operative
Segado Jiménez 2010^112^ | Type of surgery | total/partial arthroplasty, osteosynthesis, Richards osteosynthesis | total/partial arthroplasty, osteosynthesis, Richards osteosynthesis | total/partial arthroplasty, osteosynthesis, Richards osteosynthesis
Segado Jiménez 2010^112^ | Type of anesthesia Epidural Spinal General | 0/30 (0%) 30/30 (100%) 0/30 (0%) | 0/30 (0%) 30/30 (100%) 0/30 (0%) | 0/30 (0%) 0/30 (0%) 30/30 (100%)
Segado Jiménez 2010^112^ | Baseline pain score Scale name [VAS] Mean ± SD | 0.84 (n = 30) | 0.84 (n = 30) | 7.47 (n = 30)
Segado Jiménez 2010^112^ | Age (yr) Mean ± SD | 71.30 ± 12.60 | 74.60 ± 10.10 | 71.10 ± 10.20
Segado Jiménez 2010^112^ | Body weight (Kg) Mean ± SD | 69.70 ± 8.60 | 68.60± 10.20 | 68.20 ± 9.60
Segado Jiménez 2010^112^ | Height (cm) Mean ± SD | 157.00 ± 6.00 | 158.00± 7.00 | 157.00 ± 6.00
Segado Jiménez 2010^112^ | BMI (Kg/m^2^) Mean ± SD | 28.20 ± 4.20 | 27.30 ± 4.20 | 27.6 ± 3.80
Spansberg 1996^113^ | Classification | Lumbar plexus block (NS) | Placebo | NA | NA
Spansberg 1996^113^ | Type of intervention | Bolus: Bupivacaine 0.5%; Maintenence: Bupivacaine 0.25% | Bolus: Saline; Maintainence: Saline
Spansberg 1996^113^ | Dosage | 0.4mL per kg; 0.14mL/kg/hr | 0.4mL per Kg; 0.14mL/kg/hr
Spansberg 1996^113^ | Dosage Intervals | Single administration; Continuous administration | Continuous administration
Spansberg 1996^113^ | Timing of intervention | Postoperative | Postoperative
Spansberg 1996^113^ | Type of anesthesia Spinal Duration of surgery (hr) Mean ± SD (Range) | 10/10 (100%) 0.96 ± NR (0.50 –1.83) | 10/10 (100%) 1.18 ± NR (0.75 –2.08)
Tuncer 2003^114^ | Classification | 3-in-1 nerve block (NS) | IV analgesia | NA | NA
Tuncer 2003^114^ | Type of intervention | Bolus: Lidocaine 2%/Maintainence: Bupivacaine 0.125%; PCA bolus: Bupivaciane 0.125% | Morphine IV
Tuncer 2003^114^ | Dosage | 30ml; 4ml/hr; 3ml | 1mg
Tuncer 2003^114^ | Dosage Intervals | Single administration; Continuous administration; Patient cotrolled bolus on demand | On demand
Tuncer 2003^114^ | Timing of intervention | Postoperative | Postoperative
Turker 2003^115^ | Classification | Psoas compartment block (NS) | Epidural anesthesia (single) | NA | NA
Turker 2003^115^ | Type of intervention | Bupivacaine 0.5% | Bupivacaine 0.5%
Turker 2003^115^ | Dosage | 30ml | 15ml
Turker 2003^115^ | Dosage Intervals | Single administration | Single administration
Turker 2003^115^ | Timing of intervention | Intra-operative | Intra-operative
Turker 2003^115^ | Type of surgery | Partial hip replacement | Partial hip replacement
Turker 2003^115^ | Type of anesthesia Epidural Spinal General Duration of surgery (hr) Mean ± SD | 0/15 (0%) 0/15 (0%) 15/15 (100%) 2.19 ± 0.31 | 15/15 (100%) 0/15 (0%) 15/15 (100%) 2.15 ± 0.44
Turker 2003^115^ | Baseline pain score | Scale name [VAS]
Turker 2003^115^ | Mean ± SD (n) | 1.56 ± 0.97 (15) | 1.23 ± 1.05 (15)
Yun 2009^116^ | Classification | Fascia iliaca compartment nerve block (CT) | Analgesia
Yun 2009^116^ | Type of intervention | Ropivacaine | Alfentanil
Yun 2009^116^ | Dosage | 30 mL 3.75 mg/mL 2-3 min | 10 ug/kg bolus; 0.25 ug/kg/min 2 min
Yun 2009^116^ | Dosage Intervals | Single dose | Single dose
Yun 2009^116^ | Age (yr) Mean ± SD Range | 75 (69 – 85) | 75.10 (62 – 88)
Yun 2009^116^ | Body weight (Kg) Mean ± SD | 60.60 ± 7.20 | 60.30 ± 11.30
Yun 2009^116^ | Height (cm) Mean | 156.20 | 160.80
Yun 2009^116^ | Gender Females: n (%) Males: n (%) | 13/20 (65.00%) 5/20 (25.00%) | 13/20 (65.00%) 7/20 (35.00%)

CT = clinical touch; FICB = fascia iliaca compartment block; IM = intramuscular; IV = intravenous; NA = not applicable; NR = not reported; NRS = numeric rating scale; NS = nerve stimulation; NSAID = non-steroidal anti-inflamatory drugs; US = ultrasound; VAS = visual analogue scale

Table F-6 Neurostimulation

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Gorodetskyi 2007^120^ | Classification | Neurostimualtion | Sham Control | NA | NA
Gorodetskyi 2007^120^ | Type of intervention | InterX 5000 device | NA
Gorodetskyi 2007^120^ | Dosage | High peak amplitude 17 volts , low current 6 mA, damped biphasic electrical impulses | NA
Gorodetskyi 2007^120^ | Dosage Intervals | Every 24hrs | Every 24hrs
Gorodetskyi 2007^120^ | Timing of intervention | Postoperative | Postoperative
Gorodetskyi 2007^120^ | Type of surgery | DHS/dynamic condylar screw for noncomplex fractures 25/30; Gorodnichenko external fixation method for complex fractures 5/30 | DHS/dynamic condylar screw for noncomplex fractures 27/30; Gorodnichenko external fixation method for complex fractures 3/30
Gorodetskyi 2007^120^ | Type of anesthesia General | 30/30 (100%) | 30/30 (100%)
Gorodetskyi 2007^120^ | Baseline pain score Mean ± SD (n) Range | Scale name [VAS]
Gorodetskyi 2007^120^ | Baseline pain score Mean ± SD (n) Range | 9.00 ± NR (30) (7.50 – 10.00) | 8.80 ± NR (30) (7.50 – 10.00)
Lang 2007^121^ | Classification | Neurostimulation | Sham Control | NA | NA
Lang 2007^121^ | Type of intervention | Transcutaneous electrical nerve stimulation | NA
Lang 2007^121^ | Dosage | 70 mA, range: 0.5-120 Hz, pulse width: 60 to 300 us | NA
Lang 2007^121^ | Dosage Intervals | Single administration | Single administration
Lang 2007^121^ | Timing of intervention | Preoperative | Preoperative
Lang 2007^121^ | Time from fall to ED arrival (hr) Mean ± SD | 29.80 ± 8.50 | 28.20 ± 12.30
Lang 2007^121^ | Baseline pain score Mean ± SD (n) | Scale name [VAS]
Lang 2007^121^ | Baseline pain score Mean ± SD (n) | 8.90 ± 0.90 (30) | 8.60 ± 1.20 (33)

NA = not applicable; VAS = visual analogue scale

Table F-7 Rehabilitation

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Di Lorenzo 2007^122^ | Classification | Rehabilitation | Standard care | NA | NA
Di Lorenzo 2007^122^ | Type of intervention | Stretching-strengthening of spinal and psoas muscles | NR
Di Lorenzo 2007^122^ | Dosage | 1 hr of training | NR
Di Lorenzo 2007^122^ | Dosage Intervals | Every 12 hrs for four wk | NR
Di Lorenzo 2007^122^ | Timing of intervention | Postoperative | Postoperative
Di Lorenzo 2007^122^ | Baseline pain score Mean ± SD (n) Range | Scale name [VAS]
Di Lorenzo 2007^122^ | Baseline pain score Mean ± SD (n) Range | 7.94 ± 0.80 (18) (7.00 – 9.00) | 7.94 ± 0.82 (19) (7.00 – 9.00)

NA = not applicable; NR = not reported; VAS = visual analogue scale

Table F-8 Traction

| | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Anderson 1993^128^ | Classification | Skin traction | Standard care | NA | NA
Anderson 1993^128^ | Type of intervention | Hamilton-Russell skin traction | NR
Anderson 1993^128^ | Dosage | 5lb (2.3kg) | NR
Anderson 1993^128^ | Dosage Intervals | NA | NR
Anderson 1993^128^ | Timing of intervention | Preoperative | Preoperative
Anderson 1993^128^ | Baseline pain score Mean ± SD (n) | Scale name [VAS]
Anderson 1993^128^ | Baseline pain score Mean ± SD (n) | 5.11 ± NR (101) | 5.42 ± NR (151)
Finsen 1992^123^ | Classification | Skin traction | Skeletal traction | Pillow | NA
Finsen 1992^123^ | Type of intervention | Elastic bandages | Steinman pin | Standard pillow
Finsen 1992^123^ | Dosage | 3Kg | 10% of patient's wt | NA
Finsen 1992^123^ | Dosage Intervals | NA | NA | NA
Finsen 1992^123^ | Timing of intervention | Preoperative | Preoperative | Preoperative
Finsen 1992^123^ | Time from ED arrival to surgery (hr) Mean ± SD (Range) | 24.00 ± NR (10.00 – 52.00) | 23.00 ± NR (8.00 – 68.00) | 26.00 ± NR (10.00 – 90.00)
Finsen 1992^123^ | Type of surgery | Hip compression screws or uncemented endoprosthesis | Hip compression screws or uncemented endoprosthesis | Hip compression screws, uncemented endoprosthesis 24/25; cemented endoprosthesis 1/25
Ghnaimat 2005^129^ | Classification | Skin traction | Standard care | NA | NA
Ghnaimat 2005^129^ | Type of intervention | Skin traction | NR
Ghnaimat 2005^129^ | Dosage | 6lb | NR
Ghnaimat 2005^129^ | Dosage Intervals | NA | NR
Ghnaimat 2005^129^ | Timing of intervention | Preoperative | Preoperative
Jerre 2000^124^ | Classification | Skin traction | Standard care | Skin traction | Standard care
Jerre 2000^124^ | Type of intervention | Foam rubber boot with straps around lower leg | NR | Foam rubber boot with straps around lower leg | NR
Jerre 2000^124^ | Dosage | 3Kg | NR | 3Kg | NR
Jerre 2000^124^ | Dosage Intervals | NA | NR | NA | NR
Jerre 2000^124^ | Timing of intervention | Preoperative | Preoperative | Preoperative | Preoperative
Jerre 2000^124^ | Time from ED arrival to surgery (hr) Mean ± SD | 21.50 ± 37.70 | 18.50 ± 9.40 | 16.30 ± 8.20 | 15.20 ± 9.30
Jerre 2000^124^ | Time from fall to surgery (hr) Mean ± SD | 34.50 ± 44.30 | 27.20 ± 10.00 | 25.00 ± 9.30 | 28.60 ± 18.80
Jerre 2000^124^ | Baseline pain score Mean ± SD (n) | Scale name [VAS]
Jerre 2000^124^ | Baseline pain score Mean ± SD (n) | 4.10 ± 2.70 (30) | 4.50 ± 2.60 (30) | 4.30 ± 2.40 (30) | 3.90 ± 2.70 (30)
Needoff 1993^125^ | Classification | Skin traction | Pillow | NA | NA
Needoff 1993^125^ | Type of intervention | Ventilated foam strap secured by means of a crepe bandage | Standard pillow
Needoff 1993^125^ | Dosage | 2.5kg | NA
Needoff 1993^125^ | Dosage Intervals | NA | NA
Needoff 1993^125^ | Timing of intervention | Preoperative | Pre-operative
Needoff 1993^125^ | Duration of surgery (hr) Mean ± SD | 0.69 ± NR | 0.77 ± NR
Needoff 1993^125^ | Baseline pain score Mean ± SD (n) | Scale name [VAS]
Needoff 1993^125^ | Baseline pain score Mean ± SD (n) | 6.82 ± NR (30) | 6.32 ± NR (34) | NA | NA
Resch 1998^126^ | Classification | Skin traction | Skeletal traction | NA | NA
Resch 1998^126^ | Type of intervention | Foam boot | K-wire
Resch 1998^126^ | Dosage | 3kg | 3-5kg (5-10% body weight)
Resch 1998^126^ | Dosage Intervals | NA | NA
Resch 1998^126^ | Timing of intervention | Preoperative | Preoperative
Resch 1998^126^ | Time from ED arrival to surgery (hr) Mean ± SD (Range) | 24.00 ± 13.00 (20.00 – 28.00) | 21.00 ± 9.00 (18.00 – 24.00)
Resch 1998^126^ | Duration of surgery (hr) Mean ± SD (Range) | 0.80 ± 0.40 (0.68 – 0.92) | 0.97 ± 0.60 (0.78 – 1.15)
Resch 1998^126^ | Baseline pain score | Scale name [VAS]
Resch 1998^126^ | Mean ± SD (n) Range | 4.80 ± 2.50 (40) (4.00 – 5.60) | 3.80 ± 2.00 (38) (3.20 – 4.40)
Resch 2005^26^ | Classification | Skin traction | Pillow | Pillow | NA
Resch 2005^26^ | Type of intervention | Foam rubber boot | Lasse Pillow | Standard pillow
Resch 2005^26^ | Dosage | 3kg | NA | NA
Resch 2005^26^ | Timing of intervention | Preoperative | Preoperative | Preoperative
Resch 2005^26^ | Time from ED arrival to surgery (hr) Mean ± SD | 22.00 ± 6.70 | 24.00 ± 6.50 | 23.00 ± 6.60
Resch 2005^26^ | Duration of surgery (hr) Mean ± SD | 0.88 ± 0.52 | 1.08 ± 0.95 | 0.98 ± 0.55
Resch 2005^26^ | Baseline pain score | Scale name [VAS]
Resch 2005^26^ | Mean ± SD (n) | 4.30 ± 2.20 (49) | 3.30 ± 2.50 (21) | 3.90 ± 1.90 (53)
Rosen 2001^127^ | Classification | Skin traction | Pillow | NA | NA
Rosen 2001^127^ | Type of intervention | Foam traction boot | Standard pillow
Rosen 2001^127^ | Dosage | 5lb | NA
Rosen 2001^127^ | Timing of intervention | Preoperative | Preoperative
Rosen 2001^127^ | Time from ED arrival to surgery (hr) Mean ± SD | 28.80 ± 15.36 | 31.44 ± 25.44
Rosen 2001^127^ | Baseline pain score | Scale name [VAS]
Rosen 2001^127^ | Mean ± SD (n) | 5.86 ± 2.73 (50) | 6.12 ± 2.08 (50)
Saygi 2010^130^ | Classification | Skin traction | Sham traction | Pillow | NA
Saygi 2010^130^ | Type of intervention | Foam traction boot | Standard pillow | Standard pillow
Saygi 2010^130^ | Dosage | 2kg | 0kg | NA
Saygi 2010^130^ | Timing of intervention | Preoperative | Preoperative | Preoperative
Saygi 2010^130^ | Time from fall to surgery (hr) Mean | 52.8 | 52.6 | 54.2
Saygi 2010^130^ | Baseline pain score Mean ± SD (n) | Scale name [Visual analogue scale] 6.93 ± 1.14 (36) | 7.04 ± 1.08 (36) | 6.85 ± 1.29 (36)
Vermeiren 1995^132^ | Classification | Skeletal traction | Skeletal traction | NA | NA
Vermeiren 1995^132^ | Type of intervention | Skeletal traction with pillows for foot elevation | Skeletal traction with metal splint
Vermeiren 1995^132^ | Dosage | 1 kg traction weight/10 kg body weight | 1 kg traction weight/10 kg body weight
Vermeiren 1995^132^ | Dosage Intervals | NA | NA
Vermeiren 1995^132^ | Timing of intervention | Preoperative | Preoperative
Vermeiren 1995^132^ | Type of surgery | Nail-plates or screw plates 62/64; sliding hip nials 4/64 | Nail-plates or screw-plates 46/68; sliding hip nails 16/68; Ender nails 5/68; cancellous screw fixation 1/68
Yip 2002^131^ | Classification | Skin traction | Pillow | NA | NA
Yip 2002^131^ | Type of intervention | Foam boot | Standard pillow
Yip 2002^131^ | Dosage | 2kg | NA
Yip 2002^131^ | Dosage Intervals | NA | NA
Yip 2002^131^ | Timing of intervention | Preoperative | Preoperative
Yip 2002^131^ | Time from fall to ED arrival (hr) Mean ± SD (Range) | 17.52 ± 14.16 (0.00 – 96.00) | 17.52 ± 14.88 (0.00 – 72.00)
Yip 2002^131^ | Time from ED arrival to surgery (hr) Mean ± SD | 113.52 ± 51.84 | 112.56 ± 71.76
Yip 2002^131^ | Type of surgery | Hemiarthroplasty 52/166; DHS 99/166; percutaneous hip screws 10/166; other types of surgeries 4/166 | Hemiarthroplasty in 45/145; DHS 78/145; percutaneous hip screws 16/145; other types of surgeries 5/145
Yip 2002^131^ | Baseline pain score | Scale name [VAS]
Yip 2002^131^ | Mean ± SD (n) | 0.24 ± NR (166) | 0.30 ± NR (145)

NA = not applicable; NR = not reported; VAS = visual analogue scale