# Description of Included Studies

Table E-1 Systemic analgesia

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Apostolopoulos 2006^41^ | Study design: RCT Study period: Jan-03 to Jul-04 Type of hospital: General hospital Country: Switzerland Financial support: NR | Intervention #1: Classification: IV analgesia Intervention: Parecoxib IV Dosage: 40mg Intervals: Every 12hrs Intervention #2: Classification: IM analgesia Intervention: Diclofenac IM; Pethidine IM Dosage: 75mg; NR Intervals: Every 12hrs; on demand | Main inclusion criteria: Pts operated for fracture of hip joint Main exclusion criteria: NR
Baker 2004^42^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Intrathecal analgesia Intervention: Clonidine (Isotonic) Dosage: 150ug Intervals: Single administration Intervention #2: Classification: Intrathecal analgesia Intervention: Clonidine (Hypertonic) Dosage: 150ug Intervals: Single administration | Main inclusion criteria: Elderly pts undergoing surgery after traumatic hip fractures under general anesthesia Main exclusion criteria: Contraindications to spinal anesthesia, unable to understand study protocol, severe deformities of spine, history of untreated hypertensive disease, or receiving treatment with β-adrenergic blockers
Poitevin 1999^55^ | Study design: Randomized controlled trials Study period: NR to NR Type of hospital: University hospital Country: Argentina Financial support: NR | Intervention #1: Classification: Analgesia Intervention: Lysine clonixinate Dosage: 125mg Intervals: every 8 hr Intervention #2: Classification: Analgesia Intervention: Metamizole Dosage: 400mg Intervals: every 8 hr | Main inclusion criteria: Patients aged 50-85 years old; <3 days since trauma leading to hip fracture; undergoing surgery Main exclusion criteria: Patients with allergies to investigational drug; GI problems; psychiatric disorders; any other use of anti-inflammatory analgesic drugs

IM = intramuscular; IV = intravenous; NR = NR; RCT = randomized controlled trial

Table E-2 Anesthesia

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Adams 1990^56^ | Study design: Randomized controlled trials Study period: NR to NR Type of hospital: University hospital Country: Germany Financial support: | Intervention #1: Classification: Spinal anesthesia Intervention: Bupivacaine 0.5%/Mepivacaine 4% Dosage: NR Intervals: NR Intervention #2: Classification: General anesthesia Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: age 60+, proximal hip fracture Main exclusion criteria: Patients who insisted on a specific type of anesthesia or who were not eligible for the anesthesia types used in the study
Alonso Chico 2003^57^ | Study design: Randomized controlled trials Study period: NR to NR Type of hospital: University hospital Country: Spain Financial support: NR | Intervention #1: Classification: Spinal anesthesia Intervention: Bupivacaine 0.5%/ Fenantyl Dosage: 5mg/15ug Intervals: Single administration Intervention #2: Classification: Spinal anesthesia Intervention: Bupivacaine 0.5% Dosage: 7.5mg Intervals: Single administration | Main inclusion criteria: Patients aged >75 years; ASA II-III; pro-trochanteric fracture Main exclusion criteria: Patients with contraindications to subarachnoid anesthesia or uncontrolled cardiac; respiratory; or neurologic disease
Ben-David 2000^58^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Israel Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine/Fentanyl Dosage: 4mg/20ug Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine Dosage: 10mg Intervals: Single administration | Main inclusion criteria: Pts >70yr presenting for open surgical repair of hip fracture Main exclusion criteria: NR
Bredahl 1991^59^ | Study design: Randomized Controlled Trial Study period: NR Type of hospital: University Hospital Country: Denmark Financial support: NR | Intervention #1: Classification: Spinal Anaesthesia Intervention: Bupivacainc 0.5% Dosage: 2.5-3 ml Intervals: NR Intervention #2: Classification: General Anaesthesia Intervention: Thiopentone Dosage: 2-4 mg/kg Intervals: once | Main inclusion criteria: female patients, more than 60 years old, with hip fracture, otherwise healthy (ASA class I or 11) Main exclusion criteria: NR
Casati 2003^60^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Italy Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 7.5mg Intervals: Single administration Intervention #2: Classification: General anesthesia Intervention: None Dosage: NA Intervals: NA | Main inclusion criteria: Pts ASA II-III undergoing hemiarthroplasty for repair of fractured femur Main exclusion criteria: Contraindications to spinal anesthesia or laryngeal mask placement, severe cardiovascular or pulmonary disease, or psychiatric pathology
Danelli 2008^61^ | Study design: RCT Study period: May-06 to Jul-06 Type of hospital: University hospital Country: Italy Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Levobupivacaine 0.5% Dosage: 15mg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Levobupivacaine 0.75% Dosage: 15mg Intervals: Single administration | Main inclusion criteria: ASA I-III; >18 yrs Main exclusion criteria: Unable to understand, cooperate, or communicate with investigators, any contraindication to spinal anesthesia, or had a known history of hypersensitivity to local anesthetics
Favarel-Garrigues 1996^62^ | Study design: RCT Study period: Sep-92 to Apr-94 Type of hospital: University hospital Country: France Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: Bolus: Bupivacaine 5mg (1ml); Maintenance: Bupivacaine 2.5mg (0.5ml) Intervals: Single administration; Continuous administration on demand Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: Based on age and ht (15mg between 70 and 79 yr and/or >170 cm height, 12.5mg between 80 and 90 yr and/or between 150 and 170 cm, 10mg >90 yr and/or <150 cm) Intervals: Single administration | Main inclusion criteria: Pts ≥ 70 yrs, ASA I-III, undergoing hip fracture surgery Main exclusion criteria: Pts did not accept regional anesthesia, or had contraindications for spinal anesthesia, or severely altered mental status
Hooda 2006^63^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: India Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Fentanyl Dosage: 4mg (0.8ml)/20mg (0.4ml) Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Fentanyl Dosage: 5mg (1.0ml)/20mg (0.4ml) Intervals: Single administration Intervention #3: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Fentanyl Dosage: 6mg (1.2ml)/20mg (0.4ml) Intervals: Single administration | Main inclusion criteria: Pts of either sex, ≥60 yrs, scheduled to undergo open surgical repair of hip fractures Main exclusion criteria: <60 yrs, ASA III or more, contraindications to spinal anesthesia (e.g., peripheral neuropathy, coagulopathy, spinal deformity, infection at the injection site), or known hypersensitivity to amide local anesthetics or fentanyl
Juelsgaard 1998^64^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Denmark Financial support: NR | Intervention #1: Classification: Spinal anesthesia (incremental) Intervention: Bupivacaine 0.5% Dosage: 1.6ml Intervals: Incremental dosage Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 2.5ml Intervals: Single administration Intervention #3: Classification: General anesthesia Intervention: Fentanyl Dosage: Bolus: 1-2ug per kg/Maintainence: 25-50ug Intervals: Single administration/Continuous administration (on demand) | Main inclusion criteria: Pts with known CAD scheduled for osteosynthesis of a femoral neck fracture Main exclusion criteria: Uncooperative pts, recent myocardial infarction, unstable angina pectoris, significant aortic stenosis, or contraindication to spinal anesthesia, or had factors that adversely affect the quality of the Holter analysis or had failure of monitoring for 36hrs
Klimscha 1995^65^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% plus clonidine Dosage: 1ml bupivacaine/1ml Clonidine Intervals: Continuous administration (3 repetitive doses) Intervention #2: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: 10ml bupivacaine Intervals: Continuous administration (3 repetitive doses) Intervention #3: Classification: Epidural anesthesia (continuous) Intervention: Bupivacaine 0.5%/clonidine Dosage: 10ml bupivacaine/1ml Clonidine Intervals: Continuous administration (3 repetitive doses) Intervention #4: Classification: Epidural anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: 10ml bupivacaine Intervals: Continuous administration (3 repetitive doses) | Main inclusion criteria: Elderly pts undergoing hip surgery after traumatic fractures Main exclusion criteria: Pts with usual contraindications to spinal or epidural anesthesia, had senile dementia and those with severe deformities of the spinal column
Koval 1999^78^ | Study design: Prospective Cohort Study Study period: July 1987 to June 1995 Type of hospital: University Hospital Country: USA Financial support: NR | Intervention #1: Classification: Spinal Anaesthesia Intervention: NR Dosage: NR Intervals: NR Intervention #2: Classification: General Anaesthesia Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: age>=65, previously ambulatory and home dwelling, and had femoral neck or intertrochanteric hip fracture of non-pathologic origin Main exclusion criteria: moderate to severe dementia
Krobot 2006^77^ | Study design: nRCT Study period: NR Type of hospital: General hospital Country: Croatia Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Levobupivacaine/Fentanyl Dosage: 7.5mg/0.01mg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Levobupivacaine Dosage: 10mg Intervals: Single administration | Main inclusion criteria: Elderly pts undergoing hip fracture repair Main exclusion criteria: NR
Kwan 1997^66^ | Study design: RCT Study period: Jul-95 to Dec-95 Type of hospital: General hospital Country: Hong Kong Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Morphine Dosage: 2.2ml/0.2mg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 2.2ml Intervals: Single administration | Main inclusion criteria: Pts, ASA I-IV, scheduled for emergency surgery for a fractured hip Main exclusion criteria: Pts who had contraindications to regional anesthesia, or an allergy to the study drugs (bupivacaine, morphine)
Labaille 1992^79^ | Study design: Prospective cohort study Study period: NR Type of hospital: General hospital Country: France Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.125%/Bupivacaine 0.125% Dosage: Bolus: 3ml/Maintaninence: 1ml Intervals: Single administration/Continuous administration (on demand) Intervention #2: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5%/Bupivacaine 0.5% Dosage: Bolus: 3ml/Maintaninence: 1ml Intervals: Single administration/Continuous administration (on demand) | Main inclusion criteria: Pts, ASA I-II, aged 70-97 yrs old without any known CVD who were scheduled for repair of femoraI neck or trochanteric fracture under spinal anesthesia Main exclusion criteria: NR
Malek 2004^67^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Czech Republic Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Fentanyl Dosage: 3ml/50ug Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Sufentanil Dosage: 3ml/5ug Intervals: Single administration Intervention #3: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 3ml Intervals: Single administration | Main inclusion criteria: Pts scheduled to be operated on for hip fracture Main exclusion criteria: Pts with suspected allergy to opiates, common contraindications of spinal anesthesia and inability to perform dural puncture in L3—L4 or L2—L3 vertebral interspaces
Martyr 2001^68^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Australia Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivaciane/Fentanyl Dosage: 7.5mg/20ug Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine Dosage: 12.5mg Intervals: Single administration | Main inclusion criteria: Pts with a fractured neck of femur requiring internal fixation with a Richards pin and plate Main exclusion criteria: NR
Martyr 2005^69^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Australia Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine/Fentanyl Dosage: 9.0mg/20ug Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine Dosage: 11.0mg Intervals: Single administration | Main inclusion criteria: >70 yrs with fractured neck of femur requiring internal fixation with a DHS or hemiarthroplasty and < 70 kg estimated body weight Main exclusion criteria: NR
Maurette 1993^70^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: France Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bolus: lidocaine 1.6%/meperidine 1%; Maintainence: lidocaine 1.6% Dosage: NA/4ml (200mg); NA Intervals: Continuous administration Intervention #2: Classification: Spinal anesthesia (continuous) Intervention: Bolus: lidocaine 1.6%; Maintainence: lidocaine 1.6% Dosage: NA Intervals: Continuous administration | Main inclusion criteria: Pts undergoing elective surgery for fracture of the neck of the femur and able to describe their pain with accuracy Main exclusion criteria: Bedridden pts or suffering from severe dehydration or senile dementia
Miller 1990^81^ | Study design: Retrospective cohort study Study period: 30317 to 32478 Type of hospital: General hospital Country: Germany Financial support: | Intervention #1: Classification: Spinal anesthesia Intervention: Mepivacaine 4 % Dosage: 2ml (80 mg) Intervals: NR Intervention #2: Classification: General anesthesia Intervention: Fentanyl Dosage: 3-5mg per kg Intervals: NR | Main inclusion criteria: Proximal hip fracture Main exclusion criteria: NR
Minville 2006^71^ | Study design: RCT Study period: Nov-03 to Nov-04 Type of hospital: University hospital Country: France Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine Dosage: 2.5mg Intervals: Continuous administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine Dosage: 7.5mg Intervals: Single administration | Main inclusion criteria: 75 yrs who underwent surgery for open surgical repair of hip fracture Main exclusion criteria: Contraindication to spinal anesthesia or continuous spinal anesthesia including patient refusal, intracranial hypertension, major hemostasis anomalies or local infection, dementia, allergic reaction to local anesthetics, anemia (hemoglobin <10 g/dL), as well as being treated with aspirin
Minville 2008^82^ | Study design: Retrospective cohort study Study period: Jan-01 to Dec-04 Type of hospital: University hospital Country: France Financial support: No external funding | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: 2.5mg Intervals: Continuous administration Intervention #2: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: 5mg Intervals: Continuous administration Intervention #3: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: NR Intervals: Single administration Intervention #4: Classification: General anesthesia Intervention: Sulfentanil Dosage: NR Intervals: NR | Main inclusion criteria: Pts over 75 yrs old who underwent surgical repair of femoral neck fractures Main exclusion criteria: NR
Navas 2008^72^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Spain Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.15-0.25% Dosage: NR Intervals: Continuous administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: NR Intervals: Single administration | Main inclusion criteria: Pts undergoing surgery for hip fracture Main exclusion criteria: NR
Olofsson 2004^73^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Sweden Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine/sufentanil Dosage: 7.5mg/5mg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine Dosage: 15mg Intervals: Single administration | Main inclusion criteria: Pts, ASA II, scheduled for surgery after hip fracture, who could understand oral information Main exclusion criteria: Uncooperative pts, unstable angina, significant aortic stenosis, recent myocardial infarction, coagulation disorders, contraindications to spinal anesthesia
Qamarul Hoda 2007^146^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Pakistan Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine/Fentanyl Dosage: 6mg/20ug Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine/Fentanyl Dosage: 8mg/20ug Intervals: Single administration Intervention #3: Classification: Spinal anesthesia (single) Intervention: Bupivacaine Dosage: 10mg Intervals: Single administration | Main inclusion criteria: Elderly pts, ASA I-III, 65 yrs and scheduled for surgical repair of hip fracture. Main exclusion criteria: Pts with any contraindication for spinal anesthesia
Rais 2008^75^ | Study design: RCT Study period: NR Type of hospital: Orthopedic hospital Country: Tunisia Financial support: NR | Intervention #1: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: 2.5mg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (continuous) Intervention: Bupivacaine 0.5% Dosage: 5mg Intervals: Single administration | Main inclusion criteria: Pts with no contraindication to continuous spinal anesthesia Main exclusion criteria: NR
Said-Ahmed 2006^76^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Egypt Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Fentanyl Dosage: 5mg/20mcg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5%/Sufentanil Dosage: 5mg/5mcg Intervals: Single administration Intervention #3: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 10mg Intervals: Single administration | Main inclusion criteria: Pts, ASA I-II, aged 70 yrs or older, undergoing either insertion of Austin-Moore prosthesis or DHS for fixation of femur neck fractures Main exclusion criteria: NR
Sen 2007^83^ | Study design: Retrospective cohort study Study period: Aug-00 to Oct-01 Type of hospital: University hospital Country: Turkey Financial support: NR | Intervention #1: Classification: Spinal anesthesia (single - lateral) Intervention: Bupivacaine 0.5% Dosage: 10mg Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single - supine) Intervention: Bupivacaine 0.5% Dosage: 10mg Intervals: Single administration | Main inclusion criteria: Elderly pts, ASA I-II, who had undergone spinal anesthesia for hip surgery and who had ejection fraction < 50% Main exclusion criteria: NR
Shih 2010^84^ | Study design: Retrospective Cohort Study Study period: 2002 to 2006 Type of hospital: University Hospital Country: Taiwan Financial support: NR | Intervention #1: Classification Spinal Anaesthesia Intervention: Bupivacaine Dosage: 8-15 mg Intervals: once Intervention #2: Classification: General Anaesthesia Intervention: Thiopental Dosage: NR Intervals: NR | Main inclusion criteria: NR Main exclusion criteria: Patients with multiple fractures, with pathologic fractures, with other acute diseases when admitted, or with patient-controlled analgesia, or received both spinal and general anesthesia
Sutcliffe 1994^85^ | Study design: Prospective Cohort Study Study period: NR Type of hospital: University Hospital Country: England Financial support: NR | Intervention #1: Classification: Spinal Anaesthesia Intervention: Bupivacaine Dosage: NR Intervals: NR Intervention #2: Classification: General Anaesthesia Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: NR Main exclusion criteria: NR

ASA = American Society of Anesthesiology; IM = intramuscular; IV = intravenous; NR = NR; nRCT = nonrandomized controlled trial; RCT = randomized controlled trial

Table E-3 Complementary and alternative medicine (CAM)

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Barker 2006^43^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: NR | Intervention #1: Classification: Auricular acupressure Intervention: 1-mm plastic acupressure beads Dosage: 3 true auricular acupressure points Intervals: Single administration Intervention #2: Classification: Sham Control Intervention: 1-mm acupressure plastic beads Dosage: 3 sham auricular acupressure points Intervals: Single administration | Main inclusion criteria: Pts aged 80–95 yrs, ASA II–III, who sustained an isolated hip fracture without any additional trauma Main exclusion criteria: Not fluent in German, with ear deformity, severe neurologic or psychiatric disorders, long-term use of sedatives or analgesics
Martin 1991^54^ | Study design: RCT Study period: 1988 to 1989 Type of hospital: General hospital Country: US Financial support: NR | Intervention #1: Classification: Relaxation Intervention: Jacobson relaxation technique/ Meperidine/ Morphine Dosage: NA Intervals: Instruction given prior to surgery Intervention #2: Classification: Analgesia Intervention: Meperidine/Morphine Dosage: NR Intervals: NR | Main inclusion criteria: Pts, 60 yrs old and older with a fractured hip to be surgically repaired by internal fixation Main exclusion criteria: Pts with known psychiatric illness or mental retardation, pathologic fractures as a result of metastasis to bone, inability to cooperate or follow instructions, and multiple trauma

ASA = American Society of Anesthesiology; IM = intramuscular; IV = intravenous; NR = NR; RCT = randomized controlled trial

Table E-4 Multimodal pain management

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Milisen 2001^86^ | Study design: Prospective cohort study Study period: Sep-96 to Mar-97 Type of hospital: University hospital Country: Belgium Financial support: NR | Intervention #1: Classification: Multimodal pain management Intervention: Bolus: Tramadol IV; Maintainence (48hrs): Tramdol IV + propacetamol IV; Maintainence (Day 3-5): oral tramadol + oral paracetamol Dosage: 3mg/ kg; 6mg/k/ 24hrs; 120mg per kg per 24hours/NA Intervals: Continuous administration Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Dutch-speaking and verbally testable pts admitted with a traumatic frature of proximal femur within 24 hrs of surgery Main exclusion criteria: Pts with multiple trauma, concussion, pathological fractures, surgery occurring > 72 hrs after admission, aphasia, blindness, deafness, and < 9 yrs formal education
Ogilvie-Harris 1993^87^ | Study design: Prospective cohort study Study period: NR Type of hospital: University hospital Country: Canada Financial support: NR | Intervention #1: Classification: Mutlimodal pain management Intervention: Skin Traction/Morphine/Acetaminophen Dosage: NA/2.5-5mg/1000mg Intervals: Rewrap every 8hrs/every 4hrs/every 4hrs Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Geriatric pts with hip fractures Main exclusion criteria: NR

ASA = American Society of Anesthesiology; IM = intramuscular; IV = intravenous; NR = NR; RCT = randomized controlled trial

Table E-5 Nerve blocks

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Antonopoulou 2006^88^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Greece Financial support: NR | Intervention #1: Classification: Femoral nerve block Intervention: Bolus: Levobupivacaine 0.25%; Maintanence: Levobupivacaine 0.12% Dosage: 18ml Intervals: Single administration; Continuous administration Intervention #2: Classification: Analgesia Intervention: Paracetamol; Pethidine Dosage: 500mg; NR Intervals: Every 8hrs; on demand | Main inclusion criteria: Pts with hip fracture Main exclusion criteria: NR
Chudinov 1999^89^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Israel Financial support: NR | Intervention #1: Classification: Psoas Compartment Block (continuous) Intervention: Bupivacaine 0.25% Dosage: Bolus: 2mg per kg; Maintainence: 2mg per kg Intervals: Single administration/Maintainence: every 12hrs Intervention #2: Classification: IM analgesia Intervention: Meperidine IM Dosage: 1mg per kg Intervals: On demand (max every 5hrs) | Main inclusion criteria: Pts with unilateral fractures of the neck of the femur Main exclusion criteria: Severe cardiac, pulmonary, renal, or liver dysfunction, systemic infection, decubitus ulcers, dementia, aspirin or anticoagulant treatment, or known hypersensitivity to local anesthetic agents
Coad 1991^90^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: UK Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block Intervention: Bupivacaine 0.5% Dosage: 15ml Intervals: Single administration Intervention #2: Classification: Lateral cutaneous Nerve Block Intervention: Bupivacaine 0.5% Dosage: 15ml Intervals: Single administration Intervention #3: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Pts undergoing either pin-and-plate or compression-screw fixation of the femoral neck Main exclusion criteria: Pts who were receiving analgesic drugs, were suffering from dementia, or if regional anesthesia was thought to be indicated
Cuvillon 2007^91^ | Study design: Randomized controlled trials Study period: 36404 to 37408 Type of hospital: University hospital Country: France Financial support: Fondation de l'avenir (Paris) | Intervention #1: Classification: 3-in-1 nerve block (NS) Intervention: Ropivacaine Dosage: Catheter attached to pump allowing continuous ropivacaine 0.2% at 10 mL/hr × 48 hr Intervals: Continuous Intervention #2: Classification: Analgesia Intervention: Paracetamol Dosage: 1st dose 2g then 2g Intervals: every 6 hours Intervention #3: Classification: Analgesia Intervention: Morphine Dosage: 2 mg q5min in post-op until VAS <30 then 0.1 mg/kg q4 hr; if VAS >30 dosage increased by 50% Intervals: NA | Main inclusion criteria: Pts ≥70 yrs; operation for traumatic fracture sup. femur under spinal anesthetic Main exclusion criteria: Patient refusal to participate; > 72 hr delay between fall and surgery; Pts < 70 yrs; weight < 40 kg; ASA score > 4; contraindications to locoregional analgesia; neuropathy; severe renal or hepatic insufficiency; noncooperative patients; mini mental score less than 15/30
de Visme 2000^92^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: France Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Combined lumbar/sacral plexus block (NS) Intervention: Lidocaine 1.33% Dosage: 45mL Intervals: Single administration Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 3mL Intervals: Single administration | Main inclusion criteria: Pts > 65 yrs with proximal femoral fracture Main exclusion criteria: Pts with evidence of cognitive deficit (MMSE <5), contraindication to spinal anesthesia, or peripheral nerve block
Del Rosario 2008^117^ | Study design: Retrospective cohort study Study period: Oct-04 to Oct-05 Type of hospital: General hospital Country: Spain Financial support: NR | Intervention #1: Classification: Femoral nerve block (NS)/IV analgesia Intervention: Bolus: Bupivacaine 0.25%; Maintainence: bupivaine 0.1%; PCA: Paracetamol IV/metamizol IV Dosage: 30ml/5ml/1g/2g Intervals: Single administration; Maintainence: every hr; Patient controlled bolus: every 6hrs/every 8hrs Intervention #2: Classification: IV analgesia Intervention: Paracetamol IV; metamizol IV Dosage: 1g; 2g Intervals: Every 6hrs; every 8hrs | Main inclusion criteria: Pts > 50 yrs who underwent hip fracture surgery with intradural anesthesia Main exclusion criteria: Pts who received general or epidural analgesia, presented failure of femoral analgesia, or had localized infection or coagulopathy
Eyrolle 1998^93^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: France Financial support: NR | Intervention #1: Classification: Posterior lumbar plexus block Intervention: Lidocaine 2%/Bupivacaine 0.5% Dosage: NR Intervals: NR Intervention #2: Classification: Spinal anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: NR Intervals: Single administration | Main inclusion criteria: Pts undergoing femoral neck osteosynthesis Main exclusion criteria: NR
Fletcher 2003^94^ | Study design: RCT Study period: Feb to Aug Type of hospital: General hospital Country: UK Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block (NS) Intervention: Bupivacaine 0.5% Dosage: 20mL Intervals: Single administration Intervention #2: Classification: IV analgesia Intervention: Morphine IV Dosage: 5-10mg Intervals: On demand | Main inclusion criteria: Pts with all types of fractured neck of femur Main exclusion criteria: Confused, with a bleeding diathesis, taking warfarin, local or systemic infection, or previous hypersensitivity to local anesthetics
Foss 2005^95^ | Study design: RCT Study period: Jan-03 to Apr-04 Type of hospital: University hospital Country: Denmark Financial support: Financial support provided by governmental sources | Intervention #1: Classification: Epidural analgesia (continuous) Intervention: Bupivacaine 0.125%/morphine Dosage: 4ml of 50ug per ml per hr Intervals: Continuous infusion (four days) Intervention #2: Classification: Placebo Intervention: Saline Dosage: NA Intervals: Continuous inusion (four days) | Main inclusion criteria: ≥65 yrs living in own home, intact cognitive status, able to provide written informed consent, New Mobility Score of ≥3 (indicating independent indoor ambulation) Main exclusion criteria: Refused to participate, prefracture hospitalization, contraindications to epidural analgesia, regular prefracture opioid or glucocorticoid therapy, alcohol or substance abuse, morphine intolerance, and postoperative restrictions for ambulation
Foss 2007^96^ | Study design: Randomized controlled trials Study period: May-03 to Jan-06 Type of hospital: University hospital Country: Denmark Financial support: Imk Almene Fond | Intervention #1: Classification: Fascia iliaca compartment nerve block (CT) Intervention: 1.0% mepivacaine Dosage: 40 mL 1.0% mepivacaine with 1:200 000 epinephrine; 0.02 mL/kg placebo IM injection of 0.9% saline Intervals: Single dose Intervention #2: Classification: Analgesia Intervention: Morphine Dosage: 40 mL placebo FICB with 0.9% saline; 0.02 mL/kg 5.0 mg/mL morphine Intervals: Single dose | Main inclusion criteria: Clinical signs of hip fracture as assessed by the ED staff; intact cognitive status on admission; and the ability to provide written informed consent. Main exclusion criteria: Refusal to participate in the study; previous surgery in the affected hip; regular prefracture opioid or glucocorticoid therapy; alcohol or substance abuse; infection at the injection site; morphine intolerance; or any previous opioid administration for the acute pain and nonconfirmation of the hip fracture suspicion on x-ray
Gille 2006^97^ | Study design: Randomized controlled trials Study period: NR to NR Type of hospital: University hospital Country: Germany Financial support: No industry funding | Intervention #1: Classification: Femoral nerve block Intervention: Prilocaine 1%/ Ropivacaine 0.2% Dosage: 40ml/ 30ml Intervals: Single administration/ Continuous (every 6hrs) Intervention #2: Classification: Analgesia Intervention: Metamizol/ Tilidine; Ibuprofen Dosage: 1g / 100mg; 400mg Intervals: Single administration/ single administration; every 8hrs | Main inclusion criteria: Isolated hip fracture Main exclusion criteria: Open fracture or fracture associated with neurological injury; age<18 years; inability to swallow pills; contraindication for regional anesthesia or medications in trial; ongoing opiod analgesic therapy; multiple injuries; repeat intervention
Graham 2008^98^ | Study design: RCT Study period: Apr-00 to Oct-01 Type of hospital: General hospital Country: UK Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block (NS) Intervention: Bupivacaine 0.5% Dosage: 30ml Intervals: Single administration Intervention #2: Classification: IV analgesia Intervention: Morphine IV Dosage: 0.1mg per kg Intervals: Single administration | Main inclusion criteria: Pts > 16 yrs presenting with clinical or radiological evidence of fractured hip Main exclusion criteria: Pts with suspected allergy or contraindication to either morphine or bupivacaine, or if they had an abbreviated mental test score <9
Haddad 1995^99^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: UK Financial support: No external funding | Intervention #1: Classification: Femoral nerve block (CT) Intervention: Bupivacaine 0.25% Dosage: 0.3ml per kg Intervals: Single administration Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Pts with extracapsular fractures of the femoral neck Main exclusion criteria: Pts who were unable to score their pain due to dementia
Henderson 2008^100^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: US Financial support: NR | Intervention #1: Classification: Femoral nerve block/Opioids Intervention: Bupivacaine 0.5% Dosage: NR/NR Intervals: Continuous/On demand Intervention #2: Classification: Standard care Intervention: Opioids Dosage: NR Intervals: Intermittent | Main inclusion criteria: ≥55 yrs presenting to the ED with acute hip fractures Main exclusion criteria: NR
Hood 1991^101^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: UK Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block Intervention: Prilocaine 0.75% Dosage: 43ml Intervals: Single administration Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: > 60 yrs with intertrochanteric fractures of neck of femur requiring surgical correction with compression screw or pin and plate devices Main exclusion criteria: Contraindication to a regional technique, allergy to local anesthetic agents, or systemic disease that indicated an alternative method of anesthesia
Kocum 2007^118^ | Study design: Retrospective cohort study Study period: Sep-04 to Aug-05 Type of hospital: University hospital Country: Turkey Financial support: NR | Intervention #1: Classification: Lumbar plexus plus sciatic block (NS) Intervention: Ropivacaine 0.25% Dosage: 60ml Intervals: Single administration Intervention #2: Classification: Lumbar plexus plus sciatic block (NS) Intervention: Bupivacaine 0.25% Dosage: 60ml Intervals: Single administration | Main inclusion criteria: Pts, ASA III-IV, who underwent unilateral femur or hip surgery with lumbar plexus and sciatic nerve blockade Main exclusion criteria: Pts ASA I-II and those who received additional anesthesia modalities or who had other fractures
Mannion 2005^102^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Ireland Financial support: NR | Intervention #1: Classification: Psoas compartment block (NS) Intervention: Levobupivacaine 0.5%/Clonidine IV Dosage: 0.4mL per kg/1ug per kg Intervals: Single administration Intervention #2: Classification: Psoas compartment block (NS) Intervention: Levobupivacaine 0.5%/Clonidine (peripheral) Dosage: 0.4mL per kg/1ug per kg Intervals: Single administration Intervention #3: Classification: Psoas compartment block (NS) Intervention: Levobupivacaine 0.5% Dosage: 0.4mL per kg Intervals: Single administration | Main inclusion criteria: Pts scheduled for surgical repair of traumatic hip fractures Main exclusion criteria: Concurrent medication with adrenoceptor agonists, antagonists, or contraindications to regional anesthesia
Marhofer 1997^103^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block (US) Intervention: Bupivacaine 0.5% Dosage: 20ml Intervals: Single administration Intervention #2: Classification: 3-in-1 nerve block (NS) Intervention: Bupivacaine 0.5% Dosage: 20ml Intervals: Single administration | Main inclusion criteria: Pts undergoing hip surgery after trauma Main exclusion criteria: Pts who refused to participate or had contraindication to local anesthetics or puncture in the inguinal area, or unable to understand the study protocol
Marhofer 1998^104^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block (US) Intervention: Bupivacaine 0.5% Dosage: 20ml Intervals: Single administration Intervention #2: Classification: 3-in-1 nerve block (NS) Intervention: Bupivacaine 0.5% Dosage: 20ml Intervals: Single administration Intervention #3: Classification: 3-in-1 nerve block (NS) Intervention: Bupivacaine 0.5% Dosage: 30ml Intervals: Single administration | Main inclusion criteria: Pts, ASA II-III, scheduled for surgery of nondislocated hip fractures following trauma Main exclusion criteria: Refusal by the patient, allergies to local anesthetics, or general contraindications against puncture in the inguinal area, or unable to understand the study protocol because of language or other difficulty
Marhofer 2000^105^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block (NS) Intervention: Ropivacaine 0.5% Dosage: 20ml Intervals: Single administration Intervention #2: Classification: 3-in-1 nerve block (NS) Intervention: Bupivacaine 0.5% Dosage: 20ml Intervals: Single administration | Main inclusion criteria: ASA I–III, scheduled for hip surgery after trauma Main exclusion criteria: Refusal by the patient, inability to understand study protocol, allergies to local anesthetics, and contraindications against puncture in the inguinal area
Matot 2003^106^ | Study design: RCT Study period: Oct-98 to Sep-98 Type of hospital: University hospital Country: Israel Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Epidural analgesia (continuous) Intervention: Bolus: Bupivacaine 0.25%/Methadone; Maintainence: Bupivacaine 0.5%/Methadone Dosage: 7-10mL/4mg; 45mg/16mg Intervals: Continous (24hrs) Intervention #2: Classification: IM analgesia Intervention: Meperidine IM Dosage: 1mg per kg Intervals: Every 6hrs | Main inclusion criteria: ≥60 yrs with traumatic hip fracture, able to sign informed consent, known CAD or at high risk for CAD Main exclusion criteria: Contraindications to epidural analgesia, suspected allergy to study drugs, acute coronary insufficiency, ECG evidence of left bundle branch block, or ≥ 10 hrs from the time of injury
Monzon 2010^107^ | Study design: Randomized Controlled Trial Study period: June 2006 to Jan 2008 Type of hospital: University Hospital Country: Argentina Financial support: No conflicts of interest | Intervention #1: Classification: Fasciailiaca compartment block Intervention: 0.25% bupivacaine Dosage: 0.3 ml/kg Intervals: NR Intervention #2: Classification: General Anaesthesia Intervention: IV NSAID analgesics Dosage: NR Intervals: NR | Main inclusion criteria: adult patients more than 65 years old who presented to the ED because of a previously undiagnosed and untreated hip fracture Main exclusion criteria: anatomical abnormalities in the inguinal area different from fracture, known coagulation disorders, a history of allergy to any of the active ingredients used during the study and refusal to participate
Mouzopoulos 2009^108^ | Study design: RCT Study period: Jul-04 to Mar-08 Type of hospital: General hospital Country: Greece Financial support: NR | Intervention #1: Classification: Fascia iliaca compartment nerve block (CT) Intervention: Bupivacaine Dosage: 0.25mg dose of 0.3mL per kg Intervals: every 24h before and after surgery Intervention #2: Classification: Placebo Intervention: Saline Dosage: NA Intervals: Every 24h before and after surgery | Main inclusion criteria: ≥ 70 yrs, admitted for hip fracture Main exclusion criteria: Delirium at admission, metastatic hip cancer, hx bupivacaine allergy, use of cholinesterase inhibitors, severe coagulopathy, Parkinsonism, epilepsy, levodopa treatment, delay of surgery > 72 hrs after admission, inability to participate in interviews (e.g. dementia, respiratory isolation, intubation, aphasia, coma or terminal illness)
Murgue 2006^109^ | Study design: Randomized controlled trials Study period: 37622 to 37987 Type of hospital: General hospital Country: France Financial support: NR | Intervention #1: Classification: Femoral nerve block Intervention: Mepivacaine Dosage: 20 cc Intervals: NA Intervention #2: Classification: Analgesia Intervention: IV morphine Dosage: 2 mg Intervals: 1 mg q5 min until p<=4 Intervention #3: Classification: Analgesia Intervention: IV paracetamol + ketoprofen Dosage: 1 g P + 100 mg K Intervals: NA | Main inclusion criteria: Patients with suspected fractured neck of femur admitted to ED; cognitive functioning to assess pain >27 high SES >24 low SES Main exclusion criteria: Contraindications to equimolar mix of nitrous oxide/O2; contraindications to femoral block; allergy to morphine and/or paracetamol/ketoprofene; known renal insufficiency; already receiving morphine Rx
Pedersen 2008^119^ | Study design: Retrospective cohort study Study period: Jan-03 to Mar-04 Type of hospital: University hospital Country: Denmark Financial support: No external funding | Intervention #1: Classification: 3-in-1 nerve block Intervention: Bupivacaine Dosage: Bolus: 100mg; Maintainence: 50mg Intervals: Single administration; continuous (every 8hrs) Intervention #2: Classification: Analgesia Intervention: Preoperative: Morphine SC or tablets; Postoperative: Morphine SR tablets/acetaminophen or ibuprofen Dosage: 2.5-5mg/10-20mg; 1g/or 400mg Intervals: Every 12hrs; every 8hr/or every 12hrs | Main inclusion criteria: Pts undergoing surgery for a nonpathological, low-energy hip fracture Main exclusion criteria: Pts who did not receive a femoral nerve catheter or were not admitted to hip fracture unit
Scheinin 2000^110^ | Study design: RCT Study period: Jan-95 to Jan-97 Type of hospital: University hospital Country: Finland Financial support: Financial support provided by institutional, departmental and/or governmental sources | Intervention #1: Classification: Epidural analgesia (continuous) Intervention: Bupivacaine/Fentanyl Dosage: 1mg per ml + 10ug per ml Intervals: Continuous administration Intervention #2: Classification: IM analgesia Intervention: Oxycodone IM Dosage: 0.1-0.15mg per kg Intervals: On demand (max every 6hrs) | Main inclusion criteria: Elderly pts admitted for surgical repair of a traumatic hip fracture Main exclusion criteria: Known coagulation abnormalities, progressive neurologic diseases, sepsis and skin infections in lumbar region, restless or uncooperative (e.g., dementia), or significant conduction abnormalities or no sinus rhythm
Segado Jiménez 2009^111^ | Study design: RCT Study period: May 2008 to Dec 2008 Type of hospital: University hospital Country: Spain Financial support: NR | Intervention #1: Classification: Obturator/ Femoral cutaneous nerve block Intervention: NR Dosage: NR Intervals: NR Intervention #2: Classification: Obturator nerve block Intervention: NR Dosage: NR Intervals: NR Intervention #3: Classification: IV analgesia Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Patients undergoing hip surgery with subarachnoid blockage Main exclusion criteria: General anesthesia, IV analgesic drugs during surgery, untreated chronic pain, arrythmias/MI, or neurological disorders
Segado Jimenez 2010^112^ | Study design: Randomized Controlled Trial Study period: 2009 to 2010 Type of hospital: University Hospital Country: Spain Financial support: No funding | Intervention #1: Classification: Fascia iliaca compartment block Intervention: Bupivacaine 0.5% Dosage: 30 ml Intervals: NR Intervention #2: Classification: Obturator/femoralcutaneous nerves block Intervention: Bupivacaine 0.5% Dosage: 15ml / 5 ml Intervals: NR Intervention #3: Classification: General Anaesthesia Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: patients with hip surgery, total or partial arthroplasty, and osteosynthesis of femor Main exclusion criteria: patients with previous traetment for chronic pain, ischemic cardiopathic, or arrhythmia, psychiatric and neurodegenerative diseases, poor collaboration and comprehension, allergy to local anaethetics, and contraindication to local/regional anaethetics
Spansberg 1996^113^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Denmark Financial support: NR | Intervention #1: Classification: Lumbar plexus block (NS) Intervention: Bolus: Bupivacaine 0.5%; Maintenence: Bupivacaine 0.25% Dosage: 0.4mL per kg; 0.14mL per kg per hr Intervals: Single administration; Continuous administration Intervention #2: Classification: Placebo Intervention: Bolus: Saline; Maintainence: Saline Dosage: 0.4mL per Kg; 0.14mL per kg per hr Intervals: Continuous administration | Main inclusion criteria: Pts with femoral neck fractures Main exclusion criteria: NR
Tuncer 2003^114^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Turkey Financial support: NR | Intervention #1: Classification: 3-in-1 nerve block (NS) Intervention: Bolus: Lidocaine 2%/Maintainence: Bupivacaine 0.125%; PCA bolus: Bupivaciane 0.125% Dosage: 30ml; 4ml per hr; 3ml Intervals: Single administration; Continuous administration; Patient cotrolled bolus on demand Intervention #2: Classification: IV analgesia Intervention: Morphine IV Dosage: 1mg Intervals: On demand | Main inclusion criteria: Pts, ASA I–II, scheduled for trochanteric fracture repair Main exclusion criteria: Pts with coagulation abnormalities, <18 or >80 yrs, wt <50 or >100 kg, suspected allergy to bupivacaine or opioids, previous analgesic treatment with opioids, inability to understand pain scales or use a patient controlled analgesia device
Turker 2003^115^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Turkey Financial support: NR | Intervention #1: Classification: Psoas compartment block (NS) Intervention: Bupivacaine 0.5% Dosage: 30ml Intervals: Single administration Intervention #2: Classification: Epidural anesthesia (single) Intervention: Bupivacaine 0.5% Dosage: 15ml Intervals: Single administration | Main inclusion criteria: Pts, ASA I–III, scheduled for unilateral hip surgery Main exclusion criteria: Contraindications to regional anesthesia, suspected allergy to any local anesthetic, dementia preventing proper comprehension, and refusal of the procedure
Yun 2009^116^ | Study design: Randomized controlled trials Study period: 39264 to 39417 Type of hospital: University hospital Country: Korea Financial support: NR | Intervention #1: Classification: Fascia iliaca compartment nerve block (CT) Intervention: Ropivacaine Dosage: 30 mL 3.75 mg/mL 2-3 min Intervals: Single dose Intervention #2: Classification: Analgesia Intervention: Alfentanil Dosage: 10 ug/kg bolus; 0.25 ug/kg/min 2 min Intervals: Single dose | Main inclusion criteria: Patients with an isolated femoral neck fracture scheduled to undergo either compression hip screw or hip replacement surgery. Main exclusion criteria: A suspected allergy to amide local anaesthetics; haemorrhagic diathesis; periperal neuropathy or mental disorders.

ASA = American Society of Anesthesiology; CT = clinical touch; IM = intramuscular; IV = intravenous; NR = NR; NS = nerve stimulation; RCT = randomized controlled trial; US = ultrasound

Table E-6 Neurostimulation

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Gorodetskyi 2007^120^ | Study design: RCT Study period: Feb-05 to Nov-05 Type of hospital: University hospital Country: Russia Financial support: Financial support provided by a commercial party | Intervention #1: Classification: Neurostimualtion Intervention: InterX 5000 device Dosage: high peak amplitude averaging 17 volts on skin with low current of 6 mA, and damped biphasic electrical impulses Intervals: Every 24hrs Intervention #2: Classification: Sham Control Intervention: NA Intervals: Every 24hrs | Main inclusion criteria: Between 60 and 75 yrs, undergone stabilization of A2 femoral trochanteric fracture Main exclusion criteria: Lmitations that interfere with electrical stimulation (e.g., insulin pumps, pacemakers, neurostimulation implants), hx epilepsy or seizure, bilateral fractures, fractures of pathological origin, excluding osteoporosis
Lang 2007^121^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Austria Financial support: NR | Intervention #1: Classification: Neurostimulation Intervention: Transcutaneous electrical nerve stimulation Dosage: 70 mA, frequency range: 0.5 to 120 Hz, pulse width: 60 to 300 us, Intervals: Single administration Intervention #2: Classification: Sham Control Intervention: NA Intervals: Single administration | Main inclusion criteria: >19 yrs, acute pain (>60 mm VAS) in region of hip Main exclusion criteria: Analgesics in previous 48 hr, neurologic impairment of legs, cognitive impairment or inability to communicate, potentially dangerous internal diseases (ASA score >3), or hip pain from causes other than fracture

ASA = American Society of Anesthesiology; IM = intramuscular; IV = intravenous; NR = not reported; RCT = randomized controlled trial

Table E-7 Rehabilitation

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Di Lorenzo 2007^122^ | Study design: RCT Study period: Jan-02 to Oct-06 Type of hospital: General hospital Country: Italy Financial support: NR | Intervention #1: Classification: Rehabilitation Intervention: Stretching/strengthening of spinal and psoas muscles Dosage: 1 hr of training Intervals: Every 12 hrs for 4 wk Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Pts with extracapuslar unstable hip fracture who underwent surgery and have back pain on ipsilateral side of fracture despite standard rehabilitation Main exclusion criteria: Previous chronic back pain, back surgery, spinal stenosis, spondylolisthesis or anxiety and depression

NR = Not reported; RCT = randomized controlled trial

Table E-8 Traction

Study | Study characteristics | Interventions | Inclusion/Exclusion criteria
Anderson 1993^128^ | Study design: nRCT Study period: Nov-91 to Jul-93 Type of hospital: General hospital Country: UK Financial support: No external funding | Intervention #1: Classification: Skin traction Intervention: Hamilton-Russell skin traction Dosage: 5lb (2.3kg) Intervention #2: Classification: Standard care Intervention: NR Dosage: NR | Main inclusion criteria: Pts with fractures of the proximal femur Main exclusion criteria: Refused informed consent or consent could not be obtained (e.g., dementia), contraindications for use of skin traction (e.g., poor skin, ulceration of lower limb, peripheral arterial disease, severe edema and lower limb deformities)
Finsen 1992^123^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: Norway Financial support: NR | Intervention #1: Classification: Skin traction Intervention: Elastic bandages Dosage: 3kg Intervention #2: Classification: Skeletal traction Intervention: Steinman pin Dosage: 10% of the patient's body weight Intervention #3: Classification: Pillow Intervention: Standard pillow | Main inclusion criteria: > 50 yrs admitted with recent cervical, trochanteric or subtrochanteric hip fractures Main exclusion criteria: NR
Ghnaimat 2005^129^ | Study design: nRCT Study period: Feb-02 to Oct-04 Type of hospital: General hospital Country: Jordan Financial support: NR | Intervention #1: Classification: Skin traction Intervention: Skin traction Dosage: 6lb Intervals: NA Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Pts admitted with fractures of the proximal femur Main exclusion criteria: Allergy to adhesive bandages, ulceration in lower limbs, peripheral arterial disease, severe ederna or lower limb deformities, or refused to be part of the study
Jerre 2000^124^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Sweden Financial support: NR | Intervention #1: Classification: Skin traction Intervention: Foam rubber boot with straps around the lower leg Dosage: 3Kg Intervals: NA Intervention #2: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR Intervention #3: Classification: Skin traction Intervention: Foam rubber boot with straps around the lower leg Dosage: 3Kg Intervals: NA Intervention #4: Classification: Standard care Intervention: NR Dosage: NR Intervals: NR | Main inclusion criteria: Pts with cervical or trochanteric hip fractures Main exclusion criteria: Pts unwilling or unable to provide consent for enrollment
Needoff 1993^125^ | Study design: RCT Study period: NR Type of hospital: General hospital Country: UK Financial support: NR | Intervention #1: Classification: Skin traction Intervention: Ventilated foam strap secured by means of a crepe bandage Dosage: 2.5kg Intervals: NA Intervention #2: Classification: Pillow Intervention: Standard pillow Dosage: NA Intervals: NA | Main inclusion criteria: > 60 yrs with cervical or pertrochanteric femoral fractures undergoing surgical hip fracture repair Main exclusion criteria: Cognitively impaired pts on the Mini-Mental State Examination
Resch 1998^126^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Sweden Financial support: Financial support provided by governmental sources | Intervention #1: Classification: Skin traction Intervention: Foam boot Dosage: 3kg Intervals: NA Intervention #2: Classification: Skeletal traction Intervention: K-wire Dosage: 3-5kg (5-10% body weight) Intervals: NA | Main inclusion criteria: Displaced hip fractures Main exclusion criteria: Pts who could not give consent, declined participation or had local skin problems (e.g., leg ulcers)
Resch 2005^26^ | Study design: RCT Study period: NR Type of hospital: University hospital Country: Sweden Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Skin traction Intervention: Foam rubber boot Dosage: 3kg Intervals: NA Intervention #2: Classification: Pillow Intervention: Lasse Pillow Dosage: NA Intervals: NA Intervention #3: Classification: Pillow Intervention: Standard pillow Dosage: NA Intervals: NA | Main inclusion criteria: Pts who had a dislocated cervical or trochanteric hip fracture, ability to give informed consent, and no local problems which would prohibit the use of skin traction, such as ulcers, eczema, or peripheral vascular disease Main exclusion criteria: NR
Rosen 2001^127^ | Study design: RCT Study period: Jun-95 to Feb-97 Type of hospital: University hospital Country: US Financial support: No external funding | Intervention #1: Classification: Skin traction Intervention: Foam traction boot Dosage: 5lb Intervals: NA Intervention #2: Classification: Pillow Intervention: Standard pillow Dosage: NA Intervals: NA | Main inclusion criteria: Pts with an isolated femoral neck or intertrochanteric hip fracture Main exclusion criteria: < 50 yrs, underlying dementia, other concomitant injury, delayed hospital presentation (e.g., >24 hrs after the initial injury)
Saygi 2010^130^ | Study design: Retrospective cohort study Study period: NR Type of hospital: General hospital Country: Turkey Financial support: No external funding | Intervention #1: Classification: Skin traction Intervention: Traction bandages Dosage: 2kg Intervals: NA Intervention #2: Classification: Sham traction Intervention: Traction bandages Dosage: 0kg Intervals: NA Intervention #3: Classification: Pillow Intervention: Standard pillow Dosage: NA Intervals: NA | Main inclusion criteria: Pts with hip fracture Main exclusion criteria: Refusal to participate in the study or a cognitive inadequacy detected in their simple mental scores
Vermeiren 1995^132^ | Study design: Prospective cohort study Study period: Jul-87 to Jun-89 Type of hospital: General hospital Country: Belgium Financial support: NR | Intervention #1: Classification: Skeletal traction Intervention: Skeletal traction with pillows for foot elevation Dosage: 1 kg traction weight/10 kg body weight Intervals: NA Intervention #2: Classification: Skeletal traction Intervention: Skeletal traction with metal splint Dosage: 1 kg traction weight/10 kg body weight Intervals: NA | Main inclusion criteria: Pts admitted with an intertrochanteric or subtrochanteric hip fracture Main exclusion criteria: NR
Yip 2002^131^ | Study design: nRCT Study period: Aug-95 to Dec-97 Type of hospital: University hospital Country: Hong Kong Financial support: Financial support provided by institutional and/or departmental sources | Intervention #1: Classification: Skin traction Intervention: Foam boot Dosage: 2kg Intervals: NA Intervention #2: Classification: Pillow Intervention: Standard pillow Dosage: NA Intervals: NA | Main inclusion criteria: Pts with proximal femur fracture and consenting to enrollment Main exclusion criteria: Pts that were senile or had been taking regular analgesia prior to admission

NA = not applicable; NR = n; nRCT = nonrandomized controlled trial; RCT = randomized controlled trial