# Excluded Studies

## Publication Type/Study Design

1 Ahmed T, Ullah H. Paramedian technique of spinal anaesthesia in elderly patients for hip fracture surgery. J Coll Physicians Surg Pak. 2007;17(3):184. [pmid: 17374313].
2 Ahsan-ul-Haq M, Amin S, Javaid S. Paramedian technique of spinal anesthesia in elderly patients for hip fracture surgery. J Coll Physicians Surg Pak. 2005;15(3):160-1. [pmid: 15808095].
3 Al-Ani AN, Flodin L, Soderqvist A, et al. Does rehabilitation matter in patients with femoral neck fracture and cognitive impairment? A prospective study of 246 patients. Archives of Physical Medicine & Rehabilitation. 2010;91(1):51-7. [pmid: 20103396].
4 Ambulkar R, Shankar R. Analgesia after total hip replacement. Anaesthesia. 2006;61(5):507. [pmid: 16674635].
5 Bard H, Vuillemin-Bodaghi V. Sorting out trochanteric pain. J Traumatol Sport. 2006;23(3):157-63. French.
6 Barre J, Lefort P, Payen M. Locoregional anesthesia for injuries of the lower limbs. Cah Anesthesiol. 1996;44(3):197-201. (Fre). [pmid: 9005007].
7 Beaudoin FL, Nagdev A, Merchant RC, et al. Ultrasound-guided femoral nerve blocks in elderly patients with hip fractures. AM J EMERG MED. 2010;28(1):76-81. [pmid: 20006206].
8 Biboulet P, Vacher E, Deschodt J, et al. Continuous spinal anesthesia: does low-dose plain or hyperbaric bupivacaine allow the performance of hip surgery in the elderly?. Reg Anesth. 1993;18(3):170-5. [pmid: 8323890].
9 Boenigk K, Vloka JD, Hadžic A. Lower extremity nerve blocks: an update. Progr Anesthesiol. 2001;15(13):231-44.
10 Bone and Joint in brief. Lippincott's Bone & Joint Newsletter. 2009;15(11):132.
11 Bozdogan N, Caliskan E, Turkoz R. Combination of regional anesthetic blocks for femoropopliteal bypass surgery. J Cardiothorac Vasc Anesth. 2009;23(3):442.
12 Brombacher J, Hodzovic I, Ridgway S, et al. An observational study of cardiac output changes during regional anaesthesia in patients with fractured neck of femur. Internet Journal of Anesthesiology. 2009;21(1):8.
13 Brooks JM, Titler MG, Ardery G, et al. Effect of evidence-based acute pain management practices on inpatient costs. Health Serv Res. 2009;44(1):245-63. [pmid: 19146567].
14 Bruyere O, Brandi ML, Burlet N, et al. Post-fracture management of patients with hip fracture: A prospective vision [Italian]. Clinical Cases in Mineral and Bone Metabolism. 2009;6(3):270-279. Date of Publication: September-December 2009 2009;(3):270-9.
15 Bryson GL. Waiting for hip fracture repair: do outcomes and patients suffer?. Can J Anaesth. 2008;55(3):135-9. [pmid: 18310622].
16 Butler M, Forte M, Kane RL, et al. Treatment of common hip fractures (Structured abstract). Agency for Healthcare Research and Quality. 2009;1.
17 Byrd J, Chern KY. Hip pain: non-operative treatment of ACL injury. Med Sci Sports Exerc. 5 Suppl. 1995;27:S198.
18 Cai XZ, Chen XZ, Yan SG. Cemented hemiarthroplasty confers less pain and better mobility than uncemented hemiarthroplasty. Clin Orthop Relat Res. 2009;467(2):582-4. [pmid: 19037707].
19 Cameron ID, Handoll HH, Finnegan TP, et al. WITHDRAWN: Co-ordinated multidisciplinary approaches for inpatient rehabilitation of older patients with proximal femoral fractures. [Review] [34 refs][Update of Cochrane Database Syst Rev. 2001;(3):CD000106; PMID: 11686951]. COCHRANE DATABASE SYST REV. 2009;(4):CD000106. [pmid: 19821265].
20 Candal-Couto JJ, McVie JL, Haslam N, et al. Pre-operative analgesia for patients with femoral neck fractures using a modified fascia iliaca block technique. Injury. 2005;36(4):505-10. [pmid: 15755432].
21 Capdevila X, Pirat P, Bringuier S, et al. Continuous peripheral nerve blocks in hospital wards after orthopedic surgery: a multicenter prospective analysis of the quality of postoperative analgesia and complications in 1,416 patients. Anesthesiology. 2005;103(5):1035-45. [pmid: 16249678].
22 Chakladar A, White SM. Cost estimates of spinal versus general anaesthesia for fractured neck of femur surgery. Anaesthesia. 2010;65(8):810-4. [pmid: 20528835].
23 Chevaleraud E, Bouyer L. Unilateral spinal anaesthesia. Prat Anest Reanim. 2008;12(3):182-6.
24 Christmas C. Medical care of the hip fracture patient. CLIN GERIATR. 2006;14(4):40-5.
25 Coe AJ, Revanas B. Is crystalloid preloading useful in spinal anaesthesia in the elderly?. Anaesthesia. 1990;45(3):241-3. [pmid: 2334037].
26 Cook JL, Cook J. The lateral femoral cutaneous nerve block. Dermatol Surg. 2000;26(1):81-3. [pmid: 10632693].
27 Crosby G, Culley DJ, Marcantonio ER. Delirium: a cognitive cost of the comfort of procedural sedation in elderly patients?. Mayo Clin Proc. 2010;85(1):12-4. [pmid: 20042555].
28 Crotty M, Unroe K, Cameron ID, et al. Rehabilitation interventions for improving physical and psychosocial functioning after hip fracture in older people. COCHRANE DATABASE SYST REV. 2009;(2).
29 Currie CT. Rehabilitation in the elderly with fractured neck of femur. Semin Orthod. 1990;5(2):61-7.
30 Cuvillon P, Ripart J, Lalourcey L, et al. The continuous femoral nerve block catheter for postoperative analgesia: bacterial colonization, infectious rate and adverse effects. Anesth Analg. 2001;93(4):1045-9. [pmid: 11574381].
31 Daban JL, De Saint Maurice GP, Batjom E, et al. Postoperative myocardial damages are a key issue in patients' outcome after hip fracture. AGE AGEING. 2009;38(4):488-9. [pmid: 19411672].
32 Davies AJ. Dosage volume or concentration?. Anaesthesia. 1990;45(5):414.
33 Davis FM, Frampton C, Wells JE. Anaesthesia and outcome of surgery for fractured neck of femur. Br J Anaesth. 1990;64(3):403-4.
34 De Visme V, Buggy D. Peripheral blocks of the lower limb for repair of fractured neck of femur. Br J Anaesth. 1998;81(3):483-4. [pmid: 9861148].
35 Denny NM, Selander DE. Continuous spinal anaesthesia. Br J Anaesth. 1998;81(4):590-7. [pmid: 9924237].
36 Di Lorenzo L. Cervical and trochanteric hip fractures: different stories and different outcomes?. Eur J Phys Rehabil Med. 2008;44(3):367-8. [pmid: 18762747].
37 Di Roio C, Vedrinne JM, Hoen JP. Prophylactic intramuscular ephedrine reduces the incidence of hypotension after subarachnoid block in the elderly. Ann Fr Anesth Reanim. 1997;16(5):483-7. (Fre). [pmid: 9750602].
38 Diallo T, Dufeu N, Marret E, et al. Walking in PACU after unilateral spinal anesthesia a criteria for hospital discharge: a 100 out patients survey. Acta Anaesthesiol Belg. 2009;60(1):3-6. [pmid: 19459549].
39 Domsky M, Tarantino D. Patient-controlled spinal analgesia for postoperative pain control. Anesth Analg. 1992;75(3):453-5. [pmid: 1510269].
40 Donatelli F, Tran D, Mistraletti G, et al. Epidural analgesia in the post-anaesthesia care unit. Current Drug Targets. 2005;6(7):795-806. [pmid: 16305458].
41 Eftimova B. Intrathecal morphine and postoperative delirium in elderly orthopedic patients. European Journal of Pain. 2009;Conference(var.pagings):S183-S184.
42 Eger EI. General versus regional anaesthesia for hip fracture surgery. Br J Anaesth. 2000;85(3):492.
43 Egol KA, Koval KJ, Zuckerman JD. Functional recovery following hip fracture in the elderly. J Orthop Trauma. 1997;11(8):594-9. [pmid: 9415867].
44 Errando CL. Propofol to facilitate mobilization of patients with a hip fracture. Can J Anaesth. 2007;54(9):771-2. (Fre). [pmid: 17766749].
45 Farny J, Girard M, Drolet P. Posterior approach to the lumbar plexus combined with a sciatic nerve block using lidocaine. Can J Anaesth. 1994;41(6):486-91. [pmid: 8069988].
46 Foss NB, Kristensen MT, Kristensen BB, et al. Physiotherapy in fast track rehabilitation with epidural analgesia in hip fracture patients. Reg Anesth Pain Med. Suppl 1. 2003;28:14.
47 Fujlmoto T, Meguro K, Hase K, et al. Anesthetic management of the elderly patients with femoral neck fracture by sevoflurane and femoral nerve block. Masui. 2000;49(6):633. (Jap).
48 Gaillat F, Thibault S, Scemama F, et al. Lumbar and sciatic posterior blocks for hip fracture surgery in elderly patients: clinical experience. Cah Anesthesiol. 2002;50(2):99-104.
49 Gielen MJ. Continuous spinal anesthesia (CSA): does it have a role in surgery and postoperative analgesia?. Acta Anaesthesiol Belg. 1999;50(4):217-20. [pmid: 10603998].
50 Gilligan P, Taylor A, Khan A, et al. SOCRATES 6: Synopsis of Cochrane Reviews applicable to emergency services. EMERG MED J. 2005;22(4):277-8. [pmid: 15788834].
51 Gligorijevic S. Continuous spinal technique for fracture of the femoral neck-PRO. 16th Annual congress. 1997 Sep. London. 1997.
52 Greengrass RA. Posterior lumbar plexus block. Tech Reg Anesth Pain Manag. 2003;7(1):3-7.
53 Griffiths R, Rasmussen LS. Delirium in hip fracture patients. Acta Anaesthesiol Scand. 2010;54(6):661-2. [pmid: 20618161].
54 Handoll HH, Cameron ID, Mak JC, et al. Multidisciplinary rehabilitation for older people with hip fractures. Cochrane database of systematic reviews (Online). 2009;(4):CD007125. Date of Publication: 2009 2009;(Online):CD007125. [pmid: 19821396].
55 Hempelmann G, Heesen M. Timely anesthesiologic management of hip prosthesis patients. Anasthesiol Intensivmed Notfallmed Schmerzther. 1994;29(7):383-4. German. [pmid: 7819463].
56 Holdgate A, Shepherd SA, Huckson S. Patterns of analgesia for fractured neck of femur in Australian emergency departments. Emerg Med Australas. 2010;22(1):3-8. [pmid: 20015246].
57 Holt G, Todd B. Postsurgical care: time for change. Br J Hosp Med. 1990;44(6):384.
58 Horlocker TT. Will lower extremity blocks make neuraxial anesthesia and analgesia obsolete?. Tech Reg Anesth Pain Manag. 1999;3(1):1-2.
59 Hossain M. Subcapital fracture of the femoral neck in medically unwell patients: technique for fixation using direct infiltration local anaesthetic rather than regional blockade. Injury. 2008;39(7):820. [pmid: 18541247].
60 Hurley K. Do femoral nerve blocks improve acute pain control in adults with isolated hip fractures?. CJEM. 2004;6(6):441-3. [pmid: 17378965].
61 Hutchison GL. Crystalloid preloading in spinal anaesthesia. Anaesthesia. 1990;45(9):785-6. [pmid: 2240548].
62 Ilfeld BM. Preoperative epidural placement in elderly patients with hip fractures: a request for essential information. Anesthesiology. 2003;99(2):514.
63 Iserson K. Single fascia iliaca compartment block for post-hip fracture pain relief. Annual Meeting of the Society for Academic Emergency Medicine. 2005 May 22-25. New York City, New York (USA). 2005.
64 Jayasekera N, Sharif K, Diggory P, et al. Fascia iliaca block in the pre-operative pain management of elderly patients with hip fracture. 53rd Congress of the Nordic Orthopaedic Federation, Radisson SAS Scandinavia Hotel. 2006 May 31-Jun 2. Oslo, Norway. 2006.
65 Jones AG. Three in one block for fractured neck of femur. Anaesthesia. 1991;46(6):517.
66 Kamibayashi T, Harasawa K, Maze M. Alpha-2 adrenergic agonists. Can J Anaesth. 1997;44(5 II).
67 Kamibayashi T, Maze M. Perioperative use of alpha-2 adrenergic agonists. Curr Opin Anaesthesiol. 1996;9(4):323-7.
68 Kannan S, Ben-David B. Ten milligrams intrathecal bupivacaine is too high for spinal anesthesia for hip surgery in the geriatric population. Anesthesiology. 2000;93(5):1365.
69 Karaca S. Is lumbar plexus block sufficient for hip fracture surgery?. Pain Pract. 2008;8(2):147-8. [pmid: 18366470].
70 Kavuri S, Robalino J, Janardhan Y, et al. Low-dose intrathecal-meperidine for lower limb orthopaedic surgery. Can J Anaesth. 1990;37(8):947-8. Erratum in: Can J Anaesth 1991, 38(2):263. [pmid: 2253305].
71 Khatouf M, LOUGHNANE FJ, Boini S, et al. Unilateral spinal anaesthesia in elderly patient for hip trauma: a pilot study. Ann Fr Anesth Reanim. 2005;24(3):249-54. [pmid: 15792557].
72 Knight R. A response to 'A study of the initial fluid resuscitation and pain management of patients with fractured neck of femur', Levy N. Anaesthesia. 2002;57:1148. Anaesthesia 2003;58(4):403-4.
73 Kondo A, Zierler BK, Isokawa Y, et al. Comparison of outcomes and costs after hip fracture surgery in three hospitals that have different care systems in Japan. Health Policy. 2009;91(2):204-210. Date of Publication: July 2009 2009;(2):204-10. [pmid: 19162364].
74 Konttinen N, Rosenberg PH. Outcome after anaesthesia and emergency surgery in patients over 100 years old. Acta Anaesthesiol Scand. 2006;50(3):283-9. [pmid: 16480460].
75 Koursoumi E, Ioakimidou A, Biri E, et al. Acute pain management with femoral nerve block in patients with femoral neck fractures [abstract]. Reg Anesth Pain Med. 5 Suppl 1. 2005;30:51.
76 Koval KJ. Preoperative skin traction was not useful for hip fractures. J Bone Joint Surg Am. 2001;83-A(2):303. [pmid: 11216698].
77 Kunisawa T, Ota M, Suzuki A, et al. Combination of high-dose dexmedetomidine sedation and fascia iliaca compartment block for hip fracture surgery. J Clin Anesth. 2010;22(3):196-200. [pmid: 20400006].
78 Lareau C, Sawyer G. Hip fracture surgical treatment and rehabilitation. Med Health R I. 2010;93(4):108-11. [pmid: 20486521].
79 Lau TW, Leung F, Siu D, et al. Geriatric hip fracture clinical pathway: The Hong Kong experience. OSTEOPOROSIS INT. SUPPL. 4. 2010;21:S627-S636.
80 Leng K, Barnett SR. Anesthesia and the elderly patient. Progr Anesthesiol. 2004;18(15):235-48.
81 Lien CA. Regional versus general anesthesia for hip surgery in older patients: does the choice affect patient outcome?. J Am Geriatr Soc. 2002;50(1):191-4. [pmid: 12028267].
82 Lindenhovius ALC, Helmerhorst GTT. Erratum: Differences in prescription of narcotic pain medication after operative treatment of hip and ankle fractures in the United States and the Netherlands (Journal of Trauma 67:1 (160-167)). J Trauma Inj Infect Crit Care. 2010;68(3):744.
83 Liu SS, Salinas FV. Continuous plexus and peripheral nerve blocks for postoperative analgesia. Anesth Analg. 2003;96(1):263-72. [pmid: 12505964].
84 Luger TJ, Kammerlander C, Gosch M, et al. Neuroaxial versus general anaesthesia in geriatric patients for hip fracture surgery: does it matter?. OSTEOPOROSIS INT. Suppl:4. 2010;21:4-72.
85 Mackensen GB. Cognitive dysfunction after anesthesia. J Anasth Intensivbehandlung. 2004;11(2):79-80.
86 Mackenzie J, Pullinger R. The groin cannula: effective pain relief for fractured neck of femur [Letter]. J Accid Emerg Med. 1997;14(4):269.
87 MacLennan B. News and reviews. Age & Ageing. 2010;39(2):154-5.
88 MacLeod D, Grant S, Breslin D, et al. Lower limb blocks following general anaesthesia. Anaesthesia. 2003;58(6):612-3. [pmid: 12846646].
89 Mak J, Baguley IJ. Relationship between hip fracture subtypes and analgesia use. J Am Geriatr Soc. 2007;55(4):626-7.
90 Mak JC, Cameron ID, March LM. Evidence-based guidelines for the management of hip fractures in older persons: an update. Med J Aust. 2010;192(1):37-41. [pmid: 20047547].
91 Mak JC, Lattouf I, O'Rourke F, et al. Relationship between hip fracture subtypes, surgical procedure, and analgesia use. J Am Geriatr Soc. 2009;57(12):2378-80. [pmid: 20122005].
92 Mannion S. Psoas compartment block. Cont Educ Anaesth Crit Care Pain. 2007;7(5):162-6.
93 Marchant W, Goldsack C. Fractured neck of the femur in the elderly patient. Br J Hosp Med (Lond). 2001;62(1):59.
94 Marhofer P, Schrogendorfer K, Wallner T, et al. Ultrasonographic guidance reduces the amount of local anesthetic for 3-in-1 blocks. Reg Anesth Pain Med. 1998;23(6):584-8. [pmid: 9840855].
95 Matot I, Oppenheim-Eden A, Ratrot R, et al. Preoperative cardiac events in elderly patients with hip fracture randomized to epidural or conventional analgesia. Anesthesiology. 2003;98(1):156-63. [pmid: 12502992].
96 Mauffrey C. Re: Intertrochanteric fracture below Birmingham Hip Resurfacing: successful non-operative management in two cases. Injury. 2009;40(3):author reply 338-339. Date of Publication: Mar 2009 2009;(3):338-9.
97 McConnell EA. Applying an abduction pillow correctly. Nursing. 1992;22(6):22.
98 McQuillan P. Regional anesthesia. Curr Opin Anaesthesiol. 2000;13(5):529-30. [pmid: 17016352].
99 Mehmood S, Coleman M, Egan M, et al. Study of the anatomical position of the femoral nerve by magnetic resonance imaging in patients with fractured neck of femur: relevance to femoral nerve block. J Clin Anesth. 2010;22(2):122-5. [pmid: 20304354].
100 Meier G. Peripheral nerve blockades of the lower extremities. Anaesthesist. 2001;50(7):536-59. [pmid: 11496698].
101 Mnif H, Koubaa M, Zrig M, et al. Elderly patient's mortality and morbidity following trochanteric fracture. A 100-ácases prospective study. Rev Chir Orthop Traumatol. 2009;95(7):609-15.
102 Moffa-Trotter ME, Anemaet WK. Home care for hip fracture survivors and fallers: the 'Be HIP!' Program. TOP GERIATR REHABIL. 1996;12(1):46-58.
103 Monzon DG, Iserson KV, Vazquez JA. Single fascia iliaca compartment block for post-hip fracture pain relief. J Emerg Med. 2007;32(3):257-62. [pmid: 17394987].
104 Morley JE. Hip Fractures. Journal of the American Medical Directors Association. 2010;11(2):81-83. Date of Publication: February 2010 2010;(2):81-3. [pmid: 20142060].
105 Morrison RS, Magaziner J, McLaughlin MA, et al. The impact of post-operative pain on outcomes following hip fracture [abstract]. J Am Geriatr Soc. 4 Suppl. 2002;50:S178.
106 Morscher E. Femoral neck fractures. Schweiz Rundsch Med Prax. 1990;79(40):1159-60. German. [pmid: 2237037].
107 Mulroy MF. Extending indications for spinal anesthesia. Reg Anesth Pain Med. 1998;23(4):380-3. [pmid: 9690590].
108 Najran PS, Matharu GS, Porter KM. Non-operative treatment following hip fracture. Injury. 2010;41(7):1062-3.
109 Nunez Lezama L, Molina Campaña J, de la Matta Martín M, et al. Intrathecal neurolysis using phenol in a patient with a hip fracture. Rev Esp Anestesiol Reanim. 2003;50(6):310-2. (Spa). [pmid: 12940225].
110 Obideyi A, Srikantharajah I, Grigg L, et al. Nurse administered fascia iliaca compartment block for pre-operative pain relief in adult fractured neck of femur. Acute Pain. 2008;10(3-4):145-9.
111 Oliveira Filho GR, Garcia JHS, Goldschimidt R, et al. Predictors of early hypotension during spinal anesthesia. Rev Bras Anestesiol. 2001;51(4):298-304.
112 Olsson LE, Hansson E, Ekman I, et al. A cost-effectiveness study of a patient-centred integrated care pathway. J Adv Nurs. 2009;65(8):1626-35. [pmid: 19493145].
113 Parker MJ, Griffiths R, Appadu B. Nerve blocks (subcostal, lateral cutaneous, femoral, triple, psoas) for hip fractures. John Wiley & Sons, Ltd. 2002.
114 Parker MJ. Managing an elderly patient with a fractured femur. Br Med J. 2000;320(7227):102-3. [pmid: 10625268].
115 Randall A, Grigg L, Obideyi A, et al. Fascia iliaca compartment block: a nurse-led initiative for preoperative pain management in patients with a fractured neck of femur. J ORTHOP NURS. 2008;12(2):69-74.
116 Reilly CS. Regional analgesia and myocardial ischaemia. Br J Anaesth. 1993;71(4):467-8. [pmid: 8260289].
117 Reuben SS, Buvanendran A. Preventing the development of chronic pain after orthopaedic surgery with preventive multimodal analgesic techniques. J Bone Joint Surg Am. 2007;89(6):1343-58. [pmid: 17545440].
118 Richez AS, Fuzier R. Indications for continuous or sequential spinal anesthesia in 2008. Prat Anest Reanim. 2008;12(1):23-6.
119 Rodgers A, Walker N, Schug S, et al. Reduction of postoperative mortality and morbidity with epidural or spinal anaesthesia: results from overview of randomised trials. Br Med J. 2000;321(7275):1493-7. [pmid: 11118174].
120 Rodgers A. The appropriate roles of audit and randomisation in determining the efficacy of anaesthetic interventions. Anaesthesia. 1995;50(1):89-90. [pmid: 7702165].
121 Rogers BA, Rang S. Femoral nerve block for diaphyseal and distal femoral fractures in the emergency department. J Bone Joint Surg Am. 2008;90(8):1787-8.
122 Rojas-Rivera W, Abed-R M. Bloqueo femoral tres en uno para cirugía de fractura transtoncantérica de cadera: seguridad y analgesia. Acta Med Costarric. 2002;44(2):62-7. Spanish.
123 Rozzini R, Trabucchi M. Comanagement of elderly patients admitted to a hospital for hip fracture. ARCH INTERN MED. 2009;170(4):392-3.
124 Ryan JM, Singh S, Bryant G, et al. Fast tracking patients with a proximal femoral fracture: more than a broken bone. J Accid Emerg Med. 2000;17(1):76.
125 Sahota O. Reducing the risk of fractures with calcium and vitamin D. BMJ. 2010;340(7738):109. Date of Publication: 16 Jan 2010 2010;(7738):109.
126 Sandby-Thomas M. A national survey: peri-operative anaesthetic management of patients with femoral neck fractures in the UK [abstract]. Annual Meeting of the European Society of Anaesthesiology on Euroanaesthesia (Euroanaesthesia 2007). 2007 Jun 9-12. Munich, Germany. 2007.
127 Schemitsch E, Bhandari M. Femoral neck fractures: Controversies and evidence. Journal of Orthopaedic Trauma. 2009;23(6):385. Date of Publication: July 2009 2009;(6):385. [pmid: 19550222].
128 Schug SA, Raajkumar A. 11 Local anesthetics. Side Effects of Drugs Annual. 2008;30:152-63.
129 Schwemmer U, Markus CK, Brederlau J, et al. Regional anesthesia: ultrasound-guided peripheral nerve blockades. Anasthesiol Intensivmed Notfallmed Schmerzther. 2006;41(7-8):481-90. [pmid: 16874572].
130 Scott J. Educate and depate: operate to relieve the pain. Br Med J. 1994;308(6927):517-9.
131 Scott MA, Stigleman S. What is the best hypnotic for use in the elderly?. J Fam Pract. 2003;52(12):976-8. [pmid: 14653987].
132 Sharrock NE. Fractured femur in the elderly: intensive perioperative care is warranted. Br J Anaesth. 2000;84(2):139-40. [pmid: 10743442].
133 Sikorski JM, Senior J. The domiciliary rehabilitation and support program: rationale, organisation and outcome. Med J Aust. 1993;159(1):23-5. [pmid: 8316107].
134 Sindel D, Diracoglu D. Postoperative rehabilitation in patients with hip fracture. [Turkish]. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. SUPPL 1. 2009;55:8-14. Date of Publication: 2009 2009;(SUPPL.1):8-14.
135 Singelyn FJ, Gouverneur JM. Continuous 3-in-1 block as postoperative pain treatment after hip, femoral shaft, or knee surgery: a large-scale study of efficacy and side effects [abstract]. Anesthesiology. 1994;81(3A):A1054.
136 Singelyn FJ. Continuous peripheral nerve blocks and postoperative pain management. Acta Anaesthesiol Belg. 2006;57(2):109-12. [pmid: 16916179].
137 Sites BD, Spence BC, Gallagher J, et al. Regional anesthesia meets ultrasound: a specialty in transition. Acta Anaesthesiol Scand. 2008;52(4):456-66. [pmid: 18339151].
138 Stiltner J. Pain management in the elderly with traumatic hip fracture [dissertation]. Mountain State University. Beckley WV. 2008.
139 Stott DJ, Langhorne P, Knight PV. Multidisciplinary care for elderly people in the community. Lancet. 2008;371(9614):699-700. [pmid: 18313484].
140 Swenson JD, Bay N, Loose E, et al. Outpatient management of continuous peripheral nerve catheters placed using ultrasound guidance: an experience in 620 patients. Anesth Analg. 2006;103(6):1436-43. [pmid: 17122219].
141 Syed KA, Bogoch ER. Integrated care pathways in hip fracture management: demonstrated benefits are few. J Rheumatol. 2000;27(9):2071. [pmid: 10990215].
142 Tam CW, Rainer TH. Femoral nerve block for pain management of femoral fractures in the emergency department: evidence based topic review. Hong Kong J Emerg Med. 2005;12(3):178-81.
143 Tan TT, Coleman MM, Fletcher AK, et al. Femoral blockade for fractured neck of femur in the emergency department. Ann Emerg Med. 2003;42(4):596-7. [pmid: 14533636].
144 Thannikary LJ, Enneking FK. Non-opioid additives to local anesthetics. Tech Reg Anesth Pain Manag. 2004;8(3):129-40.
145 Touray ST, De Leeuw MA, Zuurmond WWA, et al. Psoas compartment block for lower extremity surgery. Br J Anaesth. 2009;102(5):721-2. [pmid: 19359401].
146 Triner W, Levine J, Lai SY, et al. Femoral nerve block for femur fractures. Ann Emerg Med. 2005;45(6):679.
147 Tully J. Increasing hip pain after a fall. JAAPA. 2003;16(4):67-8. [pmid: 14968519].
148 Vassiliadis J, Hitos K, Hill CT. Factors influencing prehospital and emergency department analgesia administration to patients with femoral neck fractures. Emerg Med (Fremantle). 2002;14(3):261-6. [pmid: 12487043].
149 Wahbi S, Lahhlou A. Les fractures pures de la paroi posterieure: a propos de 88 cas. Pan Arab J Orthop Trauma. 1997;1:19-21. French.
150 Watters M. Hypotension during subarachnoid anaesthesia. Br J Anaesth. 1996;77(6):808-9. [pmid: 9014643].
151 Webster J. Reducing delirium after hip fracture. J Am Geriatr Soc. 2002;50(3):589.
152 West R. Fractured neck of femur patients. J Public Health Med. 1995;17(1):116-7.
153 White PF, Kehlet H, Neal JM, et al. The role of the anesthesiologist in fast-track surgery: from multimodal analgesia to perioperative medical care. Anesth Analg. 2007;104(6):1380-96. [pmid: 17513630].
154 White PF. Use of alternative medical therapies in the perioperative period: is it time to get on board?. Anesth Analg. 2007;104(2):251-4. [pmid: 17242073].
155 Wilhelm S, Standl T. Anaesthesia in orthopedics and traumasurgery. Anasthesiol Intensivmed Notfallmed Schmerzther. 2004;39(5):297-327. [pmid: 15156422].
156 Wilmore DW, Kehlet H. Management of patients in fast track surgery. Br Med J. 2001;322(7284):473-6. [pmid: 11222424].
157 Wong TC, Chiu Y, Tsang WL, et al. A double-blind, prospective, randomised, controlled clinical trial of minimally invasive dynamic hip screw fixation of intertrochanteric fractures. Injury. 2009;40(4):422-7. [pmid: 19309606].
158 Zaugg M, Schulz C, Wacker J, et al. Sympatho-modulatory therapies in perioperative medicine. Br J Anaesth. 2004;93(1):53-62. [pmid: 15145819].
159 Zink W, Graf BM. Benefit-risk assessment of ropivacaine in the management of postoperative pain. Drug Saf. 2004;27(14):1093-114. [pmid: 15554745].
160 Zuckerman JD. Hip fracture. N Engl J Med. 1996;334(23):1519-25. [pmid: 8618608].

## Population Characteristics

1 Abdul-Hadi O, Parvizi J, Austin MS, et al. Nonsteroidal anti-inflammatory drugs in orthopaedics. J Bone JT Surg Ser A. 2009;91(8):2020-7.
2 Abrahamsen B, Brixen K. Mapping the prescriptiome to fractures in men--a national analysis of prescription history and fracture risk. OSTEOPOROSIS INT. 2009;20(4):585-97.
3 Acalovschi I, Bodolea C, Manoiu C. Spinal anesthesia with meperidine: effects of added a-adrenergic agonists: epinephrine versus clonidine. Anesth Analg. 1997;84(6):1333-9. [pmid: 9174316].
4 Adunsky A, Lusky A, Arad M, et al. A comparative study of rehabilitation outcomes of elderly hip fracture patients: the advantage of a comprehensive orthogeriatric approach. J Gerontol A Biol Sci Med Sci. 2003;58(6):542-7. [pmid: 12807926].
5 Akça O, Melischek M, Scheck T, et al. Postoperative pain and subcutaneous oxygen tension. Lancet. 1999;354(9172):41-2. [pmid: 10406365].
6 Akhtar S, Demuth-Anderson L, Stoller M, et al. Pain assessment and management of hip fractures in the emergency department. Ann Emerg Med. 4 Suppl 1. 2006;48:S60-S61.
7 Aparicio Ãlvarez F, Cruz Guerrero B, Hernández Morgado JM. Uso de Fármacos en el anciano con fractura de cadera. Use of drugs in the elderly with hip fracture. Mediciego. Suppl 2. 2003;9:8-14. (Spa).
8 Ausset S, Minville V, Marquis C, et al. Postoperative myocardial damages after hip fracture repair are frequent and associated with a poor cardiac outcome: a three-hospital study. AGE AGEING. 2009;38(4):473-6. [pmid: 19383771].
9 Azkan S, Gakben M, Acar HV, et al. Spinal anesthesia with low dose bupivacaine-fentanyl in hip prothesis operations. Gulhane Med J. 2002;44(2):137-41.
10 Baath C, Wilde-Larsson B, Idvall E, et al. Registered nurses and enrolled nurses assessments of postoperative pain and risk for malnutrition and pressure ulcers in patients with hip fracture. Int J Trauma Nurs. 2010;14(1):30-9.
11 Balverde M, Castroman P, Noya B, et al. Raquianestesia en fracturas de cadera: dosis bajas de ketamina mejoran el dolor y el posicionamiento. Rachianesthesia in hip fractures: low doses of ketamine reduce pain and improve positioning. Rev Argent Anestesiol. 2004;62(1):9-14. (Spa).
12 Bannister J, McClure JH, Wildsmith JAW. Effect of glucose concentration on the intrathecal spread of 0.5% bupivacaine. Br J Anaesth. 1990;64(2):232-4. [pmid: 2317424].
13 Barber M, Braid V, Mitchell SL, et al. Electrical stimulation of quadriceps during rehabilitation following proximal femoral fracture. Int J Rehabil Res. 2002;25(1):61-3. [pmid: 11953717].
14 Bastow MD, Rawlings J, Allison SP. Benefits of supplementary tube feeding after fractured neck of femur: a randomised controlled trial. Br Med J. 1995;287:1589-92.
15 bdul-Hadi O, Parvizi J, Austin MS, et al. Nonsteroidal anti-inflammatory drugs in orthopaedics. J Bone JT Surg Ser A. 2009;91(8):2020-7.
16 Beattie WS, Warriner CB, Etches R, et al. The addition of continuous intravenous infusion of ketorolac to a patient-controlled analgetic morphine regime reduced postoperative myocardial ischemia in patients undergoing elective total hip or knee arthroplasty. Anesth Analg. 1997;84(4):715-22. [pmid: 9085945].
17 Beaupre LA. Effectiveness of a caremap for treatment of elderly patients with hip fracture [dissertation]. University of Alberta (Canada). 2004.
18 Becchi C, Al Malyan M, Coppini R, et al. Opioid-free analgesia by continuous psoas compartment block after total hip arthroplasty: a randomized study. Eur J Anaesthesiol. 2008;25(5):418-23. [pmid: 18028577].
19 Bentur N, Eldar R, Davies MA. Process and outcome of care: comparison of two inpatient geriatric rehabilitation settings. Clin Rehabil. 1994;8(4):307-13.
20 Bernard JM, Kick O, Bonnet F. Comparison of intravenous and epidural clonidine for postoperative patient-controlled analgesia. Anesth Analg. 1995;81(4):706-12. [pmid: 7573998].
21 Bertini L, Tagariello V, Mancini S, et al. 0.75% and 0.5% Ropivacaine for axillary brachial plexus block: a clinical comparison with 0.5% Bupivacaine. Reg Anesth Pain Med. 1999;24(6):514-8. [pmid: 10588554].
22 Biboulet P, Capdevila X, Aubas P, et al. Causes and prediction of maldistribution during continuous spinal anesthesia with isobaric or hyperbaric bupivacaine. Anesthesiology. 1998;88(6):1487-94. [pmid: 9637641].
23 Biboulet P, Morau D, Aubas P, et al. Postoperative analgesia after total-hip arthroplasty: comparison of intravenous patient-controlled analgesia with morphine and single injection of femoral nerve or psoas compartment block: a prospective, randomized, double-blind study. Reg Anesth Pain Med. 2004;29(2):102-9. [pmid: 15029544].
24 Bigat Z, Boztug N, Hadimioglu N, et al. Comparision of low dose bupivacaine and bupivacaine-fentanyl combination for spinal anaesthesia during outpatient arthroscopic surgery. Turk Anesteziyol Reanim Dernegi Derg. 2004;32(4):289-95.
25 Bischoff-Ferrari HA, wson-Hughes B, Platz A, et al. Effect of high-dosage cholecalciferol and extended physiotherapy on complications after hip fracture: a randomized controlled trial. Arch Intern Med. 2010;170(9):813-20. [pmid: 20458090].
26 BjOrkelund KB, Hommel A, Thorngren KG, et al. Reducing delirium in elderly patients with hip fracture: a multi-factorial intervention study. Acta Anaesthesiol Scand. 2010;54(6):678-88. [pmid: 20236093].
27 Bohannon RW, Kloter KS, Cooper JA. Outcome of patients with hip fracture treated by physical therapy in an acute care hospital. TOP GERIATR REHABIL. 1990;6(2):51-8.
28 Bonnet F, Marcandoro J, Minoz O, et al. Conventional vs. continuous spinal anaesthesia with bupivacaine. Ann Fr Anesth Reanim. 1990;9(3):280-4. [pmid: 2372155].
29 Boon J. The effectiveness of massage therapy for managing symptoms of OA of the hip: a pilot study. Fourth Annual Research Symposium of the Canadian Interdisciplinary Network for Complementary and Alternative Medicine Research. Four Seasons Hotel, Vancouver, British Columbia (Canada). 2-3 Nov 2007. 2007.
30 Bovy P, Rodrigue V. Rehabilitation after fracture of the femur in elderly patients. Rev Med Liege. 1997;52(9):577-81. French. [pmid: 9441339].
31 Braz JRC, Koguti ES, Braz LG, et al. Effects of clonidine associated to hyperbaric bupivacaine during high-level spinal anesthesia. Rev Bras Anestesiol. 2003;53(5):561-72. [pmid: 19475309].
32 Brichant JF, Blom-Peters L, Buffels R, et al. Central neural blockage failed to decrease deep venous thrombosis in patients undergoing hip surgery and receiving low molecular weight heparin [abstract]. Br J Anaesth. Suppl 1. 1995;74:75.
33 Brink AC, Boonstra O, Van Der Wal BCH, et al. Is preoperative traction for proximal femoral fractures beneficial to the patient or a comfort to the doctor?. Eur J Trauma. 2005;31(1):39-43.
34 Brooker RF, Butterworth JF IV, Kitzman DW, et al. Treatment of hypotension after hyperbaric tetracaine spinal anesthesia: a randomized, double-blind, cross-over comparison of phenylephrine and epinephrine. Anesthesiology. 1997;86(4):797-805. [pmid: 9105223].
35 Brown C, Moodie J, Bisley E, et al. Intranasal ketorolac for postoperative pain: a phase 3, double-blind, randomized study. Pain Med (USA). 2009;10:1106-14.
36 Buggy D, Higgins P, Moran C, et al. Prevention of spinal anesthesia-induced hypotension in the elderly: comparison between preanesthetic administration of crystalloids, colloids, and no prehydration. Anesth Analg. 1997;84(1):106-10. [pmid: 8989009].
37 Buggy DJ, Power CK, Meeke R, et al. Prevention of spinal anaesthesia-induced hypotension in the elderly: I.M. methoxamine or combined hetastarch and crystalloid. Br J Anaesth. 1998;80(2):199-203. [pmid: 9602585].
38 Burke D, Kennedy S, Bannister J. Spinal anesthesia with 0.5% S(-)-bupivacaine for elective lower limb surgery. Reg Anesth Pain Med. 1999;24(6):519-23. [pmid: 10588555].
39 Burns A. Proximal femoral fractures in the female patient, a controlled trial: the role of the occupational therapist and the physiotherapist. Br J Occup Ther. 1992;55(10):397-400.
40 Cander B, Girisgin S, Koylu R, et al. The effectiveness of analgesics in traumatic injuries of the extremities. Adv Ther. 2005;22(5):462-6. [pmid: 16418155].
41 Capdevila X, Macaire P, Dadure C, et al. Continuous psoas compartment block for postoperative analgesia after total hip arthroplasty: New landmarks, technical guidelines, and clinical evaluation. Anesth Analg. 2002;94(6):1606-13. [pmid: 12032037].
42 Caplan GA, Coconis J, Board N, et al. Does home treatment affect delirium?: a randomised controlled trial of rehabilitation of elderly and care at home or usual treatment: the REACH-OUT trial. AGE AGEING. 2006;35(1):53-60. [pmid: 16239239].
43 Carmeli E, Sheklow SL, Coleman R. A comparative study of organized class-based exercise programs versus individual home-based exercise programs for elderly patients following hip surgery. Disabil Rehabil. 2006;28(16):997-1005. [pmid: 16882639].
44 Casati A, Fanelli G, Aldegheri G, et al. Frequency of hypotension during conventional or asymmetric hyperbaric spinal block. Reg Anesth Pain Med. 1999;24(3):214-9. [pmid: 10338170].
45 Casati A, Fanelli G, Cappelleri G, et al. Low dose hyperbaric bupivacaine for unilateral spinal anaesthesia. Can J Anaesth. 1998;45(9):850-4. [pmid: 9818107].
46 Chang AK, Bijur PE, Baccelieri A, et al. Efficacy and safety profile of a single dose of hydromorphone compared with morphine in older adults with acute, severe pain: a prospective, randomized, double-blind clinical trial. Am J Geriatr Pharmacother. 2009;7(1):1-10. [pmid: 19281935].
47 Chelly JE, Casati A, Al-Samsam T, et al. Continuous lumbar plexus block for acute postoperative pain management after open reduction and internal fixation of acetabular fractures. J Orthop Trauma. 2003;17(5):362-7. [pmid: 12759641].
48 Chen X, Zhao M, White PF, et al. The recovery of cognitive function after general anesthesia in elderly patients: a comparison of desflurane and sevoflurane. Anesth Analg. 2001;93(6):1489-94. [pmid: 11726429].
49 Choong PF, Langford AK, Dowsey MM, et al. Clinical pathway for fractured neck of femur: a prospective, controlled study. Med J Aust. 2000;172(9):423-6. [pmid: 10870534].
50 Chuang CH, Pinkowsky GJ, Hollenbeak CS, et al. Medicine versus orthopaedic service for hospital management of hip fractures. Clin Orthop Relat Res. 2010;468(8):2218-23. [pmid: 20224961].
51 Cinar SO, Oba S, Eksioglu B, et al. Comparison of the anaesthetic and analgesic effects of epidural clonidine and fentanyl. Turk Anesteziyol Reanim. 2001;29(6):271-6.
52 Clarke JV, Campbell C, Murray HM, et al. Validation of local anaesthetic hip arthrograms in the management of hip pain. 7th Domestic Meeting of the European Hip Society (EHS 2006). Sungate Port Royal Hotel, Antalya (Turkey). 21-24 Jun 2006. 2006.
53 Cogan L, Martin AJ, Kelly LA, et al. An audit of hip fracture services in the Mater Hospital Dublin 2001 compared with 2006. Irish Journal of Medical Science. 2010;179(1):51-55. Date of Publication: March 2010 2010;(1):51-5. [pmid: 19565316].
54 Cohen SP, Strassels SA, Foster L, et al. Comparison of fluoroscopically guided and blind corticosteroid injections for greater trochanteric pain syndrome: multicentre randomised controlled trial. BMJ: British Medical Journal. 2009;338:b1088.
55 Colak A, Alagöl A, Pamukçu Z, et al. Comparison of patient controlled versus continuous sufentanil addition under continuous spinal or epidural bupivacaine anesthesia in patients undergoing lower extremity fracture operations. Turk Anesteziyol Reanim Dernegi Derg. 2008;36(5):283-92.
56 Contreras-Dominguez VA, Carbonell-Bellolio PE, Ojeda-Greciet Ã, et al. Extended three-in-one block versus intravenous analgesia for postoperative pain management after reconstruction of anterior cruciate ligament of the knee. Rev Bras Anestesiol. 2007;57(3):280-8. [pmid: 19466363].
57 Couture DJ, Cuniff HM, Burkard JF, et al. The addition of clonidine to bupivacaine in combined femoral-sciatic nerve block for anterior cruciate ligament reconstruction. AANA j. 2004;72(4):273-8. [pmid: 15354916].
58 Cree M, Carriere KC, Soskolne CL, et al. Functional dependence after hip fracture. Am J Phys Med Rehabil. 2001;80(10):736-43. [pmid: 11562555].
59 Critchley LA, Conway F. Hypotension during subarachnoid anaesthesia: haemodynamic effects of colloid and metaraminol. Br J Anaesth. 1996;76(5):734-6. [pmid: 8688279].
60 Critchley LA, Stuart JC, Conway F, et al. Hypotension during subarachnoid anaesthesia: haemodynamic effects of ephedrine. Br J Anaesth. 1995;74(4):373-8. [pmid: 7734252].
61 Critchley LA, Stuart JC, Short TG, et al. Haemodynamic effects of subarachnoid block in elderly patients. Br J Anaesth. 1994;73(4):464-70. [pmid: 7755705].
62 Critchley LA, Yu SC. A comparative study of three different methods of administering metaraminol during spinal anaesthesia in the elderly. Anaesth Intensive Care. 2001;29(2):141-8. [pmid: 11314833].
63 Cuellar E, Cruz AE, Hinojosa A, et al. Intravenous patient-controlled analgesia during the postoperative period after traumatologic and orthopedic surgery. Rev Soc Esp Dolor. 2001;8(2):93-101.
64 Dai Y-T, Huang G-S, Yang R-S, et al. Effectiveness of a multidisciplinary rehabilitation program in elderly patients with hip fractures. J Formos Med Assoc. 2001;100(2):120-6. [pmid: 11393099].
65 Dai YT, Huang GS, Yang RS, et al. Functional recovery after hip fracture: six months' follow-up of patients in a multidisciplinary rehabilitation program. J Formos Med Assoc. 2002;101(12):846-53. [pmid: 12632818].
66 Danelli G, Ghisi D, Fanelli A, et al. The effects of ultrasound guidance and neurostimulation on the minimum effective anesthetic volume of mepivacaine 1.5% required to block the sciatic nerve using the subgluteal approach. Anesthesia and Analgesia. 2009;109:1674-8. [pmid: 19843807].
67 Di Monaco M, Vallero F, Di Monaco R, et al. Hip-fracture type does not affect the functional outcome after acute in-patient rehabilitation: a study of 684 elderly women. Eura Medicophys. 2007;43(4):439-44. [pmid: 18084165].
68 Dobrydnjov I, Axelsson K, Gupta A, et al. Improved analgesia with clonidine when added to local anesthetic during combined spinal-epidural anesthesia for hip arthroplasty: a double-blind, randomized and placebo-controlled study. Acta Anaesthesiol Scand. 2005;49(4):538-45. [pmid: 15777303].
69 Dobrydnjov I, Axelsson K, Samarutel J, et al. Postoperative pain relief following intrathecal bupivacaine combined with intrathecal or oral clonidine. Acta Anaesthesiol Scand. 2002;46(7):806-14. [pmid: 12139535].
70 Dobrydnjov I, Samarutel J. Enhancement of intrathecal lidocaine by addition of local and systemic clonidine. Acta Anaesthesiol Scand. 1999;43(5):556-62. [pmid: 10342005].
71 Dohnert MC, Azevedo LA, Raffone AM, et al. Comparative study betweem one or two physiotherapeutic treatment daily in patients with close articulation thighbone fracture. Fisioter Mov. 1992;5(1):32-44. (Por).
72 Drakeford MK, Pettine KA, Brookshire L, et al. Spinal narcotics for postoperative analgesia in total joint arthroplasty: a prospective study. J Bone Joint Surg Am. 1991;73(3):424-8. [pmid: 1705938].
73 Draper P, Scott F. An investigation into the application and maintenance of Hamilton Russell traction on three orthopaedic wards. J Adv Nurs. 1996;23(3):536-41. [pmid: 8655829].
74 Ducloy-Bouthors AS, Davette M, Le Fahler G, et al. Hip-flexed postures do not affect local anaesthetic spread following induction of epidural analgesia for labour. Int J Obstet Anesth. 2004;13(2):75-81. [pmid: 15321408].
75 Effect of Massage on Chronic Low Back Pain. 2010.
76 Efficacy of Acupuncture for Chronic Low Back Pain. 2010.
77 El Hefnawy AG. Effects of anaesthesia on interleukin (I) and migration inhibtion factor in orthopaedic patients with fracture femur. Egypt J Med Lab Sci. 1997:23-34.
78 Elmas C, Elmas Y, Gautschi P, et al. Combined sciatic 3-in-1-block for orthopaedic operations on the lower limb. Anaesthesist. 1992;41(10):639-43. [pmid: 1443513].
79 El-Zahaar MS, Al-Kawally HM, Said AS. A double-blind randomized study of the effects of torniquet use and type of anesthetic techniques on the incidence of deep vein thrombosis (DVT) in orthopedic surgery. J Neurol Orthop Med Surg. 1995;16(2):70-4.
80 Erdil F, Bulut S, Demirbilek S, et al. The effects of intrathecal levobupivacaine and bupivacaine in the elderly. Anaesthesia. 2009;64(9):942-6. [pmid: 19686477].
81 Erlacher W, Schuschnig C, Koinig H, et al. Clonidine as adjuvant for mepivacaine, ropivacaine and bupivacaine in axillary, perivascular brachial plexus block. Can J Anaesth. 2001;48(6):522-5. [pmid: 11444444].
82 Erskine R, Janicki PK, Neil G, et al. Spinal anaesthesia but not general anaesthesia enhances neutrophil biocidal activity in hip arthroplasty patients. Can J Anaesth. 1994;41(7):632-8. [pmid: 8087913].
83 Ethans K, Powell C. Rehabilitation of patients with hip fracture. REV CLIN GERONTOL. 1996;6(4):371-88.
84 Evaluating Yoga for Chronic Low Back Pain. 2010.
85 Fanelli G, Danelli G, Zasa M, et al. Intrathecal ropivacaine 5 mg/ml for outpatient knee arthroscopy: a comparison with lidocaine 10 mg/ml. Acta Anaesthesiol Scand. 2009;53(1):109-15. [pmid: 19032560].
86 Faraj AA. Non-operative treatment of elderly patients with femoral neck fracture. Acta Orthop Belg. 2008;74(5):627-9. [pmid: 19058696].
87 Fattorini F, Ricci Z, Rocco A, et al. Levobupivacaine versus racemic bupivacaine for spinal anaesthesia in orthopaedic major surgery. Minerva Anestesiol. 2006;72(7-8):637-44. [pmid: 16865082].
88 Faust A, Fournier R, Van Gessel E, et al. Isobaric versus hypobaric spinal bupivacaine for total hip arthroplasty in the lateral position. Anesth Analg. 2003;97(2):589-94. [pmid: 12873959].
89 Feldt K, Bjorklund D, McClurg S. Improving pain treatment in cognitively impaired hip fracture patients. Gerontologist. 2003;43(Sp. Iss. 1):118. [pmid: 12711732].
90 Fernadez-Galinski D, Pulido C, Real J, et al. Comparison of two protocols using low doses of bupivacaine for spinal anaesthesia during joint replacement in elderly patients. Pain Clinic. 2005;17(1):15-24.
91 Fernandez-Castillo A, Vilchez-Lara MaJ, Caballero J. Post-surgical acute pain complementary assessment in an analgesic power contrast. Rev Soc Esp Dolor. 2006;13(3):151-8. (Spa).
92 Fernandez-Galinski D, Rué M, Moral V, et al. Spinal anesthesia with bupivacaine and fentanyl in geriatric patients. Anesth Analg. 1996;83(3):537-41. [pmid: 8780277].
93 Fletcher D, Zetlaoui P, Monin S, et al. Influence of timing on the analgesic effect of intravenous ketorolac after orthopedic surgery. Pain. 1995;61(2):291-7. [pmid: 7659440].
94 Fournier R, Van Gessel E, Gaggero G, et al. Postoperative analgesia with '3-in-1' femoral nerve block after prosthetic hip surgery. Can J Anaesth. 1998;45(1):34-8. [pmid: 9466024].
95 Fournier R, Van Gessel E, Weber A, et al. A comparison of intrathecal analgesia with fentanyl or sufentanil after total hip replacement. Anesth Analg. 2000;90(4):918-22. [pmid: 10735799].
96 Franczuk B, Szwarczyk W, Wilk M. The impact of Continuous Passive Motion (CPM) on progress made in rehabilitation by patients with trochanteric hip fractures treated surgically with a Y-type intramedullary nail. Fizjot Pol. 2005;5(3):297-304. (Pol).
97 Frassanito L, RodolÃ F, Concina G, et al. The efficacy of the psoas compartment block versus the intrathecal combination of morphine, fentanyl and bupivacaine for postoperative analgesia after primary hip arthroplasty: a randomized single-blinded study. Eur Rev Med Pharmacol Sci. 2008;12(2):117-22. [pmid: 18575162].
98 Fredman B, Zohar E, Golan E, et al. Diclofenac does not decrease renal blood flow or glomerular filtration in elderly patients undergoing orthopedic surgery. Anesth Analg. 1999;88(1):149-54. [pmid: 9895083].
99 Fredman B, Zohar E, Tarabykin A, et al. Continuous intravenous diclofenac does not induce opioid-sparing or improve analgesia in geriatric patients undergoing major orthopedic surgery. J Clin Anesth. 2000;12(7):531-6. [pmid: 11137414].
100 Freeman C, Todd C, Camilleri-Ferrante C, et al. Quality improvement for patients with hip fracture: experience from a multi-site audit. Qual Saf Health Care. 2002;11(3):239-45. [pmid: 12486988].
101 Frohlich WH, Fogelman L. Short-term rehab maximizes patient potential. J Long Term Care Adm. 1994;22(3):4-8.
102 Gabopoulou Z, Mavromati P, Karkala E, et al. The importance of pain management in postoperative cognitive dysfunction after major orthopedic surgery in the elderly. Pain Pract. 2009;Conference(var.pagings):136-7.
103 Gaggero G, Van Gessel E, Forster A, et al. Comparison of 5 mg tetracaine diluted in 1 ml, 2 ml and 4 ml of 10% glucose for spinal anesthesia. Acta Anaesthesiol Scand. 1993;37(7):697-701. [pmid: 8249561].
104 Galvard H, Samuelsson SM. Orthopedic or geriatric rehabilitation of hip fracture patients: a prospective, randomized, clinically controlled study in Malmo, Sweden. Aging Clin Exp Res. 1995;7(1):11-6.
105 Ganesh S, Deutsch A. Pain and functional recovery in elderly medicare patients with a hip fracture treated in inpatient rehabilitation facilities [Abstract]. J Am Geriatr Soc. Suppl1. 2009;57:S205.
106 Garcia-Harel P, Casielles JL, Heredia MP, et al. Parecoxib versus ketorolac for the management of moderate postoperative acute pain. Rev Soc Esp Dolor. 2005;12(6):326-32. (Spa).
107 Geier KO. Peripheral nerve stimulator for femoral nerve block: is it really necessary?. Rev Bras Anestesiol. 2003;53(3):338-45. [pmid: 19475284].
108 Gentili M, Senlis H, Houssel P, et al. Single-shot spinal anesthesia with small doses of bupivacaine. Reg Anesth. 1997;22(6):511-4. [pmid: 9425965].
109 Gholve PA, Kosygan KP, Sturdee SW, et al. Multidisciplinary integrated care pathway for fractured neck of femur: a prospective trial with improved outcome. Injury. 2005;36(1):93-8. [pmid: 15589925].
110 Giusti A, Barone A, Oliveri M, et al. Home rehabilitation after hip fracture in the elderly. AGS Annual Meeting. 2005:S216.
111 Gjertsen JE, Vinje T, Engesaeter LB, et al. Internal screw fixation compared with bipolar hemiarthroplasty for treatment of displaced femoral neck fractures in elderly patients. J BONE JT SURG SER A. 2010;92(3):619-28.
112 Goldsmith ME. Supracondylar femoral fractures. Trauma. 1997;39(3):3-20.
113 Goldstein FC, Strasser DC, Woodard JL, et al. Functional outcome of cognitively impaired hip fracture patients on a geriatric rehabilitation unit. J Am Geriatr Soc. 1997;45(1):35-42. [pmid: 8994485].
114 Gonzalez-Montalvo JI, Alarcon T, Mauleon JL, et al. The orthogeriatric unit for acute patients: a new model of care that improves efficiency in the management of patients with hip fracture. Hip Int. 2010;20(2):229-35. [pmid: 20544649].
115 Gonzalez-Montalvo JI, Alarcon T, Saez P, et al. Geriatric management of the frail elderly with hip fracture may improve their clinical outcome. Med Clin (Barc). 2001;116(1):1-5. (Spa). [pmid: 11181252].
116 Gregory JJ, Kostakopoulou K, Cool WP, et al. One-year outcome for elderly patients with displaced intracapsular fractures of the femoral neck managed non-operatively. Injury. 2010;41(12):1273-6. [pmid: 20630527].
117 Griffith JP, Whiteley S, Gough MJ. Prospective randomized study of a new method of providing postoperative pain relief following femoropopliteal bypass. Br J Surg. 1996;83(12):1735-8. [pmid: 9038554].
118 Gulati A. Anaesthesia for hip fracture surgery, a comparison between GA and spinal anaesthesia. Annual Meeting of the European Society of Anaesthesiology on Euroanaesthesia. 2007 Jun 9-12. Munich, Germany. 2007.
119 Guryay D, Karaege GT, Katircioglu K, et al. The effects of an epidural infusion of ropivacaine versus saline on sensory block after spinal anesthesia. Reg Anesth Pain Med. 2008;33(3):217-21. [pmid: 18433672].
120 Gustafson Y, Brannstrom B, Berggren D, et al. A geriatric-anesthesiologic program to reduce acute confusional states in elderly patients treated for femoral neck fractures. J Am Geriatr Soc. 1991;39(7):655-62. [pmid: 2061530].
121 Hadi MA, Shamsul Kamaruljan H, Saedah A, et al. A comparative study of intravenous patient-controlled analgesia morphine and tramadol in patients undergoing major operation. Med J Malaysia. 2006;61(5):570-6. [pmid: 17623958].
122 Hagsten B, Svensson O, Gardulf A. Early individualized postoperative occupational therapy training in 100 patients improves ADL after hip fracture: a randomized trial. Acta Orthop Scand. 2004;75(2):177-83. [pmid: 15180233].
123 Hallberg I, Bachrach-Lindstr+Âm M, Hammerby S, et al. Health-related quality of life after vertebral or hip fracture: A seven-year follow-up study. BMC Musuloskeletal Disord. 2009;10(1).
124 Hannon VF. The relationship between type of anesthesia and incidence of postoperative confusion in elderly female hip fracture patients [dissertation]. Western Connecticut State University. 1995.
125 Hay D, Parker MJ. Hip fracture in the immobile patient. J Bone Joint Surg Br. 2003;85(7):1037-9. [pmid: 14516042].
126 Helayel PE, Da Conceição DB, Knaesel JA, et al. Effective anesthetic volumes in sciatic nerve block: comparison between the parasacral and infragluteal-parabiceps approaches with 0.5% bupivacaine with adrenaline and 0.5% ropivacaine. Rev Bras Anestesiol. 2009;59(5):521-30. [pmid: 19784508].
127 Hempsall VJ, Robertson DR, Campbell MJ, et al. Orthopaedic geriatric care-is it effective?: a prospective population-based comparison of outcome in fractured neck of femur. J R Coll Physicians Lond. 1990;24(1):47-50. [pmid: 2308114].
128 Herrick C, Steger-May K, Sinacore DR, et al. Persistent pain in frail older adults after hip fracture repair. J Am Geriatr Soc. 2004;52(12):2062-8. [pmid: 15571543].
129 Heybeli H, Kaya M, Ozalp G, et al. Psoas compartment block for total hip arthoplasty: a comparison of continuous infusion and patients controlled analgesia. Anestezi Derg. 2007;15(2):129-33. (Tur).
130 Hofman A, Geelkerken RH, Wille J, et al. Pressure sores and pressure-decreasing mattresses: controlled clinical trial. Lancet. 1994;343(8897):568-71. [pmid: 7906329].
131 Hommel A, Ulander K, Thorngren KG. Improvements in pain relief, handling time and pressure ulcers through internal audits of hip fracture patients. Scand J Caring Sci. 2003;17(1):78-83. [pmid: 12581299].
132 Hunter KF, Cyr D. The effect of delirium education on use of target PRN medications in older orthopaedic patients. AGE AGEING. 2007;36(1):98-101. [pmid: 17114202].
133 Huusko TM, Karppi P, Kautiainen H, et al. Randomized, double-blind, clinically controlled trial of intranasal calcitonin treatment in patients with hip fracture. Calcif Tissue Int. 2002;71(6):478-84. [pmid: 12370798].
134 Hwang U, Richardson LD, Sonuyi TO, et al. Emergency department pain management of older adults with hip fractures [abstract]. J Gen Intern Med. Suppl 1. 2005;20:45. [pmid: 15693927].
135 Iamaroon A, Raksakietisak M, Halilamien P, et al. Femoral nerve block versus fentanyl: analgesia for positioning patients with fractured femur. Local and Regional Anesthesia. 2010;3(1):21-6.
136 Imani F, Mohammadtaheri F, Entezary S. Evaluation of adding oral gabapentine on patient-controlled IV analgesia (PCIA) on post-operative pain after lower extremity fracture operations [abstract]. Reg Anesth Pain Med. 5 Suppl 1. 2009;33:157.
137 Imbelloni LE, Gouveia MA, Cordeiro JA. Continuous spinal anesthesia versus combined spinal epidural block for major orthopedic surgery: prospective randomized study. Sao Paulo Med J. 2009;127(1):7-11. [pmid: 19466288].
138 Imbelloni LE, Gouveia MA. Postoperative analgesia with paravascular lumbar plexus block: comparison between femoral nerve stimulation and catheter techniques. Rev Bras Anestesiol. 2001;51(1):28-36.
139 Indig R, Ronen R, Eldar R, et al. Pressure sores: impact on rehabilitation following surgically treated hip fractures. Int J Rehabil Res. 1995;18(1):54-5. [pmid: 7797320].
140 Iskandar H, Guillaume E, Dixmérias F, et al. The enhancement of sensory blockade by Clonidine selectively added to mepivacaine after midhumeral block. Anesth Analg. 2001;93(3):771-5. [pmid: 11524354].
141 Jacobsen S, Engfred KF, Nielsen PR, et al. Treatment of hip fractures in a department of general surgery and a department of orthopedic surgery: a comparison. Ugeskr Laeger. 1993;155(10):701-3. (Dan). [pmid: 8456511].
142 JAGS abstracts. Annals of Long Term Care. 2009;17(5):40-2.
143 JAGS Abstracts. Annals of Long Term Care. 2009;17(7):38-41.
144 JANZING HMJ. The Gotfried percutaneous compression plate versus the dynamic hip screw in the treatment of pertrochanteric hip fractures: minimal invasive treatment reduces operative time and postoperative pain. J Trauma. 2002;2002(2):293-8.
145 Jellish WS, Abodeely A, Fluder EM, et al. The effect of spinal bupivacaine in combination with either epidural clonidine and/or 0.5% Bupivacaine administered at the incision site on postoperative outcome in patients undergoing lumbar laminectomy. Anesth Analg. 2003;96(3):874-80. [pmid: 12598277].
146 Kalisvaart KJ, De Jonghe JFM, Bogaards MJ, et al. Haloperidol prophylaxis for elderly hip-surgery patients at risk for delirium: a randomized placebo-controlled study. J Am Geriatr Soc. 2005;53(10):1658-66. [pmid: 16181163].
147 Kalkan E, Torun F, Tavlan A, et al. The effect of meperidine-impregnated autogenous free fat grafts on postoperative pain management in lumbar disc surgery. J Spinal Disord Tech. 2008;21(2):92-5. [pmid: 18391711].
148 Kallio H, Snäll E-VT, Suvanto SJ, et al. Spinal hyperbaric ropivacaine-fentanyl for day-surgery. Reg Anesth Pain Med. 2005;30(1):48-54. [pmid: 15690268].
149 Kamel HK, Iqbal MA, Mogallapu R, et al. Pain management in elderly patients with hip fractures: the practice at a University Teaching Hospital. J Am Geriatr Soc. 2002;50(4):199. S77. [pmid: 12028270].
150 Kandler D, Lisander B. Analgesic action of metoclopramide in prosthetic hip surgery. Acta Anaesthesiol Scand. 1993;37(1):49-53. [pmid: 8424294].
151 Karaaslan P, Pirat A, Tandogan R, et al. Comparison of continuous spinal, continuous epidural and isoflorane-remifentanil anesthesia in geriatric patients undergoing total hip arthroplasty. Anestezi Derg. 2006;14(3):186-91.
152 Karn NK, Singh GK, Kumar P, et al. Management of trochanteric fractures of the femur with external fixation in high-risk patients. Int Orthop. 2009;33(3):785-8. [pmid: 18414857].
153 Kaya M, Özalp G, Tuncel G, et al. Patient-controlled regional analgesia after total hip arthroplasty: psoas compartment block versus three-in one femoral nerve block. Anestezi Derg. 2006;14(1):43-7.
154 Kelly AM. A process approach to improving pain management in the emergency department: development and evaluation. J Accid Emerg Med. 2000;17(3):185-7. [pmid: 10819380].
155 Kjaersgaard-Andersen P. Evaluating codeine plus paracetamol for pain. Nurs Times. 1991;87(16):52.
156 Klimscha W, Weinstabl C, Ilias W, et al. Continuous spinal anesthesia with a microcatheter and low-dose bupivacaine decreases the hemodynamic effects of centroneuraxis blocks in elderly patients. Anesth Analg. 1993;77(2):275-80. [pmid: 8346826].
157 Kober A, Scheck T, Greher M, et al. Prehospital analgesia with acupressure in victims of minor trauma: a prospective, randomized, double-blinded trial. Anesth Analg. 2002;95(3):723-7. [pmid: 12198060].
158 Koch T, Fichtner A, Schwemmer U, et al. Levobupivacaine for epidural anaesthesia and postoperative analgesia in hip surgery: a multi-center efficacy and safety equivalence study with bupivacaine and ropivacaine. Anaesthesist. 2008;57(5):475-82. [pmid: 18351303].
159 Koot VCM, Peeters PHM, De Jong JR, et al. Functional results after treatment of hip fracture: a multicentre, prospective study in 215 patients. Eur J Surg. 2000;166(6):480-5. [pmid: 10890545].
160 Koval KJ, Aharonoff GB, Rosenberg AD, et al. Functional outcome after hip fracture: effect of general versus regional anesthesia. Clin Orthop Relat Res. 1998;(348):37-41. [pmid: 9553531].
161 Koval KJ, Aharonoff GB, Rosenberg AD, et al. Hip fracture in the elderly: the effect of anesthetic technique. Orthopedics. 1999;22(1):31-4. [pmid: 9925195].
162 Kraus J, Volf V, Burget F, et al. [PCCP versus standard proximal femoral nail in the treatment of pertrochanteric femoral fractures]. [Czech]. Rozhledy V Chirurgii. 2009;88(8):469-74. [pmid: 20055305].
163 Kumar M, Batra YK, Panda NB, et al. Tramadol added to bupivacaine does not prolong analgesia of continuous psoas compartment block. Pain Pract. 2009;9(1):43-50. [pmid: 19019050].
164 Laberge A, Joubert P, Brodeur JM. Le risque de perte d'autonomie fonctionnelle associe a l'utilisation des ressources institutionnelles, pour la readaptation des personnes agees hosptialisees a la suite d'une fracture de la hanche. Can J Rehabil. 1997;10(3):205-14. (Fre).
165 Lahav M. Functional recovery and pain in hip fractures post DHS and PCCP [abstract]. J Am Acad Orthop Surg. 2007. 2007 February 14-18. San Diego CA.
166 Lamb SE, Oldham JA, Morse RE, et al. Neuromuscular stimulation of the quadriceps muscle after hip fracture: a randomized controlled trial. Arch Phys Med Rehabil. 2002;83(8):1087-92. [pmid: 12161829].
167 Larsen K, Hansen TB, Soballe K. Hip arthroplasty patients benefit from accelerated perioperative care and rehabilitation: a quasi-experimental study of 98 patients. Acta Orthop. 2008;79(5):624-30. [pmid: 18839368].
168 Lauridsen UB, de la Cour BB, Gottschalck L, et al. Intensive physical therapy after trochanteric femoral fracture: a randomized clinical trial. Ugeskr Laeger. 2002;164(8):1040-4. (Dan). [pmid: 11894705].
169 Lee LA, Domino KB. Complications associated with peripheral nerve blocks: lessons from the ASA closed claims project. Int Anesthesiol Clin. 2005;43(3):111-8. [pmid: 15970748].
170 Licciardone JC, Stoll ST, Cardarelli KM, et al. A randomized controlled trial of osteopathic manipulative treatment following knee or hip arthroplasty. J Am Osteopath Assoc. 2004;104(5):193-202. [pmid: 15176518].
171 Lin PC, Wang CH, Chen CS, et al. To evaluate the effectiveness of a discharge-planning programme for hip fracture patients. J Clin Nurs. 2009;18(11):1632-9. [pmid: 19490299].
172 Lindsay R, Silverman SL, Watts NB, et al. Bisphosphonate therapy and hip fractures within the risedronate and alendronate (ReAl) cohort study: subgroup with prior fracture. 14th Annual Meeting of the International Society for Clinical Densitometry. 2008 May 12-15. San Francisco, CA. 2008.
173 Lipson MJ, Minassian P. Differences in outcome: hospital rehabilitation vs skilled nursing facility rehabilitation. Arch Intern Med. 1990;150(7):1550-1. [pmid: 2369260].
174 Liu N, Bonnet F, Delaunay L, et al. Partial reversal of the effects of extradural clonidine by oral yohimbine in postoperative patients. Br J Anaesth. 1993;70(5):515-8. [pmid: 8318322].
175 Lopez S, Gros T, Bernard N, et al. Fascia iliaca compartment block for femoral bone fractures in prehospital care. Reg Anesth Pain Med. 2003;28(3):203-7. [pmid: 12772137].
176 Love DR, Owen H, Ilsley AH, et al. A comparison of variable-dose patient-controlled analgesia with fixed-dose patient-controlled analgesia. Anesth Analg. 1996;83(5):1060-4. [pmid: 8895286].
177 Lu G, Chen P-B, Lu F-M. Features of intramedullary nail INTERTAN for intertrochanteric fractures: Retrospective analysis of 19 cases. [Chinese]. Journal of Clinical Rehabilitative Tissue Engineering Research. 2009;13(26):5162-5166. Date of Publication: 25 Jun 2009 2009;(26):5162-6.
178 Lundstrom M, Olofsson B, Stenvall M, et al. Postoperative delirium in old patients with femoral neck fracture: a randomized intervention study. Aging Clin Exp Res. 2007;19(3):178-86. [pmid: 17607084].
179 MacDonald V, Hilton BA. Postoperative pain management in frail older adults. ORTHOP NURS. 2001;20(3):63-76. [pmid: 12025636].
180 MacDonald V, Hilton BA. Postoperative pain management in frail older adults. Perianesthes Ambul Surg Nurs Update. 2001;9(5):70.
181 Malawer MM, Buch R, Khurana JS, et al. Postoperative infusional continuous regional analgesia: a technique for relief of postoperative pain following major extremity surgery. Clin Orthop Relat Res. 1991;(266):227-37.
182 Manabe Y, Iwamoto S, Tsuru Y, et al. The effect of oral clonidine premedication on inferior alveolar nerve block. J Jpn Dent Soc Anesthesiol. 2007;35(2):151-7.
183 Mangione KK, Craik RL, Palombaro KM, et al. Home-based leg-strengthening exercise improves function 1 year after hip fracture: a randomized controlled study. J Am Geriatr Soc. 2010;58(10):1911-7. [pmid: 20929467].
184 Mannion S, O'Callaghan S, Murphy DB, et al. Tramadol as adjunct to psoas compartment block with levobupivacaine 0.5%: a randomized double-blinded study. Br J Anaesth. 2005;94(3):352-6. [pmid: 15608044].
185 Mannion S, O'Callaghan S, Walsh M, et al. In with the new, out with the old?: comparison of two approaches for psoas compartment block. Anesth Analg. 2005;101(1):259-64. [pmid: 15976242].
186 Markel DC, Urquhart B, Derkowska I, et al. Effect of epidural analgesia on venous blood flow after hip arthroplasty. Clin Orthop Relat Res. 1997;(334):168-74.
187 Marottoli RA, Berkman LF, Leo-Summers L, et al. Predictors of mortality and institutionalization after hip fracture: the New Haven EPESE cohort: Established Populations for Epidemiologic Studies of the Elderly. Am J Public Health. 1994;84(11):1807-12. [pmid: 7977922].
188 Martins Fonseca N, Araújo Ruzi R, Xavier Ferreira F, et al. Postoperative analgesia following orthopedic surgery: a study comparing perivascular lumbar plexus inguinal block with ropivacaine (3 in 1) and spinal anesthesia with morphine. Rev Bras Anestesiol. 2003;53(2):188-97. [pmid: 19475271].
189 Massage, Meditation, and Tai Chi for Chronic Lower Back Pain. 2010.
190 Matsui H, Terahata N, Makiyama N, et al. Significance of patient-controlled analgesia combined with continuous epidural block for patients with limb trauma. Int Orthop. 1997;21(5):298-302. [pmid: 9476158].
191 Mauker K, Bonvini JM, Ekatodramis G, et al. Continuous spinal anesthesia/analgesia vs. single-shot spinal anesthesia with patient-controlled analgesia for elective hip arthroplasty. Acta Anaesthesiol Scand. 2003;47(7):878-83. [pmid: 12859310].
192 McGilton KS, Mahomed N, Davis AM, et al. Outcomes for older adults in an inpatient rehabilitation facility following hip fracture (HF) surgery. Arch Gerontol Geriatr. 2009;49(1):e23-e31. [pmid: 18842307].
193 McNamee DA, Convery PN, Milligan KR. Total knee replacement: a comparison of ropivacaine and bupivacaine in combined femoral and sciatic block. Acta Anaesthesiol Scand. 2001;45(4):477-81. [pmid: 11300387].
194 Meeds B, Pryor GA. Early home rehabilitation for the elderly patient with hip fracture: the Peterborough hip fracture scheme. Physiotherapy. 1990;76(2):75-7.
195 Mendelsohn ME, Overend TJ, Connelly DM, et al. Improvement in erobic fitness during rehabilitation following hip fracture. 55th Annual Meeting on American College of Sports Medicine. 2008 May 28-21. Indianapolis, Indiana (USA). 2008.
196 Merle V, Moret L, Pidhorz L, et al. Does comparison of performance lead to better care? A pilot observational study in patients admitted for hip fracture in three French public hospitals. International Journal for Quality in Health Care. 2009;21(5):321-9. [pmid: 19692425].
197 Michaloudis D, Petrou A, Bakos P, et al. Continuous spinal anaesthesia/analgesia for the perioperative management of high-risk patients. Eur J Anaesthesiol. 2000;17(4):239-47. [pmid: 10866007].
198 Milisen K, Abraham IL, Broos PLO. Postoperative variation in neurocognitive and functional status in elderly hip fracture patients. J Adv Nurs. 1998;27(1):59-67. [pmid: 9515609].
199 Møiniche S, Hjortsø NC, Hansen BL, et al. The effect of balanced analgesia on early convalescence after major orthopaedic surgery. Acta Anaesthesiol Scand. 1994;38(4):328-35. [pmid: 8067218].
200 Moran AP, Stock K, Jenkins C, et al. Co-induction of anaesthesia with 0.75 mg kg propofol followed by sevoflurane: a randomized trial in the elderly with cardiovascular risk factors. Eur J Anaesthesiol. 2008;25(3):183-7. [pmid: 17888191].
201 Morrison RS, Flanagan S, Fischberg D, et al. A novel interdisciplinary analgesic program reduces pain and improves function in older adults after orthopedic surgery. J Am Geriatr Soc. 2009;57(1):1-10. [pmid: 19054187].
202 Morrison RS, Magaziner J, McLaughlin MA, et al. The impact of post-operative pain on outcomes following hip fracture. Pain. 2003;103(3):303-11. [pmid: 12791436].
203 Morrison RS, Siu AL. Inadequate treatment of pain in hip fracture patients [abstract]. J Am Geriatr Soc. 9 Suppl. 1998;46:S14.
204 Moseley AM, SC, Lord SR, et al. Mobility training after hip fracture: a randomised controlled trial. AGE AGEING. 2009;38(1):74-80. [pmid: 19017676].
205 Munuera L, Garcia-Cimbrelo E. International meeting on total hip arthroplasty: Hospital La Paz - Madrid, April 6-8, 2000. HIP International. 2000;10(3):178-90.
206 Murphy PM, Stack D, Kinirons B, et al. Optimizing the dose of intrathecal morphine in older patients undergoing hip arthroplasty. Anesth Analg. 2003;97(6):1709-15. [pmid: 14633547].
207 Mutty CE, Jensen EJ, Manka J, et al. Femoral nerve block for diaphyseal and distal femoral fractures in the emergency department. J Bone Joint Surg Am. 2007;89 A(12):2599-603. [pmid: 18056490].
208 Mutty CE, Jensen EJ, Manka MAJ, et al. Femoral nerve block for diaphyseal and distal femoral fractures in the emergency department: surgical technique. J Bone Joint Surg Am. Suppl 2 Pt 2. 2008;90:218-26. [pmid: 18829935].
209 Naglie G, Tansey C, Kirkland JL, et al. Interdisciplinary inpatient care for elderly people with hip fracture: a randomized controlled trial. CMAJ. 2002;167(1):25-32. [pmid: 12137074].
210 Nelson L, Taylor F, Adams M, et al. Improving pain management for hip fractured elderly. ORTHOP NURS. 1990;9(3):79-83. [pmid: 2377382].
211 Niemi L, Pitkänen M, Tuominen M, et al. Technical problems and side effects associated with continuous intrathecal or epidural post-operative analgesia in patients undergoing hip arthroplasty. Eur J Anaesthesiol. 1994;11(6):469-74. [pmid: 7851354].
212 Nishikawa K, Yamakage M, Omote K, et al. Prophylactic IM small-dose phenylephrine blunts spinal anesthesia-induced hypotensive response during surgical repair of hip fracture in the elderly. Anesth Analg. 2002;95(3):751-6. [pmid: 12198065].
213 O'Hara DA, Duff A, Berlin JA, et al. The effect of anesthetic technique on postoperative outcomes in hip fracture repair. Anesthesiology. 2000;92(4):947-57. [pmid: 10754613].
214 Ohsawa S, Miura A, Yagyu M, et al. Assertive rehabilitation for intracapsular fracture of the proximal femur. Clin Rehabil. 2007;21(1):36-40. [pmid: 17213239].
215 Olofsson C, Ahl T, Johansson T, et al. A multicenter clinical study of the safety and activity of maleimide-polyethylene glycol-modified hemoglobin (Hemospan) in patients undergoing major orthopedic surgery. Anesthesiology. 2006;105(6):1153-63. [pmid: 17122578].
216 Olsson LE, Karlsson J, Ekman I. Effects of nursing interventions within an integrated care pathway for patients with hip fracture. J Adv Nurs. 2007;58(2):116-25. [pmid: 17445014].
217 ONG BC. Unipolar versus bipolar hemiarthroplasty: functional Outcome after femoral neck fracture at a minimum of thirty-six months of follow-up. J Orthop Trauma. 2002;2002(5):317-22.
218 Orebaugh SL, Williams BA, Vallejo M, et al. Adverse outcomes associated with stimulator-based peripheral nerve blocks with versus without ultrasound visualization. Reg Anesth Pain Med. 2009;34(3):251-5. [pmid: 19587625].
219 Palacios Rios D, Colunga Mata JM, Lopez Sala P, et al. Femoral nerve blockade: previous application to spinal or epidural anesthesia in patients with fracture of the diafisis of the femur. Anest Mex. 1998;10(3):107-9. (Spa).
220 Pardillos C. Pre-operative '3 in 1' block for hip fracture surgery. Rev Esp Anestesiol Reanim. Suppl 1. 1997;44:212.
221 Passot S, Servin F, Pascal J, et al. A comparison of target- and manually controlled infusion propofol and etomidate/desflurane anesthesia in elderly patients undergoing hip fracture surgery. Anesth Analg. 2005;100(5):1338-42. [pmid: 15845680].
222 Pennington P, Caminiti S, Schein JR, et al. Patients' assessment of the convenience of fentanyl HCl iontophoretic transdermal system (ITS) versus morphine intravenous patient-controlled analgesia (IV PCA) in the management of postoperative pain after major surgery. Pain management nursing: official journal of the American Society of Pain Management Nurses. 2009;10:124-33. [pmid: 19706349].
223 Pennington P, Caminiti S, Schein JR, et al. Patients' assessment of the convenience of fentanyl HCl iontophoretic transdermal system (ITS) versus morphine intravenous patient-controlled analgesia (IV PCA) in the management of postoperative pain after major surgery. Pain management nursing : official journal of the American Society of Pain Management Nurses. 2009;10:124-33. [pmid: 19706349].
224 Petrella RJ, Overend T, Chesworth B. FIM™ after hip fracture: is telephone administration valid and sensitive to change? [abstract]. Am J Phys Med Rehabil. 2002;81(9):639-44. [pmid: 12172514].
225 Peyser A, Weil YA, Brocke L, et al. A prospective, randomised study comparing the percutaneous compression plate and the compression hip screw for the treatment of intertrochanteric fractures of the hip. J Bone Jt Surg Ser B. 2007;89(9):1210-7.
226 Physical CAM Therapies for Chronic Low Back Pain. 2010.
227 Pilot Study to Test the Effectiveness of Combining Conventional and Complementary Medicine to Treat Low Back Pain. 2010.
228 Pitkänen M, Rosenberg P, Silvanto M, et al. Haemodynamic changes during spinal anaesthesia with slow continuous infusion or single dose of plain bupivacaine. Acta Anaesthesiol Scand. 1992;36(6):526-9. [pmid: 1514336].
229 Ponhold H, Kulier AH, Rehak PH. 30 degree trunk elevation and quality of lumbar epidural anaesthesia for lower extremity operations. Anaesthesist. 1993;42(11):788-92. German. [pmid: 8279691].
230 Pretto M, Spirig R, Milisen K, et al. Effects of an interdisciplinary nurse-led Delirium Prevention and Management Program (DPMP) on nursing workload: a pilot study. Int J Nurs Stud. 2009;46(6):804-12. [pmid: 19249782].
231 Puolakka R, Haasio J, PitkÃ¤nen MT, et al. Technical aspects and postoperative sequelae of spinal and epidural anesthesia: a prospective study of 3,230 orthopedic patients. Reg Anesth Pain Med. 2000;25(5):488-97. [pmid: 11009234].
232 Qi X, Liu J-G, Gong Y-B, et al. Treatment of posterior wall fractures of acetabulum. Chin J Traumatol. 2009;12(2):113-7. [pmid: 19321057].
233 Quinlan MR, Quinlan JF, Lenehan B, et al. The need for multi-disciplinary management of combined orthopaedic and genito-urinary injuries. Eur J Orthop Surg Traumatol. 2009;19(4):249-54.
234 Raaymakers EL, Marti RK. Non-operative treatment of impacted femoral neck fractures. J Bone Joint Surg Br. 1991;73B(6):950-4.
235 Rabinowitz A, Bourdet B, Minville V, et al. The paramedian technique: a superior initial approach to continuous spinal anesthesia in the elderly. Anesth Analg. 2007;105(6):1855-7. [pmid: 18042894].
236 Rhee KY, Kang K, Kim J, et al. Intravenous clonidine prolongs bupivacaine spinal anesthesia. Acta Anaesthesiol Scand. 2003;47(8):1001-5. [pmid: 12904193].
237 Rivera Ordonez A., Rivera Flores J. Postoperative epidural analgesia: ketamine plus bupivacaine vs. bupivacaine alone in hip and femur surgery. Rev Mex Anestesiol. 2005;28(1):14-9. Spanish.
238 Roberts HC, Pickering RM, Onslow E, et al. The effectiveness of implementing a care pathway for femoral neck fracture in older people: a prospective controlled before and after study. AGE AGEING. 2004;33(2):178-84. [pmid: 14960435].
239 Ruecker AH. The Treatment of Intertrochanteric Fractures : Results Using an Intramedullary Nail With Integrated Cephalocervical Screws and Linear Compression. J Orthop Trauma. 2009;2009(1):22-30.
240 Ryan T, Enderby P, Rigby AS. A randomized controlled trial to evaluate intensity of community-based rehabilitation provision following stroke or hip fracture in old age. Clinical Rehabilitation. 2006;20(2):123-31. [pmid: 16541932].
241 Samkaoui MA, Bouaggad A, Al Harrar R, et al. The addition of clonidine to lidocaine 0.5% for intravenous regional anaesthesia. Ann Fr Anesth Reanim. 2001;20(3):255-9. [pmid: 11332061].
242 SaSauter AR, Dodgson MS, Stubhaug A, et al. Electrical nerve stimulation or ultrasound guidance for lateral sagittal infraclavicular blocks: a randomized, controlled, observer-blinded, comparative study. Anesth Analg. 2008;106(6):1910-5. [pmid: 18499631].
243 Schiferer A, Gore C, Gorove L, et al. A randomized controlled trial of femoral nerve blockade administered preclinically for pain relief in femoral trauma. Anesth Analg. 2007;105(6):1852-4. [pmid: 18042893].
244 Schnider TW, Mueller-Duysing S, Jöhr M, et al. Incremental dosing versus single-dose spinal anesthesia and hemodynamic stability. Anesth Analg. 1993;77(6):1174-8. [pmid: 8250309].
245 Seeberger MD, Urwyler A. Paravascular lumbar plexus block: block extension after femoral nerve stimulation and injection of 20 vs. 40 ml mepivacaine 10 mg/ml. Acta Anaesthesiol Scand. 1995;39(6):769-73. [pmid: 7484032].
246 Sell A, Olkkola KT, Jalonen J, et al. Isobaric bupivacaine via spinal catheter for hip replacement surgery: ED50 and ED95 dose determination. Acta Anaesthesiol Scand. 2006;50(2):217-21. [pmid: 16430545].
247 Senthilnathan S, Muralidharan V, Vijayaraj R, et al. Effect of anaesthesia on duration of hip surgery [abstract]. 7th Domestic Meeting of the European Hip Society (EHS 2006). 2006 Jun 21-24. Antalya, Turkey. 2006.
248 Shiri-Sharvit O, Arad M, Mizrahi EH, et al. The association between psychotropic medication use and functional outcome of elderly hip-fracture patients undergoing rehabilitation. Arch Phys Med Rehabil. 2005;86(7):1389-93. [pmid: 16003669].
249 Shyu Y-I, Liang J, Wu C-C, et al. A pilot investigation of the short-term effects of an interdisciplinary intervention program on elderly patients with hip fracture in Taiwan. J Am Geriatr Soc. 2005;53(5):811-8. [pmid: 15877556].
250 Shyu YI, Liang J, Wu CC, et al. Interdisciplinary intervention for hip fracture in older Taiwanese: benefits last for 1 year. J Gerontol A Biol Sci Med Sci. 2008;63(1):92-7. [pmid: 18245766].
251 Siddiqui ZI, Cepeda MS, Denman W, et al. Continuous lumbar plexus block provides improved analgesia with fewer side effects compared with systemic opioids after hip arthroplasty: a randomized controlled trial. Reg Anesth Pain Med. 2007;32(5):393-8. [pmid: 17961837].
252 Sieber FE, Zakriya KJ, Gottschalk A, et al. Sedation depth during spinal anesthesia and the development of postoperative delirium in elderly patients undergoing hip fracture repair. Mayo Clin Proc. 2010;85(1):18-26. [pmid: 20042557].
253 Singelyn FJ, Ferrant T, Malisse MF, et al. Effects of intravenous patient-controlled analgesia with morphine, continuous epidural analgesia, and continuous femoral nerve sheath block on rehabilitation after unilateral total-hip arthroplasty. Reg Anesth Pain Med. 2005;30(5):452-7. [pmid: 16135349].
254 Singelyn FJ, Gouverneur JMA. Postoperative analgesia after total hip arthroplasty: IV PCA with morphine, patient-controlled epidural analgesia, or continuous '3-in-1' block?: a prospective evaluation by our acute pain service in more than 1,300 patients. J Clin Anesth. 1999;11(7):550-4. [pmid: 10624638].
255 Singelyn FJ, Vanderelst PE, Gouverneur JMA. Extended femoral nerve sheath block after total hip arthroplasty: continous versus patient-controlled techniques. Anesth Analg. 2001;92(2):455-9. [pmid: 11159250].
256 Sites BD, Beach M, Biggs R, et al. Intrathecal clonidine added to a bupivacaine-morphine spinal anesthetic improves postoperative analgesia for total knee arthroplasty. Anesth Analg. 2003;96(4):1083-8. [pmid: 12651665].
257 Solares Ahedo R, Torres Valtierra E, Bojórquez Hernández F. Tratamiento de las fracturas del fémur en el anciano a nivel de la cadera: osteosíntesis con fijación externa: estudio preliminar. Rev Mex Ortop Traumatol. 1997;11(6):400-4. (Spa).
258 Souron V, Delaunay L, Schifrine P. Intrathecal morphine provides better postoperative analgesia than psoas compartment block after primary hip arthroplasty. Can J Anaesth. 2003;50(6):574-9. [pmid: 12826549].
259 Standl TG, Horn EP, Luckmann M, et al. Subarachnoid sufentanil for early postoperative pain management in orthopedic patients: a placebo-controlled, double-blind study using spinal microcatheters. Anesthesiology. 2001;94(2):230-8. [pmid: 11176086].
260 Stenvall M, Olofsson B, Nyberg L, et al. Improved performance in activities of daily living and mobility after a multidisciplinary postoperative rehabilitation in older people with femoral neck fracture: a randomized controlled trial with 1-year follow-up. Journal of Rehabilitation Medicine. 2007;39(3):232-8. [pmid: 17468792].
261 Sternlo JE, Rettrup A, Sandin R. Prophylactic i.m. ephedrine in bupivacaine spinal anaesthesia. Br J Anaesth. 1995;74(5):517-20. [pmid: 7772424].
262 Stevens RD, Van Gessel E, Flory N, et al. Lumbar plexus block reduces pain and blood loss associated with total hip arthroplasty. Anesthesiology. 2000;93(1):115-21. [pmid: 10861154].
263 Strömberg L, Öhlén G, Nordin C, et al. Postoperative mental impairment in hip fracture patients: a randomized study of reorientation measures in 223 patients. Acta Orthop Scand. 1999;70(3):250-5. [pmid: 10429599].
264 Suetta C, Magnusson SP, Rosted A, et al. Resistance training in the early postoperative phase reduces hospitalization and leads to muscle hypertrophy in elderly hip surgery patients: a controlled, randomized study. J Am Geriatr Soc. 2004;52(12):2016-22. [pmid: 15571536].
265 Sundarathiti P, Sirinan C, Seangrung R, et al. Selective spinal anesthesia versus intravenous propofol in transrectal ultrasound-guided prostate biopsy. J Med Assoc Thai. 2009;92(7):920-4. [pmid: 19626811].
266 Swanson CE, Day GA, Yelland CE, et al. The management of elderly patients with femoral fractures: a randomised controlled trial of early intervention versus standard care. Med J Aust. 1998;169(10):515-8. [pmid: 9861907].
267 Taylor AL. Risedronate: a new bisphosphonate on the block. Med Today. 2001;2(6):109-10.
268 Tha HS, Armstrong D, Broad J, et al. Hip fracture in Auckland: contrasting models of care in two major hospitals. Intern Med J. 2009;39(2):89-94. [pmid: 18771434].
269 Titler MG, Herr K, Brooks JM, et al. Translating research into practice intervention improves management of acute pain in older hip fracture patients. Health Serv Res. 2009;44(1):264-87. [pmid: 19146568].
270 Tjardes T, Paffrath T, Baethis H, et al. Computer assisted percutaneous placement of augmented iliosacral screws: a reasonable alternative to sacroplasty. Spine. 2008;33(13):1497-500. [pmid: 18520946].
271 Topcu I, Luleci N, Tekin S, et al. Effectiveness of clonidine and fentanyl addition to bupivacaine in postoperative patient controlled epidural analgesia. Anasthesiol Intensivmed Notfallmed Schmerzther. 2005;40(9):521-5. [pmid: 16145639].
272 Tuncer S, Bariskaner H, Reisli R, et al. Effect of gabapentin on postoperative pain: a randomized, placebo-controlled clinical study. Pain Clinic. 2005;17(1):95-9.
273 Tuominen M, Pitkanen M, Rosenberg PH. Effect of speed of injection of 0.5% plain bupivacaine on the spread of spinal anaesthesia. Br J Anaesth. 1992;69(2):148-9. [pmid: 1389816].
274 Ungemach JW, Andres FJ, Eggert E, et al. The role of anaesthesia in geriatric patients with hip fractures: a prospective study. Eur J Anaesthesiol. 1993;10(5):380.
275 Urbanek B, Duma A, Kimberger O, et al. Onset time, quality of blockade, and duration of three-in-one blocks with levobupivacaine and bupivacaine. Anesth Analg. 2003;97(3):888-92. [pmid: 12933423].
276 Use of the pain reliever propoxyphene is associated with a higher risk of hip fracture among the elderly. AHRQ Res Act. 2007;(319):16-7.
277 Usual Care Vs Choice of Alternative Rx: Low Back Pain. 2010.
278 Utebey G, Akkaya T, Alptekin A, et al. The effects of lumbar plexus block and epidural block on total blood loss and postoperative analgesia in total hip arthroplasty. Agri. 2009;21(2):62-8. [pmid: 19562534].
279 Uy C, Kurrle SE, Cameron ID. Inpatient multidisciplinary rehabilitation after hip fracture for residents of nursing homes: a randomised trial. Australas J Ageing. 2008;27(1):43-4. [pmid: 18713215].
280 Van Geffen GJ, Van Den Broek E, Braak GJJ, et al. A prospective randomised controlled trial of ultrasound guided versus nerve stimulation guided distal sciatic nerve block at the popliteal fossa. Anaesth Intensive Care. 2009;37(1):32-7. [pmid: 19157343].
281 Van Gessel EF, Forster A, Schweizer A, et al. Comparison of hypobaric, hyperbaric, and isobaric solutions of bupivacaine during continuous spinal anesthesia. Anesth Analg. 1991;72(6):779-84. [pmid: 2035860].
282 Van Leeuwen FL, Bronselaer K, Gilles M, et al. The 'three in one' block as locoregional analgesia in an emergency department. Eur J Emerg Med. 2000;7(1):35-8. [pmid: 10839377].
283 Van-Gessel EF, Miege B, Forster A, et al. Comparison of hyperbaric solutions of bupivacaine and tetracaine during continuous spinal anaesthesia. Can J Anaesth. 1992;39(4):323-9. [pmid: 1563056].
284 Vidan M, Serra JA, Moreno C, et al. Efficacy of a comprehensive geriatric intervention in older patients hospitalized for hip fracture: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(9):1476-82. [pmid: 16137275].
285 Wahlen BM, Kilian M, Schuster F, et al. Patient-controlled versus continuous anesthesiologist-controlled sedation using propofol during regional anesthesia in orthopedic procedures: a pilot study. Expert Opin Pharmacother. 2008;9(16):2733-9. [pmid: 18937608].
286 Watson MW, Mitra D, McLintock TC, et al. Continuous versus single-injection lumbar plexus blocks: comparison of the effects on morphine use and early recovery after total knee arthroplasty. Reg Anesth Pain Med. 2005;30(6):541-7. [pmid: 16326339].
287 Weatherall M. Does a delay in transfer to a rehabilitation unit for older people affect outcome after fracture of the proximal femur?. N Z Med J. 2001;114(1145):547-9. [pmid: 11833948].
288 Wiens CA, Jones A, Feeny DH, et al. A prospective study of pharmaceutical management of pain in patients with hip fracture. J Am Geriatr Soc. 2003;51(4):573. [pmid: 12657086].
289 Wilhelm S, Standl T, Burmeister M, et al. Comparison of continuous spinal with combined spinal-epidural anesthesia using plain bupivacaine 0.5% in trauma patients. Anesth Analg. 1997;85(1):69-74. [pmid: 9212125].
290 Wong YY. Assessment of acute pain in older adults with hip fracture: Current nursing practice. Int J Orthop Trauma Nurs. 2010;14(4):228-9.
291 Yap JC, Critchley LA, Yu SC, et al. A comparison of three fluid-vasopressor regimens used to prevent hypotension during subarachnoid anaesthesia in the elderly. Anaesth Intensive Care. 1998;26(5):497-502. [pmid: 9807603].
292 Yu-Yahiro JA, Resnick B, Orwig D, et al. Design and implementation of a home-based exercise program post-hip fracture: the Baltimore hip studies experience. Pm & R. 2009;1(4):308-18.
293 Zevedo Alves TC, Cerqueira Braz JR. Clinical evaluation of clonidine associated to ropivacaine for epidural anesthesia. Rev Bras Anestesiol. 2002;52(4):410-9. [pmid: 19479105].

## No Extractable Data Related to Outcomes of Interest

1 Cao QQ, Xu XZ, Lu YY, et al. Comparison of lumbar plexus block and epidural block for elderly patients undergoing intertrochanteric femoral fracture surgery. Zhonghua Yi Xue Za Zhi. 2008;88(37):2614-7. (Chi). [pmid: 19080708].
2 Cappannoli A, Covotta M, Perrella SM, et al. Local anesthesia in medial femoral compound fractures in critically ill patients. Reg Anesth Pain Med. 2010;Conference(var.pagings):E73. October.
3 Darling JR, Murray JM, Hainsworth AM, et al. The effect of isoflurane or spinal anesthesia on indocyanine green disappearance rate in the elderly. Anesth Analg. 1994;78(4):706-9. [pmid: 8135390].
4 Draper P, Scott F. An evaluation of Hamilton-Russell traction in the pre-operative management of patients with hip fracture. Clin Eff Nurs. 1997;1(4):179-88.
5 Draper P, Scott F. Using traction. Nurs Times. 1998;94(12):31-2.
6 Draper P. A clinical trial of Hamilton-Russell traction on a) incidence of pressure sores, and b) pre-operative pain, in patients with fractured neck of femur, The National Research Register. 2000. Accessed: 2009 Nov 5. Available from: URL: https://portal.nihr.ac.uk/Profiles/NRR.aspx?Publication_ID=D0100101.
7 Ginz HF, Henche HR, Gottschall V. Obturator nerve blockade during hip surgery. Anästhesiol Intensivmed. 2000;41(2):83-7.
8 Gioka M, Manoudis A, Panagiotou E, et al. Sedation with propofol and remifentanyl in exterior osteosynthesis of femoral neck fractures in elderly patients. Reg Anesth Pain Med. Suppl 2. 2004;29:8.
9 Hemmingsen C, Nielsen JE. Intravenous ketamine for prevention of severe hypotension during spinal anaesthesia. Acta Anaesthesiol Scand. 1991;35(8):755-7. [pmid: 1763596].
10 Heyburn G. The efficacy of analgesia in the elderly hip fracture patient [abstract]. Age Ageing. Suppl 1. 2001;29:26.
11 Kristensen BB, Rasmussen S, Foldager S, et al. Fast track rehabilitation with continuous epidural analgesia for hip fracture: fase I [abstract]. Reg Anesth Pain Med. Suppl 1. 2003;28:19.
12 Lafuente A, Moncada R, Hernandez M, et al. Hip fracture in ICU-ambulance: pain relief with remifentanil, 3To1 blockade & morphine [abstract]. 19th Annual Congress of the European Society of Intensive Care Medicine (ESICM 2006). 2006 Sep 24-27. CCIB Convention Centre. Barcelona (Spain). 2006.
13 Magistris L, Greco M, Bertoli E, et al. Postoperative analgesia with fascia iliaca clock in elderly patients with hip fracture [abstract]. Meeting of the European Society of Anaesthesiology (ESA 2006). 2006 Jun 2-5. Madrid, Spain. 2006.
14 Messaoudi K, Azaiez W, Ammous A, Raddaoui K, et al. Combined lumbar and sciatic plexus block compared with unilateral bupivacaine spinal anesthesia for hip fractures in the elderly: preliminary results. 2009.
15 Mortensen NHM, Kuurl E, Schantz K, et al. Post-operative analgesic treatment in hip fracture patients: a controlled comparison of nicomorphine and morphine. Acta Orthop Scand Suppl. 1991;62(246):42-3.
16 Mosaffa F, Esmaelijah A, Khoshnevis H. Analgesia before performing a spinal block in the lateral decubitus position in patients with femoral neck fracture: a comparison between fascia iliaca block and IV fentanyl [Abstract]. Reg Anesth Pain Med. 5 Suppl. 2005;30:61.
17 Mosaffa F, Razavi S. A comparison between fascia iliaca block and IV fentanyl for analgesia before spinal block in the lateral decubitus position in femoral neck fracture. Pain Pract. 2009;148.
18 Mosaffa F. A comparision between fascia iliaca block and IV fentanyl for analgesia before performing a spinal block in the sitting position in patients with femoral neck fracture [Abstract]. 14th World Congress of Anaesiologists (WCA 2008). 2008 Mar 2-7. Cape Town International Convention Center, Cape Town (South Africa). 2008.
19 Peiro CM, Errando CL, Soriano JL, et al. Single shot spinal anaesthesia with low dose hyperbaric bupivacaine (3.75 mg), for hip fracture repair surgery in the elderly. XXVI Annual Congress of the European Society of Regional Anaesthesia and Pain Therapy (ESRA 2007). 2007 Sep 12-15. Valencia, Spain. 2007.
20 Rebelo H, Garcia T, Oliveira R, et al. Postoperative epidural analgesia in femoral neck fracture. Reg Anesth Pain Med. 2010;Conference(var.pagings):E161. October.
21 Scott F, Butler M. Easing the pressure for hip fracture patients. Nurs Times. 1995;91(29):30-31.
22 Shaaban Ali M, Abd El Hakeem E, Askar OA, et al. Pre-incisional versus postoperative 3-in-1 femoral nerve block in patients undergoing surgery for fracture neck of femur [abstract]. Reg Anesth Pain Med. 5 Suppl 1. 2007;32:129.
23 Szucs S, Iohom G. Functional recovery following operative fixation of fractured neck of femur in the elderly. Reg Anesth Pain Med. 2010:E181.
24 Triki Z. Comparison between hypobaric unilateral spinal anaesthesia and conventional spinal anesthesia in elderly patients for hip trauma. Annual Meeting of the European Society of Anaesthesiology on Euroanaesthesia (Euroanaesthesia 2007). 2007 June 9-12. Munich, Germany. 2007.
25 Twiston-Davies CW, Goodwin MI, Baxter PJ. Rectal indomethacin for postoperative pain in orthopaedic surgery: a double-blind study. J Bone Joint Surg Br. 1990;72(3):510-1. [pmid: 1971275].
26 Vaca JM, Aldecoa C, Fernandez A, et al. Block 3 in 1 versus morphine intravenous P.C.A. in postoperative orthopaedic hip surgery pain. Rev Soc Esp Dolor. 1995;2(1):11-4. (Spa).
27 Van Haevre V, Biboulet P, Jourdan A, et al. Comparison of the hemodynamic effects in the aged patient with hip fracture during continuous spinal anesthesia, propofol targed controlled infusion and sevoflurane anesthesia. Acta Anaesthesiol Belg. 2009;60(2):143.
28 Yao CZ, Zhang Z, Diao YC, et al. Surgical repair of the fracture of neck of femur using spinal anesthesia with hypobaric bupivacaine. Chin J Anesthesiol. 1997;17(5):305-7. (Chi).

## Ongoing, Unpublished Trial

1 A new clinical pathway for patients with fractured neck of femur, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00667914.
2 Cameron J. Ultrasound guided three-in-one nerve block for the relief of acute pain from fractured neck of femur: a double-blind, randomised, controlled trial, ACTRN. 2009. Accessed: 2009 Nov 3. Available from: URL: http://www.anzctr.org.au/ACTRN12608000067370.aspx.
3 Continuous spinal anesthesia versus combined spinal epidural block, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00616044.
4 Fascia iliaca compartment blockade as analgesia for hip fractures in the acute phase, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00162630.
5 Gustafson Y. Home rehabilitation for older people with hip fracture: a randomised controlled trial, ISRCTN. 2009. Accessed: 2009 Nov 5. Available from: URL: http://www.controlled-trials.com/ISRCTN15738119/.
6 Improving pain and function in hip fracture, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00749489.
7 Intrathecal Magnesium and Postoperative Analgesia, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00560092.
8 Levens FA. Intra-and post-operative analgesia for patients undergoing surgery for hip fracture: role of fascia illiaca compartment block, ISRCTN. 2009. Accessed: 2009 Nov 10. Available from: URL: http://www.controlled-trials.com/ISRCTN75659782/ISRCTN75659782.
9 Morrison RS. Improving pain and function in hip fracture. CRISP. 2009.
10 Norspan versus oxycontin as postoperative painkiller to proximal extracapsular fractures of the femur, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00964808.
11 Park E. Ultrasound-guided femoral nerve block as a mode of analgesia in patients presenting with a hip fracture to the emergency department, ANZCTR. 2009. Accessed: 2009 Nov 10. Available from: URL: http://www.anzctr.ora.au/AClRN12609000526279.aspx.
12 Postoperative analgesia with local infiltration after hip fracture, Clinicaltrials.gov. 2009. Available from: URL: http://ClinicalTrials.gov/show/NCT00529425.
13 Resnick B. Testing the exercise plus program following hip fracture. CRISP. 2009.
14 TRAUMEEL for pain after fracture of neck of femur, Clinicaltrials.gov. 2009. Accessed: 2009 Nov 3. Available from: URL: http://ClinicalTrials.gov/show/NCT00307905.
15 Winso O. Femoral nerve blockade in hip fracture patients: a randomised controlled trial, ISRCTN. 2009. Accessed: 209 Nov 12. Available from: URL: http://www.controlled-trials.com/ISRCTN46653818/ISRCTN46653818.

## Foreign Language With No Translation Available for Review

1 Asao Y, Kasai SY, Higuchi T, et al. Which anesthetic technique is more suitable for hip fracture surgery in patients above the age of 85, spinal or epidural. Masui. 2005;54(6):638-42. (Jap). [pmid: 15966381].
2 Bendtsen TF, Koscielniak-Nielsen ZJ. Ultralydvejledt perifer nerveblokade. Ugeskr Laeger. 2007;169(12):1096. (Nor). [pmid: 17394807].
3 Biffoli F, Piacentino V, Meconcelli G, et al. The effect of anesthesiologic technique on the mental state of elderly patients submitted for orthopedic surgery of the lower limbs. Minerva Anestesiol. 1998;64(1-2):13-9. (Ita).
4 Gregersen M, Jensen NC, Morch MM, et al. [The effect of geriatric intervention on rehabilitation of elderly patients with hip fracture]. Ugeskr Laeg. 2009;171(46):3336-40. (Dan). [pmid: 19925737].
5 Idland G, Bjercke KA, Ljunggren AE. Pilot project in Ulleval: early rehabilitation of elderly patients with femoral neck fractures. Sykepleien Fag. 1993;81(6):48-51. (Nor).
6 Kamitani K, Higuchi A, Asahi T, et al. Postoperative delirium after general anesthesia vs. spinal anesthesia in geriatric patients. Masui. 2003;52(9):972-5. (Jap). [pmid: 14531256].
7 Kullenberg B, Ysberg B, Heilman M, et al. Femoral nerve block as pain relief in hip fracture: a good alternative in perioperative treatment proved by a prospective study. Lakartidningen. 2004;101(24):2104-7. (Swe). [pmid: 15282985].
8 Nagara M, Uchimura K, Nagara H, et al. Epidural anesthesia for the repair of the femoral neck fracture in elderly patients. Masui. 1995;44(3):419-22. (Jap). [pmid: 7745798].
9 Palm H, Foss NB, Kristensen MT. [Reconvalescence after surgery for proximal femoral fractures]. Ugeskr Laeg. 2009;171(40):2896-9. (Dan). [pmid: 19814935].
10 Rasmussen S, Kristensen BB, Foldager S, et al. Accelerated recovery programme after hip fracture. Ugeskr Laeger. 2003;165(1):29-33. (Dan).
11 Wajima Z, Kurosawa H, Inoue T, et al. Changes in dementia rating scale scores of elderly patients with femoral neck fracture during perioperative period. Masui. 1995;44(11):1489-97. (Jap). [pmid: 8544286].

## Unavailable for Review Through Library Services

1 Ali AM, Tahoun HM, Ahmed AA, et al. Comparative study between the analgesic efficacies of nerve stimulator-guided 3-in-1 block, ultrasonographic-guided 3-in-1 block and posterior approach lumbar plexus block following total hip arthroplasty. Egypt J Anaesth. 2003;19(1):39-44.
2 Berlin JE. Physical activity during rehabilitation and functional outcomes after rehabilitation in patients with hip fractures. Combined Sections Meeting of the Specialty Sections of the American Physical Therapy Association (CSM 2006). San Diego Convention Center, San Diego, California (USA). 1-5 Feb 2006. 2006.
3 Bonilla CÃ, Nieto E. Fracturas pertrocantéricas del extremo proximal del fémur en pacientes mayores de 60 anos: evaluación de dos métodos terapéuticos anos 1998-2003. Rev venez cir ortop traumatol. 2008;40(1):5-11. (Spa).
4 Chen FS, Rosen JE, Hiebert R, Koval KJ, et al. The efficacy of preoperative skin traction after hip fractures: a prospective randomized study. 2009.
5 Derossi D, Bo A, Bergonzi R, et al. Six-week administration of a mixture of ergogenic and osteotrophic ingredients (Restorfast) improves the clinical course of elderly patients after hip fracture surgery. [Italian]. Trends in Medicine. 2009;9(4):235-42.
6 Draper P, Scott F. Report of a project to evaluate the use of Hamilton Russell traction in the pre-operative management of patients with hip fracture [abstract]. J Orthop Nurs. 1997;2(1):56-57.
7 Farkas G. Utilization of inpatient care rehabilitation in patients with hip fracture. 7th European Trauma Congress, Cankarjev dom, Cultural and Congress Centre. 2006 14-17 May. Ljubljana, Slovenia. 2006.
8 Frondini C, Lunardelli ML. Comprehensive care of elderly patients with hip fracture: the orthogeriatric model. Ital J Med. 2010;4(2):105-10.
9 Hadzic A. Lower extremity peripheral nerve blocks: an update. Lijec Vjesn. SUPPL. 2. 2005;127:52-60.
10 Johansen A. Optimising hip fracture aftercare. Care Elderly. 1995;7(3):8.
11 Othman MM, Hasheesh MA, Attia AA. Optimal sedation of propofol versus midazolam in geriatrics during regional anaesthesia for hip orthopedic surgery. Benha Med J. 2000:171-88.
12 Scivoletto G, Bo A, Derossi D, et al. Ten week administration of a polynutritional supplement with muscle tone action (Riabylex) improves the functional recovery in elderly hip fracture patients during home rehabilitation. [Italian]. Trends in Medicine. 2010;10(2):113-20.
13 Thiagarajah S, Samad S, Maguire P, et al. Anaesthetic vs. operative time in patients undergoing femoral neck fracture fixation. First Joint Congress of the European Association for Trauma and Emergency Surgery and the European Trauma Society. 2007 May 23-26. Graz, Austria. 2007.
14 Xu ZH, Tang S, Luo AL, et al. [Application of lumber plexus blockade for hip fracture repair in elderly patients]. [Chinese]. Chung-Kuo i Hsueh Ko Hsueh Yuan Hsueh Pao Acta Academiae Medicinae Sinicae. 2010;32(3):328-31.