# Sample Data Extraction and Quality Assessment Form

Comparative Effectiveness of Pain Management Interventions for Hip Fracture

NEWCASTLE - OTTAWA QUALITY ASSESSMENT SCALE CASE CONTROL STUDIES

Note: A study can be awarded a maximum of one star for each numbered item within the Selection and Exposure categories. A maximum of two stars can be given for Comparability.

NEWCASTLE - OTTAWA QUALITY ASSESSMENT SCALE COHORT STUDIES

Note: A study can be awarded a maximum of one star for each numbered item within the Selection and Outcome categories. A maximum of two stars can be given for Comparability

RISK OF BIAS (ROB) RANDOMIZED CONTROLLED TRIALS