# Exact Search Strings

Table B-1 MEDLINE^®^—Ovid version

OvidSP_UI02.01.02.102 1950 to July Week 1 2009 | Searched: 09Jul09 Results: 1061
1. exp Pain/ 2. exp "anesthesia and analgesia"/or exp analgesia/ 3. ((an?esthet$ or an?esthesia) adj4 (regional$ or local$ or general or spinal or epidural)).mp. 4. (block or analges*).mp. 5. or/2-4 6. exp Therapeutics/or exp "Outcome Assessment (Health Care)"/or exp "Length of Stay"/or "Quality of Life"/or "functional outcome".ti,ab. 7. ((pain* or discomfort* or ache* or aching or sore* or suffer*) adj3 (assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life")).mp. 8. exp Pain/rt, th, us, rh, dh, su, pc, dt 9. pain postoperative/pc, th 10. Pain Measurement/ 11. or/7-10 12. exp Hip Fractures/rh, nu, th, dt, dh 13. exp Hip Fractures/ | 14. ((intertrochanter* or petrochanter* or subtrochanter* or extracapsular or petrochant* or trochant* or hip or femoral neck) adj4 (hemiarthroplasty or fracture*)).mp. 15. ("neck of femur" adj4 fractur*).mp. 16. or/13-15 17. 5 and 16 18. 11 and 16 19. 1 and 16 20. 6 and 12 21. or/17-20 22. exp Arthroplasty, Replacement, Hip/ 23. THA.mp. 24. total hip*.mp. 25. or/22-24 26. 21 not 25 27. (pediatric* or child or children* or adolesc* or young or youth* or pregnan*).ti,ab,jw,kw,sh. 28. animals/or exp neoplasms/or case reports/or editorials/or exp Emergency Service, Hospital/ 29. or/27-28 30. 26 not 29 31. limit 30 to yr="1990 - 2009"

Table B-2 AMED (Allied and Complementary Medicine), Global Health and International Pharmaceutical Abstracts (IPAB)—Ovid version

OvidSP_UI02.01.02.102 | | Searched: 10Jul09
Database | Dates Available | Results
AMED | 1985 to July 2009 | 340
Global Health | 1910 to June 2009 | 157
IPAB | 1970 to June 2009 | 95
1. exp Pain/ 2. exp "anesthesia and analgesia"/or exp "Nerve Block"/or exp "anesthesiological techniques"/or exp "analgesic, antiinflammatory, antirheumatic and antigout agents"/or exp "agents interacting with transmitter, hormone or drug receptors"/ 3. (block or analges*).mp. 4. (Therapy or therapeutics or "disease management" or "quality of life" or treatment or "outcome assessment" or "length of stay" or "functional outcome" or rehabilitation or traction or acupunct* or acupress* or stimulation or "continuous passive motion").ti,cw,cc,bt,id,hw,sh. 5. exp Pain Assessment/or exp Pain Measurement/ 6. ((pain* or discomfort* or ache* or aching or sore* or suffer*) adj3 (assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life")).mp. 7. or/1-6 | | 8. "fracture, hip"/or hip fracture/or hip fractures/or acetabulum fracture/or femur intertrochanteric fracture/or femur neck fracture/or femur pertrochanteric fracture/or exp femur subtrochanteric fracture/or femur trochanteric fracture/ 9. ((intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or femoral neck or “neck of femur”) adj4 fracture*).mp. 10. ("neck of femur" adj4 fractur*).mp. 11. or/8-10 12. 7 and 11 13. (THA or total hip*).mp. or exp "Arthroplasty, Replacement, Hip"/ 14. (neoplasm* or cancer* or carcinoma* or lymphoma or sarcoma* or Emergency).ti,de,cw,cc,bt,id,hw,sh. 15. case report.ti,de,cw,cc,bt,id,hw,sh. 16. (pediatric* or child or children* or adolesc* or young or youth* or pregnan*).ti,ab,hw,de,cw,cc,tt,ed,sh. 17. or/13-16 18. 12 not 17 19. limit 18 to yr="1990 -Current" 20. remove duplicates from 19

Table B-3 BIOSIS previews—Institute for Scientific Information—Thomson Reuters

1926 to 2009 Searched: 14Jul09 | Results: 206
# 3 #2 AND #1 Databases=PREVIEWS Timespan=1990-2009 # 2 TS=(intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") SAME TS=(fracture*) AND Taxa Notes=(Humans) # 1 TS=(pain* or discomfort* or ache* or aching or sore* or suffer*) SAME TS=(assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life") AND Taxa Notes=(Humans)

Table B-4 CINAHL (Cumulative Index to Nursing & Allied Health Literature), Academic Search Complete, Health Source: nursing/academic edition—Ebsco version

1937 to 2009 (CINAHL) 1985 to 2009 (Academic Search Elite) Searched: 13Jul09 | Results: 189
S11 S10 and S3 S10 (S9 or S8 or S7 or S6 or S5 or S4) S9 ( safe or safety ) or ( adverse w1 effect* or adverse w1 event* or "side effect*" ) or ( harm* or contraindicat* or contra-indicat* ) S8 ( cohort or observation* or control* or prospectiv* or volunteer* or "case-series" or "time-series" or "case-comparison" or "case-referent" or "cross-sectional" or risk* or efficacy ) S7 ( singl* w10 blind* or singl* w10 mask* or doubl* w10 blind* or doubl* w10 mask* or trebl* w10 blind* or trebl* w10 mask* or cross-over or placebo* or control* or random* or factorial or sham* or clin* w10 trial* intervention* w10 trial* or compar* w10 trial* or experiment* w10 trial* or preventive w10 trial* or therapeutic w10 trial* ) S6 ( clin* w25 trial* or random* ) S5 PT clinical trial S4 ( (MH "Random Assignment") or (MH "Random Sample") or (MH "Crossover Design") or (MH "Clinical Trials+") or (MH "Double-Blind Studies") or (MH "Single-Blind Studies") or (MH "Comparative Studies") or (MH "Control Group") or (MH "Factorial Design") or (MH "Quasi-Experimental Studies") or (MH "Experimental Studies") or (MH "One-Shot Case Study") or (MH "Study Design") or (MH "Placebos") or (MH "Clinical Nursing Research") or (MH "Clinical Research") or (MH "Community Trials") or (MH "Pretest-Postt ... S3 S2 not S1 Limiters - Exclude MEDLINE records S2 (MH "Hip Fractures") and ( pain* or "drug therapy" or pharmacological OR "quality of life" OR acupunct* OR accupress* OR traction OR "electrical stimulation" OR "passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges* ) Limiters - Exclude MEDLINE records S1 TI ( neoplasm* or cancer* or carcinoma* or lymphoma or sarcoma* or "total hip" or "THA" or arthroplasty or replacement ) or TI case report* or TI ( pediatric* or child or children* or adolesc* or young or youth* or pregnan* ) Limiters - Exclude MEDLINE records

Table B-5 Cochrane Complementary Medicine Trials Register and CAMPAIN (Complementary and Alternative Medicine and Pain Database) grant number R24-AT001293 from the National Center for Complementary and Alternative Medicine (NCCAM)

Searched: 23Jul09 | | Results: 263
ID | Search
#1 | (SR-SYMPT)
#2 | (hip OR "neck of femur" or "femoral neck" or extracapsular or intracapsular or intertrochanter* or petrochanter* or petrochant* or trochant*):ti,ab,kw
#3 | (#1 AND #2)
#4 | "total hip arthroplasty" OR replacement:ti
#5 | (osteoarthr* OR cancer* or knee or carcinoma or sarcoma):ti
#6 | MeSH descriptor Arthroplasty, Replacement, Hip explode all trees
#7 | (child* or pediatric):ti,ab,kw
#8 | (#4 OR #5 OR #6 OR #7)
#9 | (#3 AND NOT #8)

Table B-6 Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects—Wiley version

OvidSP_UI02.01.02.102 3rd Quarter 2009 | Searched: 27Jul09 Results: 36
#1 (hip OR "neck of femur" or "femoral neck" or extracapsular or intracapsular or intertrochanter* or petrochanter* or petrochant* or trochant*):ti,ab,kw #2 (osteoarthr* OR cancer* or knee or carcinoma or sarcoma or "total hip arthroplasty" OR replacement):ti #3 MeSH descriptor Arthroplasty, Replacement, Hip explode all trees #4 (child* or pediatric):ti,ab,kw #5 (#2 OR #3 OR #4) #6 ((an?esthet$ or an?esthesia) near/4 (regional$ or local$ or general or spinal or epidural)) in Cochrane Reviews and Other Reviews #7 (block or analges*) in Cochrane Reviews and Other Reviews #8 (pain* or discomfort* or ache* or aching or suffer*) NEAR/3 (assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life") in Cochrane Reviews and Other Reviews #9 (#6 OR #7 OR #8) #10 (#1 AND #8) #11 (#10 AND NOT #5)

Table B-7 EBM reviews—Cochrane Central Register of Controlled Trials—Ovid version

OvidSP_UI02.01.02.102 2nd Quarter 2009 | Searched: 09Jul09 Results: 263
1. exp Pain/ 2. exp Postoperative pain/ 3. exp "anesthesia and analgesia"/or exp "Nerve Block"/or exp "anesthesiological techniques"/or exp "analgesic, antiinflammatory, antirheumatic and antigout agents"/or exp "agents interacting with transmitter, hormone or drug receptors"/ 4. (block or analges*).mp. 5. exp Therapy/or exp therapeutics/or disease management/or exp "quality of life"/or exp treatment outcome/or exp "outcome assessment"/or "length of stay"/or "functional outcome".ti,ab. 6. exp Pain Assessment/or exp Pain Measurement/ 7. ((pain* or discomfort* or ache* or aching or sore* or suffer*) adj3 (assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life")).mp. 8. or/1-7 | 9. exp hip fracture/or exp hip fractures/or exp acetabulum fracture/or exp femur intertrochanteric fracture/or exp femur neck fracture/or exp femur pertrochanteric fracture/or exp femur subtrochanteric fracture/or exp femur trochanteric fracture/ 10. ((intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or femoral neck) adj4 fracture*).mp. 11. ("neck of femur" adj4 fractur*).mp. 12. or/9-11 13. 8 and 12 14. (THA or total hip*).mp. or exp "Arthroplasty, Replacement, Hip"/ 15. exp neoplasms/or exp Emergency Service, Hospital/ 16. (pediatric* or child or children* or adolesc* or young or youth* or pregnan*).ti,ab,hw,jn. 17. or/14-16 18. 13 not 17 19. limit 18 to yr="1990 -Current"

Table B-8 EMBASE—Ovid version

OvidSP_UI02.01.02.102 1980 to 2009 Week 28 | Searched: 10Jul09 Results: 1179
1. exp Pain/ 2. exp Postoperative pain/ 3. (pain* or discomfort* or ache* or aching or sore* or suffer*).mp. 4. or/1-3 5. exp "Nerve Block"/or exp "anesthesiological techniques"/or exp "analgesic, antiinflammatory, antirheumatic and antigout agents"/or exp "agents interacting with transmitter, hormone or drug receptors"/ 6. (block or analges*).mp. 7. exp Therapy/or disease management/or exp "quality of life"/or exp treatment outcome/or exp outcome assessment/or "length of stay"/or "functional outcome".ti,ab. 8. or/5-7 9. 4 and 8 10. exp Pain/dt, rh, pc, th, dm, rt, su, dr 11. exp Pain Assessment/ 12. ((pain* or discomfort* or ache* or aching or sore* or suffer*) adj3 (assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life")).mp. 13. or/10-12 14. 9 or 13 15. exp hip fracture/dm, th, rh, dt 16. exp femur neck fracture/dm, th, rh, dt 17. or/15-16 | 18. exp hip fracture/or exp acetabulum fracture/or exp femur intertrochanteric fracture/or exp femur neck fracture/or exp femur pertrochanteric fracture/or exp femur subtrochanteric fracture/or exp femur trochanteric fracture/ 19. ((intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or femoral neck) adj4 fracture*).mp. 20. ("neck of femur" adj4 fractur*).mp. 21. or/18-20 22. 14 and 21 23. (4 or 8) and 17 24. or/22-23 25. exp "Total Hip Prosthesis"/ 26. THA.mp. 27. total hip*.mp. 28. or/25-27 29. 24 not 28 30. limit 29 to (embryo or infant or child or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) 31. (pediatric* or child or children* or adolesc* or young or youth* or pregnan*).ti,ab,hw,jx. 32. "nonhuman"/or exp neoplasm/or cancer.hw. or case report/or emergency.af. 33. 29 not (30 or 31 or 32) 34. limit 33 to yr="1990 - 2009" 35. limit 34 to (article or conference paper or proceeding or report or "review")

Table B-9 Global Health Library—World Health Organization

Searched: 28Jul09 | Results: 110
(hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") AND fractur* AND (pain* or heal or healing or therap* or recover* or "quality of life" or rehabilitat* or "drug therapy" or pharmacological OR acupunct* OR acupress* OR traction OR "electrical stimulation" OR "passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges*) AND NOT (child* or adolesc* or young or youth or pediatric* or cancer* or replace* or "total hip arthroplasty" or nail or screw or "case reports" or osteoporosis)

Table B-10 Pascal—Ovid version

OvidSP_UI02.01.02.102 1987 to Jan Week 4 2010 | Searched: 03Feb10 Results: 169
1. exp Pain/ 2. exp "anesthesia and analgesia"/or exp "Nerve Block"/or exp "anesthesiological techniques"/or exp "analgesic, antiinflammatory, antirheumatic and antigout agents"/or exp "agents interacting with transmitter, hormone or drug receptors"/ 3. (block or analges*).mp. 4. exp Pain Assessment/or exp Pain Measurement/ 5. ((pain* or discomfort* or ache* or aching or sore* or suffer*) adj3 (assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life")).mp. 6. or/1-5 7. "fracture, hip"/or hip fracture/or hip fractures/or acetabulum fracture/or femur intertrochanteric fracture/or femur neck fracture/or femur pertrochanteric fracture/or exp femur subtrochanteric fracture/or femur trochanteric fracture/ | 8. ((intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or femoral neck) adj4 fracture*).mp. 9. ("neck of femur" adj4 fractur*).mp. 10. or/7-9 11. 6 and 10 12. (THA or total hip*).mp. or exp "Arthroplasty, Replacement, Hip"/ 13. (neoplasm* or cancer* or carcinoma* or lymphoma or sarcoma* or Emergency).ti,de,cw,cc,bt,id,hw,sh. 14. case report.ti,de,cw,cc,bt,id,hw,sh. 15. (pediatric* or child or children* or adolesc* or young or youth* or pregnan*).ti,ab,hw,de,cw,cc,tt,ed,sh. 16. or/12-15 17. 11 not 16 18. limit 17 to yr="1990 -Current" 19. remove duplicates from 18

Table B-11 PEDro—The Physiotherapy Evidence Database

1929 to 2009 Searched: 14Jul09 | Results: 256 of which 33 were selected
Problem: pain Body part: thigh or hip Published since 1990

Table B-12 ProQuest dissertations and theses—full text

1637 to 2009 Searched: 24Jul09 | Results: 43
(hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") AND (fracture*) AND (pain* or "quality of life" or traction or "physical therapy" or acupunct* OR acupress* OR traction OR "electrical stimulation") AND NOT (child* or adolesc* or young or youth or pediatric* or cancer* or replace* or "total hip arthroplasty") Look for terms in: Citation and abstract; Publication type: All publication types (hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") AND (fracture*) AND ("passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges*) AND NOT (child* or adolesc* or young or youth or pediatric* or cancer* or replace* or "total hip arthroplasty") Look for terms in: Citation and abstract; Publication type: All publication types

Table B-13 Scopus—Elsevier B.V.

1990 to July 2009 | Searched: 13Jul09 Results: 900
(((((TITLE(pain*) OR KEY(pain*)) AND SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci) AND PUBYEAR AFT 1989) AND ((TITLE-ABS-KEY(assess* OR relief OR reliev* OR reduc* OR treat* OR manage* OR control* OR experience* OR medicat* OR duration OR evaluat* OR alleviat* OR level OR score* OR subjective OR felt OR prevent* OR duration OR outcome* OR heal OR healing OR therap* OR recover*) OR TITLE-ABS-KEY("quality of life" OR acupunct* OR accupress* OR traction OR "electrical stimulation" OR "passive motion")) AND SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci) AND PUBYEAR AFT 1989)) AND NOT ((TITLE-ABS-KEY("total hip replacement" OR "total hip arthroplasty" OR "THA") OR TITLE-ABS-KEY(cancer* OR carcinoma* OR neoplasm* OR pediatric* OR children* OR adolesc* OR "case report")) AND SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci) AND PUBYEAR AFT 1989)) AND (TITLE-ABS-KEY((hip* OR femur* OR femoral* OR trochant* OR pertrochant* OR intertrochant* OR subtrochant* OR intracapsular* OR extracapsular*) AND fractur*) AND SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci) AND PUBYEAR AFT 1989)) AND NOT (TITLE(diagnos* OR predictive OR accurac* OR specificity OR probability OR likelihood OR screen* OR test* OR "risk factors")) AND (EXCLUDE(DOCTYPE, "no") OR EXCLUDE(DOCTYPE, "sh") OR EXCLUDE(DOCTYPE, "ed")) AND (EXCLUDE(SUBJAREA, "BIOC") OR EXCLUDE(SUBJAREA, "VETE") OR EXCLUDE(SUBJAREA, "ENGI") OR EXCLUDE(SUBJAREA, "DENT") OR EXCLUDE(SUBJAREA, "CENG") OR EXCLUDE(SUBJAREA, "ENVI") OR EXCLUDE(SUBJAREA, "ECON") OR EXCLUDE(SUBJAREA, "COMP") OR EXCLUDE(SUBJAREA,

Table B-14 Web of Science—Institute for Scientific Information—Thomson Reuters

1900 to 2009 Searched: 14Jul09 | Results: 596
# 4 #2 AND #1 Refined by: [excluding] Subject Areas=( PEDIATRICS OR VETERINARY SCIENCES ) Databases=SCI-EXPANDED, SSCI Timespan=1990-2009 # 3 #2 AND #1 # 2 TS=(intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") SAME TS=(fracture*) # 1 TS=(pain* or discomfort* or ache* or aching or sore* or suffer*) SAME TS=(assess* or relief or reliev* or reduc* or treat* or manage* or control* or experience* or medicat* or duration or evaluat* or alleviat* or level or score* or subjective or felt or prevent* or duration or outcome* or heal or healing or therap* or recover* or "quality of life")

Table B-15 TOXLINE—ProQuest

1998 to 2009 Searched: 29Jul09 | Results: 74
(TI=(hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or "femoral neck") or DE=(hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or "femoral neck") or AB=(hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or "femoral neck")) and DE=fractur* and (DE=(pain* or heal or healing or therap* or recover* or "quality of life" or rehabilitat* or "drug therapy" or pharmacological OR acupunct* OR acupress* OR traction OR "electrical stimulation" OR "passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges*) or AB=(pain* or heal or healing or therap* or recover* or "quality of life" or rehabilitat* or "drug therapy" or pharmacological OR acupunct* OR acupress* OR traction OR "electrical stimulation" OR "passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges*) or TI=(pain* or heal or healing or therap* or recover* or "quality of life" or rehabilitat* or "drug therapy" or pharmacological OR acupunct* OR acupress* OR traction OR "electrical stimulation" OR "passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges*)) not (DE=(child* or adolesc* or young or youth or pediatric* or cancer* or neoplasm* or carcinoma or anemia or alendronate or replace* or osteoporosis or "total hip arthroplasty" or "hip fractures: prevention control" or "hip fractures: epidemiology" OR"Hip Fractures: chemically induced”))

## Conference Proceedings

Table B-16 Conference papers index—ProQuest

1982 to 2009 Searched: 24Jul09 | Results: 97
TI=(hip or intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") and DE=(pain* or heal or healing or therap* or recover* or "quality of life" or rehabilitat* or "drug therapy" or pharmacological OR acupunct* OR acupress* OR traction OR "electrical stimulation" OR "passive motion" or morphine OR acetaminophen or paracetamol or tylenol or anesth* or analges* ) not TI=(child* or adolesc* or young or youth or pediatric* or cancer* or replace* or "total hip arthroplasty") Limits: 1990-2009

Table B-17 OCLC papers first—OCLC FirstSearch

Searched: 24Jul09 | Results: 12
((((ti: hip or ti: intertrochanter* or ti: petrochanter* or ti: subtrochanter* or ti: intracapsular or ti: extracapsular or ti: petrochant* or ti: trochant* or ti: hip or ti: femoral w neck)) and kw: pain*) and (kw: heal or kw: healing or kw: therap* or kw: recover* or kw: quality w1 life or kw: rehabilitat* or kw: drug w therapy or kw: pharmacological OR kw: acupunct* OR kw: acupress* OR kw: traction OR kw: electrical w stimulation OR kw: passive w motion or kw: morphine OR kw: acetaminophen or kw: paracetamol or kw: tylenol or kw: anesth* or kw: analges*) and yr: 1990-2009) not (ti: replacement or ti: total w hip) and yr: 1990-2009

Table B-18 ScienceDirect tables of contents

Searched: 28Jul09 | Results: 24
Regional Anesthesia and Pain Medicine Pain Management Nursing Acute Pain European Journal of Pain Journal of Pain and Symptom Management Techniques in Regional Anesthesia and Pain Management Anesthesiology Clinics Pain Searched tables of contents using the strategy below for the journals listed above: pub-date > 1989 and TITLE-ABSTR-KEY((intertrochanter* or petrochanter* or subtrochanter* or intracapsular or extracapsular or petrochant* or trochant* or hip or "femoral neck") AND fractur*) and SRCTITLEPLUS(pain)

Table B-19 Conference proceedings hand searched

Searched: 28Jul09
American Geriatric Society (AGS) | 2005-2009
American Physical Therapy Association (APTA) | 2005-2009
American Society of Regional Anesthesia and Pain Medicine (ASRA) | 2007-2009
European Society of Regional Anesthesia (ESRA) | 2005-2009
European Society of Anesthesiology (ESA) | 2008-2009
International Anesthesia Research Society (IARS) | 2005-2009

## Trials Registers

Table B-20 ClinicalStudyResults.org

Searched: 03Sep09 | Results: 0
Searched by Indication Word hip fracture | Searched by Study Indication/Disease: Hip Fracture Recovery; Pain, Postoperative; Pain, Postsurgical

Table B-21 ClinicalTrials.Gov—National Institutes of Health

Searched: 27Jul09 | Results: 33
Pain* AND ( hip OR intertrochanter* OR petrochanter* OR subtrochanter* OR intracapsular OR extracapsular OR petrochant* OR trochant* OR femoral neck ) AND fracture*

Table B-22 Current controlled trials—Biomed Central

Excluding Leukaemia Research Fund and ClinicalTrials.gov

Searched: 03Sep09 | Results: 17
Pain* AND (hip OR intertrochanter* OR petrochanter* OR subtrochanter* OR intracapsular OR extracapsular OR petrochant* OR trochant* OR femoral neck) AND fracture*

Table B-23 ICTRP search portal – World Health Organization

Searched: 03Sep09 | Results: 199
(hip OR intertrochanter* OR petrochanter* OR subtrochanter* OR intracapsular OR extracapsular OR petrochant* OR trochant* OR femoral neck) AND fracture* ALL studies (not restricted to Recruiting)

Table B-24 IFPMA clinical trials portal—International Federation of Pharmaceutical Manufacturers & Associations

Searched: 04Sep09 | Results: 37
(hip OR intertrochanter* OR petrochanter* OR subtrochanter* OR intracapsular OR extracapsular OR petrochant* OR trochant* OR femoral neck) AND fracture*

Table B-25 UMIN-CTR Clinical Trials—University Hospital Medical Information Network

Searched: 04Sep09 | Results: 7
“hip fracture” “femoral neck”