# Technical Expert Panel and Peer Reviewers

Technical Expert Panel

In designing the study questions and methodology, the UAEPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Due to these differences in opinion, the study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Technical Expert | Affiliations/Location
Paul M. Arnstein, R.N., Ph.D, A.P.R.N.-B.C. | Massacheusetts General Hospital Boston, MA
Mohit Bhandari, M.D. | McMaster University Hamilton, ON
Cary A. Brown, Ph.D. | University of Alberta and Glenrose Hospital Edmonton, AB
Jeffrey Fudin, B.S., Pharm.D. D.A.A.P.M., Diplomate, A.A.P.M. | Albany College of Pharmacy & Health Sciences Albany, NY
Jay Magaziner, M.D. | University of Maryland Medical Center Baltimore, MD
Kathleen K. Mangione, P.T., Ph.D. | Arcadia University Glenside, PA
R. Sean Morrison, M.D. | Mount Sinai School of Medicine New York, NY
Richard Rosenquist, M.D. | Anesthesia Pain Clinic Iowa City, IA

Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the University of Alberta Evidence-based Practice Center in preparation of the final report. The synthesis presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewer | Affiliations/Location
Paul M. Arnstein, R.N., Ph.D, A.P.R.N.-B.C. | Massacheusetts General Hospital Boston, MA
Jeffrey Fudin, B.S., Pharm.D. D.A.A.P.M., Diplomate, A.A.P.M. | Albany College of Pharmacy & Health Sciences Albany, NY
Jay Magaziner, M.D. | University of Maryland Medical Center Baltimore, MD
Kathleen K Mangione, P.T., Ph.D. | Arcadia University Glenside, PA
John C. Rowlingson, M.D. | University of Virginia Health System Charlottesville, VA
Shelly L. Gray, Pharm.D., M.S. | University of Washington Seattle, WA
Kenneth J. Koval, M.D. | Dartmouth-Hitchcock Medical Center Lebanon, NH
Ian Cameron, M.D. | University of Sydney Sydney, Australia
Roger Chou, M.D. | Oregon Health & Science University Portland, OR
Richard Rosenquist, M.D. | Anesthesia Pain Clinic Iowa City, IA