# Appendixes

Appendix A Technical Expert Panel and Peer Reviewers

Appendix B Exact Search Strings

Appendix C Sample Data Extraction and Quality Assessment Form

Appendix D Excluded Studies

Appendix E Description of Included Studies

Appendix F Characteristics of Interventions

Appendix G Risk of Bias Assessment for Randomized Controlled Trials and Nonrandomized Controlled Trials

Appendix H Summary Risk of Bias Assessments

Appendix I Newcastle-Ottawa Scale Assessment of Cohort Studies

Appendix J GRADE Tables: Assessing the Strength of Evidence