# Acronyms and Abbreviations

AE: adverse effect
AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CAM: complementary and alternative medicine
CI: confidence intervals
COX-2: Cyclooxygenase-2
EPC: Evidence-based Practice Center
GI: gastrointestinal
GRADE: Grading of Recommendation Assessment, Development and Evaluation
HRQOL: health-related quality of life
IM: intramuscular
IQR: interquartile range
IV: intravenous
KQ: Key Question
LOS: length of stay
MD: mean difference
mg: milligrams
MMSE: mini-mental state examination
MI: myocardial infarction
NB: nerve block
NS: neurostimulation
NOS: Newcastle-Ottawa Scale
NSAIDS: nonsteroidal anti-inflammatory drugs
nRCT: nonrandomized controlled trial
NA: not applicable
NE: not estimable
NR: not reported
NRS: numeric rating score
PICOTS: Population, Intervention, Comparison, Outcome, Timing, and Setting
RCT: randomized controlled trial
RoB: risk of bias
SRC: Scientific Resource Center
SD: standard deviation
SMD: standardized mean difference
TENS: transcutaneous electrical neurostimulation
US: ultrasound
UAEPC: University of Alberta Evidence-based Practice Center
VAS: visual analog scale