# Acknowledgments

We are grateful to members of the technical expert panel, Dr. Paul Arnstein (Massacheusetts General Hospital, MA), Dr. Mohit Bhandari (McMaster University, ON), Dr. Cary Brown (University of Alberta and Glenrose Hospital, AB), Dr. Jeffrey Fudin (Albany College of Pharmacy & Health Sciences, NY), Dr. Jay Magaziner (University of Maryland Medical Center, MD), Dr. Kathleen Mangione (Arcadia University, PA), Dr. R. Sean Morrison (Mount Sinai School of Medicine, NY), and Dr. Richard Rosenquist (Anesthesia Pain Clinic, IA) who provided direction for the scope and content of the review.

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Annabritt Chisholm (article retrieval), Ms. Teodora Radisic (article retrieval), Mr. Ben Vandermeer (data analysis), Ms. Andrea Milne (literature searching), Ms. Amy Beaith (literature searching), Ms. Carol Spooner (data verification), Dr. Lisa Hartling (French translation), Ms. Jennifer Seida (German translation), Dr. Susan Armijo-Olivo (Spanish translation), and Dr. Liliane Zorzela (Portuguese, Spanish translation).