# Cited References and Included Studies

Abels RI. Use of recombinant human erythropoietin in the treatment of anemia in patients who have cancer. Semin Oncol. 1992;19(3 Suppl 8):29-35.
Acs G, Zhang PJ, Rebbeck TR, et al. Immunohistochemical expression of erythropoietin and erythropoietin receptor in breast carcinoma. Cancer. 2002;95:969-981. [pmid: 12209679].
Akaike H. Fitting autoregressive models for prediction. Ann Inst Statist Math. 1969;21(2):243-7.
Alcalay A, Wun T, Khatri V, et al. Venous thromboembolism in patients with colorectal cancer: incidence and effect on survival. J Clin Oncol. 2006;24(7):1112-8. [pmid: 16505431].
Alexopoulos CG, Kotsori AA. A randomized comparison of rHuEPO with darbepoetin for cancer related anemia. Ann Oncol. 2004;15(Suppl 3). Abstract.
Altman DG. Systematic reviews of evaluations of prognostic variables. Egger M, Smith GD, Altman DG, editors. Systematic Reviews in Health Care - Meta-Analysis in Context. London. BMJ Publishing Group. 2001:228-247.
Altman DG, Royston P. What do we mean by validating a prognostic model?. Stat Med. 2000;19:453-473. [pmid: 10694730].
Amgen, Inc. Aranesp® (darbepoetin alfa) prescribing information. Thousand Oaks, CA. Issue date: March 24, 2006. Available online at http://www.aranesp.com/pdf/aranesp_PI.pdf. Last accessed April 2006.
Amgen, Inc. Epogen® (epoetin alfa) prescribing information. Thousand Oaks, CA. Issue date: October 26, 2005. Available online at http://www.epogen.com/pdf/epogen_pi.pdf. Last accessed March 2006.
Aravantinos G, Linardou H, Makridaki D, et al. Recombinant human erythropoietin for platinum-based chemotherapy-induced anaemia: A single-centre randomised study. J BUON. 2003;8(2):127-32. [pmid: 17472238].
Aronson N, Seidenfeld J, Piper MA, et al. Use of erythropoietin in oncology. Evidence report/technology assessment No 30. Prepared by the Blue Cross and Blue Shield Association Evidence-based Practice Center under Contract No 290-97-0015. AHRQ Publication No 01-E009. Rockville (MD). Agency for Healthcare Research and Quality. June. 2001.
Bamias A, Aravantinos G, Kalofonos C, et al. Prevention of anemia in patients with solid tumors receiving platinum-based chemotherapy by recombinant human erythropoietin (rHuEpo): A prospective, open label, randomized trial by the Hellenic Cooperative Oncology Group. Oncology. 2003;64(2):102-10. [pmid: 12566906].
Besarab A, Bolton WK, Browne JK, et al. The effects of normal as compared with low hematocrit values in patients with cardiac disease who are receiving hemodialysis and epoetin. N Engl J Med. 1998;339(9):584-90. [pmid: 9718377].
Bircan A, Berktas B, Bayiz H, et al. Effects of chemotherapy on quality of life for patients with lung cancer. Turkish Respiratory Journal. 2003;4:61-66.
Blajchman MA, Hebert PC. Red blood cell transfusion strategies. Transfus Clin Biol. 2001;8(3):207-10. [pmid: 11499959].
Bohlius J, Langensiepen S, Schwarzer G, et al. Erythropoietin for patients with malignant disease. Cochrane Database Syst Rev. 2004;(3):CD003407.
Bohlius J, Langensiepen S, Schwarzer G, et al. Recombinant human erythropoietin and overall survival in cancer patients: results of a comprehensive meta-analysis. J Natl Cancer Inst. 2005;97(7):489-98. [pmid: 15812074].
Bokemeyer C, Aapro MS, Courdi A, et al. EORTC guidelines for the use of erythropoietic proteins in anaemic patients with cancer. Eur J Cancer. 2004;40(15):2201-16. [pmid: 15454245].
Bokemeyer C, Oechsle K, Hartmann JT, et al. Treatment-induced anaemia and its potential clinical impact in patients receiving sequential high dose chemotherapy for metastatic testicular cancer. Br J Cancer. 2002;87:1066-1071. [pmid: 12402143].
Boogaerts M, Coiffier B, Kainz C. Epoetin Beta QOL Working Group. Impact of epoetin beta on quality of life in patients with malignant disease. Br J Cancer. 2003;88(7):988-95. [pmid: 12671693].
Boracchi P, Biganzoli E. Markers of prognosis and response to treatment: ready for clinical use in oncology? A biostatistician’s viewpoint. Int J Biol Markers. 2003;18(1):65-9. [pmid: 12699067].
Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: The STARD Initiative. Ann Intern Med. 2003;138:40-44. [pmid: 12513043].
Busch MP, Kleinman SH, Nemo GJ. Current and emerging infectious risks of blood transfusions. JAMA. 2003;289(8):959-62. [pmid: 12597733].
Canon JL, Vansteenkiste J, Bodoky G, et al. Randomized, double-blind, active-controlled trial of every-3-week darbepoetin alfa for the treatment of chemotherapy-induced anemia. J Natl Cancer Inst. 2006;98(4):273-84. [pmid: 16478746].
Carabantes FJ, Benavides M, Trujillo R, et al. Epoetin alfa in the prevention of anemia in cancer patients undergoing platinum-based chemotherapy (CT). A prospective randomized study. Proc Am Soc Clin Oncol. 1999;18:596a. Abstract 2303.
Caro JJ, Salas M, Ward A, et al. Anemia as an independent prognostic factor for survival in patients with cancer: a systemic, quantitative review. Cancer. 2002;91(12):2214-21.
Cascinu S, Fedeli A, Del Ferro E, et al. Recombinant human erythropoietin treatment in cisplatin-associated anemia: a randomized, double-blind trial with placebo. J Clin Oncol. 1994;12:1058-62. [pmid: 8164030].
Case DC, Bukowski RM, Carey RW, et al. Recombinant human erythropoietin therapy for anemic cancer patients on combination chemotherapy. J Natl Cancer Inst. 1993;85(10):801-6. [pmid: 8487324].
Cazzola M, Beguin Y, Kloczko J, et al. Once-weekly epoetin beta is highly effective in treating anaemic patients with lymphoproliferative malignancy and defective endogenous erythropoietin production. Br J Haematol. 2003;122(3):386-93. [pmid: 12877665].
Cazzola M, Messinger D, Battistel V, et al. Recombinant human erythropoietin in the anemia associated with multiple myeloma or non-Hodgkin’s lymphoma: dose finding and identification of predictors of response. Blood. 1995;86(12):4446-53. [pmid: 8541533].
Cella D, Eton DT, Lai JS, et al. Combining anchor and distribution-based methods to derive minimal clinically important differences on the Functional Assessment of Cancer Therapy (FACT) anemia and fatigue scales. J Pain Symptom Manage. 2002;24(6):547-61. [pmid: 12551804].
Chang J, Couture F, Young S, et al. Weekly epoetin alfa maintains hemoglobin, improves quality of life, and reduces transfusion in breast cancer patients receiving chemotherapy. J Clin Oncol. 2005;23(12):2597-605. [pmid: 15452188].
Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, NJ. Lawrence Erlbaum Associates. 1988.
Concato J, Feinstein AR, Holford TR. The risk of determining risk with multivariable models. Ann Intern Med. 1993;118:201-210. [pmid: 8417638].
Crawford J, Robert F, Perry M, et al. for the Anemia Prevention in NSCLC Study Group. Epoetin alfa 40,000 IU once weekly maintains hemoglobin in advanced non-small-cell lung cancer patients receiving first-line chemotherapy. Proc Am Soc Clin Oncol. 2003;22:628. abstract 2527. Abstract and full poster available online at http://www.asco.org/portal/site/ASCO/menuitem.34d60f5624ba07fd506fe310ee37a01d/?vgnextoid=76f8201eb61a7010VgnVCM100000ed730ad1RCRD&vmview=abst_detail_view&confID=23&abstractID=101646. Last accessed March 2006.
Dammacco F, Castoldi G, Rodjer S. Efficacy of epoetin alfa in the treatment of anaemia of multiple myeloma. Br J Haematol. 2001;113(1):172-9. [pmid: 11328297].
Deicher R, Horl WH. Differentiating factors between erythropoiesis-stimulating agents: a guide to selection for anaemia of chronic kidney disease. Drugs. 2004;64(5):499-509. [pmid: 14977387].
Del Mastro L, Venturini M, Lionetto R, et al. Randomized phase III trial evaluating the role of erythropoietin in the prevention of chemotherapy-induced anemia. J Clin Oncol. 1997;15(7):2715-21. [pmid: 9215845].
Demetri GD, Kris M, Wade J, et al. Quality-of-life benefit in chemotherapy patients treated with epoetin alfa is independent of disease response or tumor type: results from a prospective community oncology study. Procrit Study Group. J Clin Oncol. 1998;16(10):3412-25. [pmid: 9779721].
Donaldson GW, Moinpour CM. Learning to live with missing quality-of-life data in advanced-stage disease trials. J Clin Oncol. 2005;23(30):7380-7384. [pmid: 16186589].
Dunphy FR, Harrison BR, Dunleavy TL, et al. Erythropoietin reduces anemia and transfusions. Cancer. 1999;86:1362-7. [pmid: 10506726].
Egger M, Smith GD, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
Engels EA, Schmid CH, Terrin N, et al. Heterogeneity and statistical significance in meta-analysis: an empirical study of 125 meta-analyses. Stat Med. 2000;19:1707-28. [pmid: 10861773].
Engert A. Recombinant human erythropoietin as an alternative to blood transfusion in cancer-related anaemia. Dis Manag Clin Outcomes. 2000;8(5):259-72.
EPO-CAN-15. Protocol EPO-CAN-15: “A randomized, double-blind placebo controlled study to evaluate the impact of maintaining haemoglobin levels using EPREX (Epoetin alfa) in limited disease small cell lung cancer (LD SCLC) patients receiving combined chemotherapy and radiation therapy.” (The LEGACY Trial). Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
EPO-CAN-20. “A randomized trial of epoetin alfa in patients with advanced non-small cell carcinoma of the lung.” Reported in Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
EPO-GBR-07. Protocol EPO-GBR-7: “Open-label randomized, comparative group evaluation of the effect of epoetin alfa on local disease-free survival and quality of life in head and neck cancer patients receiving radical radiotherapy.” Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
Estrin JT, Schocket L, Kregenow R, et al. A retrospective review of blood transfusions in cancer patients with anemia. Oncologist. 1999;4(4):318-24. [pmid: 10476543].
Fallofield L, Gagnon D, Zagari M, et al. Multivariate regression analyses of data from a randomised, double-blind, placebo-controlled study confirm quality of life benefit of epoetin alfa in patients receiving non-platinum chemotherapy. Br J Cancer. 2002;87:1341-53. [pmid: 12454760].
Federation Nationale des Centres de Lutte Contre le Cancer (FNCLCC). Recommandations pour la pratique clinique: Standards, Options et Recommandations 2003 pour l’utilisation de l’érythropoïétine recombinante (époetine alfa et bêta, darbepoetine alfa, EPO) dans la prise en charge de l’anémie en cancérologie, mise à jour. Federation Nationale des centres de lutte contre le cancer. Paris (France): FNCLCC; November 2003. Available online at http://www.fnclcc.fr/sor/SORSpecialistes/Traitements/Medicaments/Util-EPO/TT_MED_Util-EPO_int/html/pdf/TT_MED_Util_EPO_int.pdf. Last accessed March 2006.
Fjornes T, Wiedemann GJ, Sack K, et al. Serum erythropoietin and creatinine concentrations as predictive factors for response to recombinant human erythropoietin treatment in anaemic tumour patients on chemotherapy. Oncol Rep. 1998;5(1):81-6. [pmid: 9458299].
Food and Drug Administration Oncologic Drugs Advisory Committee. May 4, 2004, Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
Gabrilove JL, Cleeland CS, Livingston RB, et al. Clinical evaluation of once-weekly dosing of epoetin alfa in chemotherapy patients: improvements in hemoglobin and quality of life are similar to three-times-weekly dosing. J Clin Oncol. 2001;19(11):2875-82. [pmid: 11387360].
Garton JP, Gertz MA, Witzig TE, et al. Epoetin alfa for the treatment of the anemia of multiple myeloma. Arch Intern Med. 1995;155:2069-74. [pmid: 7575066].
Glaspy JA. The potential for anemia treatment to improve survival in cancer patients. Oncology (Williston Park). 2002;16(9 Suppl 10):35-40.
Glaspy J, Berg R, Tomita D, et al. Final results of a phase 3, randomized, open-label study of darbepoetin alfa 200 mcg every 2 weeks (Q2W) versus epoetin alfa 40,000 U weekly (QW) in patients with chemotherapy-induced anemia (CIA). Proc Am Soc Clin Oncol. 2005;23:760s. Abstract 8125.
Glaspy J, Bukowski R, Steinberg D, et al. Impact of therapy with epoetin alfa on clinical outcomes in patients with nonmyeloid malignancies during cancer chemotherapy in community oncology practice. Procrit Study Group. J Clin Oncol. 1997;15(3):1218-34. [pmid: 9060566].
Glaspy JA, Jadeja JS, Justice G, et al. A randomized, active-control, pilot trial of front-loaded dosing regimens of darbeopetin-alfa for the treatment of patients with anemia during chemotherapy for malignant disease. Cancer. 2003;97:1312-20. [pmid: 12599240].
Glaspy JA, Jadeja JS, Justice G, et al. Darbepoetin alfa given every 1 or 2 weeks alleviates anaemia associated with cancer chemotherapy. Br J Cancer. 2002;87(3):268-76. [pmid: 12177793].
Glaspy JA, Tchekmedyian NS. Darbepoetin alfa administered every 2 weeks alleviates anemia in cancer patients receiving chemotherapy. Oncology (Huntingt). 2002B;16(10 Suppl 11):23-9.
Glimelius B, Linne T, Hoffman K, et al. Epoetin beta in the treatment of anemia in patients with advanced gastrointestinal cancer. J Clin Oncol. 1998;16(2):434-40. [pmid: 9469326].
GOG-191. Study GOG-191 (PR01-04-005): “A phase III trial to evaluate the efficacy of maintaining Hgb levels above 120 g/l with erythropoietin versus above 100 g/l without erythropoietin in anemic patients receiving concurrent radiation and cisplatin for cervical cancer.” Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
Gonzalez M, Ordonez A, Jua VO, et al. Predicting factors to epoetin alfa treatment. Proc ASCO. 1999. Abstract 2308.
Gonzalez-Baron M, Ordonez A, Franquesa R, et al. Response predicting factors to recombinant human erythropoietin in cancer patients undergoing platinum-based chemotherapy. Cancer. 2002;95(11):2408-13. [pmid: 12436449].
Goodnough LT. Risks of blood transfusion. Anesthesiol Clin North Am. 2005;23(2):241-52.
Granetto C, Ricci S, Martoni A, et al. Comparing the efficacy and safety of fixed versus weight-based dosing of epoetin alpha in anemic cancer patients receiving platinum-based chemotherapy. Oncol Rep. 2003;10(5):1289-96. [pmid: 12883695].
Groopman JE, Itri LM. Chemotherapy-induced anemia in adults: incidence and treatment. JNCI. 1999;91(19):1616-34. [pmid: 10511589].
Grote T, Yeilding AL, Castillo R, et al. Efficacy and safety analysis of epoetin alfa in patients with small-cell lung cancer: a randomized, double-blind, placebo-controlled trial. J Clin Oncol. 2005;23(36):9377-86. [pmid: 16361638].
Gurevitch J, Hedges LV. Statistical issues in ecological meta-analyses. Ecology. 1999;80:1142-1149.
Guyatt GH, Norman GR, Juniper EF, et al. A critical look at transition ratings. J Clin Epidemiol. 2002;55:900-8. [pmid: 12393078].
Guyatt GH, Osoba D, Wu AW, et al. Methods to explain the clinical significance of health status measures. Mayo Clin Proc. 2002;77:371-83. [pmid: 11936935].
Halstenson CE, Macres M, Katz SA, et al. Comparative pharmacokinetics and pharmacodynamics of epoetin alfa and epoetin beta. Clin Pharmacol Ther. 1991;50(6):702-12. [pmid: 1752115].
Hedenus M, Adriansson M, San Miguel J, et al. Efficacy and safety of darbepoetin alfa in anaemic patients with lymphoproliferative malignancies: a randomized, double-blind, placebo-controlled study. Br J Haematol. 2003;122(3):394-403. [pmid: 12877666].
Hedenus M, Hansen S, Taylor K, et al. Randomized, dose-finding study of darbepoetin alfa in anaemic patients with lymphoproliferative malignancies. Br J Haematol. 2002;119:79-86. [pmid: 12358906].
Hedenus M, Vansteenkiste J, Kotasek D, et al. Darbepoetin alfa for the treatment of chemotherapy-induced anemia: disease progression and survival analysis from four randomized, double-blind, placebo-controlled trials. J Clin Oncol. 2005;23(28):6941-8. [pmid: 16192582].
Hedges LV, Olkin I. Vote counting methods in research synthesis. Psychol Bull. 1980;88:359-369.
Henke M, Guttenberger R, Barke A, et al. Erythropoietin for patients undergoing radiotherapy: a pilot study. Radiother Oncol. 1999;50(2):185-90. [pmid: 10368042].
Henke M, Laszig R, Ruebe C, et al. Erythropoietin to treat head and neck cancer patients with anaemia undergoing radiotherapy: randomised, double-blind, placebo-controlled trial. Lancet. 2003;362:1255-60. [pmid: 14575968].
Henry D, Abels R, Larholt K. Prediction of response to recombinant human erythropoietin (r-HuEPO/epoetin-alpha) therapy in cancer patients. Blood. 1995a;85:1676-1678.
Henry DH, Brooks BJ Jr, Case DC Jr, et al. Recombinant human erythropoietin therapy for anemic cancer patients receiving cisplatin chemotherapy. Cancer J Sci Am. 1995;1(4):252-60. [pmid: 9166485].
Henze G, Michon J, Morland B, et al. Phase III randomized study: efficacy of epoetin alfa in reducing blood transfusions in newly diagnosed pediatric cancer patients receiving chemotherapy. Proc Am Soc Clin Oncol. 2002;21. Abstract 1547.
Hesketh PJ, Arena F, Patel D, et al. A randomized controlled trial of darbepoetin alfa administered as a fixed or weight-based dose using a front-loading schedule in patients with anemia who have nonmyeloid malignancies. Cancer. 2004;100(4):859-68. [pmid: 14770445].
Higgins J, Thompson S, Deeks J, et al. Statistical heterogeneity in systematic reviews of clinical trials: a critical appraisal of guidelines and practice. J Health Serv Res Policy. 2002;7(1):51-61. [pmid: 11822262].
Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327:557-60. [pmid: 12958120].
Hollander N, Schumacher M. On the problem of using “optimal” cutpoints in the assessment of quantitative prognostic factors. Onkologie. 2001;24:194-199. [pmid: 11441304].
Holzner B, Kemmler G, Greil R, et al. The impact of hemoglobin levels on fatigue and quality of life in cancer patients. Ann Oncol. 2002;13:965-973. [pmid: 12123343].
Huddart RA, Welch RS, Chan S, et al. A prospective randomised comparative-group evaluation of epoetin alfa for the treatment of anaemia in UK cancer patients receiving platinum-based chemotherapy. Ann Oncol. 2002;13(Suppl 5):177. [pmid: 12401687].
Iconomou G, Koutras A, Rigopoulos A, et al. Effect of recombinant human erythropoietin on quality of life in cancer patients receiving chemotherapy: results of a randomized, controlled trial. J Pain Symptom Manage. 2003;25(6):512-8. [pmid: 12782431].
Ihaka R, Gentleman R. A language for data analysis and graphics. J Comput Graph Stat. 1996;5(3):299-314.
Infante-Rivard C, Villeneuve JP, Esnaola S. A framework for evaluating and conducting prognostic studies: an application to cirrhosis of the liver. J Clin Epidemiol. 1989;42(8):791-805. [pmid: 2668451].
INT-1. Study of epoetin supportive care in ovarian cancer. Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
INT-3. Study of epoetin supportive care in multiple myeloma. Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
Janinis J, Dafni U, Aravantinos G, et al. Quality of life (QoL) outcome of epoietin-alfa (EPO-A) in anemic cancer patients undergoing platinum or non-platinum-based chemotherapy: a randomized study conducted by the Hellenic Cooperative Oncology Group. Proc Am Soc Clin Oncol 22. 2003;789. Abstract.
Johansson JE, Wersall P, Brandberg Y, et al. Efficacy of epoetin beta on hemoglobin, quality of life, and transfusion needs in patients with anemia due to hormone-refractory prostate cancer--a randomized study. Scand J Urol Nephrol. 2001;35(4):288-94. [pmid: 11676354].
Jones M, Schenkel B, Just J, et al. Epoetin alfa improves quality of life in patients with cancer. Results of a meta-analysis. Cancer. 2004;101:1720-32. [pmid: 15386341].
Joy MS. Darbepoetin alfa: a novel erythropoiesis-stimulating protein. Ann Pharmacother. 2002;36:1183-92. [pmid: 12086553].
Justice AC, Covinsky KE, Berlin JA. Assessing the generalizability of prognostic information. Ann Intern Med. 1999;130:515-524. [pmid: 10075620].
Justice G, Kessler JF, Jadeja J, et al. A randomized, multicenter study of subcutaneous and intravenous darbepoetin alfa for the treatment of chemotherapy-induced anemia. Ann Oncol. 2005;16(7):1192-1198. [pmid: 15860486].
Kasper C, Terhaar A, Fossa A, et al. Recombinant human erythropoietin in the treatment of cancer-related anaemia. Eur J Haematol. 1997;58(4):251-6. [pmid: 9186536].
Katodritou E, Speletas M, Kapetanos D, et al. Evaluation of traditional and novel predictive markers of anemia response to recombinant human erythropoietin (rh-EPO) in patients with multiple myeloma and lymphoma: emerging role of functional iron deficiency. Blood. 2004;104(11). Abstract 3690.
Khorana AA, Francis CW, Culakova E, et al. Risk factors for chemotherapy-associated venous thromboembolism in a prospective observational study. Cancer. 2005;104(12):2822-9. [pmid: 16284987].
Knight K, Wade S, Balducci L. Prevalence and outcomes of anemia in cancer: a systematic review of the literature. Am J Med. 2004;116(Suppl 7A):11S-26S.
Koeller JM. Clinical guidelines for the treatment of cancer-related anemia. Pharmacotherapy. 1998;18(1):156-69. [pmid: 9469689].
Kotasek D, Canon JL, San Miguel J, et al. Correction/maintenance dosing (front loading) of darbepoetin alfa: final results from a randomized phase 3 active controlled trial. Proceedings of the American Society of Hematology. Blood. 2004;104:455a. abstract number 1636.
Kotasek D, Steger G, Faught W, et al. Darbepoetin alfa administered every 3 weeks alleviates anaemia in patients with solid tumours receiving chemotherapy; results of a double-blind, placebo-controlled, randomised study. Eur J Cancer. 2003;39(14):2026-34. [pmid: 12957457].
Kunikane H, Watanabe K, Fukuoka M, et al. Double-blind randomized control trial of the effect of recombinant human erythropoietin on chemotherapy-induced anemia in patients with non-small cell lung cancer. Int J Clin Oncol. 2001;6:296-301. [pmid: 11828949].
Kurz C, Marth C, Windbichler G, et al. Erythropoietin treatment under polychemotherapy in patients with gynecologic malignancies: a prospective, randomized, double-blind placebo-controlled multicenter study. Gynecol Oncol. 1997;65(3):461-6. [pmid: 9190976].
L’Abbe KA, Detsky AS, O’Rourke K. Meta-analysis in clinical research. Ann Intern Med. 1987;107(2):224-33. [pmid: 3300460].
Levine MN, Lee AY, Kakkar AK. Thrombosis and cancer. American Society of Clinical Oncology Educational Book. Perry MC, editor. Alexandria, VA. American Society of Clinical Oncology. 2005:748-57.
Leyland-Jones B. Breast cancer trial with erythropoietin terminated unexpectedly. Lancet Oncol. Aug. 2003;4(8):459-60. [pmid: 12901958].
Leyland-Jones B, Semiglazov V, Pawlicki M, et al. Maintaining normal hemoglobin levels with epoetin alfa in mainly nonanemic patients with metastatic breast cancer receiving first-line chemotherapy: A survival study. J Clin Oncol. 2005;23:5960-5972. [pmid: 16087945].
Littlewood TJ, Bajetta E, Nortier JW, et al. Effects of epoetin alfa on hematologic parameters and quality of life in cancer patients receiving nonplatinum chemotherapy: results of a randomized, double-blind, placebo-controlled trial. J Clin Oncol. 2001;19(11):2865-74. [pmid: 11387359].
Littlewood TJ, Kallich JD, San Miguel J, et al. Efficacy of darbepoetin alfa in alleviating fatigue and the effect of fatigue on quality of life in anemic patients with lymphoproliferative malignancies. J Pain Symptom Manage. 2006;31:317-25. [pmid: 16632079].
Littlewood TJ, Zagari M, Pallister C, et al. Baseline and early treatment factors are not clinically useful for predicting individual response to erythropoietin in anemic cancer patients. Oncologist. 2003;8(1):99-107. [pmid: 12604736].
Ludwig H, Fritz E, Leitgeb C, et al. Prediction of response to erythropoietin treatment in chronic anemia of cancer. Blood. 1994;84:1056-63. [pmid: 7741835].
Ludwig H, Sundal E, Pecherstorfer M, et al. Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy. Cancer. 1995;76(11):2319-29. [pmid: 8635038].
Luksenburg H, Weir A, Wagner R. FDA Briefing Document May 4, 2004 Oncologic Drugs Advisory Committee: Safety Concerns Associated with Aranesp (darbepoetin alfa) Amgen, Inc. and Procrit (epoetin alfa) Ortho Biotech, L.P., for the Treatment of Anemia Associated with Cancer Chemotherapy. Available online at http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037B2_04_FDA-Aranesp-Procrit.htm. Last accessed January 2006.
Machtay M, Pajak T, Suntharalingam M, et al. Definitive radiotherapy erythropoietin for squamous cell carcinoma of the head and neck: preliminary report of RTOG 99-03. Proceedings from the 46th annual meeting of the American Society for Therapeutic Radiology and Oncology. Atlanta GA. 2004. Abstract 5.
McEvoy GK, editor. Epoetin alfa. AHFS Drug Information 2005. Bethesda. American Society of Health-system Pharmacists. 2005:1486-98.
McGuire WL. Breast cancer prognostic factors: evaluation guidelines. J Natl Cancer Inst. 1991;83(3):154-5. [pmid: 1988696].
McKenzie RS, Lefebvre P, Rosberg J, et al. Comparison of anemia outcomes associated with early response to epoetin alfa (EPO) with QW and TIW dosing. J Clin Oncol. 2004;22(14S). Abstract 6141.
Miller CB, Platanias LC, Mills SR, et al. Phase I–II trial of erythropoietin in the treatment of cisplatin-associated anemia. J Natl Cancer Inst. 1992;84(2):98-103. [pmid: 1735886].
Musto P, Falcone A, D’Arena G, et al. Clinical results of recombinant erythropoietin in transfusion-dependent patients with refractory multiple myeloma: role of cytokines and monitoring of erythropoiesis. Eur J Haematol. 1997;58(5):314-9. [pmid: 9222286].
N93 004. Final Study Report, Protocol N93-004 (“The Effect of r-HuEPO in Patients with Small Cell Cancer (SCLC): A Randomized, Double blind, Placebo-controlled Trial), Johnson & Johnson, October 25, 2002. Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
National Cancer Institute (NCI) Cancer Therapy Evaluation Program (CTEP). Common toxicity criteria (Version 2.0). Published April 30, 1999. Available online at: http://ctep.cancer.gov/forms/CTCv20_4-30-992.pdf. Last accessed January 2006.
National Institute for Health and Clinical Excellence. Appraisal Consultation Document: Erythropoietin for anaemia induced by cancer treatment. June. 2005. Available online at http://www.nice.org.uk/page.aspx?o=263492. Last accessed March 2006.
NCCN (National Comprehensive Cancer Network). Practice Guidelines in Oncology: Cancer- and Treatment-Related Anemia. Available online at www.nccn.org/professionals/physician_gls/PDF/anemia.pdf. Last accessed January 25, 2006.
Nieboer P, Buijs C, Rodenhuis S, et al. Fatigue and relating factors in high-risk breast cancer patients treated with adjuvant standard or high-dose chemotherapy: a longitudinal study. J Clin Oncol. 2005;23(33):8296-8304. [pmid: 16219926].
Oberhoff C, Neri B, Amadori D, et al. Recombinant human erythropoietin in the treatment of chemotherapy- induced anemia and prevention of transfusion requirement associated with solid tumors: a randomized, controlled study. Ann Oncol. 1998;9(3):255-60. [pmid: 9602258].
Okuyama T, Akechi T, Kugaya A, et al. Factors correlated with fatigue in disease-free breast cancer patients: application of the Cancer Fatigue Scale. Support Care Cancer. 2000;8:215-222. [pmid: 10789963].
Olsson AM, Svensson JH, Sundstrom J, et al. Erythropoietin treatment in metastatic breast cancer--effects on Hb, quality of life and need for transfusion. Acta Oncologica. 2002;41(6):517-24. [pmid: 12546524].
Ortho-Biotech Products. Procrit® (epoetin alfa) prescribing information. Raritan, NJ. Issue date: November 2005. Available online at http://www.procrit.com/common/prescribing_information/PROCRIT/PDF/ProcritBooklet.pdf. Last accessed March 2006.
O’Shaughnessy JA. Effects of epoetin alfa on cognitive function, mood, asthenia, and quality of life in women with breast cancer undergoing adjuvant chemotherapy. Clin Breast Cancer. 2002;3(Suppl 3):S116-20. [pmid: 12533272].
O’Shaughnessy JA, Vukelja SJ, Holmes FA, et al. Feasibility of quantifying the effects of epoetin alfa therapy on cognitive function in women with breast cancer undergoing adjuvant or neoadjuvant chemotherapy. Clin Breast Cancer. 2005;5(6):439-46. [pmid: 15748464].
Osoba D, Rodriguew G, Hyles J, et al. Interpreting the significance of changes in health-related quality of life scores. J Clin Oncol. 1998;16:139-144. [pmid: 9440735].
Osterborg A, Boogaerts MA, Cimino R, et al. Recombinant human erythropoietin in transfusion-dependent anemic patients with multiple myeloma and non-Hodgkin’s lymphoma - A randomized multicenter study. Blood. 1996;87(7):2675-82. [pmid: 8639883].
Osterborg A, Brandberg Y, Hedenus M. Impact of epoetin-beta on survival of patients with lymphoproliferative malignancies: long-term follow up of a large randomized study. Br J Haematol. 2005;129(2):206-9. [pmid: 15813848].
Osterborg A, Brandberg Y, Molostova V, et al. Randomized, double-blind, placebo-controlled trial of recombinant human erythropoietin, epoetin beta, in hematologic malignancies. J Clin Oncol. 2002;20(10):2486-94. [pmid: 12011126].
P-174. Study of epoetin supportive care in CLL. Reported in Food and Drug Administration Oncologic Drugs Advisory Committee May 4, 2004 Meeting Briefing Information (available at: http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm) and Slides (available at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm). Online sources last accessed July 26, 2005.
Parmar MKB, Torri V, Stewart L. Extracting summary statistics to perform meta-analyses of the published literature for survival endpoints. Stat Med. 1998;17:2815-34. [pmid: 9921604].
Patrick DL, Gagnon DD, Zagari MJ, et al. Epoetin Alfa Study Group. Assessing the clinical significance of health-related quality of life (HrQOL) improvements in anaemic cancer patients receiving epoetin alfa. Eur J Cancer. 2003;39(3):335-45. [pmid: 12565986].
Pealer LN, Marfin AA, Petersen LR, et al. Transmission of West Nile virus through blood transfusion in the United States in 2002. N Engl J Med. 2003;349(13):1236-45. [pmid: 14500806].
Pepe MS. The statistical evaluation of medical tests for classification and prediction. Oxford. Oxford University Press. 2003.
Poole C, Greenland S. Random-effects meta-analyses are not always conservative. Am J Epidemiol. 1999;150(5):469-75. [pmid: 10472946].
Quirt I, Bramwell V, Charette M, et al. the Systemic Treatment Disease Site Group. The role of erythropoietin in the management of cancer patients with non-hematologic malignancies receiving chemotherapy. Practice Guideline Report #12-1. #12-1. 2005. Available online at http://www.cancercare.on.ca/pdf/pebc12-1f.pdf. Last accessed March 2006.
Quirt I, Micucci S, Moran LA, et al. The role of recombinant human erythropoietin (EPO) in reducing red blood cell transfusions and maintaining quality of life (QOL) in patients with lymphoma and solid tumors receiving cytotoxic chemotherapy. Results of a randomized, double-blind, placebo-controlled clinical trial. Blood. 1996;88(10 Suppl 1):347a.
Razzouk BI, Hockenberry M, Hinds PS, et al. A double-blind, placebo-controlled study of once-weekly epoetin alfa in children with cancer undergoing myelosuppressive chemotherapy. J Clin Oncol. 2004;22(14S). Abstract 8527.
Rearden TP, Charu V, Saidman B, et al. Results of a randomized study of every three-week dosing (Q3W) of darbepoetin alfa for chemotherapy-induced anemia (CIA). J Clin Oncol. 2004;22(14 Suppl). Abstract 8064.
Richart JM, Petruska PJ, Klebert KS, et al. A phase III trial of epoetin alfa: early vs late administration in patients treated with chemotherapy. Blood. 2002;100:175b. Proceedings of the 44th Annual Meeting of the American Society of Hematology. December 6–10, 2002. Philadelphia, PA. Abstract 4199.
Rizzo JD, Lichtin AE, Woolf SH, et al. Use of epoetin in patients with cancer: evidence-based clinical practice guidelines of the American Society of Clinical Oncology and the American Society of Hematology. J Clin Oncol. 2002;20(19):4083-107. [pmid: 12351606].
Rose E, Rai K, Revicki D, et al. Clinical and health status assessments in anemic chronic lymphocytic leukemia (CLL) patients treated with epoetin alfa (EPO). Blood. 1994;84(10 Suppl 1):526a. [pmid: 8025281].
Rosenzweig MQ, Bender CM, Lucke JP, et al. The decision to prematurely terminate a trial of R-HuEPO due to thrombotic events. J Pain Symptom Manage. 2004;27(2):185-90. [pmid: 15157043].
Sakai H, Ohashi Y, Hirashima K, et al. Once weekly epoetin beta to increase hemoglobin and improve quality of life in anemic cancer patients receiving chemotherapy: A randomized, double-blind, dose-finding study. J Clin Oncol. ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22(14S, July 15 Suppl). Abstract 8169.
Samol J, Littlewood TJ. The efficacy of rHuEPO in cancer-related anaemia. Br J Haematol. Apr. 2003;121(1):3-11. [pmid: 12670326].
Savonije J, van Groeningen C, van Bochove A, et al. Early intervention with epoetin-alfa during platinum-based chemotherapy. J Clin Oncol. 2004;22(14S). Abstract 8111.
Savonije JH, van Groeningen CJ, van Bochove A, et al. Effects of early intervention with epoetin alfa on transfusion requirement, hemoglobin level and survival during platinum-based chemotherapy: Results of a multicenter randomised controlled trial. Eur J Cancer. 2005;41(11):1560-9. [pmid: 15953714].
Schumacher M, Hollander N, Schwarzer G, et al. Prognostic factor studies. Crowley J, editor. Handbook of statistics in clinical oncology. New York. Marcel Dekker. 2001:321-78.
Schwartzberg LS, Yee LK, Senecal FM, et al. A randomized comparison of every-2-week darbepoetin alfa and weekly epoetin alfa for the treatment of chemotherapy-induced anemia in patients with breast, lung, or gynecologic cancer. Oncologist. 2004;9(6):696-707. [pmid: 15561813].
Seidenfeld J, Piper M, Flamm C, et al. Epoetin treatment of anemia associated with cancer therapy: a systematic review and meta-analysis of controlled clinical trials. J Natl Cancer Inst. 2001;93(16):1204-14. [pmid: 11504766].
Shasha D, George MJ, Harrison LB. Once-weekly dosing of epoetin-alpha increases hemoglobin and improves quality of life in anemic cancer patients receiving radiation therapy either concomitantly or sequentially with chemotherapy. Cancer. 2003;98(5):1072-9. [pmid: 12942577].
Silvestris F, Romito A, Fanelli P, et al. Long-term therapy with recombinant human erythropoietin (rHu-EPO) in progressing multiple myeloma. Ann Hematol. 1995;70:313-8. [pmid: 7632811].
Simon R, Altman DG. Statistical aspects of prognostic factor studies in oncology. Br J Cancer. 1994;69:979-985. [pmid: 8198989].
Stasi R, Amadori S, Littlewood TJ, et al. Management of cancer-related anemia with erythropoietic agents: doubts, certainties and concerns. Oncologist. 2005;10:539-54. [pmid: 16079321].
Steensma DP, Loprinzi CL. Erythropoietin use in cancer patients: a matter of life and death?. J Clin Oncol. 2005;23(25):5865-8. [pmid: 16087951].
Steensma DP, Molina R, Sloan JA, et al. A phase III randomized trial of two different dosing schedules of erythropoietin (epo) in patients with cancer-associated anemia: North Central Cancer Treatment Group (NCCTG) Study N02C2. J Clin Oncol. 2005. Proceedings of the 41th Annual Meeting of the American Society of Oncology. 13–17 May 2005. Orlando FL. Abstract 8031.
Steensma DP, Molina R, Sloan JA, et al. Phase III study of two different dosing schedules of erythropoietin in anemic patients with cancer. J Clin Oncol. 2006;24(7):1079-89. [pmid: 16505427].
Storring PL, Tiplady RJ, Gaines Das RE, et al. Epoetin alfa and beta differ in their erythropoietin isoform compositions and biological properties. Br J Haematol. 1998;100:79-89. [pmid: 9450795].
Straus DJ, Testa M, Riggs SA, et al. Early treatment with epoetin alfa improves anemia, quality of life, and productivity in patients with hematologic malignancies and mild anemia during chemotherapy. Blood. 2003;102:497a. Abstract 1811. [pmid: 12649146].
Streiner DL. The case of the missing data: methods of dealing with dropouts and other research vagaries. Can J Psychiatry. 2002;47(1):68-75. [pmid: 11873711].
ten Bokkel Huinink WW, De Swart CA, Van Toorn DW, et al. Controlled multicentre study of the influence of subcutaneous recombinant human erythropoietin on anaemia and transfusion dependency in patients with ovarian carcinoma treated with platinum-based chemotherapy. Med Oncol. 1998;15(3):174-82. [pmid: 9819794].
Thatcher N, De Campos ES, Bell DR, et al. Epoetin alpha prevents anaemia and reduces transfusion requirements in patients undergoing primarily platinum-based chemotherapy for small cell lung cancer. Br J Cancer. 1999;80(3–4):396-402. [pmid: 10408844].
Thomas DR. Anemia and quality of life: unrecognized and undertreated. J Gerontol A Biol Sci Med Sci. 2004;59(3):238-41. [pmid: 15031307].
Thomas H, McAdam KF, Thomas RJ, et al. Early intervention with epoetin alfa for treatment of anaemia and improvement of quality of life in cancer patients undergoing myelotoxic chemotherapy. Ann Oncol. 2002;13(suppl 5):177. Abstract. [pmid: 12401687].
Thompson SG, Higgins JP. How should meta-regression analyses be undertaken and interpreted?. Stat Med. 2002;21:1559-73. [pmid: 12111920].
Thompson SG, Sharp SJ. Explaining heterogeneity in meta-analysis: a comparison of methods. Stat Med. 1999;18:2693-708. [pmid: 10521860].
Throuvalas NA, Antonadou D, Boufi M, et al. Erythropoietin decreases transfusion requirements during radiochemotherapy. Proc ASCO. 2000;19:394a. Abstract 1558.
Vadhan-Raj S, Mirtsching B, Charu V, et al. Assessment of hematologic effects and fatigue in cancer patients with chemotherapy-induced anemia given darbepoetin alfa every two weeks. J Support Oncol. 2003;1(2):131-8. [pmid: 15352656].
Vadhan-Raj S, Skibber JM, Crane C, et al. Randomized, double-blind, placebo-controlled trial of epoetin alfa (Procrit) in patients with rectal and gastric cancer undergoing chemo-radiotherapy (CT/RT) followed by surgery: early termination of the trial due to increased incidence of thrombo-embolic events (TEE). Blood. 2004;104(pt 1):797a. Abstract 2915.
Vansteenkiste J, Pirker R, Massuti B, et al. Double-blind, placebo-controlled, randomized phase III trial of darbepoetin alfa in lung cancer patients receiving chemotherapy. J Natl Cancer Inst. 2002;94:1211-20. [pmid: 12189224].
Waltzman R, Croot C, Justice GR, et al. Randomized comparison of epoetin alfa (40,000 U weekly) and darbepoetin alfa (200 microg every 2 weeks) in anemic patients with cancer receiving chemotherapy. Oncologist. 2005;10(8):642-50. [pmid: 16177289].
Waltzman RJ, Croot C, Williams D. Final hematologic results: epoetin alfa (EPO) 40,000 U QW vs. darbepoetin alfa (DARB) 200 mcg Q2W in anemic cancer patients (pts) receiving chemotherapy (CT). Proc Am Soc Clin Oncol. 2005;23:736s. Abstract 8030.
Watine J, Bouarioua N. Anemia as an independent prognostic factor for survival in patients with cancer. Cancer. 2002;94(10):2793-6.
Weiss RB. Section 8, Miscellaneous Toxicities, Chapter 55, Adverse Effects of Treatment. Cancer: Principles & Practice of Oncology. DeVita VT Jr, Hellman S, Rosenberg SA, editors. 6th edition. Lippincott Williams & Wilkins. Philadelphia. 2001:2964.
Welch RS, James RD, Wilkinson PM. Recombinant human erythropoietin and platinum-based chemotherapy in advanced ovarian cancer. Cancer J Sci Am. Nov. 1995;1(4):261. [pmid: 9166486].
Westenfelder C, Baranowski RL. Erythropoietin stimulates proliferation of human renal cell carcinoma cells. Kidney Int. 2000;58:647-657. [pmid: 10916088].
Wilson J, Yao G, Raftery J, et al. A systematic review and economic evaluation of epoetin alfa, epoetin beta and darbepoetin alfa in anaemia associated with cancer, especially that attributable to cancer treatment. National Institute for Health and Clinical Excellence. UK. March. 2005. Available at: http://www.nice.org.uk/pdf/Anaemia_Assessment_Report.pdf. Last accessed March 2006.
Wisloff F, Gulbrandsen N, Hjorth M, et al. Quality of life may be affected more by disease parameters and response to therapy than by haemoglobin changes. Eur J Haematol. 2005;75:293-8. [pmid: 16146535].
Witzig TE, Silberstein PT, Loprinzi CL, et al. Phase III, randomized, double-blind study of epoetin alfa versus placebo in anemic patients with cancer undergoing chemotherapy. J Clin Oncol. 2004;23(12):2606-17. [pmid: 15452187].
Wun T, Law L, Harvey D, et al. Increased Incidence of symptomatic venous thrombosis in patients with cervical carcinoma treated with concurrent chemotherapy, radiation, and erythropoietin. Cancer. 2003;98:1514-20. [pmid: 14508840].
Wurnig C, Windhager R, Schwameis E, et al. Prevention of chemotherapy-induced anemia by the use of erythropoietin in patients with primary malignant bone tumors (a double-blind, randomized, phase III study). Transfusion. 1996;36(2):155-9. [pmid: 8614967].
Yost KJ, Eton DT. Combining distribution- and anchor-based approaches to determine minimally important differences: the FACIT experience. Eval Health Prof. 2005;28(2):172-91. [pmid: 15851772].
Zhang Y, Thamer M, Stefanik K, et al. Epoetin requirements predict mortality in hemodialysis patients. Am J Kidney Dis. 2004;44:866-876. [pmid: 15492953].