# Abbreviations

AE: adverse events
AHRQ: Agency for Healthcare Research and Quality
AJCC: American Joint Committee on Cancer
ALL: acute lymphocytic leukemia
ASCO: American Society of Clinical Oncology
ASH: American Society of Hematology
AUC: area under the curve
BCBSA: Blue Cross and Blue Shield Association
ca: cancer
CCOPG: Cancer Care Ontario Practice Guidelines
CDC: Centers for Disease Control and Prevention
CDER: Center for Drug Evaluation and Research
CERA: continuous erythropoiesis-receptor activator
chemo: chemotherapy
CLAS: cancer linear analog scale
CLL: chronic lymphocytic leukemia
CR: complete response
CT: chemotherapy
darb: darbepoetin
DBP: diastolic blood pressure
dL: deciliter
EORTC: European Organization for Research and Treatment of Cancer
EPC: Evidence-based Practice Center
epo: epoetin
est: estimated
FACT: Functional Assessment of Cancer Therapy, including G-General; F-Fatigue; An-Anemia
FDA: Food and Drug Administration
FNCLCC: Federation Nationale des Centres de Lutte Contre le Cancer
g: grams
G-CSF: granulocyte colony-stimulating factor
GI: gastrointestinal
GU: genitourinary
Gy: Gray
gyne: gynecologic
H&N: head and neck
Hb: hemoglobin
Hct: hematocrit
HD: Hodgkin’s disease
hematol: hematologic
HG: mercury
HIV: human immunodeficiency virus
HR: hazard ratio
ID: identification
IPD: individual patient data
ITT: intention-to-treat
IU: international units
IV: intravenous
J&J: Johnson and Johnson
kg: kilogram
K-M: Kaplan-Meier
KQ: key question
LASA: linear analog self-assessment
MA: meta-analysis
malign: malignancy
MDACC: M.D. Anderson Cancer Center
MM: multiple myeloma
n, N: number
NCCN: National Comprehensive Cancer Network
NESP: novel erythropoiesis-stimulating protein
NHL: non-Hodgkin’s lymphoma
NICE: National Institute for Health and Clinical Excellence
NNH: number needed to harm
NNT: number needed to treat
NR: not reported
NS: not significant
NSCLC: non-small cell lung cancer
ODAC: Oncologic Drugs Advisory Committee
plat: platinum
PR: partial response
pub: publication
q2w: every two weeks
QLQ: Quality of life Questionnaire
QoL: quality of life
qw: every week
radio: radiotherapy
random: randomized
RBC: red blood cell
RBCT: red blood cell transfusion
RCT: randomized, controlled trial
RR: relative risk
SBP: systolic blood pressure
SC: subcutaneous
sc: subcutaneous
SCLC: small cell lung cancer
SD: standard deviation
TEC: Technology Evaluation Center
tiw: three times weekly
tx: treatment
U: units
U.K.: United Kingdom
U.S.: United States
VAS: visual analog scales
WHO: World Health Organization