# Acknowledgments

The research team would like to acknowledge the efforts of Maxine A. Gere, M.S., for general editorial assistance and program support; Carol Gold-Boyd for administrative support; Tracey Perez, R.N., J.D., for program support; Mark D. Grant, M.D., M.P.H., for methods and editorial input; Gordon Guyatt, M.D., M.Sc., for conceptual consultation regarding quality of life and clinical significance; Steve Goodman, M.D., M.H.S., Ph.D., for statistical consultation; and Elise Berliner, Ph.D., of the Agency for Healthcare Research and Quality, for advice as our Task Order Officer.

AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Elise Berliner, Ph.D.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD