# Future Research

The present review incorporates not only published literature, but also abstracts and presentation materials from major specialty meetings through spring of 2005. Research on the use of erythropoietic stimulants to manage cancer therapy-related anemia is ongoing.^30^ Following are recommendations for future research.

30 Appendix G provides a summary of trials listed on clinicaltrials.gov investigating treatment of cancer patients with darbepoetin or epoetin, including some testing effects on survival and disease progression endpoints.

1. Reporting of adverse events should be complete and consistent in all trials.

The first AHRQ evidence report (Seidenfeld, Aronson, Piper, et al., 2001) found no statistically significant differences in reported adverse events for epoetin compared to controls. Of 22 trials (N=1,927) that reported on efficacy outcomes, nine (N=722) reported on hypertension and 6 (N= 580) on deep vein thrombosis or thromboembolism. However, it is now clear that erythropoietic stimulants do increase the risk of thromboembolic events.

While reporting of adverse events has improved, it is far from complete and consistent. Adverse events should be clearly classified with respect to severity and occurrence, or absence of events explicitly stated in all reports. In the present review, 30 of 48 trials of epoetin versus control reported on thromboembolic events, as did one of four trials of darbepoetin versus control, and three of seven trials comparing epoetin and darbepoetin. Reporting is markedly less consistent for other adverse events. For example, approximately 25 percent of all trials of epoetin reported on thrombocytopenia or hemorrhagic events; no trials of darbepoetin compared to control or epoetin reported on this outcome.

Trials that compare alternative dosing strategies do not adequately address the possibility that risk of adverse events may be greater with some dosing strategies than others. Of nine dosing strategy comparisons addressed in this review (19 trials), reports of thromboembolic events were available for only five strategies (six trials). For other adverse events, data were available for only four comparisons (six trials).

2. Unpublished studies should be made available as full-text publications.

Many of the trials investigating the effects of erythropoietic stimulants on tumor response and survival have not been published as full-text reports. Much of the evidence that suggests detrimental effect on tumor response and survival was available for the present review only from briefing information presented to the Food and Drug Administration Oncologic Drugs Advisory Committee, May 4, 2004. In the absence of the FDA briefing, this important evidence would not have been available to clinicians, researchers and the public.

3. The following steps should be taken to improve the quality of evidence available from trials reporting quality of life (QoL) outcomes:

- Methods for evaluating clinically significant change in quality of life measures should be refined and used consistently in all reports to support interpretation of findings. To determine the clinical significance of improvements on the FACT-An and its subscales, a clear, empirically-based estimation of the minimum clinically important difference (MID) is needed for each scale. Because anchor-based approaches are difficult to validate and distribution-based methods are statistical, rather than clinical in nature, methodologists currently recommend that MID should be estimated with more than one well established anchor. Distribution-based methods may supplement but should not substitute for anchor-based methods.
- There should be a consensus among researchers as to the core QoL measures. Even for the FACT instrument, the variety of modules used in the present literature makes it difficult to quantitatively compare results. Use of general QoL measures would assist in interpreting anemia-specific measures.
- Investigators should evaluate change in QoL by comparison of change between study and control arms from RCTs. RCTs should be double-blinded and study protocols should minimize bias in administering QoL measures to patients. Results should be reported as the proportion of patients in each study arm achieving the MID.
- Authors should clearly state, by study arm, the numbers of study participants to which QoL results apply. QoL analyses should clearly identify losses to followup and reasons. Prospectively planned statistical analysis should adequately minimize the impact of losses to followup and explore the impact of alternative assumptions about missing data mechanisms as part of their analysis strategies.
- Investigators should give absolute numbers as well as percentages, with measures of variance, when reporting QoL results.

4. Collect and report economic outcomes, particularly when comparing doses, frequencies of treatment, and alternative dosing strategies.

Economic outcomes were not reported in any of the trials included in this review. Economic data could support the development of strategies to maximize value and reduce cost of using erythropoietic stimulants in the management of cancer-related anemia. The present review found no evidence to show that one dosing strategy was superior to another. If outcomes of alternative regimens are equivalent, lower cost may be the deciding factor in selecting one over another.

5. Additional research on single predictors of response is unlikely to be fruitful. Algorithms combining multiple factors might be more useful, but none tested thus far has been shown to have clinical utility.

6. Systematically review existing evidence on baseline and ongoing risks for transfusion and for adverse events, to individualize clinical decisions.

Clinicians need better information to estimate and balance potential benefits (reduced transfusion risk) versus potential harms (increased risk of serious thromboembolic events; other adverse events) based on individual patient characteristics (e.g., type of malignancy, prior treatment history, current regimen, age, sex, comorbidities, etc.). More complete understanding of risks for transfusion and thromboembolic events in cancer patients could be obtained from a systematic review of literature unrelated to erythropoietic stimulant intervention. A patient-level meta-analysis of completed trials on erythropoietic stimulants could delineate risks in better-described, more homogeneous patient categories; questions regarding risk differences in specific patient populations (e.g., younger versus older adults; women versus men) could also be addressed. A patient-level meta-analysis could also determine whether risk of adverse events increases with increasing exposure to erythropoietic stimulants, particularly in non-responding patients who are given higher doses over time. Synthesis of all this information would support decision analysis to aid clinical decisions.

Currently available evidence is insufficient to compare the balance of risk versus benefit of treatment in children versus adults; more trials are needed in pediatric populations.