# Results

## Key Question 1. What are the comparative efficacy and safety of epoetin (alfa or beta) and darbepoetin?

### Overview of Evidence and Findings for KQ1

Three sets of relevant trials were summarized and analyzed for Key Question 1 (for full study details, please refer to Appendix C, KQ1 Appendix Tables C1–C42). Seven studies directly compared epoetin versus darbepoetin (pooled N=1,415 randomized to epoetin, 1,087 to darbepoetin); 48 RCTs tested epoetin versus control (pooled N=4,518 to epoetin, 3,743 to control); and four RCTs tested darbepoetin versus control (pooled N=598 to darbepoetin, 396 to control). Trials within each set differed with respect to outcomes reported, and variables prespecified for subgroup analysis on: study samples’ baseline characteristics; treatment protocols; and publication type, quality ratings, and methods. Effects of baseline hemoglobin concentration on outcomes are also relevant to Key Question 3, which examines alternative thresholds for initiating treatment. To avoid duplication of Forest plots, those shown for this Key Question have trials grouped by mean (or median) baseline hemoglobin.

No trials reported outcomes separately by elderly vs. non-elderly adults, ethnicity, or gender. Only two trials studied pediatric populations (Razzouk, Hockenberry, Hinds, et al., 2004; Henze, Michon, Morland, et al., 2002); each compared epoetin versus control (N=456; 228 each to epoetin and control).

Major findings are summarized in Tables 6-12.

Table 6

Overview: Hematologic Response

Parameter | Darbepoetin vs. epoetin | Epoetin vs. control | Darbepoetin vs. control | (Epoetin or darbepoetin)
Number of studies | 6 | 15 | 3 | no combined analysis for this intermediate (surrogate) outcome; transfusion risk is the relevant primary outcome
Patients analyzed | 2,205 | 3,293 | 659 | no combined analysis for this intermediate (surrogate) outcome; transfusion risk is the relevant primary outcome
Pooled relative risk (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | not amenable to meta- analysis: trials defined response, initiated and adjusted doses, differently; only one RCT (N=352) found significant difference favoring epoetin, but may be biased: dose adjusted differently in each arm; five trials (N=1,853) reported no significant differences | 3.42^1^ (3.03, 3.86)^1^ <0.00001 66%^1^ | 3.36 (2.48, 4.56) <0.00001 0 | no combined analysis for this intermediate (surrogate) outcome; transfusion risk is the relevant primary outcome

1 Since I^2^>25%, compared fixed-effects analysis with random-effects analysis showing RR=3.73; (95% CI: 2.94, 4.74); p<0.00001

CI: confidence interval; RCT: randomized, controlled trial; RR: relative risk

Table 7

Overview: Transfusion Rates

Parameter | Darbepoetin vs. epoetin | Epoetin vs. control | Darbepoetin vs. control | (Epoetin or darbepoetin) vs. control
Number of studies | 6 | 34 | 4 | 32^3^
Patients analyzed | 2,158 | 5,210 | 950 | 5,063^3^
Pooled relative risk (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | 1.10^1^ (0.93, 1.29)^1^ 0.27 42.8%^1^ | 0.63^2^ (0.59, 0.67)^2^ <0.00001 62.9%^2^ | 0.61 (0.52, 0.72) <0.00001 0 | no significant difference, darbepoetin versus epoetin (p=0.35) by univariate analysis of all 38 trials; fixed-effects meta-regression^3^ shows risk reduced more with solid tumors, shorter studies, and unpublished data
Number needed to treat (95% CI) by baseline risk: 30% 50% 70% | | 9 (8, 10) 5 (5, 6) 4 (3, 4) | 9 (7, 12) 5 (4, 7) 4 (3, 5)

1 Since I >25%, compared fixed-effects analysis with random-effects analysis showing RR=0.87; 95% CI: 0.63, 1.20; p=0.40

2 Since I^2^>25%, compared fixed-effects analysis with random-effects analysis showing RR=0.60; 95% CI: 0.53, 0.67), p<0.00001

3 Six trials (N=1,097) lacking information on one or more meta-regression variables were omitted from this analysis. Fixed-effect meta-regression analysis compared darbepoetin with epoetin indirectly, and explored causes of heterogeneity.

Table 8

Overview: Quality of Life

Parameter | Darbepoetin vs. epoetin | (Epoetin or darbepoetin) vs. control^1^
Number of studies | 1 | 15 (13 of epoetin; 2 of darbepoetin)
Patients analyzed | 731^2^ | 3, 610 randomized^3^ (2,947 to epoetin; 663 to darbepoetin)
QoL instruments | FACT-An, FACT-fatigue subscale | FACT-An, FACT-G, FACT-fatigue and FACT-anemia non-fatigue subscales; various general measures; 3-item VAS
Results | No statistically significant differences between study arms in changes from baseline to 16 weeks | QoL results could not be combined quantitatively because of incomplete reporting; therefore we evaluated patterns of tabulated results. Main findings are:; - ○ no results significantly favored control for any QoL measure;; - ○ for each FACT measure, balance among results significantly favoring treatment, not significantly different, and significantly favoring control, favors treatment;; - ○ results from general measures were inconclusive due to heterogeneity of measures and few studies reporting any one measure;; - ○ for each VAS item, balance among results significantly favoring treatment, not significantly different, and significantly favoring control, favors treatment.; Analysis of study quality detected threats to validity in most studies, including lack of blinding, unclear allocation concealment, missing data, and insufficient detail on methods of QoL instrument administration. The clinical significance of study results is uncertain.

1 Studies of epoetin vs. control and darbepoetin vs. control were analyzed together as a class.

2 40% of randomized patients not evaluable for QoL; study available only as abstract/poster.

3 Proportion of enrolled patients not evaluable for QoL varied by study and by instrument, ranging from 0 to 63% and averaging close to 20%.

An: anemia; FACT: Functional Assessment of Cancer Therapy; G: general; QoL: quality of life; VAS: visual analog scale

Table 9

Overview: Survival

Parameter | Darbepoetin vs. epoetin | Epoetin vs. control | Darbepoetin vs. control | (Epoetin or darbepoetin) vs. control
Number of studies^1^ | 1 | 35 | 4 | 39
Patients analyzed | 358 | 6,918 | 973 | 7,891
Pooled hazard ratio (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | Single Trial HR = 1.25^2^ (0.76, 2.07) 0.4 | 1.11 (1.00, 1.22) 0.05 0% | 0.96 (0.78, 1.17) 0.66 72.2% | 1.08 (0.98, 1.18) 0.11 13.4%
HR (95% CI) for subgroups^3^: Labeled use Unlabeled use | | 0.91 (0.47, 1.78) 1.12 (1.01, 1.24) | | 0.91 (0.47, 1.78) 1.09 (0.99, 1.19)
HR (95% CI) for subgroups^3^: Max Hb target: 13 g/dL 14 g/dL 15 g/dL 16 g/dL Trend analysis | | 0.91 (0.47, 1.78) 1.16 (1.00, 1.35) 1.03 (0.90, 1.19) 1.67 (1.13, 2.48) p=0.67 | | 0.91 (0.47, 1.78) 1.16 (1.00, 1.35) 1.01 (0.90, 1.13) 1.67 (1.13, 2.48)

1 Only 7 (N=2,188) studies were prospectively designed to evaluate survival. Other studies may have collected retrospective data after study closure, so that patient management was no longer protocol-directed.

2 Darbepoetin compared to epoetin

3 Subgroup analyses (two shown here) failed to distinguish adverse studies (i.e. poorer survival with epoetin) from others.

CI: confidence interval; Hb: hemoglobin; HR: hazard ratio

Table 10

Overview: Tumor Response and Progression

Parameter | Darbepoetin vs. epoetin | Epoetin vs. control | Darbepoetin vs. control | (Epoetin or darbepoetin)
Tumor Response
Number of studies | none | 5^1^ | none | not applicable
Patients analyzed | | 688
Pooled relative risk (95% CI) | | 1.00 (0.92, 1.10)
p-value for test of overall effect | | 0.91
Test for heterogeneity I^2^ | | 0
Tumor Progression | | one trial (n=351) reported decreased progression- free survival with epoetin; four smaller trials (total N=585) reported no significant effect, but three of four closed prematurely and all likely were underpowered | one trial (n=314) reported progression-free survival did not differ significantly between arms over 24 months followup

1 Studies reported on solid tumors only; none reported on hematologic malignancies.

CI: confidence interval;

Table 11

Overview: Thromboembolic Events

Parameter | Darbepoetin vs. epoetin | Epoetin vs. control | Darbepoetin vs. control | (Epoetin or darbepoetin)
Number of studies | 3 | 30 | 1 | 31
Patients analyzed | 1,879 | 6,092 | 314 | 6,406
Pooled risk ratio^1^ (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | 0.86 (0.61, 1.21) 0.40 0% | 1.69 (1.36, 2.10) <0.00001 0% | Single trial RR = 1.44 (0.47, 4.43) | 1.68 (1.36, 2.08) <0.00001 0%
Number needed to harm (95% CI) by baseline risk: 2.5% 5% 10% 20% | | 58 (36, 111) 29 (18, 56) 15 (9, 28) 7 (5, 14)
RR (95% CI) for subgroups^2^: Labeled use (6.4% of patients) Unlabeled use (93.6% of patients) | | 0.70 1.75 (p=0.046)
RR (95% CI) for subgroups^2^: Max Hb target: 13 g/dL 14 g/dL 15 g/dL 16 g/dL Trend analysis | | 0.70 (0.29, 1.67) 1.71 (1.23, 2.40) 1.92 (1.22, 3.02) 1.66 (1.08, 2.54) p=0.74

1 Unless otherwise noted

2 Subgroup analyses are consistent with the explanation that Hb target >13 g/dL increases thromboembolic event risk; but may be confounded by small numbers in the ≤13 g/dL category and by other factors. There is no clear relationship between incremental increases in target Hb > 13 g/dL and RR for thromboembolic events; the trend is not statistically significant (p=0.742).

CI: confidence interval; Hb: hemoglobin; RR: relative risk;

Table 12

Overview: Other Adverse Events

Parameter | Darbepoetin vs. epoetin | Epoetin vs. control | Darbepoetin vs. control | (Epoetin or darbepoetin) vs. control
Hypertension 1
Number of studies | none | 15 | 1 | not done
Patients analyzed | | 1,949 | 314
Pooled relative risk (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | | 1.22 (0.98, 1.52) 0.07 8.2% | 1.54 (0.56, 4.22) 0.40 not applicable
Thrombocytopenia/Hemorrhage
Number of studies | none | 9 | none | not applicable
Patients analyzed | | 1,422
Pooled relative risk (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | | 1.08 (0.76, 1.53) 0.66 0
Rash
Number of studies | none | 6 | none | not applicable
Patients analyzed | | 522
Pooled relative risk (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | | 1.77 (0.82, 3.81) 0.14 0
Seizures
Number of studies | 1 | 3 | none | not applicable
Patients analyzed | 122 | 389
Pooled relative risk (95% CI) p-value for test of overall effect Test for heterogeneity I^2^ | no seizures in either study arm | 1.19 (0.33, 4.35) 0.79 0

1 definition of hypertension not consistently reported

CI: confidence interval

### Detailed Analysis

#### KQ1 Outcome I. Hematologic Response

This analysis excludes trials with mean or median baseline Hb >12 g/dL, and defines hematologic response as proportion of patients with hemoglobin (Hb) concentration increased from baseline by ≥2 g/dL, or hematocrit (Hct) by six percent, before end of study (see “Introduction” for rationale). Data were abstracted and summarized from trials that defined hematologic response differently, and are reported here qualitatively, but were not included for meta-analyses.

##### Darbepoetin versus Epoetin

Six trials (Appendix C Tables C6, C7, C10, and C13), compared hematologic response rates of patients randomized to darbepoetin versus epoetin (Glaspy and Tchekmedyian, 2002B; Glaspy, Jadeja, Justice, et al., 2003; Waltzman, Croot, Williams, 2005; Schwartzberg, Yee, Senecal, et al., 2004; Alexopoulos and Kotsori 2004; Glaspy, Berg, Tomita, et al., 2005). All were rated as poor study quality, since each was unblinded and described randomization methods inadequately. Results of these trials were not amenable to meta-analysis due to differences in definition of hematologic response, differences in initial doses, and, in three studies (Glaspy and Tchekmedyian, 2002B; Glaspy, Jadeja, Justice, et al., 2003; Waltzman, Croot, Williams, 2005), differences in dose adjustments between epoetin and darbepoetin arms. Three studies compared a darbepoetin dose used commonly in U.S. practices (200 mcg every two weeks; NCCN 2005) with a labeled epoetin dose (40,000 IU/week) (Glaspy, Berg, Tomita, et al., 2005; Schwartzberg, Yee, Senecal, et al., 2004; Waltzman, Croot, Williams, 2005). Study characteristics and results are summarized in Table 13.

Table 13

Study Characteristics and Results of RCTs Directly Comparing Hb Response Rates for Darbepoetin versus Epoetin

Trial | N | | Response: ≥2 g/dL ? | Hb Response Rates | | comment
Trial | Darb | Epo | Response: ≥2 g/dL ? | Darb | Epo | comment
Darbepoetin 200 mcg once per 2 weeks versus Epoetin 40,000 IU once weekly
Waltzman 2005 | 177 | 175 | yes | 41.8% | 57.7% | arms differed in dose adjustment for inadequate response^1^
Waltzman 2005 | 177 | 175 | yes | RR=0.72 (95% CI: 0.58, 0.90) p=0.004 | | arms differed in dose adjustment for inadequate response^1^
Glaspy 2005 | 606 | 603 | no^2^ | 90.3% (95% CI: 87.5%, 93.1%) | 95.5% (95% CI: 93.6%, 97.4%)
Schwartzberg 2004 | 157 | 155 | no^3^ | 68.8% | 72.3%
Schwartzberg 2004 | 157 | 155 | no^3^ | no significant difference
Other Doses
Alexopoulos 2004 4 | 25 | 25 | no^4^ | 44% | 44%
Alexopoulos 2004 4 | 25 | 25 | no^4^ | no significant difference
Glaspy 2002 Part B 5 | 31–33, each of 4 arms | 32 | yes | 56% to 81% | 59% | dose-finding study; dose adjusted only in Epo arm^5^
Glaspy 2002 Part B 5 | 31–33, each of 4 arms | 32 | yes | no significant difference, lowest two darb doses versus epo | | dose-finding study; dose adjusted only in Epo arm^5^
Glaspy 2003 6 | 30–32, each of 3 arms | 30 | yes | 57% to 67% | 50% | dose-finding study of front-loaded darb, not increased for inadequate response^6^
Glaspy 2003 6 | 30–32, each of 3 arms | 30 | yes | no significant difference, any darb arm versus epo arm | | dose-finding study of front-loaded darb, not increased for inadequate response^6^

1 Waltzman 2005 patients with <1 g/dL Hb rise from baseline had 1.5-fold dose increase at week 6 if randomized to darbepoetin (from 200 to 300 mcg Q2W), but at week 4 if randomized to epoetin (from 40,000 to 60,000 IU/week).

2 Glaspy 2005 defined response as reaching Hb ≥11 g/dL and remaining between 11 and 13 g/dL.

3 Schwartzberg 2004 defined response as reaching Hb ≥12 g/dL or increasing by 2 g/dL from baseline to end of study.

4 Alexopoulos 2004 compared 150 mcg darbepoetin once weekly versus 10,000 IU epoetin thrice weekly, and defined Hb response as increasing by ≥1.5 g/dL over baseline by end of study.

5 Glaspy 2002 Part B compared arms given 3, 5, 7, or 9 mcg/kg darbepoetin Q2W versus epoetin 40,000 IU QW; dose increase for inadequate Hb response only permitted for epoetin arm.

6 Glaspy 2003 compared three arms given different front-loaded darbepoetin regimens versus epoetin 40,000 IU QW; dose increase for inadequate Hb response only permitted for epoetin arm.

###### Results

In all but one study, differences in hematologic response rates were not statistically significant, whether measured as defined for this review (proportion with Hb increased by ≥2g/dL from baseline by end of study), or otherwise. The exception was Waltzman, Croot, Williams, (2005), which reported a statistically significant difference in responses by week 17 that favored epoetin. However, this study adjusted dose for inadequate initial response at different times in the two arms (Table 13), potentially biasing the results. Patients with <1 g/dL rise in Hb had the dose increased 1.5-fold at week 6 if randomized to darbepoetin (from 200 to 300 mcg every 2 weeks), but at week 4 if randomized to epoetin (from 40,000 to 60,000 IU/week).

Taken together, trials directly comparing darbepoetin versus epoetin did not demonstrate that one drug achieves hematologic response in a larger proportion of patients than the other. However, conclusions from direct comparisons were limited since trials defined hematologic response, and initiated and adjusted doses, differently. Therefore, we also examined indirect evidence from trials comparing epoetin versus control or darbepoetin versus control.

###### Epoetin versus Control

Characteristics of reporting studies are enumerated in Table 14. Fifteen trials (N=3,293; 1,844 to epoetin, 1,449 to control) reported hematologic response rates as defined for this review (Bamias, Aravantinos, Kalofonos, et al., 2003; Boogaerts, Coiffier, Kainz, 2003; Case, Bukowski, Carey, et al., 1993; Cazzola, Messinger, Battistel, et al, 1995; Chang, Couture, Young, et al., 2005; Dammacco, Castoldi, Rodjer, et al., 2001; Henry, Brooks, Case, et al., 1995; Iconomou, Koutras, Rigopoulos, et al., 2003; Littlewood, Bajetta, Nortier, et al., 2001; Oberhoff, Neri, Amadori, et al., 1998; Osterborg, Boogaerts, Cimino, et al., 1996; Osterborg, Brandberg, Molostova, et al., 2002; Rose, Rai, Revicki, et al., 1994; Savonije, Van Groeningen, Van Bochove, et al., 2004; Witzig, Silberstein, Loprinzi, et al., 2005). Two of the 15 studies (Cazzola, Messinger, Battistel et al., 1995; Osterborg, Boogaerts, Cimino et al., 1996) tested two different epoetin doses and were evaluated as two trials each.

Table 14

Study Characteristics and Subgroup Analyses of RCTs Reporting Hematologic Responses (as defined in Scope and Key Questions)

Outcome | Epoetin versus Control | | | | | Darbepoetin versus Control
Subgroup | # Studies | # Total Patients | #Epo/#Ctl Patients | RR | 95% CI (p- value) | # Studies | # Total Patients | #Darb/#Ctl Patients | RR | 95% CI (p- value)
Hb Response | 15 | 3,293 | 1844/1449 | 3.42 | 3.03; 3.86 | 3 | 659 | 427/232 | 3.36 | 2.48; 4.56
(Heterogeneity) | | | | | (<0.0001) | | | | | (0.98)
Subgroup Analyses: Patient Baseline Characteristics
Baseline Hb <10 | 11 | 2,372 | 1,329/1,043 | 3.24 | 2.82; 3.73 | (all) | 659 | 427/232
Baseline Hb 10–12 | 4 | 921 | 515/406 | 3.98 | 3.11; 5.10
Baseline Hb >12
Baseline Hb ?
(Group difference^1^) | | | | | (0.563)
Solid tumors | 7^*^ | 1,660 | 925/735 | 3.30 | 2.80; 3.88 | 1 | 249 | 198/51 | 3.51 | 1.74; 7.08
Hematologic | 6^*^ | 1,093 | 643/450 | 3.30 | 2.68; 4.06 | 2 | 410 | 229/181 | 3.31 | 2.37; 4.63
Mixed | 3 | 450 | 276/264 | 4.32 | 3.04; 6.13
(Group difference^1^) | | | | | (0.136) | | | | | (0.9715)
Children
Adults | (all) | 3,293 | 1844/1449 | | | (all) | 659 | 427/232
(Group difference^1^)
Subgroup Analyses: Treatment Protocols
Chemo, all plat | 3 | 584 | 347/237 | 2.89 | 2.18; 3.84
Chemo, some plat | 5 | 1,053 | 535/518 | 3.12 | 2.56; 3.81
Chemo, no plat | 7 | 1,656 | 962/694 | 3.84 | 3.21; 4.58
Chemo, plat ?
Chemo+RT or RT
Unknown
(Group difference^1^) | | | | | (0.212)
Iron, fixed | 2 | 441 | 222/219 | 2.43 | 1.92; 3.07
Iron, as needed | 10 | 2,249 | 1,244/1,005 | 4.13 | 3.51; 4.85
Iron ? | 3 | 603 | 378/225 | 2.25 | 1.94; 3.35
(Group difference^1^) | | | | | (0.002)
Epo tx 6–9 weeks | 1 | 86 | 57/29 | 8.91 | 2.30; 34.50
Epo tx 12–16 weeks | 11 | 2,560 | 1,376/1,184 | 3.31 | 2.91; 3.77 | (all) | 659 | 427/232
Epo tx >20 weeks | 4 | 647 | 411/236 | 3.65 | 2.62; 5.05
Epo tx ? weeks
(Group difference^1^) | | | | | (0.1509)
Subgroup Analyses: Reporting and Study Quality
High quality | 6 | 1,530 | 864/666 | 2.94 | 2.53; 3.43 | (all) | 659 | 427/232
Low quality | 9 | 1,763 | 980/783 | 4.13 | 3.40; 5.01
(Group difference^1^) | | | | | (0.0414)
Data from full text | 9 | 1966 | 1,055/91 | 4 | 3.39; 4.71 | (all) | 659 | 427/232
Data from abstract | 1 | 314 | 211/104 | 2.25 | 1.66; 3.04
Data unpublished | 5 | 1012 | 578/434 | 3.05 | 2.45; 3.80
Data from FDA
(Group difference^1^) | | | | | (0.0416)

1 p value for differences among subgroup categories calculated by inverse variance method (see Methods/Data Extraction and Analysis/Statistical Data Analysis)

* Note: Littlewood 2001 was split into two subsets for malignancies: solid and hematologic malignancies since Hb responses were reported separately

CI: confidence interval; Ctl: control; darb: darbepoetin; epo: epoetin; Hb: hemoglobin; plat: platinum;

RT: radiotherapy; tx: treatment

Eight others (Carabantes, Benavides, Trujillo, et al., 1999; Cascinu, Fedeli, Del Ferro, et al., 1994; Del Mastro, Venturini, Lionetto, et al., 1997; Henke, Guttenberger, Barke, et al., 1999; Henke, Laszig, Ruebe, et al., 2003; Huddart, Welch, Chan, et al., 2002; Kurz, Marth, Windbichler, et al., 1997; Silvestris, Romito, Fanelli, et al., 1995) used different definitions or did not report separately by study arm.

Trials that defined hematologic response rates as in this review differed with respect to several variables prespecified for subgroup analysis (Figure 3, Table 14). Baseline characteristics of study populations differed by average baseline Hb concentration and type of malignancy. Treatment protocols differed by therapies for malignancy, iron supplementation, and duration of epoetin treatment. Trials also varied with respect to publication type and overall quality rating.

###### Results

Each trial reported significantly more hematologic responses among patients randomized to epoetin than among patients randomized to controls. Trials that used the most common definition of hematologic response were pooled for meta-analysis. A test for heterogeneity across these 15 trials was strongly significant (p<0.0001, I^2^ =66.0 percent). Therefore, both fixed- and random-effects meta-analyses were conducted and showed no substantive difference in the results.

Meta-analysis of data from all 15 trials^1^ (Figure 4) yielded:

1 In the Cazzola and Osterborg studies, two different epoetin dosages were compared with one control group. For the meta-analysis, each trial’s control group was split artificially into two groups. Given the low total weight for these two studies (4.98%), it is unlikely that splitting the controls influenced the meta-analytic results.

- Fixed-effects: relative risk (RR) = 3.42 (95 percent CI: 3.03, 3.86), p<0.00001
- Random-effects: RR = 3.73 (95 percent CI: 2.94, 4.74), p<0.00001
- Pooled response (event) rates (range across trials) were 58 percent (20.8 percent to 72.7 percent) for epoetin treatment arms and 16.5 percent (2.8 percent to 31.7 percent) for control arms.
- RRs ranged from 2.25 (95 percent CI: 1.66, 3.04; Savonije 2004) to 10.45 (95% CI: 5.84, 18.71; Chang 2004).

Figure 4

Fixed-Effects Meta-Analysis of Data on Hematologic Response Rates from 15 RCTs of Epoetin versus Control

Univariate subgroup analyses found three statistically significant associations (Table 14). All subgroup differences were in magnitude rather than direction of effect: hematologic responses were consistently more frequent in epoetin arms than in controls for all subgroups. Variables significantly associated with increased likelihood (larger RR) of hematologic response were: iron supplementation as needed (vs. fixed iron or iron unknown); lower quality studies (vs. higher quality studies); and full-text publication (vs. abstract only or unpublished data).

However, availability of only two trials (N=441) in the “fixed iron” subgroup (Table 14) limits the analysis on effects of iron. These data were compared with 10 trials (N=2,299) that gave iron supplementation as necessary and three (N=603) that did not report on iron supplementation. The significant difference found in univariate analysis might be confounded by other factors.

Five trials that defined hematologic response differently from those in the pooled analysis also reported greater response rates in the arms randomized to epoetin than in control arms (Appendix C Table C14). Definitions included reaching and maintaining Hb >10 g/dL (Cascinu, 1994; Del Mastro, 1997), reaching Hb>14 for women or >15 for men (Henke 2003), a 2 g/dL increase or reaching Hb >12 g/dL (Kurz 1997), and a 2 g/dL increase or an increase in reticulocyte counts >40×10^9^ (Huddart 2002).

###### Darbepoetin versus Control

Characteristics of reporting studies are enumerated in Table 14. Three of four trials comparing darbepoetin versus control (Hedenus, Hansen, Taylor, et al., 2002; Hedenus, Adriansson, San Miguel, et al., 2003; Kotasek, Steger, Faught, et al., 2003) reported the proportion of hematologic responders as defined for this review (N=659; 427 to darbepoetin, 232 to control). Two of these studies (Hedenus, Hansen, Taylor, et al., 2002; Kotasek, Steger, Faught, et al., 2003) tested several doses and were evaluated as three and six trials, respectively. The fourth trial used a different definition of response and was not included in the meta-analysis (Vansteenkiste, Pirker, Massuti, et al., 2002).

Trials that reported Hb response rates as defined for this review differed with respect to several variables prespecified for subgroup analysis (Figure 3, Table 14). Patient groups differed only by type of malignancy. Treatment protocols differed by therapies for malignancy and use of iron supplementation.

###### Results

As with the epoetin versus control trials, each trial reported more frequent hematologic responses among patients treated with darbepoetin than among controls (see Figure 5). Results were not statistically significant for any arm from the two dose-finding studies (Hedenus 2002; Kotasek 2003), but were significant for the third trial (Hedenus 2003). A test for heterogeneity across trials included for Hb response was not statistically significant (p=0.98, I^2^ =0 percent). An I^2^ value of zero percent indicates no observed statistical heterogeneity, thus only a fixed-effects meta-analysis was done.

Figure 5

Fixed-Effects Meta-Analysis of Data on Hematologic Response Rates from Three RCTs of Darbepoetin versus Control

Fixed-effects meta-analysis^1^ (Figure 5) yielded:

1 In two studies, three (Hedenus 2002) or six (Kotasek 2003) different darbepoetin dosages were compared with one control group. For the meta-analysis the control group was split artificially into the same number of dose groups. As this might influence weighting of the studies, the analysis was repeated with the all relevant dose arms of each study merged into a single experimental arm compared to the entire control group. The overall result (RR 3.45 (95% CI: 2.53, 4.71) was similar to the base model. Additionally, a meta-analysis was performed using FastPro, which allows multi-dose entries with a single control arm, and combination using an empirical Bayes method. Setting 2.25 mcg/kg per week as the standard dose, the results were again similar: RR 3.50 (95% CI: 2.03, 6.04).

- RR = 3.36 (95% CI: 2.48, 4.56), p<0.00001
- pooled response rates (range by trial arms): darbepoetin arms 54.1% (25% to 84 percent); control arms: 16.9% (9% to 18.2%)
- RR (likelihood) to achieve response across the trials’ darbepoetin dose arms ranged from 1.36 to 6.30 (Hedenus 2002a, 95% CI: 0.24, 7.66; Hedenus 2002c, 95% CI: 0.45, 89.06).

Univariate subgroup analyses found no statistically significant differences.

#### KQ1 Outcome II. Transfusion Rates

For purposes of this report, transfusion rate is defined as the proportion of patients transfused with red blood cells (or whole blood) at least once during the study.

##### Evidence for Comparative Effectiveness

###### Darbepoetin versus Epoetin

Characteristics of reporting studies are enumerated in Table 15. Six RCTs (N=2,158; 1,169 to darbepoetin, 989 to epoetin) compared darbepoetin versus epoetin for their effects on transfusion rates (Appendix C Table C21; Glaspy, Jadeja, Justice, et al., 2002A; Waltzman, Croot, Williams, 2005; Schwartzberg, Yee, Senecal, et al., 2004; Alexopolous and Kotsori, 2004; Glaspy, Berg, Tomita, et al., 2005; Glaspy and Tchekmedyian, 2002B). All were judged to be of poor quality, since each was unblinded and described randomization methods inadequately. Another trial monitored, but did not report, transfusion rates (Glaspy, Jadeja, Justice, et al., 2003). Available studies defined transfusion rate consistently, permitting pooled analysis of data from trials comparing adequate doses of the two drugs. One study reported separately on three patient groups, each with a different malignancy (Schwartzberg 2004 arms a–c). Two studies compared different doses of darbepoetin versus a single dose of epoetin (Glaspy 2002A and B; Figure 6). The meta-analysis evaluated darbepoetin doses of 1.5, 2.25, and 4.5 mcg/kg weekly from one trial (Glaspy 2002A arms c–e), and all doses (3, 5, 7, and 9 mcg/kg biweekly) from the other (Glaspy 2002B arms a–d) as three and four trials, respectively. Thus, the meta-analysis included a total of 13 comparisons.

Table 15

Study Characteristics and Subgroup Analyses of RCTs Reporting Transfusion Responses

Outcome | Darbepoetin versus Epoetin | | | | | Epoetin versus Control | | | | | Darbepoetin versus Control
Subgroup | # Studies | #Total Patients | #Darb/#Epo Patients | Relative Risk | 95% CI (p-value) | # Studies | #Total Patients | #Epo/#Ctl Patients | Relative Risk | 95% CI (p-value) | # Studies | #Total Patients | #Darb/#Ctl Patients | Relative Risk | 95% CI (p-value)
Transfusion | 6 | 2,158 | 1,169/989 | 1.10 | 0.93; 1.29 | 34 | 5,210 | 2,859/2,351 | 0.63 | 0.59; 0.67 | 4 | 950 | 566/384 | 0.61 | 0.52; 0.72
(Heterogeneity) | | | | | (0.27) | | | | | (<0.00001) | | | | | (1.00)
Subgroup Analyses: Patient Baseline Characteristics
Bsln Hb <10 | 2 | 199 | 144/55 | 0.55 | 0.31; 0.96 | 15 | 2,805 | 1,547/1,258 | 0.70 | 0.64; 0.76 | 3 | 636 | 410/226 | 0.61 | 0.49; 0.76
Bsln Hb 10–12 | 4 | 1,959 | 1,025/934 | 1.16 | 0.97; 1.37 | 12 | 1,781 | 972/809 | 0.42 | 0.36; 0.50 | 1 | 314 | 156/158 | 0.60 | 0.47, 0.78
Bsln Hb >12 | | | | | | 5 | 302 | 179/123 | 0.56 | 0.40; 0.80
Bsln Hb ? | | | | | | 2 | 322 | 161/161 | 0.80 | 0.68; 0.95
(Group difference^1^) | | | | | | | | | | (<0.0001) | | | | | (0.967)
Solid tumors | (all) | | | | | 22 | 2,924 | 1,620/1,304 | 0.5 | 0.45; 0.56 | 2 | 552 | 344/208 | 0.59 | 0.48; 0.73
Hematologic | | | | | | 6 | 1,111 | 647/464 | 0.74 | 0.66; 0.84 | 2 | 398 | 222/176 | 0.64 | 0.49; 0.83
Mixed/unknown^2^ | | | | | | 7 | 1,175 | 592/583 | 0.74 | 0.67; 0.83
(Group difference^1^) | | | | | | | | | | (<0.0001) | | | | | (0.6984)
Children | | | | | | 2 | 454 | 227/227 | 0.87 | 0.77; 0.99
Adults | (all) | | | | | 32 | 4,756 | 2,632/2,124 | 0.59 | 0.55; 0.64 | (all)
(Group difference^1^) | | | | | | | | | | (0.0001)
Subgroup Analyses: Treatment Protocols
Chemo, all plat | | | | | | 13 | 1,251 | 744/507 | 0.51 | 0.45; 0.58 | 1 | 314 | 156/158 | 0.60 | 0.47; 0.78
Chemo, some plat | 2 | 1,471 | 745/726 | 1.24 | 1.03; 1.41 | 7 | 1,478 | 744/734 | 0.59 | 0.50; 0.68 | 1 | 238 | 188/50 | 0.56 | 0.38; 0.83
Chemo, no plat | | | | | | 8 | 1,733 | 999/734 | 0.72 | 0.64; 0.80 | 2 | 398 | 222/176 | 0.64 | 0.49; 0.83
Chemo, plat unknown
Chemo+RT | | | | | | 2 | 113 | 56/57 | 0.31 | 0.13; 0.71
Unknown | 4 | 687 | 424/263 | 0.75 | 0.54; 1.04 | 4 | 635 | 316/319 | 0.76 | 0.67; 0.87
(Group difference^1^) | | | | | | | | | | (<0.0001) | | | | | (0.8824)
Iron, fixed | | | | | | 5 | 898 | 450/448 | 0.51 | 0.41; 0.65
Iron, as needed | | | | | | 18 | 3,030 | 1,684/1,346 | 0.65 | 0.59; 0.71 | 1 | 332 | 167/165 | 0.65 | 0.49; 0.86
Iron unknown | (all) | | | | | 11 | 1,282 | 725/557 | 0.64 | 0.58; 0.72 | 3 | 618 | 399/219 | 0.59 | 0.47; 0.72
(Group difference^1^) | | | | | | | | | | (0.0195) | | | | | (0.5269)
Epo tx 6–9 weeks | | | | | | 5 | 320 | 182/138 | 0.43 | 0.28; 0.65
Epo tx 12–16 weeks | (all) | | | | | 18 | 3,189 | 1,689/1,500 | 0.64 | 0.59; 0.69 | (all)
Epo tx >20 weeks | | | | | | 10 | 1,329 | 802/527 | 0.67 | 0.60; 0.75
Epo tx ? Weeks | | | | | | 1 | 372 | 186/186 | 0.4 | 0.23; 0.67
(Group difference^1^) | | | | | | | | | | (0.0062)
Subgroup Analyses: Reporting and Quality
High quality | | | | | | 13 | 2,190 | 1,194/996 | 0.69 | 0.63; 0.76 | (all)
Low quality | (all) | | | | | 21 | 3,020 | 1,665/1,355 | 0.58 | 0.52; 0.63
(Group difference^1^) | | | | | | | | | | (0.2342)
Data from full text | 3 | 637 | 399/238 | 0.72 | 0.52; 1.01 | 18 | 2,472 | 1,376/1,096 | 0.56 | 0.50; 0.63 | 3 | 636 | 410/226 | 0.61 | 0.49; 0.76
Data from abstract | 3 | 1,521 | 770/751 | 1.25 | 1.03; 1.5 | 10 | 1,560 | 834/726 | 0.62 | 0.55; 0.69
Data unpublished | | | | | | 6 | 1,178 | 649/529 | 0.75 | 0.66; 0.84
Data from FDA | | | | | | | | | | | 1 | 314 | 156/158 | 0.6 | 0.47; 0.78
(Group difference^1^) | | | | | | | | | | (0.0003) | | | | | (0.967)

1 p value for differences among subgroup categories calculated by inverse variance method (see Methods/Data Extraction and Analysis/Statistical Data Analysis)

2 The Littlewood 2001 study was split into two separate studies for this analysis (solid tumors and hematological malignancies), therefore the overall number of studies in this subgroup analysis appears to be 35 instead of 34. The Thomas 2002 (n=127) study did not report type of malignancy investigated and was classified in the ‘mixed’ category.

Figure 6

Fixed-Effects Meta-Analysis of Data on Transfusion Rates from Six RCTs of Darbepoetin versus Epoetin

Trials that reported transfusion rates differed with respect to several variables prespecified for subgroup analysis (Figure 3, Table 15). Patient groups varied by average baseline Hb concentration, but univariate subgroup analysis was not done since the variation was minimal (Appendix C Table C7). Treatment protocols differed by therapies for malignancy and epoetin/darbepoetin treatment duration. The trials also varied with respect to publication type.

###### Results

Seven of 13 comparisons for relative risk of transfusion (RR, darbepoetin to epoetin, Figure 6) favored darbepoetin. RR ranged from 0.12 to 0.62 (Glaspy 2002 PB a, 95% CI: 0.01, 1.11; Glaspy 2002 PB b, 95% CI: 0.21, 1.88). The other six comparisons (darbepoetin to epoetin) favored epoetin, and RR ranged from 1.16 to 1.56 (Glaspy 2002 PA c, 95% CI: 0.41, 3.25; Schwartzberg 2004b, 95% CI: 0.74, 3.27). However, no single comparison was statistically significant: each RR had 95% CI limits that included 1.0. A test for heterogeneity across studies just reached statistical significance (p=0.05); an I^2^ value of 42.8% suggested moderate heterogeneity (Higgins, Thompson, Deeks et al., 2005). However, fixed- and random-effects meta-analyses showed no meaningful difference in the results; although point estimates for the two types of meta-analysis were on opposite sides of 1.0, confidence intervals for both included 1.0, overlapped considerably, and were not statistically significantly different.

Meta-analysis^6^ showed (Figure 6):

6 In two of the six included studies, three (Glaspy 2002 Part A) and four (Glaspy 2002 Part B) different darbepoetin doses were compared with one control group each. For meta-analysis, the control groups were split artificially into the corresponding number of groups. As this might influence weighting of studies, the analysis was repeated with all dose arms of each study merged into one experimental arm, then compared to the trial’s full control group. The overall result (RR=1.10, 95% CI: 0.93, 1.29) was almost identical to the base model. Additionally, a second meta-analysis used FastPro, which allows multi-dose entries with a single control arm, and combines results using an empirical Bayesian method. With standard dose set as 2.25 μg/kg weekly, relative risk was 0.99, 95% CI: 0.70, 1.39.

- Fixed-effects RR = 1.10 (darbepoetin to epoetin; 95% CI: 0.93,1.29), p=0.27
- Random-effects RR= 0.87 (darbepoetin to epoetin; 95% CI: 0.63, 1.20), p=0.40
- pooled transfusion rates (ranges across trials and dose arms): darbepoetin arms, 21.6% (3.3% to 27.5%); epoetin arms, 20% (12% to 42.9%)
- subgroup analyses were not done since the few differences between trials were either minimal (baseline Hb) or lacked adequate information (therapies for malignancy).

With respect to effects on transfusion rates, the fixed-effects and random-effects meta-analyses support neither superiority nor inferiority for darbepoetin compared with epoetin. The fixed-effects point estimate favors epoetin, while the random-effects point estimate favors darbepoetin; however, the confidence intervals overlap, and each includes 1.0 (no difference). The analyses do not exclude the possibility that a larger and more homogeneous data set might show superiority (within these confidence limits) for one of the drugs. We evaluated indirect evidence (studies of epoetin versus control and darbepoetin versus control) to further compare effects on transfusion rates.

###### Epoetin versus Control

Characteristics of reporting studies are enumerated in Table 15. Thirty-four RCTs (N=5,210; 2,859 to epoetin, 2,351 to control) reported transfusion rates as defined for this review (Appendix C Tables C2, C3, and C8; Aravantinos, Linardou, Makridaki, et al., 2003; Bamias, Aravantinos, Kalofonos, et al., 2003; Boogaerts, Coiffier, Kainz, 2003; Carabantes, Benavides, Trujillo, et al., 1999; Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Cazzola, Messinger, Battistel, et al, 1995; Chang, Couture, Young, et al., 2005; Dammacco, Castoldi, Rodjer, et al., 2001; Del Mastro, Venturini, Lionetto, et al., 1997; Dunphy, Harrison, Dunleavy, et al., 1999; Henry, Brooks, Case, et al., 1995; Henze, Michon, Morland, et al., 2002; Huddart, Welch, Chan, et al., 2002; Iconomou, Koutras, Rigopoulos, et al., 2003; Janinis, Dafni, Aravantinos, et al., 2003; Kunikane, Watanabe, Fukuoka, et al., 2001; Kurz, Marth, Windbichler, et al., 1997; Littlewood, Bajetta, Nortier, et al., 2001; Oberhoff, Neri, Amadori, et al., 1998; Osterborg, Boogaerts, Cimino, et al., 1996; Osterborg, Brandberg, Molostova, et al., 2002; Quirt, Micucci, Moran, et al., 1996; Razzouk, Hockenberry, Hinds, et al., 2004; Rose, Rai, Revicki, et al., 1994; Savonije, Van Groeningen, Van Bochove, et al., 2004; ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; Thomas, McAdam, Thomas, et al., 2002; Throuvalas, Antonadou, Boufi, et al., 2000; Vadhan-Raj, Skibber, Crane, et al., 2004; Welch, James, Wilkinson, 1995; Witzig, Silberstein, Loprinzi, et al., 2005; Wurnig, Windhager, Schwameis, et al., 1996). Five trials (Cazzola 1995 c-d; ten Bokkel Huinink 1998 a-b; Kunikane 2001 a-b; Thatcher 1999 a-b; Osterborg 1996 a-b) each tested two different doses or methods of titrating dose; each study was evaluated as two trials.

One other trial focusing on QoL outcomes was excluded (Appendix C Table C24: O’Shaughnessy, Vukelja, Holmes, et al., 2005), since patients were removed from either arm of this double-blind study if 1) Hb fell below 8 g/dL; 2) they were transfused for another clinical indication; or 3) they received non-study (“commercial”) epoetin based on clinical necessity.

Trials that reported transfusion rates differed with respect to several variables prespecified for subgroup analysis (Figure 3, Table 15). Baseline characteristics of study populations differed by average baseline Hb concentration, type of malignancy, and age range. Treatment protocols differed by therapies for malignancy, iron supplementation, and epoetin treatment duration. Trials also varied with respect to publication type and overall quality rating.

###### Results

The overwhelming majority of trials reported fewer transfusions among those randomized to epoetin than among those randomized to control. However, differences between epoetin and control arms (or reductions in risk of transfusion) were not always statistically significant (see Figure 7). A test for heterogeneity across trials included for transfusion was strongly significant (p<0.00001, I^2^ = 62.9 percent). Fixed- and random-effects meta-analyses showed no substantive difference in results.

Figure 7

Meta-Analysis of Data on Relative Risk of Transfusion from 34 RCTs of Epoetin versus Control

Meta-analysis of data from all 34 RCTs^7^ (Figure 7) yielded:

7 In two of the six included studies, three (Glaspy 2002 Part A) and four (Glaspy 2002 Part B) different darbepoetin doses were compared with one control group each. For meta-analysis, the control groups were split artificially into the corresponding number of groups. As this might influence weighting of studies, the analysis was repeated with all dose arms of each study merged into one experimental arm, then compared to the trial’s full control group. The overall result (RR=1.10, 95% CI: 0.93, 1.29) was almost identical to the base model. Additionally, a second meta-analysis used FastPro, which allows multi-dose entries with a single control arm, and combines results using an empirical Bayesian method. With standard dose set as 2.25 μg/kg weekly, relative risk was 0.99, 95% CI: 0.70, 1.39.

- Fixed-effects RR = 0.63 (95 percent CI: 0.59; 0.67), p<0.00001
- Random-effects RR = 0.60 (95 percent CI: 0.53; 0.67), p<0.00001
- pooled transfusion rates (range across trials): epoetin arm, 30.2 percent (0 percent to 91.4 percent); control arms, 47.2 percent (0 percent to 100 percent)
- RR ranged from 0.11 to 2.89 (ten Bokkel 1998 a, 95 percent CI: 0.02, 0.47; Kunikane 2001 b, 95 percent CI: 0.15, 54.98).

Epoetin consistently reduced transfusion risk in all subgroups analyzed (see Table 15). Seven variables were statistically significant predictors (by univariate analysis; see Methods/Data Extraction and Analysis/Statistical Data Analysis) for subgroups with a smaller relative risk of transfusion in epoetin arms compared with controls (p values in bold font, Table 15). Univariate analysis also suggested transfusion risk may have been reduced to a greater extent in trials whose participants had mean baseline Hb from 10 to 12 g/dL (RR=0.42; 95 percent CI: 0.36, 0.50) than in trials with baseline Hb <10 g/dL (RR=0.70; 95 percent CI: 0.64, 0.76) or >12 g/dL (RR=0.56; 95 percent CI: 0.40, 0.80). However, subgroup differences for other patient and study variables may have confounded this result.

Seeking better insight into potentially important subgroup differences identified in univariate analyses, we used meta-regression to explore independent sources of heterogeneity across included trials (follows next two sections).

###### Darbepoetin versus Control

Characteristics of reporting studies are enumerated in Table 15.

Four trials (N=950; 566 to darbepoetin, 384 to control) reported effects of darbepoetin on transfusion rates (Appendix C Tables C4, C5, and C9; Hedenus, Hansen, Taylor, et al., 2002; Hedenus, Adriansson, San Miguel, et al., 2003; Kotasek, Steger, Faught, et al., 2003; Vansteenkiste, Pirker, Massuti, et al., 2002). Two trials (Hedenus 2002a–c; Kotasek 2003 a–f) tested different doses of darbepoetin (three and six, respectively) versus single control groups; therefore, each dosage arm was analyzed as a separate study.

Trials that reported transfusion rates differed with respect to several variables prespecified for subgroup analysis (Figure 3, Table 15). Patient groups differed by average baseline Hb concentration and malignancy type. Treatment protocols differed by therapies for malignancy and iron supplementation. The trials also varied with respect to type of publication.

###### Results

Each trial comparing darbepoetin versus control reported proportionally fewer transfusions in darbepoetin arms than in controls. However, risk reduction was not statistically significant in any individual dose arm from multi-dose trials (Figure 8), most likely because each trial’s single control arm was artificially split into smaller groups for the analysis. A test for heterogeneity across trials and dose arms included for transfusion was not statistically significant (p=1.00, I^2^ =0 percent). An I^2^ value of zero percent indicates absence of statistical heterogeneity, thus only a fixed-effects meta-analysis was done.

Figure 8

Meta-Analysis of Data on Transfusion Rates from Four RCTs of Darbepoetin versus Control

Meta-analysis of data from the four RCTs^8^ (Figure 8) yielded:

8 In two studies, 3 (Hedenus 2002a–c) and 6 (Kotasek 2003a–f) different darbepoetin dose arms were compared with one control group each. For meta-analysis, the control groups were split artificially into the corresponding number of groups. As this might influence weighting of studies, the analysis was repeated with all dose arms of each study merged into one experimental arm, then compared to the trial’s full control group. The overall result (RR 0.61; 95% CI: 0.51, 0.72) was almost identical to the base model. Additionally, a second meta-analysis used FastPro, which allows multi-dose entries with a single control arm, and combines results using an empirical Bayesian method. With standard dose set as 2.25 mcg/kg weekly, relative risk was slightly more favorable: 0.51; 95 % CI: 0.40, 0.64.

- Fixed-effects RR = 0.61 (95% CI 0.52; 0.72), p<0.00001
- pooled transfusion rates (ranges across trials and dose arms): darbepoetin arms, 29.2% (13.6% to 34.0%); control arms, 51% (25% to 66.7%)
- RR ranged from 0.41 to 0.69 (Hedenus 2002a, 95% CI: 0.12, 1.43; Kotasek 2003 e, 95% CI: 0.24, 1.97).

For each variable tested by univariate analysis, there were no statistically significant differences among subgroups.

###### Indirect Comparison

Thirty four trials (N=5,210) compared epoetin versus control. Pooled RR of transfusion for epoetin treated patients compared to control was 0.63 (95 percent CI: 0.59, 0.67; p<0.00001). Four trials (N=950) compared darbepoetin versus control. Pooled RR of transfusion for darbepoetin treated patients compared to control was 0.61 (95 percent CI: 0.52, 0.72; p<0.00001). Pooled transfusion rates also showed similar results for epoetin or darbepoetin vs. control: epoetin 30 percent versus control 47 percent darbepoetin 29 percent versus control 51 percent

The actual benefit of treatment with an erythropoietic stimulant depends on the patient’s underlying risk of transfusion. Trials ranged widely with respect to the percent of control arm patients who underwent transfusion: 0–100 percent in epoetin trials and 25 percent to 66.7 percent in darbepoetin trials. To illustrate, we calculated overall number-needed-to-treat (NNT) with epoetin^9^ or darbepoetin to spare one patient from transfusion, at representative baseline transfusion risks (Table 16).

9 Since the epoetin-versus-control meta-analysis showed statistically significant heterogeneity across trials, we used a L’Abbe plot (transfusion rate in the epoetin arm as a function of transfusion rate in the corresponding control arm; see Methods and Appendix F) to confirm that RR was relatively constant across the range of baseline risks, justifying calculation of an overall number-needed-to-treat (NNT) to spare one patient from transfusion.

Table 16

Calculated Numbers Needed to Treat (NNT) to Spare One Patient from Transfusion, at Representative Baseline Risks of Transfusion

Baseline Risk | Epoetin | | | Darbepoetin
Baseline Risk | NNT | 95% confidence interval | | NNT | 95% confidence interval
Baseline Risk | NNT | lower limit | upper limit | NNT | lower limit | upper limit
30% | 9.01 | 8.13 | 10.10 | 8.55 | 6.94 | 11.90
50% | 5.41 | 4.88 | 6.06 | 5.13 | 4.17 | 7.14
70% | 3.86 | 3.48 | 4.33 | 3.66 | 2.98 | 5.10

At each level of baseline risk, the NNT (rounded to the nearest whole number) to spare one patient from transfusion is the same for darbepoetin as for epoetin, except that confidence intervals are slightly wider.

###### Meta-regression of RCTs that Compared Epoetin or Darbepoetin versus Control

To better compare darbepoetin with epoetin indirectly for their transfusion-sparing effects, and also to explore causes of heterogeneity in meta-analysis on red blood cell transfusion rates, we used a fixed-effect meta-regression analysis.

###### Pooling studies

Because epoetin (RR=0.63; 95% CI: 0.59, 0.67) and darbepoetin (RR=0.61; 95% CI: 0.52, 0.72) appeared similar in their ability to reduce transfusion risk, we pooled studies comparing epoetin versus placebo/no treatment and studies comparing darbepoetin versus placebo/no treatment, to increase statistical power. After pooling, the following categorical variables (subgroups defined in Table 15) were statistically significant in univariate analyses (p values calculated by inverse variance method; see Methods/Data Extraction and Analysis/Statistical Data Analysis):

- Hemoglobin at study entry (p<0.0001)
- Type of malignancy (p<0.0001)
- Type of treatment (p<0.0001)
- Iron supplementation (p=0.041)
- Duration of epoetin or darbepoetin treatment (p=0.0042)
- Type of publication (p=0.0008)
- Age range (adults versus children) (p<0.0001)

Univariate analyses showed that neither study quality nor type of erythropoietic stimulant (epoetin or darbepoetin; p=0.35) were statistically significant predictors for RR of transfusion. Consequently, both variables were omitted from the meta-regression.

##### Evidence Regarding the Class of Erythropoietic Stimulants

The meta-regression explored whether variables found statistically significant in univariate analyses contributed independently to heterogeneity in meta-analysis of transfusion risk reduction by erythropoietic stimulants.

###### Adjustments for inadequate information

For iron supplementation, the “unclear” subgroup (i.e., studies that did not report on iron use) included 14 trials with 1,900 patients (34.6 weight percent of the overall analysis), which hampered meaningful analysis. Consequently, we omitted the iron supplementation variable from further univariate or multivariate analyses, despite current uncertainties concerning optimal adjunctive iron therapy. All other factors significant in initial univariate analyses remained significant after omitting the iron supplementation variable.

To define a data set limited to trials with unambiguous information on each significant variable, we also omitted six trials with 1,097 patients (19.7 weight percent of the overall analysis) that were classified as “unclear” for one or more variable(s) (Quirt, Micucci, Moran, et al., 1996; Henze, Michon, Morland, et al., 2002; Huddart, Welch, Chan, et al., 2002;, McAdam, Thomas, et al., 2002; Janinis, Dafni, Aravantinos, et al., 2003; Razzouk, Hockenberry, Hinds, et al., 2004). Since Razzouk 2004 and Henze 2002 were the only trials on pediatric patients, the age range variable was deleted, and five variables were included in the meta-regression analysis.

###### Meta-regression

We used a back-wise selection method to derive the model; the covariate with the largest p value was consecutively removed until all remaining covariates were significant according to the Akaike Information Criterion (Akaike, 1969; see Methods). Variables included in the final model were “type of malignancy,” “duration of treatment,” and “source of data” (see Table 17). For each combination of variable subgroups, the relative risk can be calculated from Table 17. The following examples approximate the range of possible risk ratios:

- ln RR = −0.52–0.19-0.24-0.08 = −1.03; RR = e^−1.03^ = 0.36 (for patients with solid tumors, treated/followed 6–9 weeks, with results in full text publications).
- ln RR = −0.52+0.08+0.15+0.14 = −0.15; RR = e^−0.15^ = 0.86 (for patients with hematologic malignancies, treated/followed more than 20 weeks, with unpublished results).

Table 17

Meta-Regression Analysis for Red Blood Cell Transfusion

Variable | Effect | S.E. (effect) | 95% CI | p value
(Intercept) | −0.52 | 0.09 | −0.69; −0.35 | <0.0001
hematological malignancies | 0.08 | 0.06 | −0.03; 0.19 | 0.1368
mixed | 0.10 | 0.06 | −0.02; 0.22 | 0.1061
solid tumors | −0.19 | 0.05 | −0.29; −0.08 | 0.0004
6 to 9weeks | −0.24 | 0.15 | −0.53; 0.05 | 0.1097
12 to 16 weeks | 0.09 | 0.08 | −0.07; 0.25 | 0.2811
>20weeks | 0.15 | 0.09 | −0.02; 0.32 | 0.0849
abstract publication | −0.06 | 0.08 | −0.22; 0.11 | 0.4949
full text publication | −0.08 | 0.06 | −0.19; 0.03 | 0.1371
unpublished data | 0.14 | 0.06 | 0.02; 0.26 | 0.0216

CI: confidence interval; SE: standard error

For each statistically significant variable, meta-regression results of Table 17 suggest the following subgroup differences in magnitude of treatment benefit from an erythropoietic stimulant (hypotheses that may explain these differences are suggested):

- RR appears smaller (suggesting larger benefit) in trials on patients with solid tumors than in those on patients with hematologic malignancies. (Hypothesis: some patients with a hematologic malignancy may be less able to respond due to bone marrow involvement.)
- RR appears smaller (suggesting larger benefit) in trials that treated/followed patients for shorter durations, relative to those treated/followed for longer durations. (Hypothesis: risk reduction may be greatest soon after the first few weeks of treatment.)
- RR appears larger (suggesting smaller benefit) in trials that provided unpublished results, relative to trials that reported data in full text or abstract publications. (Hypothesis: treatment benefit may be estimated more conservatively when investigators provide fuller, more complete access to primary data.)

#### KQ1 Outcome III. Quality of Life

For purposes of this report, we required health-related quality of life (QoL) to be measured as change from baseline to final followup and change in treatment arm(s) compared to that in the control arm. Ideally, studies would also report the percentage of patients in each study arm that achieved a prespecified minimum amount of improvement known from prior studies to be clinically significant. However, only two studies reported results in this format (Vansteenkiste, Pirker, Massuti, et al., 2002; Witzig, Silberstein, Loprinzi, et al., 2005), and used different thresholds for improvement without documenting the validity of these thresholds.

We required the use of a validated instrument, such as the SF-36; European Organisation for Research and Treatment of Cancer (EORTC) Quality of life Questionnaire (QLQ-C30) or the Functional Assessment of Cancer Therapy (FACT; Table 18). Some QoL scales are general (also referred to as “generic” or “global” in some publications) measures of QoL in cancer patients (e.g. FACT-G; EORTC QLQ-C30) or in patients with any type of condition (e.g. SF-36), while others are targeted to specific cancers or symptoms. For example, the FACT-fatigue subscale of the FACT-Anemia symptom-specific instrument is sensitive to different, aspects of fatigue as a consequence of anemia. Thus, improvement in the FACT-fatigue subscale indicates improvement in that domain of QoL-related symptoms, but not necessarily in general or overall QoL. To demonstrate improvement in overall QoL there should be improvement in general QoL measures in addition to symptom-specific measures.

Table 18

Description of the FACT Scales and Subscales Evaluated in this Review

FACT instrument or subscale | Type of instrument | Domains addressed (#questions) | Range of scale
FACT-G(eneral) | General | Physical well-being (7) Social/family well-being (7) Emotional well-being (6) Functional well-being (7) | 0–108
FACT-An(emia) | Symptom-specific | Includes FACT-G, all domains (27)^1^ | 0−188
| | Anemia-specific symptoms (20)
FACT-fatigue subscale | Symptom-specific | Fatigue-specific questions from the anemia- specific questions of FACT-An (13) | 0−52
FACT non-fatigue anemia subscale | Symptom-specific | Questions from the anemia-specific questions of FACT-An that are not part of the FACT-fatigue subscale | 0−28

1 While FACT-Anemia incorporates FACT-G, it was not classified as a general instrument since the results could be dominated by either the general FACT-G or the symptom-specific subscales.

Study qualities not required for this review but nevertheless desirable include blinding and a plan for minimizing the effect of QoL instrument administration on results (see Introduction of Aronson, Seidenfeld, Piper, et al., 2001). In addition, while missing data tend to be unavoidable in QoL evaluations of cancer patients, the best methodologic practice is to prespecify how missing data will be handled to avoid significant bias in results (Donaldson and Moinpour, 2005).

We also abstracted QoL data from unidimensional visual analog scales (VAS) that in trials of epoetin or darbepoetin typically evaluate 3 items: energy, daily activities, and overall QoL. However, while some VAS QoL scales have been formally validated, validation of the 3-item VAS scale used in these studies has not been well documented (Introduction of Aronson, Seidenfeld, Piper, et al., 2001). Thus, we give less weight to the results of VAS results in these studies.

##### Evidence for Comparative Effectiveness

###### Darbepoetin versus Epoetin

Characteristics of reporting studies are enumerated in Table 13.

Six trials directly compared darbepoetin to epoetin and measured QoL outcomes. Of those, one trial (Glaspy, Berg, Tomita, et al., 2005) used standard darbepoetin doses and administration schedules; used a validated instrument; and reported results separately for darbepoetin and epoetin study arms. Of the total number of patients randomized in Glaspy, Berg, Tomita, et al. (2005; N=1,220), 60 percent (N=731) were evaluable for QoL. We excluded the other 5 studies because they used nonstandard darbepoetin doses and administration schedules (Glaspy, Jadeja, Justice, et al., 2003); reported QoL results by Hb change rather than by study arm (Glaspy, Jadeja, Justice, et al., 2002A; Glaspy and Tchekmedyian, 2002B); did not include QoL results in an abstract-only publication (Alexopolous and Kotsori, 2004); or were intended to validate an anemia questionnaire (Schwartzberg, Yee, Senecal, et al., 2004).

###### Results

In this open-label study, Glaspy, Berg, Tomita, et al. (2005) randomized patients with a variety of solid or hematological malignancies and receiving different treatment regimens to either epoetin or darbepoetin, and evaluated the FACT-An and FACT-fatigue subscale at 17 weeks. There were positive changes in both scores in the darbepoetin arms and in the epoetin arms (Table 19). The differences between changes from baseline to 17 weeks in the darbepoetin and epoetin arms were not statistically significant, suggesting no difference in treatment effect on anemia-related symptoms. While the primary endpoint of the trial was transfusion incidence and no power calculations were reported for QoL, the trial was large (N=1,220 randomized) and thus likely to detect meaningful differences between treatment arms on QoL scales.

Table 19

Results for Functional Assessment of Cancer Treatment (FACT) Quality of Life Scales for Studies Comparing Darbepoetin to Epoetin

Study | Study Arm | Dose | Follow up (wks)- | N Rand | N Evaluable for QoL | % Not eval- uable | Blinded? | FACT-Anemia | | | FACT Fatigue subscale
Study | Study Arm | Dose | Follow up (wks)- | N Rand | N Evaluable for QoL | % Not eval- uable | Blinded? | Change in score, from baseline | Diff, Darb - Epo | 95% CI of Diff | Change in score, from baseline | Diff, Darb – Epo | 95% CI of Diff
Glaspy 2005 | Darb | 200 mg every 2 weeks | 17^1^ | 613 | 374^2^ | 39 | No | 7.1 | 0.60 | −3.1; 4.3 | 4.2^3^ | 0.7 | −0.8; 2.2
Glaspy 2005 | Epo | 40,000 IU weekly | 17^1^ | 607 | 357^2^ | 41 | | 6.5 | | | 3.5^3^

1 Final assessment, assumed to be week 17, 1 week after completion of 16 weeks of therapy

2 For the FACT-fatigue subscale, the numbers of evaluable patients were 373 for the Darb arm and 356 for the Epo arm

3 Analysis of covariance adjusting for stratification variables (variables not reported) rand = randomized; Con = control; Epo = erythropoietin alfa or beta; Darb = darbepoetin; Hb = hemoglobin; wks = weeks; N, number of patients

The availability of only one study limited the evaluation of the impact of darbepoetin versus epoetin on anemia-related fatigue. In addition, 40% of randomized patients were not evaluable for QoL outcomes, and the authors did not present a prespecified plan for avoiding bias due to missing data in the abstract or poster for this otherwise unpublished study. Because this study was not available as a full publication, trial design and methods related to QoL could not be fully evaluated.

###### Epoetin vs. Control

Of twenty-four potentially relevant RCTs, thirteen were included for this review (N=2,947 randomized) (Bamias, Aravantinos, Kalofonos, et al., 2003; Boogaerts, Coiffier, Kainz, 2003; Dammacco, Castoldi, Rodjer, et al., 2001; Littlewood, Bajetta, Nortier, et al., 2001; Witzig, Silberstein, Loprinzi, et al., 2005; Del Mastro, Venturini, Lionetto, et al., 1997; Razzouk, Hockenberry, Hinds, et al., 2004; Iconomou, Koutras, Rigopoulos, et al., 2003; Chang, Couture, Young, et al., 2005; Osterborg, Brandberg, Molostova, et al., 2002; Abels 1992;10 Kurz, Marth, Windbichler, et al., 1997; Thatcher, De Campos, Bell, et al., 1999).

10 Abels 1992 pooled three studies: Abels 1992 (n=124); Case, Bukowski, Carey, et al., 1993 (n=157); and Henry, Brooks, Case, et al., 1995 (n=132). These studies had slightly different protocols and in the Abels 1992 study patients did not receive chemotherapy. Thus, the Abels 1992 report includes some patients who do not exactly fulfill inclusion criteria for this review.

Of the total number of patients randomized, 81 percent (range across studies, 41–100 percent) were evaluable for QoL (N=2,374). More than 20 percent of data were missing (range: 22–59 percent) from 5 studies. Characteristics of reporting studies are enumerated in Tables 10, 11, and 12. Of the twenty-five potentially relevant RCTs, the 11 studies we excluded accounted for 35% of the patients randomized (N=1,619); thus, data on over one-third of the randomized patients could not be included because of reporting problems. We excluded eight studies because authors did not state the numbers of participants evaluated for QoL results (Huddart, Welch, Chan, et al., 2002; Janinis, Dafni, Aravantinos, et al., 2003; Leyland-Jones, Semiglazov, Pawlicki 2005; O’Shaughnessy, 2002; Quirt, Micucci, Moran, et al., 1996; Rose, Rai, Revicki, et al., 1994; Savonije, Van Groeningen, Van Bochove, et al., 2005; Thomas, 2004; Welch, James, Wilkinson, 1995); one study because the authors did not report the number of patients evaluated for QoL separately for the epoetin and control groups (Carabantes, Benavides, Trujillo, et al., 1999); and two studies (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995) because they duplicated the QoL results reported in another included study (Abels, 1992).

###### Darbepoetin vs. Control

Two studies (N=663 randomized) compared darbepoetin treatment vs. control and reported QoL outcomes (Vansteenkiste, Pirker, Massuti, et al., 2002; Hedenus, Adriansson, San Miguel, et al., 2003). There were no excluded studies. Characteristics of reporting studies and results are enumerated in Tables 20–23.

Table 20

Results for Symptom-Specific FACT Quality of Life Scales from Studies Comparing Epoetin or Darbepoetin to Placebo or No Treatment

Study | Study arm | Follow- up (wks) | N rand | N evaluable for QoL | % not evaluable | Blinded? | FACT-An | | FACT-G | | FACT anemia subscale | | FACT fatigue subscale | | FACT non-fatigue anemia subscale
Study | Study arm | Follow- up (wks) | N rand | N evaluable for QoL | % not evaluable | Blinded? | % Change^1^ | p-value^2^ | % Change^1^ | p-value^2^ | % Change^1^ | p-value^2^ | % Change^1^ | p-value^2^ | % Change^1^ | p-value^2^
MEAN/MEDIAN BASELINE Hb <10 g/dl
Boogaerts 2003 | Ctl | 12 | 129 | 109 | 16 | No | | | | | | | Not given | | Not given
Boogaerts 2003 | Epo | | 133 | 104 | 22 | | | | | | | | 11 | <0.05 | 5 | 0.076, NS
Littlewood 2001 | Ctl | 4–24 | 124 | 88 | 29 | Yes | | | −5
Littlewood 2001 | Epo | | 251 | 194 | 23 | | | | 3 | 0.004
Littlewood 2001 | Ctl | 4–24 | 124 | 90 | 27 | | | | | | | | −8
Littlewood 2001 | Epo | | 251 | 200 | 20 | | | | | | | | 10 | 0.004
Osterborg 2002 | Ctl | 16 | 173 | 101 | 42 | Yes | 8
Osterborg 2002 | Epo | | 170 | 105 | 38 | | 13 | <0.05
Osterborg 2002 | Ctl | 16 | 173 | 103 | 40 | | | | 5
Osterborg 2002 | Epo | | 170 | 106 | 38 | | | | 9 | <0.05
Osterborg 2002 | Ctl | 16 | 173 | 130 | 25 | | | | | | | | 10 | | 10
Osterborg 2002 | Epo | | 170 | 133 | 22 | | | | | | | | 18 | >0.05, NS | 12 | >0.05, NS
Witzig 2005 | Ctl | 16 | 170 | 139 | 18 | Yes | 0
Witzig 2005 | Epo | | 174 | 148 | 15 | | 0 | 0.4, NS
Witzig 2005 | Ctl | 16 | 170 | 140 | 18 | | | | 0
Witzig 2005 | Epo | | 174 | 148 | 15 | | | | −2 | 0.6, NS
Witzig 2005 | Ctl | 16 | 170 | 148 | 13 | | | | | | | | 1
Witzig 2005 | Epo | | 174 | 151 | 13 | | | | | | | | 6 | 0.18, NS
Hedenus 2003 | Ctl | 12 | 173 | 151 | 13 | Yes | | | | | | | 2
Hedenus 2003 | Darb | | 176 | 152 | 14 | | | | | | | | 9 | NS
MEAN/MEDIAN BASELINE Hb 10 to 12 g/dl
Chang 2005 | Ctl | 12 | 175 | 170 | 3 | No | | | | | −8 | | −11 | | −4
Chang 2005 | Epo | | 175 | 168 | 4 | | | | | | 4 | <0.0001 | 5 | <0.0001 | 1 | <0.001
Iconomou 2003 | Ctl | 12 | 61 | 55 | 10 | No | | | | | | | −4
Iconomou 2003 | Epo | | 61 | 57 | 7 | | | | | | | | 21 | 0.022
Vansteenkiste 2002 | Ctl | 12 wks | 158 | 128 | 19 | Yes | | | | | | | Not given
Vansteenkiste 2002 | Darb | | 156 | 127 | 19 | | | | | | | | Not given | 0.019^3^
MEAN/MEDIAN BASELINE Hb >12 g/dl
No trials

1 % change calculated as (end-baseline)/baseline; positive values indicate improved quality of life.

2 comparing %change in treatment arm to %change in control arm.

3 %change not reported; 56% of darbepoetin-treated patients and 44% of placebo-treated patients had an improved FACT-fatigue score (p=0.052); 32% of darbepoetin-treated patients and 19% of placebo-treated patients showed ≥25% improvement in FACT-fatigue score (p=0.019).

Table 21

Results for FACT Submeasures Categorized as Significantly Pro-treatment, Not Significant, or Significantly Pro-control

Study | N evaluable for QoL | % of enrolled not evaluable | Blinded? | FACT Scale | significantly pro-tx | not significant | significantly pro-control
Littlewood 2001 | 282 | 25 | Yes | FACT-G | X
Osterborg 2002 | 209 | 39 | Yes | FACT-G | X
Witzig 2005 | 288 | 16 | Yes | FACT-G | | X
Osterborg 2002 | 206 | 40 | Yes | FACT-An | X
Witzig 2005 | 287 | 16 | Yes | FACT-An | | X
Chang 2005 | 338 | 4 | No | FACT anemia subscale * | X
Boogaerts 2003 | 213 | 19 | No | FACT fatigue subscale | X
Littlewood 2001 | 290 | 22 | Yes | FACT fatigue subscale | X
Osterborg 2002 | 263 | 24 | Yes | FACT fatigue subscale | | X
Witzig 2005 | 299 | 13 | Yes | FACT fatigue subscale | | X
Hedenus 2003 | 303 | 14 | Yes | FACT fatigue subscale | | X
Chang 2005 | 338 | 4 | No | FACT fatigue subscale | X
Iconomou 2003 | 112 | 8 | No | FACT fatigue subscale | X
Vansteenkiste 2002 | 255 | 19 | Yes | FACT fatigue subscale | X
Boogaerts 2003 | 213 | 19 | No | FACT non-fatigue anemia subscale | | X
Osterborg 2002 | 263 | 24 | Yes | FACT non-fatigue anemia subscale | | X
Chang 2005 | 338 | 4 | No | FACT non-fatigue anemia subscale | X

* Includes the FACT-fatigue subscale

Table 22

Results for General QoL Scales from Studies Comparing Epoetin or Darbepoetin to Placebo or No Treatment

Study | Study arm | Time (wks) | N randomized | N evaluable for QoL | % not evaluable | Blinded? | QoL measure | % change^1^ | p-value^2^
MEAN/MEDIAN BASELINE Hb < 10 g/dl
Bamias 2003 | Ctl | ≤24 | 72 | 27 | 63 | No | EORTC QLQ-C30 | Not given
Bamias 2003 | Epo | | 72 | 32 | 56 | | | Not given | NS
Boogaerts 2003 | Ctl | 12 | 129 | 109 | 16 | No | SF-36 PCS | Not given
Boogaerts 2003 | Epo | | 133 | 104 | 22 | | | 9 | <0.05
Dammacco 2001 | Ctl | 12 | 76 | 72 | 5 | Yes | NHP (each of 6 domains) | Not given
Dammacco 2001 | Epo | | 69 | 66 | 4 | | | Not given | NS
Littlewood 2001 | Ctl | 4–24 | 124 | 90 | 27 | Yes | SF-36 PCS | −1
Littlewood 2001 | Epo | | 251 | 200 | 20 | | | 5 | 0.0512, NS
Littlewood 2001 | Ctl | 4–24 | 124 | 90 | 27 | | SF-36 MCS | −1
Littlewood 2001 | Epo | | 251 | 200 | 20 | | | 5 | 0.0952, NS
Witzig 2005 | Ctl | 16 | 170 | 147 | 14 | Yes | SDS | 3
Witzig 2005 | Epo | | 174 | 151 | 13 | | | 1 | 0.39, NS
MEAN/MEDIAN BASELINE Hb 10 to 12 g/dl
No trials
MEAN/MEDIAN BASELINE Hb >12 g/dl
Del Mastro 1997 | Ctl | 26 | 31 | 26 | 16 | No | PDI | 3
Del Mastro 1997 | Epo | | 31 | 27 | 13 | | | 0 | 0.4, NS
MEAN/MEDIAN BASELINE Hb UNCLEAR
Razzouk 2004A | Ctl | 16 | 111 | 86 | 23 | Yes | Patient reported PedQL-I total score | 8
Razzouk 2004A | Epo | | 111 | 94 | 15 | | | 10 | NS

1 % change calculated as (end-baseline)/baseline; positive values indicate improved quality of life.

2 comparing %change in treatment arm to %change in control arm.

EORTC QLQ-C3, European Organization for Research & Treatment of Cancer quality of life questionnaire; SF-36 PCS & MCS, Medical Outcomes Study, Short Form 36, Physical/Mental Component Score; NHP, Nottingham Health profile; SDS, Symptom Distress Scale; PDI, Psychological Distress Inventory; PedQL-I, Pediatrics Quality of Life Inventory; Hb, hemoglobin; Con, control; Epo, epoetin; QoL, quality of life; wks, weeks; NS, not significant; N, number of patients

Table 23

Results for Visual Analog Scales (VAS) from Studies Comparing Epoetin or Darbepoetin to Placebo or No Treatment

Study | Study arm | Time (wks) | N rand | N evaluable for QoL | % not evaluable | Blinded? | % change: energy^1^ | p value: energy^2^ | % change: daily activities^1^ | p value: daily activities^2^ | % change: overall QoL^1^ | p value: overall QoL^2^
MEAN/MEDIAN BASELINE Hb < 10 g/dl
Abels 1992 | Ctl | 12 | 207 | 143 | 31 | Yes | Not given | | Not given | | −5
Abels 1992 | Epo | | 206 | 159 | 23 | | Not given | >0.05, NS | Not given | >0.05, NS | 9 | <0.05
Boogaerts 2003 | Ctl | 12 | 129 | 112 | 13 | No | | | | | 2
Boogaerts 2003 | Epo | | 133 | 111 | 17 | | | | | | 18 | 0.004
Dammacco 2001 | Ctl | 12 | 76 | 72 | 5 | Yes | Not given | | Not given | | Not given
Dammacco 2001 | Epo | | 69 | 66 | 4 | | Not given | NS | Not given | NS | Not given | NS
Kurz 1997 | Ctl | 12 | 12 | 12 | 0 | Yes | Not given | | Not given | | Not given
Kurz 1997 | Epo | | 23 | 23 | 0 | | Not given | 0.71, NS | Not given | 0.53, NS | Not given | 0.77, NS
Littlewood 2001 | Ctl | 4–24 | 124 | 108 | 13 | Yes | −13 | | −13
Littlewood 2001 | Epo | | 251 | 228 | 9 | | 18 | 0.0007 | 16 | 0.0018
Littlewood 2001 | Ctl | 4–24 | 124 | 107 | 14 | | | | | | −12
Littlewood 2001 | Epo | | 251 | 228 | 9 | | | | | | 9 | 0.0048
Witzig 2005 | Ctl | 16 | 170 | 147 | 14 | Yes | | | | | −6
Witzig 2005 | Epo | | 174 | 150 | 14 | | | | | | −9 | 0.58, NS
MEAN/MEDIAN BASELINE Hb 10 to 12 g/dl
Chang 2005 | Ctl | | 175 | 169 | 3 | No | −9 | | −8 | | −10
Chang 2005 | Epo | | 175 | 166 | 5 | | 6 | <0.014 | 7 | <0.01 | 6 | <0.001
Iconomou 2003 | Ctl | 12 | 61 | 55 | 10 | No | −3 | | −3 | | −2
Iconomou 2003 | Epo | | 61 | 57 | 7 | | 14 | 0.022 | 19 | 0.003 | 15 | 0.03
MEAN/MEDIAN BASELINE Hb >12 g/dl
Thatcher 1999 | Ctl | 16 to 24 | 44 | 27 | 39 | No | 3 | | 26 | | 16
Thatcher 1999 | Epo | | 42 | 33 | 21 | | −4 | NS | 6 | NS | 24 | NS
| Ctl | 16 to 24 | 44 | 27 | 39 | | 3 | | 26 | | 16
| Epo (higher dose) | | 44 | 32 | 27 | | 6 | NS | 10 | NS | 11 | NS

1 % change calculated as (end-baseline)/baseline; positive values indicate improved quality of life.

2 comparing %change in treatment arm to %change in control arm. rand = randomized; Con = control; Epo = erythropoietin alfa or beta; Hb = hemoglobin; wks = weeks; NS = not significant (p>0.05); N, number of patients; QoL, quality of life

##### Evidence Regarding the Class of Erythropoietic Stimulants

Erythropoietic stimulants are considered to have similar pharmacodynamic properties (Food and Drug Administration Oncologic Drugs Advisory Committee Meeting Briefing Information, 2004). Moreover, erythropoietic stimulants raise Hb levels and ameliorate anemia and its consequences. Studies directly comparing epoetin and darbepoetin show similar ability to elicit Hb response, and based on one large study do not appear to differ in effects on QoL related to the symptoms of anemia. Therefore, we analyzed epoetin and darbepoetin vs. control trials that reporting QoL outcomes together for more robust results.

##### Analysis of Epoetin versus Control and Darbepoetin versus Control

Fifteen controlled studies randomized a total of 3,610 patients to treatment; 81 percent of randomized patients were evaluable for QoL (N=2,932).

Analysis of study quality detected threats to validity in most included studies. Six of 15 studies were not blinded (see Tables 20–23). In 6 studies, allocation concealment was unclear (Bamias, Aravantinos, Kalofonos, et al., 2003; Chang, Couture, Young, et al., 2005; Dammacco, Castoldi, Rodjer, et al., 2001; Iconomou, Koutras, Rigopoulos, et al., 2003; Razzouk, Hockenberry, Hinds, et al., 2004; Witzig, Silberstein, Loprinzi, et al., 2005). Several comparisons that significantly favored treatment were in relatively large studies for which only approximately 60–75 percent of randomized patients were evaluable for QoL (e.g., Osterborg, Brandberg, Molostova, et al., 2002; Littlewood, Bajetta, Nortier, et al., 2001). Most studies with adequate followup used a last observation carried forward approach to impute missing data, which may distort results in either direction but particularly in favor of treatment if subjects whose outcomes are worsening are lost early (Streiner, 2002). Finally, many studies provided limited details about the timing and circumstances under which the QoL measures were administered.

###### Results

We preferred to analyze QoL results by quantitative techniques, but could not because of incomplete reporting in several trials of both the numerical results (e.g., some study publications reported only percentage change without baseline value) and measures of their dispersion. Meta-analysis of subsets of trials reporting sufficient data may not be representative of all trials reporting QoL results and could risk significant bias. For example, of 8 studies that administered a FACT QoL instrument, all reported results for the FACT-fatigue subscale. However, only 3 reports included information on result variance. In the absence of sufficient data for a representative meta-analysis, we evaluated the results of all included studies reporting QoL results similarly, based on patterns in the tabulated results (“vote-counting”). We stratified results according to the specific measurement tool employed, distinguishing QoL measured by condition-specific FACT subscales from that measured by global instruments or by VAS.

###### Results from FACT scales

Eight studies contributed data on QoL assessed by FACT modules (Table 20; for details on FACT scales, refer to Table 18). Of the total number of patients randomized in these studies (N=2,459), 84 percent (N=2,073) were evaluable for QoL (range evaluable across studies, 60–86 percent). The relatively large studies by Littlewood, Bajetta, Nortier, et al. (2001) and Osterborg, Brandberg, Molostova, et al. (2002) reported on QoL for only 75–78 percent and 60–77 percent of 375 and 343 randomized patients, respectively, depending on FACT measure.

When authors clearly presented numerical results, results generally favored treatment (though were not necessarily statistically significant), with only 2 comparisons (1 each in FACT-An and FACT-G; note that FACT-G is a general measure, and FACT-An includes the FACT-G as well as the symptom-specific modules FACT-fatigue subscale and FACT-anemia non-fatigue subscale.) showing no difference or slightly favoring control (Table 20, shaded). All symptom-specific instrument comparisons favored treatment, although not all were statistically significant. For each FACT measure, the balance among study results significantly in favor of treatment, not significantly different, and significantly in favor of control, favors active treatment (Table 21). The FACT-fatigue subscale was used most often; it significantly favored treatment in 5 trials and favored treatment, but not significantly, in three other trials. However, for each FACT measure used in more than 1 trial, both significant and nonsignificant results were reported. Five of 11 results (45 percent) reported by blinded trials were significant, while 5 of 6 results (83 percent) reported by unblinded trials were significant (Table 21).

Six of 10 significantly favorable results were in studies that had 19 percent or more missing data. Only 2 studies compared darbepoetin to control; results are qualitatively similar to those comparing epoetin to control. Although there is consistency in the direction of effect on FACT-based measures, there is marked variation in size of effect. Without complete data allowing quantitative meta-analysis, it is not possible to determine the size or the statistical significance of the effect.

###### Results from general instruments

Seven studies contributed data on QoL assessed by validated general instruments other than FACT-G (Table 22). Of the total number of patients randomized (N=1,554), 79% (N=1,231) were evaluable for QoL (range evaluable across studies, 41–96 percent). Bamias, Aravantinos, Kalofonos, et al. (2003) is a relatively small study, with more than 50 percent of patients in each arm not evaluable for QoL results. Only one result significantly favored treatment and none significantly favored control. The rest of the study findings were not significantly different and where numerical results were given, 3 slightly favored treatment and 2 slightly favored control. The heterogeneity of measures and small number of studies reporting any one measure makes an overall pattern difficult to identify with confidence.

Only four studies administered both symptom-specific and global scales (Osterborg, Brandberg, Molostova, et al., 2002; Witzig, Silberstein, Loprinzi, et al., 2005; Littlewood, Bajetta, Nortier, et al., 2001; Boogaerts, Coiffier, Kainz, 2003). The pattern of results is different for each study (Table 24); thus, there are insufficient data to determine whether the positive results from symptom-specific scales are routinely detectable on general QoL scales.

Table 24

Significant vs. Nonsignificant QoL Results for Studies Reporting both Symptom-Specific and General Scale Results

Study | Symptom-specific measure | | General measure
| FACT-fatigue subscale | FACT-anemia non-fatigue subscale | FACT-G | Other general instrument
Littlewood 2001 | p<0.05 | | p<0.05 | NS
Osterborg 2002 | NS | NS | p<0.05
Witzig 2005 | NS | | NS | NS
Boogaerts 2003 | p<0.05 | NS | | p<0.05

###### Results from VAS instruments

Nine studies contributed VAS data on the impact of epoetin on QOL (Table 23). Thatcher 1999 tested 2 different epoetin doses and is counted as two trials. Of the total number of patients randomized (N=2,176), 86 percent (N=1,865) were evaluable for QoL (range evaluable across studies, 71–100%). The balance among studies reporting significantly in favor of treatment, no significant difference, and significantly in favor of control is: 3 studies vs. 5 studies vs. 0 studies for VAS-energy; 3 vs. 5 vs. 0 for VAS-abilities; and 5 vs. 5 vs. 0 for VAS-overall (all respectively). Because several studies did not report numerical data, it could not be determined whether, without regard to statistical significance, treatment or control was more often favored.

#### KQ1 Outcome IV. Survival

We abstracted death events from included studies reporting this outcome. Hazard ratios (HR) for death were calculated as reported in Methods, Statistical Data Analysis. While all studies reporting survival are included, only 7 studies of either epoetin or darbepoetin (Henke, Laszig, Ruebe, et al., 2003; Leyland-Jones 2003; Machtay, Pajak, Suntharalingam, et al., 2004; GOG-191, 2004; N93 004, 2004, Vansteenkiste, Pirker, Massuti, et al., 2002; EPO-CAN-15) were actually designed to evaluate either overall or progression-free survival. Other studies were neither designed nor powered for this outcome, and in some studies evaluated retrospective data, collected after the study closed and when patient management was no longer directed by the study protocol. Additionally, studies differed in tumor type studied (e.g. solid vs. solid and hematologic), and in homogeneity of tumor type (e.g. one type of solid tumor vs. many types of solid tumors). Disease progression patterns of different types of malignancies can significantly influence survival outcomes. Moreover, the underlying mortality in each patient population studied interferes with the observation of specific effects on overall mortality, and cause-specific mortality data were not available. Studies also differed in length of reported followup, and seldom reported survival at several different time points.

We pooled all-cause survival data in a meta-analysis to update and test the hypothesis of improved survival with epoetin treatment suggested by an earlier analysis (Bohlius, Langensiepen, Schwarzer et al., 2005). While we would have preferred to utilize data on cause-specific mortality (e.g. from tumor progression, thrombosis, CVD), these data were not available. Given the limitations of the data as described, quantitative pooling of all-cause mortality is necessarily problematic, and the use of these data is largely hypothesis-generating, rather than conclusive.

##### Evidence for Comparative Effectiveness

###### Darbepoetin versus Epoetin

Only one of the included studies comparing darbepoetin to epoetin assessed overall survival (Waltzman, Croot, Williams, 2005); survival was a secondary outcome. In this study of 358 randomized patients undergoing chemotherapy for solid tumors, the authors reported that 16% of patients in the darbepoetin arm and 13% of those in the epoetin arm died “on study”. In absolute numbers, 29 of 180 patients in the darbepoetin arm died, as did 23 of 178 in the epoetin arm, not significantly different at p=0.4.

This single trial directly comparing commonly-used doses of darbepoetin and epoetin found no difference in survival. A limitation of the trial is that it was not powered for survival outcomes; the primary outcome was comparison of hematologic response rates. Additional limitations are the short followup time (17 weeks) and variety in tumor types and chemotherapy regimens. Given limited direct evidence from only one trial, we evaluated indirect evidence (epoetin vs. control, darbepoetin vs. control) for effect on survival outcomes.

###### Epoetin versus Control

Characteristics of reporting studies are shown in Table 25. Thirty-five trials (N=6,918; 3,825 randomized to epoetin, 3,093 to control) reported survival outcomes (Bamias, Aravantinos, Kalofonos, et al., 2003; Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Cazzola, Messinger, Battistel, et al, 1995; Chang, Couture, Young, et al., 2005; Coiffier and Boogaerts, 2001; Dammacco, Castoldi, Rodjer, et al., 2001; Del Mastro, Venturini, Lionetto, et al., 1997; Dunphy, Harrison, Dunleavy, et al., 1999; Henke, Laszig, Ruebe, et al., 2003; Henry, Brooks, Case, et al., 1995; Kurz, Marth, Windbichler, et al., 1997; Leyland-Jones, 2003; Littlewood, Bajetta, Nortier, et al., 2001; Machtay, Pajak, Suntharalingam, et al., 2004; Oberhoff, Neri, Amadori, et al., 1998; O’Shaughnessy, Vukelja, Holmes, et al., 2005; Osterborg, Brandberg, Hedenus, 2005; Osterborg, Boogaerts, Cimino, et al., 1996; Razzouk, Hockenberry, Hinds, et al., 2004; Rose, Rai, Revicki, et al., 1994; Savonije, Van Groeningen, Van Bochove, et al., 2004; ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; Throuvalas, Antonadou, Boufi, et al., 2000; Vadhan-Raj, Skibber, Crane, et al., 2004; Witzig, Silberstein, Loprinzi, et al., 2005; EPO-CAN-15, 2004; EPO-CAN-20, 2004; EPO GBR-07, 2004; GOG-191, 2004; N93 004, 2004; INT-1, 2004; INT-3, 2004; P-174, 2004).

Table 25

RCTs Reporting Survival: Overall and Subgroup Analyses of Hazard Ratios for Death, Epoetin Compared to Control

Outcome | Epoetin versus Control | | | | | Darbepoetin versus Control
Subgroup | # Studies | #Total Patients | #Epo/#Ctl Patients | Hazard Ratio for death | 95% CI (p-value) | # Studies | #Total Patients | #Darbepoetin/#Ctl Patients | Hazard Ratio for death | 95% CI (p-value)
Overall Survival | 35 | 6,918 | 3,825/3,093 | 1.11 | 1.00; 1.22 | 4 | 973 | 583/390 | 0.96 | 0.78; 1.17
(Heterogeneity) | | | | | (0.48) | | | | | (0.03)
Subgroup Analyses: Patient Baseline Characteristics
Bsln Hb <10 | 14 | 2,830 | 1,590/1,240 | 0.96 | 0.83; 1.10 | 3 | 659 | 428/231 | 1.31 | 0.95; 1.81
Bsln Hb 10–12 | 7 | 1,398 | 782/616 | 1.17 | 0.93; 1.49 | 1 | 314 | 155/159 | 0.78 | 0.60, 1.01
Bsln Hb >12^1^ | 7 | 1,696 | 870/826 | 1.27 | 1.05; 1.54
Bsln Hb unclear^1^ | 7 | 994 | 583/411 | 1.63 | 1.07; 2.49
(Group difference^2^) | | | | | (0.025) | | | | | (0.015)
Solid tumors | 23 | 4,526 | 2,420/2,106 | 1.22 | 1.07; 1.38 | 2 | 563 | 353/210 | 0.77 | 0.60; 1.00
Hematologic | 6 | 1,044 | 626/418 | 1.02 | 0.81; 1.29 | 2 | 410 | 230/180 | 1.36 | 0.98; 1.89
Mixed | 6 | 1,348 | 779/569 | 0.86 | 0.68; 1.08
(Group difference^2^) | | | | | (0.027) | | | | | (0.008)
Subgroup Analyses: Treatment Protocols
Chemo, any | 10 | 1,474 | 884/590 | 1.14 | 0.74; 1.7 | 1 | 314 | 155/159 | 0.78 | 0.60; 1.01
Chemo, some plat | 4 | 955 | 482/473 | 1.01 | 0.79; 1.30 | 1 | 249 | 198/51 | 0.55 | 0.11; 2.61
Chemo, no plat | 13 | 3,302 | 1,859/1,443 | 1.06 | 0.92; 1.21 | 2 | 410 | 230/180 | 1.36 | 0.98; 1.89
Chemo+RT or RT | 8 | 1,187 | 600/587 | 1.27 | 1.05; 1.55
(Group difference^2^) | | | | | (0.4134) | | | | | (0.027)
Iron, fixed | 2 | 360 | 181/179 | 1.08 | 0.82; 1.42
Iron, as needed | 19 | 3,522 | 1,964/1,558 | 0.99 | 0.86; 1.13 | 1 | 344 | 175/169 | 1.36 | 0.98; 1.89
Iron unknown | 13 | 3,036 | 1,680/1,356 | 1.32 | 1.11; 1.55 | 3 | 629 | 408/221 | 0.77 | 0.60; 1.00
(Group difference^2^) | | | | | (0.033) | | | | | (0.008)
Epo tx 6–9 weeks | 6 | 823 | 461/362 | 1.25 | 0.97; 1.59
Epo tx 12–16 weeks | 19 | 3,679 | 2,009/1,670 | 1.05 | 0.90; 1.23 | (all)
Epo tx >20 weeks | 7 | 1,958 | 1,113/845 | 1.13 | 0.95; 1.33
Epo tx ? Weeks | 3 | 458 | 242/216 | 1.02 | 0.71; 1.46
(Group difference^2^) | | | | | (0.68)
Subgroup Analyses: Reporting and Quality
High quality | 20 | 4,384 | 2,380/2,004 | 1.14 | 1.02; 1.27 | (all)
Low quality | 15 | 2,534 | 1,445/1,089 | 1 | 0.81; 1.24
(Group difference^2^) | | | | | (0.3087)
Full Text | 8 | 1,800 | 983/817 | 0.98 | 0.84; 1.13 | 2 | 315 | 253/62 | 0.55 | 0.11; 2.61
Abstract | 3 | 678 | 394/284 | 1.27 | 0.79; 2.06
Unpublished data | 5 | 384 | 199/185 | 0.6 | 0.25; 1.41
FDA documents | 19 | 4,056 | 2,249/1,807 | 1.25 | 1.08; 1.44 | 2 | 658 | 330/328 | 0.96 | 0.79; 1.18
(Group difference^2^) | | | | | (0.17) | | | | | (0.48)
Followup <1 year | 24 | 3,393 | 1,998/1,395 | 1.00 | 0.77; 1.31 | 2 | 315 | 253/62 | 0.55 | 0.11; 2.61
Followup >1 year | 11 | 3,525 | 1,827/1,698 | 1.12 | 1.01; 1.25 | 2 | 658 | 330/328 | 0.96 | 0.79; 1.18
(Group difference^2^) | | | | | (0.43) | | | | | (0.48)

1 The N93-004 epoetin trial was published in full in December, 2005 (Grote, Yeilding, Castillo, et al., 2005) and included information on baseline Hb which classified it into subgroup Hb >12. A re-categorized analysis of epoetin vs. control trials resulted in subgroup Hb>12 RR 1.28 (95% CI, 1.06, 1.54), an insignificant change. Because this did not alter the interpretation of results, we did not alter our presentation of the overall analysis.

2 p-value for differences among subgroup categories calculated by inverse variance method (see Methods/Data Extraction and Analysis/Statistical Data Analysis).

Trials that reported survival differed with respect to several variables. Baseline characteristics of study populations differed by average baseline Hb concentration, type of malignancy, treatment for malignancy, and age. One study included pediatric patients (Razzouk, Hockenberry, Hinds, et al., 2004). Treatment protocols also differed by therapies for iron supplementation, and duration of epoetin treatment. Trials varied with respect to publication type, overall quality rating, and duration of followup. In addition, several trials (Cazzola, Messinger, Battistel, et al, 1995; INT-1, 2004; Henke, Laszig, Ruebe, et al., 2003; Osterborg, Boogaerts, Cimino, et al., 1996; ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Throuvalas, Antonadou, Boufi, et al., 2000) tested 2 or more doses, such that one or more treatment arms received doses that are 50 percent higher than currently recommended. However, for these studies survival data were available only for pooled treatment arms. Thatcher, De Campos, Bell, et al. (1999) also tested 2 different doses but reported death events by treatment arm; treatment arm b tested a higher than usual dose.

###### Results

A test for heterogeneity across trials included for survival outcomes was not statistically significant (p=0.48, I^2^=0.0%). An I^2^ value of 0% indicates no observed statistical heterogeneity.

Meta-analysis of data from all 35 trials (Figure 9) yielded:

- Fixed-effects HR=1.11 (95% CI 1.00; 1.22)^11,12,13^, p=0.05
  11 Thatcher, De Campos, Bell, et al. (1999) compared 2 different epoetin doses to one control group; for this study, survival data were available for each epoetin arm and the control arm was randomly divided into 2 separate control arms for meta-analysis. As this study contributed only 0.47% weight to the meta-analysis, the influence of changes in control arm weight was judged to be negligible.
  12 Two studies (Littlewood, Bajetta, Nortier, et al., 2001; Henke, Laszig, Ruebe, et al., 2003) reported both adjusted (for potential prognostic factors) and unadjusted survival data. We used unadjusted data for our base model, but the overall result was similar when adjusted data were used (see below). If the analysis used either the best-case or worst-case results from these two studies, the results varied only minimally.
  Unadjusted data: HR 1.11 (95% CI 1.00; 1.23) (base model)
  Adjusted data: HR 1.11 (95% CI 1.01; 1.23)
  Best case scenario: HR 1.10 (95% CI 0.99; 1.21)
  Worst case scenario: HR 1.12 (95% CI 1.01; 1.23)
  13 For the Leyland-Jones study there is a discrepancy between the numbers of death events used in this review (148) and those reported by NICE (141). The major difference between this review and the NICE report is that we retrieved the survival data from the briefing document for the FDA-ODAC hearing in May 2004. The FDA briefing document notes that the reported percentages of patients who survived or died are based on Kaplan-Meier estimates. The obtained hazard ratio (1.37), derived from the data reported in the FDA document (see Figure 9) is the same as that reported in the Leyland-Jones et al., 2005 publication. The NICE report used the information from the Leyland-Jones 2003 paper, in which the absolute number of deaths was not specified, for the estimation of death events. We assume that the NICE team used the reported 70% survival rate in the epoetin arm to estimate the absolute number of deaths (i.e. 30% of 470 = 141).
- Total event rates were 26.4% for epoetin treatment arms and 26.8% for control arms.
- HRs ranged from 0.13 to 2.7 with one extreme value of 7.39.

Figure 9

Meta-Analysis of Data on Survival from 35 RCTs of Epoetin versus Control

Meta-analysis of all studies included for survival outcomes does not show improved survival with epoetin treatment. The point estimate of the HR for death is greater than 1 but not significant; the 95% confidence interval of the estimate indicates either no effect or a slight detrimental effect of epoetin.

Since many trials lacked information on baseline Hb and iron supplementation, subgroup analysis was not informative. While there appeared to be a statistically significant increase in HR for death for the subgroup of patients with solid tumors receiving epoetin, the effect was small and the confidence interval overlapped substantially with that for hematologic malignancies, which did not differ significantly from 1.0. No subgroups had HR point estimates significantly less than 1.0.

Most studies only provided qualitative information on followup duration (e.g. duration of chemotherapy plus 28 days). One study (Leyland-Jones, 2003) reported an increase in deaths in the epoetin arm, compared to control, within the first 4 months of followup. Thus, an analysis of early events across trials might be informative but for most studies data were unavailable to differentiate early (e.g., <4 months) from late events, or analyze survival at specific times across studies.

###### Additional Analyses

After initial review of results, we conducted additional analyses not anticipated in the original protocol in order to answer specific questions or explore new hypotheses. We used an influence analysis to identify those studies that most strongly influenced the pooled HR for death. We conducted a subgroup analysis of those studies that administered epoetin according to current labeled criteria vs. those studies that used criteria exceeding the labeled limits of initial dose or target Hb value. We also compared HR for death among subgroups defined by 1 g/dL increments in maximum Hb target value. Finally, because few studies were actually designed to prospectively evaluate survival outcomes during the followup period specified by the original study protocol, we evaluated subgroups according to whether or not trials had key design characteristics necessary for reliable survival outcomes.

Results of the influence analysis, which omits each study, one at a time, and pools the remaining studies, are shown in Figure 10. Three studies that most strongly change the results are Henke, Laszig, Ruebe, et al., 2003; Leyland-Jones, 2003; and Littlewood, Bajetta, Nortier, et al., 2001 (Table 26). Omitting Leyland-Jones (2003) or Henke, Laszig, Ruebe, et al. (2003) reduces the HR point estimate such that the result is clearly nonsignificant. Omitting Littlewood, Bajetta, Nortier, et al. (2001) increases the HR point estimate and the result is statistically significant for decreased survival with epoetin treatment.

Figure 10

Influence Analysis: Hazard Ratios for Death Recalculated after Omission of One Study at a Time; Point Estimates (Squares) and 95% Confidence Intervals (Lines)

Table 26

Key Characteristics of Studies that Strongly Influence Survival Meta-Analysis

Study omitted | Starting epoetin dose | Baseline Hb category | Hb target, upper limit | Pooled HR for death after study omitted (95% CI)
Leyland-Jones 2003 | 1×40,000 IU/wk | 12 | 14 | 1.06 | (0.95; 1.18)
Henke 2003 | 3×300 IU/kg/wk | 10–12 | 15 | 1.08 | (0.97; 1.21)
(none) | | | | 1.11 | (1.00; 1.22)
Littlewood 2001 | 3×150 IU/kg/wk | 10 | 15 | 1.16 | (1.04; 1.29)

Over time, clinical trials of epoetin have recruited patients with higher baseline Hb and/or administered higher doses to raise Hb to higher target values, beyond that specified in the labeled drug administration criteria. Differences in these variables among the three studies, however, do not clearly explain the contrasting results of Henke, Laszig, Ruebe, et al. (2003) and Leyland-Jones (2003) vs. Littlewood, Bajetta, Nortier, et al. (2001). While Henke, Laszig, Ruebe, et al. (2003) used twice the labeled dose of epoetin, Leyland-Jones (2003) administered a standard dose as in the Littlewood study (Appendix C Table C28); all three studies targeted a final Hb value well above the current labeled limit of 13 g/dL. The studies each enrolled patients in different baseline Hb categories, which were <10, 10–12, and >12 for Littlewood, Bajetta, Nortier, et al. (2001), Henke, Laszig, Ruebe, et al. (2003), and Leyland-Jones (2003), respectively.

Due to recent concern with increased epoetin exposure (see Scope and Key Questions), a major question of interest for clinicians and their patients is whether there is a clear distinction between FDA-recommended (“labeled”) and “unlabeled” use. As listed in Table 1 of the Introduction, the current product labels include recommended doses and hemoglobin or hematocrit levels at which to reduce dose or temporarily stop administration, although no starting Hb level is specified. We identified 3 studies (Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995), constituting 5.6% of all patients evaluated for survival in included trials, that most closely met current labeled criteria for use and compared these to all other trials in a subgroup analysis. These studies used labeled (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995) or slightly lower doses (Cascinu, Fedeli, Del Ferro, et al., 1994) and stopped administration when Hb reached 13 g/dL. Dose reduction strategies were slightly different from labeled recommendations. Of these, one trial (Cascinu, Fedeli, Del Ferro, et al., 1994) reported no deaths in either arm and thus does not contribute to the analysis.

For this subgroup analysis there was no evidence of heterogeneity within subgroups or overall (I^2^ = 0–1%). Subgroup meta-analysis results (Figure 11) are as follows:

- Labeled: HR 0.91, 95% CI 0.47; 1.78
- Unlabeled: HR 1.12, 95% CI 1.01; 1.24
- Unclear^14^: HR 0.56, 95% CI 0.23; 1.39
  14 Oberhoff, Neri, Amadori, et al., 1998; Kurz, Marth, Windbichler, et al., 1997; Throuvalas, Antonadou, Boufi, et al., 2000; the latter two studies have 0–1 events.

Figure 11

Meta-Analysis of Data on Survival: Labeled vs. Unlabeled Criteria for Use in Trials Comparing Epoetin to Control

The HR for death is not significantly different from 1.0 for labeled use of epoetin. For unlabeled use, the HR for death is greater than 1.0. A major limitation of this analysis is that data are scant from studies closely approximating labeled recommendations for epoetin use; as a result, the 95 percent confidence interval is extremely wide and the labeled use subgroup cannot be statistically distinguished from unlabeled use. Two studies (Rose, Rai, Revicki, et al., 1994; P-174, 2004) used a value of Hb at which to stop epoetin administration only slightly higher (at or near 13.3 g/dL or hematocrit 40%) than the currently recommended 13 g/dL. Including these studies in the labeled use subgroup changes the HR to 1.08 (95 percent CI, 0.63; 1.84) but still accounts for only about 11 percent of the overall study weight and affords no clearer distinction between subgroups.

Because FDA considers a high Hb target a potential risk factor for greater mortality, and because trial protocols have tested various Hb values at which epoetin is discontinued (“stopping value”), we also conducted an analysis by Hb stopping value in 1 g/dL increments (Figure 12). By visualizing the data at different stopping points, this analysis asked whether the data form a continuum, or whether there is a discernable Hb cutoff value separating risk from no risk of increased mortality. The results (Table 27) show that for Hb stopping values above the labeled value of ≤13 g/dL, the HR point estimate tends to increase but differences among the subgroup HR point estimates are not statistically significant (p=0.11) and a trend analysis was also not significant (p=0.6709) Data are concentrated at stopping values >13 and ≤15 and there are no useful data at stopping points higher than 16.

Figure 12

Meta-Analysis of Data on Survival by 1 g/dL Hb Unit Increments for Treatment Stopping Point in Trials Comparing Epoetin to Control

Table 27

Meta-Analysis of Hazard Ratio for Death by Hb Stopping Value in 1 g/dL Increments

Hb Stopping Value | #Treated Patients | #Control Patients | Hazard Ratio for Death | 95% CI
≤ 12 g/dL | 50 | 50 | not estimable (0 events)
>12 and ≤ 13 g/dL | 148 | 141 | 0.91 | 0.47; 1.78
>13 and ≤ 14 g/dL | 1751 | 1436 | 1.16 | 1.00; 1.35
>14 and ≤ 15 g/dL | 1328 | 1005 | 1.03 | 0.90; 1.19
>15 and ≤ 16 g/dL | 368 | 303 | 1.67 | 1.13; 2.48
>16 and ≤ 17 g/dL | 0 | 0 | (no studies)
>17 and ≤ 18 g/dL | 15 | 15 | 0 Tx events, 1 Ctl event
(Unclear) | 165 | 143

As noted, most studies included in our analyses of survival were not designed to evaluate survival as a primary outcome. The FDA Oncologic Drugs Advisory Committee identified study design factors of importance to test the effect of products on survival: enrolling patients with homogeneous primary tumor types and treatment regimens; sufficient duration of followup within the investigator-controlled course of the study; and sufficient patient numbers such that significant differences in survival, or in surrogate measures such as progression-free survival or tumor response can be detected (see Scope and Key Questions). We compared a subgroup of studies that met homogeneous tumor and treatment criteria, whether or not they were originally designed to evaluate survival outcomes, with the larger subgroup that did not (Figure 13).

Figure 13

Meta-Analysis of Epoetin Trial Data on Survival: Studies Meeting Homogeneous Tumor and Treatment Criteria vs. Those that Did Not

Studies meeting these criteria suggest a statistically significant, detrimental effect of epoetin on survival while the pooled effect is not significant across those studies that do not meet criteria. However, the results for the two subgroups overlap considerably and cannot be clearly differentiated. Note that the Leyland-Jones (2003) study, while designed by the investigators to evaluate survival as the primary outcome, did not ensure homogeneous treatment regimens for malignancy, and thus the study does not meet criteria for homogeneous tumor type and treatment regimen.

###### Darbepoetin versus Control

Four trials (N=973; 583 randomized to darbepoetin, 390 randomized to control) reported survival (Hedenus, Hansen, Taylor, et al., 2002; Hedenus, Adriansson, San Miguel, et al., 2003; Kotasek, Steger, Faught, et al., 2003; Vansteenkiste, Pirker, Massuti, et al., 2002). However, for one study (Hedenus, Hansen, Taylor, et al., 2002) the hazard ratio could not be estimated because there were no events in either study arm. Characteristics of reporting studies are enumerated in Table 25.

Trials that reported survival differed with respect to several variables. Baseline characteristics of study populations differed by average baseline Hb concentration and type of malignancy. Treatment protocols differed by therapies for malignancy and iron supplementation. Trials also varied with respect to publication type and duration of followup. Two studies (Hedenus, Hansen, Taylor, et al., 2002; Kotasek, Steger, Faught, et al., 2003) were designed as dose-finding studies, but reported survival only for pooled treatment arms.

###### Results

A test for heterogeneity across trials included for survival outcomes was strongly significant (p=0.03, I^2^=72%). Therefore, a random-effects meta-analysis was also performed.

Meta-analysis of data from 4 trials (Figure 14) yielded:

- Fixed-effects: HR 0.96 (95% CI 0.78; 1.17), p=0.66
- Random-effects: HR 0.97 (95% CI 0.59; 1.58), p=0.90
- Total event rates were 31% for epoetin treatment arms and 47% for control arms.
- Hazard ratios ranged from 0.55 (Kotasek, Steger, Faught, et al., 2003) to 1.36 (Hedenus, Adriansson, San Miguel, et al., 2003).

Figure 14

Meta-Analysis of Data on Survival from 4 RCTs of Darbepoetin versus Control

Our combined summary estimate of effect is nearly identical to the results of a recently published meta-analysis (Hedenus, Vansteenkiste, Kotasek et al., 2005), which included the same four trials but likely had access to different data sources for some of the trials. They reported HR=0.95 (95% CI 0.78; 1.16).

No conclusion can be drawn from the limited evidence on the effect of darbepoetin on survival. In the two studies that contributed >98 percent of the weight to the meta-analysis, hazard ratio point estimates showed opposite effects but neither was significantly different from 1.0 (Hedenus, Adriansson, San Miguel, et al., 2003: HR 1.36, 95% CI 0.98; 1.89 and Vansteenkiste, Pirker, Massuti, et al., 2002: HR 0.78 95% CI 0.60; 1.01). The two dose-finding trials (Hedenus, Hansen, Taylor, et al., 2002; Kotasek, Steger, Faught, et al., 2003) contributed very little weight to the meta-analysis and thus did not influence the results. Too few trials were available for subgroup analyses to be meaningful.

##### Evidence Regarding the Class of Erythropoiesis-Stimulating Products

###### Combined Analysis of Epoetin versus Control and Darbepoetin versus Control

Erythropoiesis-stimulating products are considered to have similar pharmacodynamic properties and class effects (Food and Drug Administration Oncologic Drugs Advisory Committee Meeting Briefing Information, 2004); therefore we conducted a combined analysis of trials reporting survival outcomes for more robust results. When we combined studies of epoetin or darbepoetin versus control, the overall hazard ratio changed little in value and not at all in interpretation (Table 28 and Figure 15). While heterogeneity is high (I^2^=72.2 percent) for darbepoetin vs. control because of few studies, heterogeneity is minimal (I^2^=13.4 percent) for the combined analysis. Planned subgroup analyses were inconclusive due to lack of information from several studies.

Figure 15

Meta-Analysis of Data on Survival from 35 RCTs of Epoetin versus Control Combined with Four RCTs of Darbepoetin versus Control

Table 28

Overall Survival Meta-Analyses: Epoetin vs. Control; Darbepoetin vs. Control; and Epoetin vs. Control and Darbepoetin Combined

Parameter | Epoetin vs. control meta-analysis | Darbepoetin vs. control meta-analysis | Epoetin + darbepoetin combined meta- analysis
Number of studies | 35 | 4 | 39
Patients analyzed | 6,918 | 973 | 7,891
HR (95% CI) | 1.11 (1.00; 1.22) p=0.05 I^2^=0% | 0.96 (0.78; 1.17) p=0.66 I^2^=72.2% | 1.08 (0.98; 1.18) p=0.11 I^2^=13.4%
HR (95% CI) for subgroups: Labeled use Unlabeled use | 0.91 (0.47; 1.78) 1.12 (1.01; 1.24) | | 0.91 (0.47; 1.78) 1.09 (0.99; 1.19)
HR (95% CI) for subgroups: Max Hb target 12 g/dL Max Hb target 13 g/dL Max Hb target 14 g/dL Max Hb target 15 g/dL Max Hb target 16 g/dL | (no events) 0.91 (0.47; 1.78) 1.16 (1.00; 1.35) 1.03 (0.90; 1.19) 1.67 (1.13; 2.48) | | (no events) 0.91 (0.47; 1.78) 1.16 (1.00; 1.35) 1.01 (0.90; 1.13) 1.67 (1.13; 2.48)
HR (95% CI) for subgroups: Homogeneous tumor + tx Not homogeneous tumor + tx | 1.26 (1.04; 1.53) 1.06 (0.94; 1.19) | | 1.06 (0.91; 1.24) 1.08 (0.97; 1.21)

Additional analyses of trials by labeled vs. unlabeled use, by target hemoglobin 1 g/dL increments, and by homogeneous tumor and treatment criteria were also conducted. In each case, combined results for epoetin and darbepoetin trials were similar to those for epoetin trials alone, as shown in Table 28. Notably, the combined subgroup of trials meeting homogeneous tumor and treatment criteria for analysis of survival outcomes showed less differentiation from the subgroup of trials not meeting those criteria.

#### KQ1 Outcome V. Tumor Response and Progression

Investigators have hypothesized opposite effects of epoetin or darbepoetin on malignancies. Some proposed that by improving tumor oxygenation, these drugs might enhance cytocidal effects of certain chemotherapy regimens and/or radiation therapy (e.g., Glaspy 2002). Alternatively, tumor cells with erythropoietin receptors (e.g., Westenfelder and Baranowski, 2000; Acs, Zhang, Rebbeck, et al., 2002) might proliferate and progress more rapidly if either drug is present. The first hypothesis suggests erythropoietic stimulants might increase tumor response rate to therapy, which could then increase survival. The second suggests they may decrease response duration or increase progression, which could then reduce survival. These are not mutually exclusive possibilities; but testing each hypothesis requires different outcomes that must be analyzed separately.

This report defines tumor response as the proportion of patients with a complete response (CR) to nonsurgical treatment of their malignancy (see Introduction/Scope; Appendix C Table C33). We focus on CR since for many malignancies, achieving CR is a prerequisite for long term survival without additional treatment. Several studies also reported overall response (OR), which is the sum of CR plus partial response (PR) rates. Studies were excluded unless prospectively designed to assess tumor response in a homogeneous population (i.e., one malignancy) given a protocol-specified cancer treatment regimen.

Outcomes related to response duration (e.g., time to progression, progression-free survival) were abstracted if available from studies that met the same selection criteria (one malignancy; protocol-specified regimen). They are summarized in Results (see below) and included in Appendix C tables, but cannot be pooled with tumor response for meta-analysis.

##### Darbepoetin versus Epoetin

Trials that directly compared darbepoetin versus epoetin did not report tumor response rate or duration-related outcomes.

##### Epoetin versus Control

Five trials (EPO GBR-07, 2004; Machtay, Pajak, Suntharalingam, et al., 2004; N93 004, 2004^15^; Throuvalas, Antonadou, Boufi, et al., 2000; Vadhan-Raj, Skibber, Crane, et al., 2004) reported tumor response rate as defined for this review (N=788 randomized, 688 evaluated; 344 from epoetin arms, 344 from control arms). Table 29 enumerates variables prespecified for subgroup analysis (Fig. 1) from these five trials. Two of these trials (EPO GBR-07, 2004; Machtay, Pajak, Suntharalingam, et al., 2004) plus three others (GOG-191, 2004; Henke, Laszig, Ruebe, et al., 2003; EPO-CAN-15, 2004) reported time to progression (TTP), progression-free survival (PFS), or disease-free survival (DFS). Table 30 lists noteworthy features of all eight studies that reported tumor response rate or a duration-related outcome.

15 As this report was released, a full-text version of this trial was published (Grote, Yeilding, Castillo et al., 2005).

Table 29

Study Characteristics of RCTs Reporting Tumor Response Rates

Outcome | Epoetin versus Control
Subgroup | # Studies | # Total Patients | # Epo/# Ctl Patients | Relative Risk | 95% CI (p-value)
Tumor Response – HR | 5 | 688 | 344/344 | 1.00 | 0.92; 1.10
(Heterogeneity) | | | | | 0.94
Subgroups: Patient Baseline Characteristics
Bsln Hb <10
Bsln Hb 10–12 | 2 | 195 | 99/96
Bsln Hb >12 | 3 | 493 | 245/248
Bsln Hb ?
(Group difference^1^)
Solid tumors | (all) | 688 | 344/344
Hematologic
Mixed
(Group difference^1^)
Children
Adults | (all) | 688 | 344/344
(Group difference^1^)
Subgroups: Treatment Protocols
Chemo, all plat | 1 | 224 | 109/115
Chemo, some plat
Chemo, no plat
Chemo, plat unknown
Chemo+RT or RT | 4 | 464 | 235/229
Unknown
(Group difference^1^)
Iron, fixed
Iron, as needed | 1 | 54 | 28/26
Iron unknown | 4 | 634 | 316/318
(Group difference^1^)
Epo tx 6–9 weeks | 2 | 195 | 99/96
Epo tx 12–16 weeks | 3 | 493 | 245/248
Epo tx >20 weeks
Epo tx ? Weeks
(Group difference^1^)
Subgroups: Reporting and Quality
High quality | 2 | 274 | 135/139
Low quality | 3 | 414 | 209/205
(Group difference^1^)
Data from full text
Data from abstract
Data unpublished | 1 | 54 | 28/26
Data from FDA | 4 | 634 | 316/318
(Group difference^1^)

1 p value for differences among subgroup categories calculated by inverse variance method (see Methods/Data Extraction and Analysis/Statistical Data Analysis)

Table 30

Features of Studies Reporting Tumor Response or Duration-Related Outcomes

STUDY: feature: | N93-004^1^ | Throuvalas 2000 | Machtay 2004 | Vadhan-Raj 2004 | EPO GBR-7 | EPO CAN-15 | GOG-0191 | Henke 2003
Control N | 115 | 26 | 70 | 22 | 111 | 53 | 55 | 171
EPO N | 109 | 28 | 71 | 22 | 114 | 53 | 58 | 180
malignancy | SCLC (limited or extensive) | cervix or bladder | head&neck (no mets., unresected) | gastric or rectal | head&neck (stages I-IV) | SCLC (limited only) | cervix cancer | head&neck (stages III or IV)
Tx regimen | cisplatin + etoposide | Pt chemo + radioTx | chemo (?)+ radioTx | 5FU + radioTx | radioTx | Pt chemo + radioTx | Pt chemo + radioTx | adjuvant radioTx
Tx duration | NR | 5–6 weeks | NR | NR | NR | NR | NR | 6–7 weeks
outcome | CR, OR | CR | CR, PFS | CR | CR, OR, DFS | median TTP | PFS | PFS
when assessed | after last cycle | 2–3 mos after Tx | 12 mos median | NR | CR: wk 12 DFS: 3 yrs | NR | NR | ~2 yrs
EPO dose | 150 IU/kg 3X/wk | 10,000 IU 5X/wk | 150 IU/kg 3X/wk | 40,000 IU/wk | 10,000 IU 3X/wk | 40,000 IU/wk | 40,000 IU/wk | 300 IU/kg 3X/wk
EPO duration | 12 wks | 5–6 wks | 9–10 wks | 16 wks | throughout radioTx | 12–24 weeks | NR | throughout radioTx
baseline Hb (cont/EPO) | 12.8/13.0 g/dL | 11.1/11.5 g/dL | 12.2/12.0 g/dL | 13.0 | 13.4 g/dL | NR | NR | 11.7/11.8 g/dL
Hb target, UL | 16 g/dL | NR | 14 g/dL (F) 16 g/dL (M) | 15 g/dL | 15 g/dL | 16 g/dL | 14 g/dL | 14 g/dL (F) 15 g/dL (M)
re-start if Hb< | 14 g/dL | NR | 12.5 (F) 13.5 (M) | 14 g/dL | 12.5 g/dL | 14 g/dL | 13 g/dL | 14 g/dL (F) 15 g/dL (M)

1 As this report went to press, a full-text version of this trial was published (Grote, Yeilding, Castillo et al., 2005).

Among trials that reported tumor response rate (Table 29), characteristics of study populations differed only by average baseline Hb concentration. Each trial reporting this outcome enrolled only adult patients with solid tumors. Three trials studied head and neck cancer, two each treated small cell lung cancer or gynecologic tumors, and the remaining trial investigated gastric and rectal tumors (Table 30). Treatment protocols differed by therapies for malignancy, iron supplementation and duration of epoetin treatment. Trials also varied with respect to publication type and overall quality rating. Epoetin dosage and dose adjustments also varied (Table 30). While five of the eight trials initiated epoetin treatment with FDA-recommended dosages, none conform to currently recommended dose adjustments or Hb targets.

###### Results

Five of eight trials reported CR rate (the most frequently reported tumor response outcome); epoetin did not affect CR rate in any trial (Figure 16). Two studies reported OR rate, with no significant differences between epoetin and control arms (EPO-GBR-07; N93 004).

Figure 16

Meta-Analysis of Data on Relative Risk (Likelihood) of Achieving CR from Five RCTs of Epoetin versus Control

Relative risk (likelihood) to achieve CR ranged from 0.99 to 1.13 across reporting trials (EPO-GBR-7 FDA and Machtay, Pajak, Suntharalingam, et al., 2004; Throuvalas, Antonadou, Boufi, et al., 2000). Each 95 percent CI included 1.0. A test for heterogeneity across trials included for tumor response was not statistically significant (p=0.94, I^2^ =0 percent). An I^2^ value of zero percent indicates no observed statistical heterogeneity, thus only a fixed-effects meta-analysis was done.

Fixed-effects meta-analysis of CR data from the five trials (Figure 16) yielded:

- relative risk (RR) = 1.00 (95% CI: 0.92, 1.10), p=0.91
- pooled CR rates (range by trial): epoetin arms, 63% (18% to 95%); control arms, 61% (18% to 96%)

Subgroup analyses were not done since the five trials were quite homogeneous for prespecified variables.

In one of five studies reporting outcomes related to response duration or tumor progression, with 351 head and neck cancer patients undergoing radiation therapy alone, locoregional PFS was significantly worse among those randomized to epoetin than among controls (RR = 1.62; 95 percent CI: 1.22, 2.14; p=0.0008; Henke, Laszig, Ruebe, et al., 2003). The other four studies reported no significant differences between arms in PFS (Machtay, Pajak, Suntharalingam, et al., 2004; GOG 0191), median TTP (EPO-CAN-15), or DFS (EPO-GBR-7). However, these trials likely lacked adequate statistical power to detect a difference, since only one randomized >100 patients per arm (EPO GBR-7). Additionally, three of the four (GOG 0191; EPO-CAN-15; EPO-GBR-7) closed before meeting accrual targets, due to excess thromboembolic events and following reports from Henke, Laszig, Ruebe, et al. (2003) and Leyland-Jones (2003) that survival decreased relative to controls in epoetin arms. Note also that FDA labeling for epoetin products comments on the Leyland-Jones trial as follows: “At four months, death attributed to disease progression also was higher (6% vs. 3%) in women receiving Epoetin alfa.”

##### Darbepoetin versus Control

No trials comparing darbepoetin versus control reported CR or OR rates. One trial reported PFS and the proportion of patients whose tumors progressed (Vansteenkiste, Pirker, Massuti, et al., 2002; N=320 randomized; 314 evaluated; 155 from darbepoetin arm, 159 from control arm; see Appendix C Table C34).

This trial enrolled adult patients with small cell and non-small cell lung cancers, whose mean baseline Hb was just above 10 g/dL; used platinum-based chemotherapy for all patients, and administered darbepoetin at the labeled dose of 2.25 mcg/kg per week for 12 weeks, but did not conform to current recommendations for dose adjustments. Darbepoetin was discontinued if Hb rose above 15 g/dL for males or 14 g/dL for females, and was reinstated (at half the dose) if Hb fell below 13 g/dL for either sex. The trial did not report on iron use; and was rated a high-quality study, published in full text, and updated at the May 2004 ODAC meeting.

###### Results

PFS over 24 months’ followup reportedly did not differ significantly between arms (HR = 0.81; 95 percent CI: 0.64, 1.03). Cox proportional hazards analysis reportedly showed less frequent tumor progression over 12 months median followup in the darbepoetin than in the control arm (HR = 0.70; 95 percent CI: 0.53, 0.92).

#### KQ1 Outcome VI. Thromboembolic Events

Thromboembolic events were not well defined in the reports of included trials; definitions in general did not appear to be prespecified.^16^ Studies usually did not provide a detailed definition of thromboembolic events. Most studies did not provide information on severity of reported events. Only 10 studies reported detailed lists of thromboembolic events (Razzouk, Hockenberry, Hinds, et al 2003; Rosenzweig, Bender, Lucke, et al., 2004; Henke, Laszig, Ruebe, et al., 2003; Witzig, Silberstein, Loprinzi, et al., 2005; Ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; EPO GBR-07 2004; GOG-191 2004; N93-004 2004; EPO-CAN-15 2004; Vadhan-Raj, Skibber, Crane, et al., 2004). Given these difficulties, we required neither grade nor elaboration of different types of thromboembolic events for inclusion in the analysis. Events for this review included: thrombosis or related complications such as transient ischemic attacks, stroke, pulmonary embolism or myocardial infarction. However, given the lack of detailed reporting, it was not possible to quantify the frequency of specific thromboembolic events.

16 For example, Johnson & Johnson applied the following definition in their document prepared for the FDA ODAC hearing (Food and Drug Administration Oncologic Drugs Advisory Committee. May 4, 2004, Meeting Briefing Information) and from which several sets of study data were abstracted: “The list of general TVEs [thrombovascular {i.e., thromboembolic} event] is the Sponsor’s broadest approach for identifying TVEs, and includes all superficial TVEs, all catheter related TVEs and events that could but not necessarily would, be caused by an underlying thrombovascular event and where no information was available to prove the contrary. General TVEs are also subclassified as clinically relevant, a definition that is broader than the generally accepted clinically important TVEs (e.g. DVT, PE, stroke/TIA, and MI).” We found no consistent definitions for data abstracted from the Roche FDA ODAC hearing document or hearing documents prepared by FDA reviewers.

Discrepancies among data for the same study from different sources also posed a problem. Twelve of the 30 studies of epoetin vs. control evaluated for thromboembolic complications and contributing 72.7 percent of the weight to the overall analysis were reported in two or more documents (e.g. abstracts, full publications, FDA reviewer documents and reports submitted by the pharmaceutical companies for the FDA ODAC hearing in May 2004) and thromboembolic event data did not agree. The discrepancies were resolved for Henke, Laszig, Ruebe, et al., 2003 (the journal publication reported hypertension and thromboembolic events together whereas the Roche FDA ODAC document reported the events separately) and for Leyland-Jones 2003 (the journal publication reported thromboembolic events during the first four months, the FDA reviewer summary listed deaths following thromboembolic event during the first 4 months, and clinically relevant events were reported in the J&J FDA ODAC document/slides; the latter was chosen for the analysis). For the other 10 studies (EPO-CAN-20 2004; EPO-GBR-07, 2004; GOG-191, 2004; Machtay, Pajak, Suntharalingam, et al., 2004; N93-004 2004; Witzig, Silberstein, Loprinzi, et al., 2005; Vadhan-Raj, Skibber, Crane, et al., 2004; Littlewood, Bajetta, Nortier, et al., 2001; Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995) it was not possible to resolve the data discrepancies. For these studies, we employed a predefined rule: the most complete data set (largest sample size) OR data with consistent outcome definitions across trials were chosen for analysis.

##### Evidence for Comparative Safety

###### Darbepoetin versus Epoetin

Characteristics of reporting studies are enumerated in Table 31. Three RCTs directly compared thromboembolic event rates after darbepoetin or epoetin treatment (N = 1,879; 948 to darbepoetin, 931 to epoetin) (Glaspy, Berg, Tomita, et al., 2005; Schwartzberg, Yee, Senecal, et al., 2004; Waltzman, Croot, Williams, 2005). Patients varied only by type of malignancy across studies; treatment protocols did not differ. Trials varied with respect to type of publication.

Table 31

Characteristics and Subgroup Analyses of RCTs Reporting Thromboembolic Events

Outcome | Darbepoetin versus Epoetin | | | | | Epoetin versus Control
Subgroup | # Studies | #Total Patients | #Darb/#Epo Patients | Point Estimate | 95% CI (p-value) | # Studies | #Total Patients | #Epo/#Ctl Patients | Point Estimate | 95% CI (p-value)
Thromboembolism – RR | 3 | 1,879 | 948/931 | 0.86 | 0.61; 1.21 | 30 | 6,092 | 3,355/2,737 | 1.69 | 1.36; 2.10
(Heterogeneity) | | | | | (0.98) | | | | | (0.67)
Subgroup Analyses: Patient Baseline Characteristics
Bsln Hb <10 | | | | | | 10 | 2,172 | 1,205/967 | 1.53 | 0.98; 2.39
Bsln Hb 10–12 | (all) | | | | | 7 | 1,394 | 782/612 | 1.78 | 1.12; 2.83
Bsln Hb >12^1^ | | | | | | 5 | 1,505 | 771/734 | 1.71 | 1.08; 2.70
Bsln Hb unclear^1^ | | | | | | 8 | 1,021 | 597/424 | 1.74 | 1.18; 2.56
(Group difference^2^) | | | | | | | | | | (0.93)
Solid tumors | 2 | 670 | 337/333 | | | 20 | 4,108 | 2,200/1,908 | 1.70 | 1.33; 2.16
Hematologic | | | | | | 5 | 898 | 509/389 | 3.00 | 1.10; 8.12
Mixed/unknown | 1 | 1,209 | 611/598 | | | 5 | 1,086 | 646/440 | 1.33 | 0.76; 2.32
(Group difference^2^) | | | | | | | | | | (0.34)
Subgroup Analyses: Treatment Protocols
Children
Adults | (all) | | | | | (all)
(Group difference^2^)
Chemo, all plat | | | | | | 9 | 1,439 | 861/578 | 1.15 | 0.77; 1.71
Chemo, some plat | (all) | | | | | 2 | 478 | 237/241 | 2.02 | 0.83; 4.89
Chemo, no plat | | | | | | 7 | 2,494 | 1,362/1,132 | 1.46 | 1.04; 2.05
Chemo, plat unknown
Chemo+RT or RT | | | | | | 8 | 1,187 | 601/586 | 3.00 | 1.77; 5.10
Unknown | | | | | | 4 | 494 | 294/200 | 3.99 | 1.28; 12.41
(Group difference^2^) | | | | | | | | | | (0.036)
Iron, fixed | | | | | | 1 | 333 | 168/165 | 1.47 | 0.54; 4.05
Iron, as needed | | | | | | 14 | 2,730 | 1,513/1,217 | 1.56 | 1.09; 2.23
Iron unknown | (all) | | | | | 15 | 3,029 | 1,674/1,355 | 1.80 | 1.35; 2.39
(Group difference^2^) | | | | | | | | | | (0.97)
Epo tx 6–9 weeks | | | | | | 4 | 646 | 329/317 | 1.91 | 0.78; 4.64
Epo tx 12–16 weeks | (all) | | | | | 15 | 2,836 | 1,546/1,290 | 1.48 | 1.11; 1.98
Epo tx >20 weeks | | | | | | 8 | 1,953 | 1,107/846 | 1.85 | 1.26; 2.72
Epo tx ? Weeks | | | | | | 3 | 657 | 373/284 | 2.89 | 1.11; 7.55
(Group difference^2^) | | | | | | | | | | (0.43)
Subgroup Analyses: Reporting and Quality
High quality | | | | | | 18 | 4,224 | 2,292/1,932 | 1.55 | 1.21; 1.99
Low quality | (all) | | | | | 12 | 1,868 | 1,063/805 | 2.18 | 1.38; 3.44
(Group difference^2^) | | | | | | | | | | (0.21)
Data from full text | 1 | 312 | 157/155 | | | 9 | 1,388 | 764/624 | 1.73 | 1.01; 2.95
Data from abstract | 2 | 1,567 | 791/776 | | | 4 | 732 | 422/310 | 3.61 | 1.21; 10.74
Data unpublished
Data from FDA | | | | | | 17 | 3,972 | 2,169/1,803 | 1.59 | 1.25; 2.03
(Group difference^2^) | | | | | | | | | | (0.29)

1 The N93-004 trial was published in full in December, 2005 (Grote, Yeilding, Castillo, et al., 2005) and included information on baseline Hb which classified it into subgroup Hb >12. A re-categorized analysis resulted in subgroup Hb>12 HR 1.36 (95% CI, 0.97; 1.89); the p-value for the group difference changed from 0.93 to 0.1381. Because this did not alter the interpretation of results, we did not alter our presentation of the overall analysis.

2 p-value for differences among subgroup categories calculated by inverse variance method (see Methods/Data Extraction and Analysis/Statistical Data Analysis).

###### Results

No single trial reported a statistically significant difference in thromboembolic events between epoetin and darbepoetin trial arms. A test for heterogeneity across included trials for thromboembolic events was not statistically significant (p=0.98, I^2^=0 percent). An I^2^ value of 0 percent indicates no observed statistical heterogeneity.

Fixed-effects meta-analysis of data from these studies (Figure 17) showed:

- Relative risk (RR) = 0.86 (darbepoetin to epoetin; 95 percent CI 0.61; 1.21), p=0.40
- Pooled event rates (ranges across trials): darbepoetin, 6.1 percent (2.6 percent to 9.4 percent); epoetin, 7.1 percent (2.6 percent to 11.2 percent)
- RRs ranged from 0.84 to 0.99.

Figure 17

Meta-Analysis of Data on Thromboembolic Event Rates from Three RCTs of Darbepoetin versus Epoetin

Pooled analysis did not show evidence of a statistically significant difference in rates of thromboembolic events for epoetin vs. darbepoetin. Subgroup analyses were not done since differences between trials were minimal. Given limited direct evidence from only three trials, indirect evidence (epoetin vs. control, darbepoetin vs. control) was evaluated for effect on thromboembolic events.

###### Epoetin versus Control

Characteristics of reporting studies are enumerated in Table 31. Thirty RCTs (N=6,092; 3,355 to epoetin, 2,737 to control) reported thromboembolic events (Bamias, Aravantinos, Kalofonos, et al., 2003; Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Chang, Couture, Young, et al., 2005; Dammacco, Castoldi, Rodjer, et al., 2001; EPO-CAN-15, 2004; EPO-CAN-20, 2004; EPO-GBR-07, 2004; GOG-191, 2004; Henke, Laszig, Ruebe, et al., 2003; Henry, Brooks, Case, et al., 1995; Leyland-Jones, 2003; Littlewood, Bajetta, Nortier, et al., 2001; Machtay, Pajak, Suntharalingam, et al., 2004; N93 004, 2004; Osterborg, Boogaerts, Cimino, et al., 1996; Osterborg, Brandberg, Molostova, et al., 2002; Razzouk, Hockenberry, Hinds, et al., 2004; Rose, Rai, Revicki, et al., 1994; Rosenzweig, Bender, Lucke, et al., 2004; Savonije, Van Groeningen, Van Bochove, et al., 2004; ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; Throuvalas, Antonadou, Boufi, et al., 2000; Vadhan-Raj, Skibber, Crane, et al., 2004; Welch, James, Wilkinson, 1995; Witzig, Silberstein, Loprinzi, et al., 2005; EPO-INT-1, 2004;EPO-INT-3, 2004; P-174, 2004).

Trials that reported thromboembolic events differed with respect to several variables prespecified for subgroup analysis. Baseline characteristics of study populations differed by average baseline Hb concentration and type of malignancy. Treatment protocols differed by therapies for malignancy, iron supplementation, and epoetin treatment duration. Trials also varied with respect to publication type and overall quality rating.

###### Results

Although most trials (25 of 33 comparisons^17^; see Figure 18) reported thromboembolic events in a larger proportion of patients randomized to epoetin than of controls, only one trial reported a statistically significant increase in relative risk (EPO-CAN-15 FDA report; RR=8.00 favoring controls; 95% CI: 1.93, 33.09). A test for heterogeneity across included trials was not statistically significant (p=0.67, I^2^=0%).

17 Three RCTs compared two arms given different epoetin doses (ten Bokkel 1998; Thatcher 1999) or a fixed versus a titrated dosing regimen (Osterborg 1996) against one control arm per study. Together, these studies contributed N=394 (7.1%) to the total number of evaluated patients. For the meta-analysis, each control arm was split artificially and randomly into two groups, each entered with one experimental arm as a separate study. As this might influence weighting of the studies, the analysis was repeated with both experimental arms of each study merged and compared to that study’s full control arm. The original (unmerged) result (RR = 1.69; 95% CI: 1.36, 2.10) was nearly identical to the result using merged experimental arms (RR = 1.70; 95% CI: 1.37, 2.12).

Figure 18

Meta-Analysis of Relative Risk of Thromboembolic Events from RCTs of Epoetin versus Control

Fixed-effects meta-analysis of data from all 30 RCTs (Figure 18) yielded:

- RR = 1.69 (95% CI: 1.36, 2.10), p<0.00001
- Pooled event rates (range by trial): epoetin, 6.5% (0 to 30%); control, 4.1% (0 to 22.6%)
- RR for a thromboembolic event ranged from 0.33 to 5.5 with extreme values of 8.0 and 8.4.

RR was not estimable in three small trials because no events occurred in either arm (Cascinu 1994; P-174 J&J; Thatcher 1999a). Pooled results indicate that thromboembolic events are statistically significantly more likely to occur in patients administered epoetin than controls.

We calculated number needed to harm (NNH; Table 32) from the meta-analytic point estimate, which depends on baseline risk of thromboembolic event in untreated controls. Baseline risk is influenced by: tumor type, extent of cancer, treatment regimen, extrinsic factors (e.g., surgery, immobilization), and prior history. Data from Figure 18 showed that event rates in control arms of included RCTs ranged from zero (reported from 11 RCTs; next lowest rate was 0.67%) to 22.6% (next highest rate was 12.31%). NNH ranged from 7 to 58 for baseline risk values of 20% to 2.5%. Thus, at a baseline thromboembolic event risk of 2.5%, one additional thromboembolic event would occur in every 58 patients treated; at a baseline risk of 20%, one additional thromboembolic event would occur in every seven patients.

Table 32

Number of Patients that Must Be Treated with Epoetin to Cause One Extra Thromboembolic Event, as a Function of Baseline Event Risk

Baseline Risk^1^ | NNH | lower limit 95% CI | upper limit 95% CI
2.5% | 58 | 36 | 111
5% | 29 | 18 | 56
10% | 15 | 9 | 28
20% | 7 | 5 | 14

1 To put baseline risk in clinical context, we used a recent review on thrombosis and cancer (Levine, Lee and Kakkar, 2005). The review tabulated data on thrombosis incidence reported from published studies (mostly case series), but did not include confidence intervals. The following table summarizes these findings by incidence range:

Footnote Table. Thrombosis incidence in various malignancies

Incidence Range (%) | Malignancies (Regimens)
<2.5% | Early stage breast cancer (without chemotherapy)
2.5% to ≤ 5% | Early stage breast cancer (e.g. FAC, CMF); cervix cancer (cisplatin + radiation); lung cancer (not specified);
5% to ≤10% | Early stage breast cancer (CMFVP); lymphoma (not specified); germ cell tumors (not specified)
10% to ≥20% | ovarian (not specified); malignant glioma (not specified)

Abbreviations: CMF(VP) = cyclophosphamide, methotrexate, fluorouracil, (vincristine, prednisone); FAC = fluorouracil, doxorubicin, cyclophosphamide

Univariate subgroup analyses resulted in RR point estimates that were greater than 1.0 (i.e., increased risk in the epoetin arms) for every subgroup evaluated and that in most cases were statistically significant. Cancer treatment regimen was the only statistically significant predictor of a thromboembolic event from epoetin treatment (p=0.0361, Table 31). Trials with regimens including radiation therapy (RR=3.00; 95% CI: 1.77, 5.10), and those that did not report the type of regimens utilized (RR=3.99; 95% CI: 1.28, 12.41), had the largest increases in relative risk. However, it is uncertain whether this finding is clinically meaningful or a result of confounding by other factors such as tumor type.

###### Additional Analyses

As for survival outcomes, additional analyses not anticipated in the original protocol were conducted to answer specific questions or explore new hypotheses. We conducted an influence analysis to identify those studies that most strongly influenced the pooled RR for thromboembolic events. We conducted a subgroup analysis of those studies that administered epoetin according to current FDA-recommended (“labeled”) criteria vs. those studies that used criteria exceeding the labeled limits of dose or target Hb value. We also compared RR for thromboembolic events among subgroups defined by 1 g/dL increments in maximum Hb target value (Table 33).

Table 33

Meta-Analysis of Risk Ratio for Thromboembolic Event by Hb Stopping Value in 1 g/dL Increments

Hb Stopping Value | #Treated Patients | #Control Patients | Risk Ratio for Thromboembolic Event | 95% CI
≤ 12 g/dL | 50 | 50 | not estimable (0 events)
>12 and ≤13 g/dL | 148 | 141 | 0.70 | 0.29, 1.67
>13 and ≤14 g/dL | 1,596 | 1,290 | 1.71 | 1.23, 2.40
>14 and ≤15 g/dL | 1,151 | 914 | 1.92 | 1.22, 3.02
>15 and ≤16 g/dL | 368 | 303 | 1.66 | 1.08, 2.54
>16 and ≤17 g/dL | 0 | 0 | (no studies)
>17 and ≤18 g/dL | 0 | 0 | (no studies)
(Unclear) | 42 | 39 | 5.59 | 0.71, 43.94

The results of the influence analysis, in which each study is omitted, one at a time, and the remaining studies are pooled, are shown in Figure 19. The two studies most strongly influencing the meta-analysis are EPO-CAN-15 (2004) and N93-004 (2004). Interestingly, both studies enrolled patients with small cell lung cancer, used standard epoetin doses, and targeted a Hb value of 16 g/dL, but each study influenced the meta-analysis in the opposite direction. However, summary point estimates are not markedly changed by omission of either study, and remain statistically significant.

Figure 19

Influence Analysis: Relative Risk for Thromboembolic Event Recalculated after Omission of One Study at a Time; Point Estimates (Squares) and 95% Confidence Intervals (Lines)

Three studies (Cascinu, Fedeli, Del Ferro, et al., 1994; Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995), constituting 6.4% of all patients evaluated for thromboembolic events, that most closely met current labeled criteria for use were compared to all other trials in a subgroup analysis. These studies used labeled (Case, Bukowski, Carey, et al., 1993; Henry, Brooks, Case, et al., 1995) or slightly lower epoetin doses (Cascinu, Fedeli, Del Ferro, et al., 1994) and stopped administration when Hb reached 13 g/dL, as recommended on the product label. Dose reduction strategies were slightly different from labeled recommendations.

For this subgroup analysis there was no evidence of heterogeneity within subgroups or overall (I^2^ =0%). Subgroup meta-analysis results (Figure 20) are as follows:

- Labeled: RR 0.70, 95% CI 0.29; 1.67
- Unlabeled: RR 1.75, 95% CI 1.40; 2.20
- Unclear^18^: RR 5.59, 95% CI 0.71; 43.9
  18 Rosenzweig, Bender, Lucke, et al. (2004) and Throuvalas, Antonadou, Boufi et al. (2000) have 0–4 events per arm and together contribute only 1.7% of the total weight to the analysis.

Figure 20

Meta-Analysis of Data on Thromboembolic Events: Labeled versus Unlabeled Criteria for Use in Trials Comparing Epoetin to Control

The labeled and unlabeled groups differ significantly from each other (p=0.046), consistent with the explanation that targeting higher than recommended Hb values increases thromboembolic event risk. However, given the small number of studies and patients comprising the labeled group (3 studies, N=389) versus the unlabeled group (25 studies, N=5,622), these results could be confounded by other characteristics that affect risk, such as tumor type or treatment regimen.

Visualizing the data by 1 g/dL increments in upper limit of target Hb (Figure 21) again suggests that beyond the labeled target of 13 g/dL, thromboembolic event risk is greater, but there is no clear relationship between increasing Hb and increasing risk and the trend is not statistically significant (p=0.742). Limitations to this representation are similar in that studies targeting 13.0 g/dL or less are few and results may be confounded by other factors.

Figure 21

Meta-Analysis of Data on Survival by 1 g/dL Hb Unit Increments for Treatment Stopping Point in Trials Comparing Epoetin to Control

###### Darbepoetin versus Control

Only one trial compared darbepoetin versus control and reported the proportion of participants with a thromboembolic event (Vansteenkiste, Pirker, Massuti, et al., 2002; n=320 randomized; 314 evaluated; 155 from darbepoetin arm, 159 from control arm). This trial enrolled adult patients with solid tumors whose mean baseline Hb was just above 10 g/dL; used platinum-based chemotherapy for all patients; administered darbepoetin for 12 weeks, but did not report on iron use; and was rated a high-quality study, published in full text, and updated at the May, 2004 ODAC meeting.

###### Results

The point estimate was not statistically significant for an increased relative risk of thromboembolism (RR = 1.44; 95% CI: 0.47, 4.43). Reported event rates were 4.5% in the darbepoetin arm and 3.1% in controls.

##### Evidence Regarding the Class of Erythropoiesis-Stimulating Products

###### Combined Analysis of Epoetin versus Control and Darbepoetin versus Control

Erythropoiesis-stimulating products are considered to have similar pharmacodynamic properties when used at recommended doses (Food and Drug Administration Oncologic Drugs Advisory Committee Meeting Briefing Information, 2004); therefore we conducted a combined analysis of trials reporting thromboembolic events for more robust results. However, because there is only one trial of darbepoetin vs. control, the result changed little (RR, 1.68; 95% CI: 1.36, 2.08) and the additional influence analysis and analysis by 1 g/dL Hb increments are not presented.

#### KQ1 Outcome VII. Other Adverse Events

Adverse events other than thromboembolism reported separately by study arm from multiple RCTs include: hypertension (16 trials), thrombocytopenia and/or hemorrhage (nine trials), rash (six trials), and seizures (three trials). Also summarized here are published data from RCTs on development of antibodies to epoetin or darbepoetin that might neutralize natural erythropoietin.

##### Darbepoetin versus Epoetin

One direct comparative study (Glaspy, Jadeja, Justice, et al., 2003) reported there were no seizures in either study arm. No other trials that directly compared darbepoetin versus epoetin reported rates of these adverse events separately by study arm.

###### Antibodies

Three trials that directly compared darbepoetin versus epoetin tested for antibodies to either product (Schwartzberg, Yee, Senecal, et al., 2004; Glaspy, Berg, Tomita, et al., 2005; Glaspy, Jadeja, Justice, et al., 2003). Another comparative RCT only tested for antibodies to darbepoetin (Glaspy, Jadeja, Justice et al., 2002). Antibodies were not detected in any patients.

##### Epoetin versus Control

###### FDA-approved Prescribing Information

Hypertension, thrombocytopenia/hemorrhage, rash and seizures were not included in tables listing adverse experiences that occurred in >10 percent of patients from either arm of FDA-reviewed trials with cancer patients on chemotherapy. Sections on Information for Patients with cancer on chemotherapy note that “Hypertension, associated with a significant increase in hemoglobin, has been noted rarely in patients treated with…” Epogen® or Procrit®. While these sections do not estimate the frequency of hypertension, they recommend that blood pressure “…should be monitored carefully, particularly in patients with an underlying history of hypertension or cardiovascular disease.” These sections also note that seizures occurred in 3.2 percent of those treated with the thrice-weekly regimen in double blind, placebo-controlled trials reviewed by FDA, and in 2.9 percent of placebo-treated controls. In similar trials using the weekly dosing regimen, seizures occurred in 1.2 percent of those given Epogen® or Procrit® and 1 percent of placebo-treated controls.

###### Evidence from Published Trials

Table 34 summarizes available evidence and overall results for adverse events other than thromboembolism reported by multiple RCTs. Since heterogeneity was not statistically significant (i.e., each I^2^ was well below 25 percent), data were pooled using fixed-effects meta-analysis (separately for each adverse event). Subgroup analyses were not done for any adverse event, since event rates were not reported separately for subgroups with different malignancies or other baseline characteristics.

Table 34

Other Adverse Events Reported by RCTs of Epoetin versus Control

Outcome | # studies reporting | Total N evaluated | N to epoetin | N to control | RR | 95% CI | p-value overall effect | heterogeneity
Outcome | # studies reporting | Total N evaluated | N to epoetin | N to control | RR | 95% CI | p-value overall effect | p value | I^2^
hypertension | 15 | 1,949 | 1,156 | 793 | 1.22 | 0.98; 1.52 | 0.07 | 0.36 | 8.2%
thrombocytopeni a &/or hemorrhage | 9 | 1,422 | 830 | 592 | 1.08 | 0.76; 1.53 | 0.66 | 0.74 | 0%
rash | 6 | 522 | 306 | 216 | 1.77 | 0.82; 3.81 | 0.14 | 0.66 | 0%
seizures | 3 | 389 | 198 | 191 | 1.19 | 0.33; 4.35 | 0.79 | 0.74 | 0%

###### Hypertension

Only two of 15 reporting studies defined hypertension in their published Methods sections (ten Bokkel Huinink, de Swart, van Toorn et al., 1998; Kunikane, Watanabe, Fukuoka et al., 2001). Reviewers extracted definitions from details of results reported by two additional trials (Welch, James, Wilkinson, 1995; Thatcher, De Campos, Bell et al., 1999). Reviewers also extracted definitions from clinical study reports made available by sponsors of two other trials, each of which specified thresholds for systolic and diastolic hypertension (Rose, Rai, Revicki et al., 1994; Dammacco, Castoldi, Rodjer, et al., 2001). Trials differed with respect to hypertension thresholds, ranging from 140 to 180 mm Hg for systolic pressure, and from 95 to 105 mm Hg for diastolic pressure (Appendix C Table C39). The remaining nine trials did not report definitions or details for hypertension. Thus, severity of hypertension could not be ascertained.

Among 19 comparisons^19^ (see Figure 22 and Appendix C Table C39), point estimates of relative risk (RR) for hypertension were not estimable in two (i.e., no events in either arm; Cascinu, Fedeli, Del Ferro, et al., 1994; Iconomou, Koutras, Rigopoulos, et al., 2003), <1 (i.e., favoring epoetin) in four (Kunikane 2001a and b; Rose, Rai, Revicki, et al., 1994; Henry, Brooks, Case, et al., 1995), and >1 (i.e., favoring control) in 13 (Bamias, Aravantinos, Kalofonos, et al., 2003; Case, Bukowski, Carey, et al., 1993; Dammacco, Castoldi, Rodjer, et al., 2001; Littlewood, Bajetta, Nortier, et al., 2001; Osterborg 1996 a and b; Rosenzweig, Bender, Lucke, et al., 2004; Silvestris, Romito, Fanelli, et al., 1995; ten Bokkel Huinink, de Swart, van Toorn et al., 1998a and b; Thatcher, De Campos, Bell et al., 1999a and b; Welch, James, Wilkinson, 1995).

19 Four studies compared two arms given different epoetin doses (ten Bokkel 1998; Kunikane 2001; Thatcher 1999) or a fixed versus a titrated dosing regimen (Osterborg 1996) against one control arm per study. For the meta-analysis, each control arm was split artificially and randomly into two groups, each entered with one experimental arm as a separate study. As this might influence weighting of the studies, the analysis was repeated with both experimental arms of each study merged and compared to that study’s full control arm. Results with each study’s experimental groups merged (RR=1.24; 95% CI: 0.99, 1.54) were similar to results with the control groups split (RR=1.22; 95% CI: 0.98, 1.52).

Figure 22

Meta-Analysis of 15 Epoetin-versus-Control RCTs that Reported Hypertension

Meta-analysis^19^ of 15 reporting RCTs (see Figure 22; N=1,949; 1,156 to epoetin, 793 to control) showed:

- Increased risk for hypertension in epoetin arms was not statistically significant (RR=1.22; 95 percent CI: 0.98, 1.52; p=0.07)
- Pooled event rates: epoetin, 12.2 percent; controls, 8.1 percent

Several aspects of the evidence available on hypertension limit interpretability and conclusions from the meta-analysis. Although 15 RCTs reported, one trial with 11.3 percent of the total patient population but 66.3 percent of events contributes 75 percent weight and thus likely dominates the analysis’ results (Rose 1994). Additionally, reporting trials used a wide range of thresholds to define hypertension. Furthermore, only a minority of RCTs on epoetin versus control reported on hypertension (15 of 48 with 23.6 percent of randomized patients).

###### Thrombocytopenia and/or Hemorrhage

Among 12 comparisons (see Figure 23), point estimates for relative risk (RR) of thrombocytopenia and/or hemorrhage were not estimable in one (i.e., no events in either arm; Cascinu, Fedeli, Del Ferro, et al., 1994), <1 (i.e., favoring epoetin) in two (Boogaerts, Coiffier, Kainz, 2003; Osterborg, Boogaerts, Cimino, et al., 1996), indistinguishable from 1.0 in two (Del Mastro, Venturini, Lionetto, et al., 1997; Littlewood, Bajetta, Nortier, et al., 2001), and >1 (i.e., favoring control) in seven (Thatcher 1999a and b; Osterborg 1996a; Kunikane 2001 a and b; Dammacco, Castoldi, Rodjer, et al., 2001; Bamias, Aravantinos, Kalofonos, et al., 2003).

Figure 23

Meta-Analysis of Seven Epoetin-versus-Control RCTs that Reported Thrombocytopenia and/or Hemorrhage

Meta-analysis^20^ of nine reporting RCTs (see Figure 23; N=1,422; 830 to epoetin, 592 to control) showed:

20 Three studies compared two arms given different epoetin doses (Kunikane 2001; Thatcher 1999) or a fixed versus a titrated dosing regimen (Osterborg 1996) against one control arm per study. For the meta-analysis, each control arm was split artificially and randomly into two groups, each entered with one experimental arm as a separate study. As this might influence weighting of the studies, the analysis was repeated with both experimental arms of each study merged and compared to that study’s full control arm. Results with each study’s experimental groups merged (RR=1.08; 95% CI: 0.74, 1.57) were similar to results with the control groups split (RR=1.19; 95% CI: 0.80, 1.76).

- Increased relative risk for thrombocytopenia and/or hemorrhage in epoetin arms was not statistically significant (RR=1.08; 95 percent CI: 0.76, 1.53; p=0.66)
- Pooled event rates: epoetin, 9.5 percent; controls, 7.6 percent

###### Rash

Among eight comparisons (see Figure 24), point estimates for relative risk (RR) for rash were not estimable in one (i.e., no events in either arm; Kurz, Marth, Windbichler, et al., 1997), <1 (i.e., favoring epoetin) in one (Thatcher 1999b), and >1 (i.e., favoring control) in six (Thatcher 1999a; Osterborg 1996a and b; Henry, Brooks, Case, et al., 1995; Del Mastro, Venturini, Lionetto, et al., 1997).

Figure 24

Meta-Analysis of Six Epoetin-versus-Control RCTs that Reported Rash

Meta-analysis^21^ of six reporting RCTs (see Figure 24; N=522; 306 to epoetin, 216 to control) showed:

21 Two studies compared two arms given different epoetin doses (Thatcher 1999) or a fixed versus a titrated dosing regimen (Osterborg 1996) against one control arm per study. For the meta-analysis, each control arm was split artificially and randomly into two groups, each entered with one experimental arm as a separate study. As this might influence weighting of the studies, the analysis was repeated with both experimental arms of each study merged and compared to that study’s full control arm. Results with each study’s experimental groups merged (RR=1.86; 95% CI: 0.84, 4.09) were similar to results with the control groups split (RR=1.77; 95% CI: 0.82, 3.81).

- Increased relative risk for rash in epoetin arms was not statistically significant (RR=1.77; 95 percent CI: 0.82, 3.81; p=0.14)
- Pooled event rates: epoetin, 5.9 percent; controls, 2.8 percent

###### Seizures

Among three reporting trials, (see Figure 25), point estimates for relative risk (RR) of seizure were not estimable in one (i.e., no events in either arm; Cascinu, Fedeli, Del Ferro, et al., 1994), just below 1 (i.e., favoring epoetin) in a second (Case, Bukowski, Carey, et al., 1993), and >1 (i.e., favoring control) in the third (Henry, Brooks, Case, et al., 1995).

Figure 25

Meta-Analysis of Three Epoetin-versus-Control RCTs that Reported Seizures

Meta-analysis of the three reporting RCTs (see Figure 25; N=389; 198 to epoetin, 191 to control) showed:

- Increased relative risk for seizure in epoetin arms was not statistically significant (RR=1.19; 95 percent CI: 0.33, 4.35; p=0.79)
- Pooled event rates: epoetin, 2.5 percent; controls, 2.1 percent

###### Antibodies

Six trials of epoetin versus control tested for antibodies to erythropoietin (Chang, Couture, Young, et al., 2005; Henry, Brooks, Case, et al., 1995; Oberhoff, Neri, Amadori, et al., 1998; Thatcher, De Campos, Bell, et al., 1999; ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Osterborg, Brandberg, Molostova, et al., 2002). Antibodies were not detected in any tested patient.

##### Darbepoetin versus Control

###### FDA-approved Prescribing Information

Tables summarizing adverse events in cancer patients receiving chemotherapy enrolled in FDA-reviewed trials reported incidence of hypertension, rash, and seizures or convulsions (Table 35). The tables did not report incidence of thrombocytopenia and/or hemorrhage.

Table 35

Incidence of Selected Adverse Events in FDA-Reviewed Trials of Aranesp®

| Aranesp® | controls
N | 873 | 221
hypertension | 3.7% | 3.2%
rash | 7% | 3%
seizures or convulsions | 0.6% | 0.5%

###### Evidence from Published Trials

One trial (Vansteenkiste, Pirker, Massuti, et al., 2002) reported that hypertension occurred in nine of 155 patients (5.8 percent) receiving darbepoetin, and in six of 159 controls (3.8 percent) (RR 1.54, 95 percent CI 0.56; 4.22, n=314). The between-arm difference was not statistically significant (p=0.40). Investigators did not report a definition for hypertension.

No studies that compared darbepoetin versus control reported data separately by study arm on rates of thrombocytopenia and/or hemorrhage, rash, or seizures.

###### Antibodies

Each included trial of darbepoetin versus control tested for antibodies to that product and found none in any patients.

### KQ1 Discussion and Conclusions

Erythropoietic stimulants effectively increase Hb levels and reduce transfusion risk. This review did not identify evidence demonstrating that either of the available erythropoietic stimulants (epoetin or darbepoetin) achieves hematologic response or reduces transfusion risk in a larger proportion of patients than the other. Meta-regression results for transfusion risk suggest that the magnitude of the benefit varies with type of tumor and with treatment duration.

Evidence for the effect of erythropoietic stimulants on quality of life and on survival and associated outcomes is much more difficult to evaluate and interpret, and is therefore the major focus of this discussion.

#### Quality of Life

One large study found that the difference in the FACT-An and FACT-fatigue QoL assessments during treatment between darbepoetin- and epoetin-treated study arms was not statistically significant, suggesting no difference in impact on QoL measures targeted to anemia symptoms. Evidence from studies of epoetin or darbepoetin vs. control suggest that patients treated with erythropoietic stimulants show improvement from baseline in QoL assessments, particularly on symptom-specific scales. Whether patients experience perceptible improvement in QoL is less clear for the following reasons (details follow):

- Factors other than Hb are associated with cancer fatigue;
- Empirically based estimates of the minimally important difference (MID) in QoL scales are not fully developed;
- FACT-fatigue subscale trial results have been compared to MID estimates anchored to ECOG and Karnovsky performance scores. FACT-fatigue improvements may achieve clinical significance in some of the few studies that adequately report this measure;
- Our conclusions regarding quality of life benefits disagreed with a recent meta-analysis of selected epoetin trials (Jones, Schenkel, Just, et al., 2004), which concluded that epoetin significantly improves QoL in patients with cancer. However, results of this other study could be biased by an analysis heavily weighted by inclusion of uncontrolled studies, and by the considerable amount of QoL data missing in some studies.

##### Other factors that may influence the effect of erythropoietic stimulants on QoL

Fallowfield, Gagnon, Zagri, et al. (2002) conducted a multivariate analysis of the Littlewood, Bajetta, Nortier, et al. (2001) QoL data that confirmed the statistically significant results of the univariate analysis, but showed that significant improvements were limited to patients without disease progression. Wisloff, Gulbrandsen, Hjorth et al. (2005) examined the impact of Hb concentration on EORTC QLQ-C-30 scores for 745 multiple myeloma patients while adjusting for disease characteristics including response/progression. The statistical significance of the effect of Hb change on the 3-item fatigue component of QoL was reduced by a factor of 10 when adjusted for response to therapy. Thus, only a subset of patients may be able to realize a QoL benefit with epoetin or darbepoetin treatment. In another study (Nieboer, Buijs, Rodenhuis, et al., 2005), of patients treated with chemotherapy for breast cancer, fatigue, an important component of the FACT-An assessment of QoL, was strongly correlated with mental health and with muscle and joint pain, but not with hemoglobin status, suggesting that multiple causes of fatigue need to be taken into account. Other studies similarly indicate that Hb values alone do not fully account for perceived fatigue (Holzner, Kemmler, Greil et al., 2002; Okuyama, Akechi, Kugaya et al., 2000).

##### Clinical significance of statistically significant changes in QoL

Whether statistically significant improvements detected in QoL assessments are clinically significant and meaningful to the patient is inadequately answered by the data presented here. The FACT scales and subscales most often used are, as designed, symptom specific. Treatment-associated improvement on these scales refers to fatigue and other aspects of anemia-related QoL. Seven of ten studies using global QoL scales (including FACT-G but not FACT-An, which contains a substantial proportion of symptom-specific questions) found nonsignificant changes with treatment, suggesting that the less-sensitive global scales may not reflect the changes seen in the anemia symptom-specific FACT scales. Alternatively the improvements reported may not be large enough to be detected as a change in overall quality of life. However, this question is not answered sufficiently by the data as only 4 studies used both symptom-specific and global scales and result patterns were different for each.

To determine the clinical significance of improvements on the FACT-An and its subscales, a clear, empirically-based estimation of the minimum clinically important difference (MID) is needed for each scale. Anchor-based and distribution-based methods can be employed to estimate the MID. Anchor-based methods evaluate the relationship between change in the QoL scale of interest (target) and an independent measure (anchor). Required qualities of the anchor are, first, that it is an accepted clinical measure for which the clinical significance of change in the measure is well understood. The anchor should also measure QoL in some way. Second, there should be an association between the anchor and the target (Yost and Eton, 2005; Guyatt, Osoba, Wu et al., 2002); associations of 0.5 or greater are strongly recommended (Guyatt, Norman, Juniper et al., 2002). This information should be included in reports of MID studies. Distribution-based methods rely on QoL score statistical distributions, and may use standard deviation (SD) or standard error of measurement (SEM) as the criterion for clinical significance. Because anchor-based approaches are difficult to validate, and distribution-based methods are statistical, rather than clinical, in nature, current recommendations are to estimate MID with more than one anchor; distribution-based methods may supplement but should not substitute for anchor-based methods (Guyatt, Osoba, Wu, et al., 2002; Osoba, Rodrigues, Myles et al., 1998).

Both anchor- and distribution-based methods have been used to estimate MID for FACT-An and subscales in cancer patients treated with epoetin (Cella, Eton, Lai, et al., 2002; Patrick, Gagnon, Zagari, et al., 2003). Using change in Hb as an anchor; Patrick, Gagnon, Zagari, et al. (2003) reported correlations of 0.26 (FACT-G) and 0.29 (FACT-fatigue subscale) between QoL scale and a Hb increase of 1 g/dL.^22^ No correlation information was provided by Cella, Eton, Lai, et al. (2002), using the same anchor, nor was additional information on interpretation of the Hb change anchor provided in either study. Given correlations between anchor and target that are not strong, and no documented validation of the anchor’s interpretability, it is unclear what the identified minimal change in the anchor of 1 g/dL means to the perceived QoL of the patient. Furthermore, whether or not increased Hb is interpretable as a measure of QoL is part of the question at hand: does the use of epoetin or darbepoetin, which increase Hb levels, improve QoL? Thus, change in Hb is not an informative anchor.

22 These correlations are similar to those reported by studies included in this review (e.g. 0.35 for change in FACT-fatigue subscale and Hb, Iconomou, Koutras, Rigopoulos 2003; 0.26 (FACT-G) and 0.29 (FACT-fatigue subscale for change in QoL scale and change in Hb, Littlewood, Bajetta, Nortier 2001).

Anchoring changes in FACT scales to performance scores, however, is more persuasive. Cella, Eton, Lai, et al. (2002) also used ECOG and Karnovsky performance scores as anchors in their study.^23^ The authors did not report information on the correlation of either performance scores with target QoL scales, or on the interpretability of change in the performance scores. However, as these scores reflect physical function, changes are likely to be more closely linked to the physical aspects of QoL in epoetin and darbepoetin-treated patients. This is supported by data from an unrelated study of chemotherapy in patients with lung cancer, where baseline ECOG performance score was strongly correlated with the EORTC QLQ C-30 scales at −0.52 (physical function), −0.63 (global health status), and 0.52 (fatigue) (Bircan, Berktas, Bayiz et al., 2003). Similar published information could not be found for FACT scales in epoetin-treated patients.

23 Due to few patients in categories of considerable disability, Cella, Eton, Lai, et al. (2002) collapsed such categories into a single category for both ECOG and Karnovsky performance scales.

##### Interpreting the results of this review

When results of the most commonly reported QoL scale, the symptom-specific FACT-fatigue subscale, are compared to MID estimates from anchoring to performance scores, the results are not strong. The estimated MID range is 3.5–8.8 (Cella, Eton, Lai, et al., 2002). As shown in Table 36, four of six absolute mean change differences in scores between epoetin and control arms fall within the lower half of the estimated MID range of 3.5–8.8, while the other 2 are below that range. When these results are translated into effect size, most effect sizes would be considered small.^24^ Thus, this analysis suggests that in the small sample of studies that reported results for the FACT-fatigue subscale, some improvements in QoL may be clinically significant (depending on the “true” MID value) but the magnitude of the effect is likely to be small.^25^

24 Cohen (1988) arbitrarily defined effect sizes of 0.2 as “small,” 0.5 as “moderate,” and 0.8 as “large.”

25 As this report went to press, an analysis of the clinical significance of QoL data from Hedenus, Adriansson, San Miguel et al. (2003) was published (Littlewood, Kallich, San Miguel et al. (2006). In this analysis, treatment and control arms were pooled; patients who improved by at least 3 points on their FACT-fatigue subscale score were significantly more likely to show improvement in other FACT scales (except social well-being), in Brief Symptom Inventory Depression and Anxiety subscales, and in numeric rating scales of Energy, Activity, and Overall Health.

Table 36

FACT-Fatigue Subscale Mean Change Differences Between Epoetin and Control Arms in 6 Included Studies and Corresponding Effect Sizes

Study | FACT-fatigue subscale difference in change from baseline, Epoetin - Control | Effect size | p-value for comparison of change
Boogaerts 2003 | 5.2 | 0.45 | <0.05
Littlewood 2001 | 5.5 | (cannot be calculated) | 0.004
Osterborg 2002 | 2.2 | 0.20 | >0.05
Iconomou 2003 | 3.6 | 0.32 | 0.022
Witzig 2005 | 2.4 | 0.11 | 0.18
Chang 2005 | 4.6 | 0.41 | <0.001

Results were similar using a distribution-based method (Cella, Eton, Lai, et al., 2002). For the FACT-fatigue subscale, the average MID based on SEM was 2.6 while the average MID based on 0.5 SD was 5.8. Thus, if 2.6 was used as the MID, results from 4 of 6 studies in Table 36 would be clinically significant, whereas if 5.8 was the MID, none of the studies would be clinically significant.

Thus, for purposes of this review, the true MID is not known with certainty, only a few studies reporting QoL results can be evaluated in this way, and the clinical significance of their results remains unclear. Additional limitations on interpretation are the unknown effects of potential bias due to substantial missing data in included studies and other concerns regarding study validity, including lack of blinding and of information on QoL instrument administration.

###### Other analyses of the effects of erythropoietic stimulants on QoL

While our analysis relies on a non-quantitative vote-counting method due to the lack of sufficient published information for quantitative analysis, Jones, Schenkel, Just, et al. (2004) conducted a quantitative meta-analysis of change from baseline score on a variety of QoL measures reported in published and unpublished studies. For example, the authors report a mean change of 4.6 for the FACT-fatigue subscale after adjustment for potential confounders, which would be within the MID range of 3.5–8.8 estimated by Cella, Eton, Lai, et al. (2002). However, difficulties with this study include an analysis heavily weighted by inclusion of uncontrolled studies, which are subject to bias. Although the authors report that statistical significance was retained when the analysis was repeated without large cohort (“community”) studies, the resulting score change was not reported. Because the authors include cohort studies, they also analyze treatment and control arms of randomized controlled trials as separate cohorts, losing the advantage of within-study comparison to control. The authors report that statistical significance is retained for some measures, when the analysis is “controlled” for placebo effect, but again do not report the resulting score change. Because factors other than epoetin intervention may affect outcomes, randomized controlled trials are necessary for accurate, within-study comparison to placebo. Finally, there is no mention of the considerable amount of QoL data missing in some studies and the resulting potential for bias.

#### Survival, Thromboembolic Events, and Tumor Response

Because these outcomes are interrelated, they are discussed together. Limited evidence from trials directly comparing epoetin to darbepoetin found no significant differences in survival or thromboembolic events; tumor response was not reported. The majority of the evidence for these outcomes is derived from trials of epoetin or darbepoetin versus control. Major topics discussed include:

- Results of other recent evidence summaries;
- Results of large trials designed for survival outcomes and FDA analysis for the Oncologic Drugs Advisory Committee;
- Potential confounding variables and how they may affect interpretations of results;
- Limitations of the data.

##### Recent evidence summaries

Prior to this review, major summaries on survival outcomes of erythropoietin product administration include a review conducted by the Cochrane Haematological Malignancies Group (http://www.cochrane.org/reviews/en/ab003407.html; Bohlius, Langensiepen, Schwarzer et al., 2005), a systematic review from the National Institute for Health and Clinical Excellence (Wilson, Yao, Rafferty, et al., 2005), and a review of safety conducted by the FDA Oncologic Drugs Advisory Committee (ODAC) on May 4, 2004 (Food and Drug Administration Oncologic Drugs Advisory Committee Meeting Briefing Information, 2004). The Cochrane review included studies published through December 2001, none of which were designed to evaluate survival as the primary outcome. Rather, survival was a secondary outcome, often collected retrospectively after the close of the study and after patient treatment was no longer controlled by the study protocol. In many cases results were not included in the trial’s published report but were available only from investigators responding to the authors’ request for supplementary data. The pooled, unadjusted hazard ratio for death was 0.84 (95% CI, 0.69–1.02), favoring epoetin treatment. The result, however, was not statistically significant. Given the limitations of the evidence, the results were considered inconclusive.

The NICE report updated the Cochrane review with 9 new studies reporting survival outcomes and published through September 2004. The pooled HR for death was 1.03 (95% CI 0.92–1.16), also not statistically significant and suggesting no effect on survival. The report’s authors commented that “The marked change in the results is due to the fairly extreme results favouring no treatment/placebo in the newer studies.”

Changes in study characteristics over time are illustrated in Figure 26, which shows the percentages of studies published before 2003 and after 2003 with the listed characteristics. Studies published in 2003 or later enrolled patients with higher baseline Hb, used higher epoetin doses and/or targeted higher final Hb levels compared to studies published before 2003. Later studies also tended to enroll patients with solid tumors rather than hematologic tumors, likely affecting chemotherapy regimen. Later studies were more likely to have a HR for death greater than 1. Of 18 studies published in 2003 or later and included in this review, 12 reported HR for death >1 and 11 reported RR for thromboembolic event >1 (Appendix C Table C28).

Figure 26

Changes over Time in Studies Reporting on Survival

##### Trials designed for survival outcomes precipitating FDA analysis

Two recent and larger trials designed for overall or progression-free survival (Leyland-Jones 2003; Henke, Laszig, Ruebe, et al., 2003) had increased mortality in the epoetin study arms; two other trials designed to measure survival outcomes (EPO-CAN-15; GOG-191) and 1 trial designed for local tumor response (Vadhan-Raj, Skibber, Crane, et al., 2004) had significant increases in thromboembolic events in the treatment arms and were consequently closed prematurely. The adverse events reported in these trials prompted the FDA to examine the safety of higher doses of erythropoietic stimulants or higher Hb target levels, in an ODAC meeting on May 4, 2004. Both the Leyland-Jones (2003) and Henke, Laszig, Ruebe, et al. (2003) studies were intended to assess survival and tumor response outcomes. Results showed shorter overall survival; shorter progression-free survival; and increased incidence of thrombotic/cardiovascular events in the patients receiving epoetin (Table 37). Particularly troubling was the increased mortality due to thrombotic vascular and cardiovascular adverse events in the epoetin-treated arm of the Leyland-Jones study at 4 months’ followup.

Table 37

Summary of Adverse Events, Tumor Response, and Survival Outcomes reported in the FDA Briefing Document, Oncologic Drugs Advisory Committee meeting, May 4, 2004

Trial [Epo Product, dose] | Trial Description | Epo Target | Thrombosis/ Cardiovascul ar (CV) Outcomes | Epoetin Arm Results | Placebo Arm Results | Disease Progression/Tumor Response | Epoetin Arm Results | Placebo Arm Results | Survival Outcome | Epoetin Arm Results | Placebo Arm Results
Leyland-Jones 2003 Breast Cancer Erythropoietin Trial (BEST) [EPREX, 40,000 IU qw] | RCT of epoetin in 939 women with metastatic breast cancer; designed to assess overall survival | initiation of epoetin when Hb ≤ 13 g/dL, to target Hb 12–14 g/dL | fatal thrombotic or CV events in the first 4 mo | 2.3% | 0.4% | disease progression | 6% | 3% | 12-mo OS rates | 70% | 76%
Leyland-Jones 2003 Breast Cancer Erythropoietin Trial (BEST) [EPREX, 40,000 IU qw] | RCT of epoetin in 939 women with metastatic breast cancer; designed to assess overall survival | initiation of epoetin when Hb ≤ 13 g/dL, to target Hb 12–14 g/dL | fatal thrombotic or CV events after 4 mo | 0.6% | 1.5% | early mortality (by 4 mo) | 8.7% | 3.4% | Hazard ratio, 12 mo followup | HR = 1.37 95% CI, 1.07–1.74 p=0.012
Henke et al. (2003) [NeoRecormon, 300 IU/kg tiw] | 351 head and neck cancer patients receiving radiotherapy; designed to assess locoregional progression-free survival | ≤ 14 g/dL for women and ≤ 15 g/dL for men | hypertension, hemorrhage, venous thrombosis, pulmonary embolism or CV event | 11% | 5% | locoregional progression-free survival | RR = 1.62^1^ 95% CI, 1.22–2.14 p=0.0008 | | Median OS | 605 days | 928 days
Henke et al. (2003) [NeoRecormon, 300 IU/kg tiw] | 351 head and neck cancer patients receiving radiotherapy; designed to assess locoregional progression-free survival | ≤ 14 g/dL for women and ≤ 15 g/dL for men | hypertension, hemorrhage, venous thrombosis, pulmonary embolism or CV event | 11% | 5% | locoregional progression-free survival | RR = 1.62^1^ 95% CI, 1.22–2.14 p=0.0008 | | Median OS | p=0.09 (logrank)
Henke et al. (2003) [NeoRecormon, 300 IU/kg tiw] | 351 head and neck cancer patients receiving radiotherapy; designed to assess locoregional progression-free survival | ≤ 14 g/dL for women and ≤ 15 g/dL for men | hypertension, hemorrhage, venous thrombosis, pulmonary embolism or CV event | 11% | 5% | locoregional progression-free survival | RR = 1.62^1^ 95% CI, 1.22–2.14 p=0.0008 | | Relative Risk of death | RR = 1.4^1^ 95% CI, 1.05–1.84 p=0.02 (Cox)
Henke et al. (2003) [NeoRecormon, 300 IU/kg tiw] | 351 head and neck cancer patients receiving radiotherapy; designed to assess locoregional progression-free survival | ≤ 14 g/dL for women and ≤ 15 g/dL for men | died of “cardiac disorders” | 5% | 3% | locoregional progression | RR = 1.69 95% CI, 1.16–2.47 p=0.007 | | Relative Risk of death | RR = 1.4^1^ 95% CI, 1.05–1.84 p=0.02 (Cox)
N93-004^2^ [Procrit, 150 IU/kg tiw] | post-marketing, non-inferiority RCT of epoetin in 224 patients^3^ with small cell lung cancer undergoing first line therapy; powered at n=400 to assess tumor response | epoetin dose was not reduced until Hb ≥ 16 g/dL | incidence of thrombotic vascular events^4^ | 22% | 23% | CR+PR response rate after 3 chemo cycles | 72% | 67% p=NS | Median OS, 3 yr followup | 10.5 mos. | 10.4 mos.
N93-004^2^ [Procrit, 150 IU/kg tiw] | post-marketing, non-inferiority RCT of epoetin in 224 patients^3^ with small cell lung cancer undergoing first line therapy; powered at n=400 to assess tumor response | epoetin dose was not reduced until Hb ≥ 16 g/dL | incidence of thrombotic vascular events^4^ | 22% | 23% | CR+PR response rate after 3 chemo cycles | 72% | 67% p=NS | Overall mortality rate, 3 yr followup | 92% | 88%
N93-004^2^ [Procrit, 150 IU/kg tiw] | post-marketing, non-inferiority RCT of epoetin in 224 patients^3^ with small cell lung cancer undergoing first line therapy; powered at n=400 to assess tumor response | epoetin dose was not reduced until Hb ≥ 16 g/dL | incidence of thrombotic vascular events^4^ | 22% | 23% | CR+PR response rate after 3 chemo cycles | 72% | 67% p=NS | Hazard ratio, 3 yr followup | HR^5^ = 1.53 95% CI, 0.65–3.61
980297 (Vansteenkiste 2002) [Aranesp, 2.25 mcg/kg qw] | 320 anemic patients with lung cancer being treated with platinum chemotherapy; powered for transfusion outcomes | Epo dose was not adjusted until Hb ≥ 14 g/dL for women and ≥ 15 g/dL for men. | thrombotic events | 5% | 3% | disease progression over median 12 mo | HR = 0.71^6^ 95% CI, 0.54–0.94 | | Median time to death | 43 wks | 35 wks
980297 (Vansteenkiste 2002) [Aranesp, 2.25 mcg/kg qw] | 320 anemic patients with lung cancer being treated with platinum chemotherapy; powered for transfusion outcomes | Epo dose was not adjusted until Hb ≥ 14 g/dL for women and ≥ 15 g/dL for men. | thrombotic events | 5% | 3% | locoregional PFS, over median 12 mo | HR = 0.74^6^ 95% CI, 0.57–0.97 | | Hazard ratio, 11 mo median followup | HR = 0.80^6^ 95% CI, 0.58–1.11
Studies halted prematurely by Johnson & Johnson
EPO-CAN-15 [Procrit, 40,000 IU qw] | 106 patients with SCLC receiving chemoradiation therapy | Hb 14–16 g/dL | thrombotic vascular events | 34% | 6% | | | | Hazard ratio, ?followup | HR^5^ = 2.70 95% CI, 1.17– 6.21
GOG-191 [Procrit, 40,000 IU qw] | 113 patients with cervical cancer receiving chemo-radiation | Hb 13–14 g/dL | thrombotic vascular events | 16% | 5% | | | | Hazard ratio, ?followup | HR^5^ = 0.82 95% CI, 0.29–2.29
PR00-03-006 (Vadhan-Raj 2004) [Procrit, 40,000 IU qw] | 60 patients with gastric or rectal cancer undergoing preoperative chemoradiation | Hb 14–15 g/dL | thrombotic vascular events | 24% | 6% | | | | Hazard ratio, ?followup | HR^5^ = 0.15 95% CI, 0.00–7.69

1 Adjusted for stage and randomization stratum

2 The N93-004 epoetin trial was published in full in December, 2005 (Grote, Yeilding, Castillo, et al., 2005)

3 66% of pts in epoetin arm (n=109) had extensive stage SCLC cf. 59% of pts in placebo arm (n=115); else no differences in baseline characteristics; trial terminated early for poor accrual

4 Incidences of specific subtypes of thrombotic vascular events similar except for chest pain (7% epoetin; 14% placebo) and extracardiac vascular disorders (10% epoetin, 4% placebo)

5 Not available from FDA Briefing Document; abstracted from Industry-supplied summaries for ODAC meeting.

6 Adjusted for tumor type and region

Complicating the analysis was a concomitant decrease in progression-free survival in the treatment arms of the Leyland-Jones and Henke, Laszig, Ruebe, et al. (2003) trials. The FDA analysis of these studies could not determine whether epoetin potentiates tumor progression. The other studies analyzed were not powered for survival outcomes, but thrombosis or vascular events were more frequent in the treatment arms of most.

Some have questioned the generalizability of the Henke, Laszig, Ruebe, et al. (2003) results based on the number of protocol violations (60 radiotherapy violations and 20 medication violations among N=180 assigned to epoetin; 54 radiotherapy violations and 8 medication violations among 171 assigned to control; nature and direction of violations unspecified). However, the relative risk for locoregional progression-free survival remained significantly in favor of control if analysis was restricted to patients given correct radiotherapy (RR=1.42; 95 percent CI: 1.01, 2.01). For all three outcomes shown in Table 37, results favored control although statistical significance was lost in per-protocol analyses. Thus, the protocol violations do not clearly explain the unfavorable results. Additionally, published comments on both the Henke, Laszig, Ruebe, et al. (2003) and Leyland-Jones (2003) trials noted some imbalances in baseline characteristics, suggesting that the epoetin arms in both trials had slightly greater proportions of patients with poor prognostic factors. However, these imbalances were detected by a retrospective chart review, something that was not done for studies reporting more favorable survival outcomes with administration of erythropoiesis-stimulating products. Therefore this reporting of imbalances is selective and may bias the comparison of Henke, Laszig, Ruebe, et al. (2003) and Leyland-Jones (2003) to other studies.

##### Variables that contribute to survival outcome

Survival depends upon several interrelated factors such as cancer type and stage, treatment, and presence of other co-morbidities. Potential effects of erythropoietic stimulants on tumor progression may be positive, negative, or neutral depending on type of cancer, density of erythropoietin receptors, and cancer treatment regimen. The individual risk of thromboembolic events also varies with tumor type and extent, and additionally with type of anticancer therapy, previous history of thrombosis, and presence of other risk factors such as surgery or immobilization (Levine, Lee, Kakkar 2005). Risk appears to be higher with certain types of chemotherapy (e.g. cisplatin) and with drug combinations (e.g., chemotherapy plus tamoxifen) (Weiss 2001). There is evidence that the presence of metastatic disease and number of comorbidities influences risk (Alcalay, Wun, Khatri 2006). Other significant risk factors may include prechemotherapy platelet count, and use of white cell growth factors (Khorana, Francis, Culakova 2005). It is against this background variability that we attempt to define the influence of erythropoietic stimulants on survival, tumor progression, and thromboembolic risk.

The limited evidence available does not support the hypothesis that erythropoietic stimulants increase rates of solid tumor response to therapy. However, other observations raise the possibility that erythropoietic stimulants may accelerate progression of solid tumors expressing erythropoietin receptors. For example, Dr. Michael Henke and colleagues tested tumor samples from a subset of trial patients for erythropoietin receptors and found that epoetin administration to patients with receptor-expressing tumors correlated with shorter progression-free intervals (personal communication; manuscript submitted).

Our analysis of outcomes from 30 studies of epoetin treatment versus control found that erythropoietic stimulation increases relative risk for a thromboembolic event in anemic oncology patients undergoing cancer therapy. Whether survival and thromboembolic event outcomes in these studies were adversely affected by use of epoetin doses and/or Hb target levels higher than recommended in the product label is unclear. Prior studies on patients with chronic renal failure (CRF) and concurrent cardiovascular disease given erythropoietic stimulants dosed to achieve and maintain target Hb above current recommendations reported an increased risk of cardiovascular and thromboembolic adverse events and death (Besarab, Bolton, Browne, et al., 1998). FDA-conducted exploratory analyses of data from the licensing studies of darbepoetin (which included a comparison group treated with epoetin) suggested that increasing thrombosis/ischemic events in patients treated with epoetin or darbepoetin were associated with increasing rate of rise in Hb, but not with absolute Hb concentration (Food and Drug Administration Oncologic Drugs Advisory Committee Meeting Briefing Information, 2004). However, an FDA-requested analysis by Amgen of the Aranesp Integrated Summary of Safety (ISS) database (873, 115, and 221 cancer patients who received darbepoetin, epoetin, and placebo, respectively) found no evidence of an association between maximum achieved Hb level, or the rapidity of increase in Hb, and risk of cardiovascular or thrombotic adverse events. The analysis did indicate that the highest rate of death events in patients receiving darbepoetin or epoetin was in the category of patients with the highest rate of Hb increase. But most patients died of tumor progression, rather than thromboembolic events. While the data from cancer patients are less clear than those in ESRD patients, the accumulation of adverse events in trials using higher doses and/or achieving higher maximum Hb levels resulted in the recommendation to target maximum Hb levels during treatment no higher than 12 g/dL, and to adhere to recommended doses and dose adjustments to avoid a rapid Hb increase. The current product labels reflect these recommendations.

Additional analysis of end-stage renal disease Medicare patient data suggests that the highest mortality rates may be associated with total exposure to erythropoietic stimulants. Zhang, Thamer, Stefanik et al. (2004) report high inter-patient variation in epoetin dose requirements to attain defined hematocrit levels, and for the same achieved hematocrit, there is a wide variation in survival. For every hematocrit cohort studied, patients administered higher doses of epoetin had significantly lower hematocrit values and greater mortality rates. The association between hematocrit and survival may be confounded by patients’ ability to respond; patients who are better able to respond may achieve better outcomes regardless of intervention. Two possible explanations may account for the data: 1) resistance to erythropoietic stimulants could be a marker for undefined comorbidities explaining high mortality rates among trial participants who did not achieve the target hematocrit; or 2) there are side effects of erythropoietic stimulants independent of their effect on hematocrit that may be more pronounced in nonresponders who are administered more product. An accurate investigation of the effects of erythropoietic stimulant exposure on survival in cancer patients receiving therapy would require a patient-level meta-analysis to account for dose adjustments during the course of treatment, information that at present is not publicly available.

##### Limitations of the data

Pooled results from the evidence included in this review do not show improved survival with administration of erythropoietic stimulants. The data from included trials have several limitations. Few studies were designed to evaluate survival outcomes, or met limited criteria of homogeneous tumor types and treatment regimens, to avoid confounding from these important variables. For many trials, particularly the older ones, survival outcomes may have been collected beyond the stipulated followup period of the randomized controlled trial, when patient management was not controlled by the trial protocol.

Two studies originally intended to evaluate survival outcomes (Henke, Laszig, Ruebe, et al., 2003; Leyland-Jones 2003) found poorer survival with epoetin administration and were two of the most influential studies in the pooled analysis. The studies were notable in that Henke, Laszig, Ruebe, et al. (2003) used a higher than recommended dose, and both targeted a maximum Hb well above current recommendations. However, these studies were not unique in these attributes; the study reported by Littlewood, Bajetta, Nortier, et al. (2001), also a strongly influential study in the pooled analysis, targeted a higher than recommended Hb level yet survival outcomes favored epoetin treatment. The Littlewood study used a recommended epoetin dose, as did the Leyland-Jones study, but survival was not a primary outcome and data were collected after study completion.

Various subgroup analyses of important study attributes (labeled vs. unlabeled use; maximum target Hb by 1 g/dL increments; and homogeneous tumor type and treatment regimen vs. not homogeneous) did not distinguish studies that showed an adverse effect on survival from those that did not. Because tumor progression over longer followup times may dilute the effects of erythropoietic stimulant treatment, examination of survival outcomes at shorter followup times (e.g., during study period) vs. later followup times (1–3 years) might be more informative. Figure 27 shows the results of such an exploratory analysis; the results suggest greater adverse effects of erythropoietic stimulant treatment on survival at earlier time points. However, since the available data are extremely limited and not representative of all included studies, no conclusions can be drawn.

Figure 27

Exploratory Meta-Analysis of Data on Survival at Early vs. Late* Timepoints from Trials with Available Data Comparing Epoetin to Control

## Key Question 2: How do alternative dosing strategies affect the comparative efficacy and safety of epoetin and darbepoetin?

### Overview of Evidence and Findings for KQ2

Dosing of erythropoietic stimulants can be individualized based on weight or identical for all regardless of weight (fixed dosing). The same dose can be given in fewer or more frequent injections over time. The amount per unit time can be constant throughout treatment; start high then decrease (front-loading); or adjusted to hematologic response (titrated). They can be given subcutaneously or intravenously. Nineteen trials addressing seven different comparisons (only two done separately for epoetin and darbepoetin) met selection criteria for Key Question 2 (see Table 38). Table 39 summarizes major findings for each comparison.

Table 38

Evidence for Direct Comparison of Alternative Doses, Frequencies, Regimens or Routes

comparison | erythropoietic stimulant | # trials available | total N randomized (all study arms) | N evaluated in non-control arms | outcomes reported
comparison | erythropoietic stimulant | # trials available | total N randomized (all study arms) | N evaluated in non-control arms | Hb response | transfusions | QOL | thromboembo li | other AEs | costs
smaller (S) versus intermediate (I) versus larger (L) weight- based doses | darbepoetin | 3 | 485 | S: 76 I: 211 L: 94 | ✓ | ✓
smaller (S) versus intermediate (I) versus larger (L) weight- based doses | epoetin | 3 | 324 | S: 103 I: 0 L: 104 | | ✓ | 1 of 3 | 1 of 3 | 2 of 3
smaller (S) versus intermediate (I) versus larger (L) fixed doses | darbepoetin | 0
smaller (S) versus intermediate (I) versus larger (L) fixed doses | epoetin | 5 | 676 | S: 280 I: 89 L: 278 | ✓ | ✓ | 4 of 5 | 2 of 5 | 2 of 5
weight-based (W) versus fixed dose (F) regimens | Darbepoetin^1^ | 1 | 242 | W: 120 F: 122 | | ✓
weight-based (W) versus fixed dose (F) regimens | epoetin | 1 | 546 | W: 264 F: 268 | ✓ | ✓ | | ✓ | ✓
same total/unit time given in more (M) versus less (L) frequent dosing | epoetin | 2 | 602 | M: 302 L: 300 | ✓ | ✓ | 1 of 2 | 1 of 2
front-loaded (F) versus constant (C) weight-based dosing | darbepoetin | 2 | 854 | F: 420 C: 399 | 1 of 2 | 1 of 2 | ✓
titrated (T) versus constant (C) fixed dosing | epoetin | 1 | 144 | T: 48 C: 47 | ✓ | ✓ | | ✓ | ✓
intravenous (I) versus subcutaneous (S) administration | darbepoetin | 1 | 120 | I: 59 S: 59 | | ✓

✓ = reported by each relevant trial

1 As this report was released, a new trial was published reporting similar outcomes with weekly (2.25 mcg/kg) versus every third week (500 mcg) darbepoetin (Canon, Vansteenkiste, Bodoky et al., 2006).

Table 39

Major Findings of Trials Comparing Doses, Regimens, Schedules, or Routes

Drug | # Trials (arms/ trial | Total N (N per arm) | Comparisons | Hb Response | Transfusion Risk
Different Weight-Based Doses
Darbepoetin | 2 (5 & 4) | 226 (11–33) | 3.0, 5.0, 7.0, or 9.0 mcg/kg/week versus 40,000 IU/week of epoetin | Similar at >2.25 mcg/kg/ week | Similar at >2.25 mcg/kg/ week
Darbepoetin | 2 (5 & 4) | 226 (11–33) | 1.0, 2.25 or 4.5 mcg/kg/week versus placebo | Similar at >2.25 mcg/kg/ week | Similar at >2.25 mcg/kg/ week
Darbepoetin | 1 (7) | 259 (17–46) | 4.5, 6.75, 9.0, 12.0, 13.5, or 15.0 mcg/kg every third week versus placebo | Greater with 12–15 than 4.5 mcg/kg | Similar at all doses
Epoetin | 3 (3) | 324 (16–45) | 100 versus 200 IU/kg 3x/week versus placebo; or 150 versus 300 IU/kg 3x/week versus untreated (two trials) | not reported separately by dose | Similar in each dose pair, 2 of 3 trials
Different Fixed Doses
Epoetin | 5 (2–5) | 676 (26–90) | 1K, 2K, 5K or 10K IU/day versus untreated; 2K versus 10K IU thrice weekly; 1K versus 5K IU thrice weekly (2 trials); or 9K versus 18K versus 36K IU once weekly | Greater at highest dose(s), each trial | Similar at all doses compared
Weight-Based versus Fixed Doses
Darbepoetin | 1 (2) | 242 | 4.5 mcg/kg weekly (N=120) | Similar Similar | Similar Similar
Darbepoetin | 1 (2) | 242 | 325 mcg weekly (N=122) | Similar Similar | Similar Similar
Epoetin | 1 (2) | 546 | 150 IU/kg thrice weekly (N=264) | Similar Similar | Similar Similar
Epoetin | 1 (2) | 546 | 10,000 IU thrice weekly (N=268) | Similar Similar | Similar Similar
More versus Less-Frequent Dosing
Epoetin | 1 (2) | 237 | 10,000 IU thrice weekly (N=119) | Similar | Similar Similar
Epoetin | 1 (2) | 237 | 30,000 IU once weekly (N=118) | Similar | Similar Similar
Epoetin | 1 (2) | 365 | 40,000 IU weekly (N=183) | Greater | Similar Similar
Epoetin | 1 (2) | 365 | 120,000 IU every third week (N=182) | — | Similar Similar
Front-Loaded Regimens
Darbepoetin | 1 | 723 | 4.5 mcg/kg 1X, weeks 1–4, 7, 10, 13, 16 (N=356) | Similar Similar | Similar
Darbepoetin | 1 | 723 | 2.25 mcg/kg weekly (N=367) | Similar Similar | Similar
Darbepoetin | 1 (4) | 127 (31–32) | Various front-loaded regimens | Similar Similar | Not Reported
Titrated versus Constant-Dose Regimens
Epoetin | 1 (3) | 144 (47-19) | Treatment titrated by Hb changes versus 10,000 IU/day versus untreated | Similar in treated arms | Similar in treated arms
Intravenous versus Subcutaneous Administration
Darbepoetin | 1 (2) | 120 (60) | 4.5 mcg/kg weekly, intravenous | — | Similar
Darbepoetin | 1 (2) | 120 (60) | 4.5 mcg/kg weekly, subcutaneous | Greater | Similar

Trials for Key Question 2 differed with respect to several variables prespecified for subgroup analysis (see Figure 3). Since each comparison has few relevant trials, study and population parameters are summarized below, with results for each comparison. Transfusion rate was the outcome most consistently reported; no studies reported costs or other economic measures.

### Detailed Analysis

#### KQ2 Comparison I. Different Weight-Based Doses

##### A. Darbepoetin

###### Characteristics of Available Studies

Three studies randomized 485 patients to one of multiple darbepoetin doses adjusted by body weight or to epoetin (Glaspy and Tchekmedyian, 2002B) or placebo-treated controls (Hedenus, Hansen, Taylor, et al., 2002; Kotasek, Steger, Faught, et al., 2003). Table 40 summarizes doses compared, evaluable sample sizes, and differences in study and population characteristics between these trials. Each trial studied adult patients with mean baseline Hb ≤10 g/dL given darbepoetin for 12 weeks, and was published as a full paper.

Table 40

Designs and Populations of Studies Comparing Weight-Based Doses of Darbepoetin

Study | lower doses^1^ | N eval.^1^ | higher doses^1^ | N eval.^1^ | malignancy type | cancer therapy | iron use
Glaspy 2002 Part B | 3.0 mcg/kg/2wk 5.0 | A: 33 B: 31 | 7.0 mcg/kg/wk 9.0 | C: 32 D: 32 | solid tumors | unspecified chemotherapy | not reported
Hedenus 2002 | 1.0 mcg/kg/wk 2.25 | A: 11 B: 22 | 4.5 mcg/kg/wk | C: 22 | hematologic | unspecified chemotherapy | as needed
Kotasek 2003 | 4.5 mcg/kg/3wk 6.75 mcg/kg/3wk 9 | A: 32 B: 17 C: 46 | 12 mcg/kg/3wk 13.5 mcg/kg/3wk 15 | D: 28 E: 35 F: 40 | solid tumors | chemotherapy some platinum | not reported

1 Letters denoting study arms in Table 40 correspond to letters denoting study arms compared in Figures 28 and 29.

###### Results

Figure 28 shows likelihood (relative risks) for a Hb response, comparing each pair of darbepoetin doses in the same study. Each arm of Hedenus, Hansen, Taylor, et al. (2002) and Kotasek, Steger, Faught, et al. (2003) is compared with placebo controls (from the corresponding trial) in Figure 5 of Key Question 1. Results from Glaspy and Tchekmedyian (2002) comparing each darbepoetin arm to epoetin controls are summarized in Table 13. Meta-analysis was not done since doses varied substantially within and across trials. The only statistically significant findings favoring higher doses were in the Kotasek, Steger, Faught, et al. (2003) study, in which Hb responses were more frequent with every third week doses ≥12 mcg/kg than at the lowest dose (4.5 mcg/kg).

Figure 28

Darbepoetin Dose and Likelihood (Relative Risk) of Hematologic Response

Figure 29 shows relative risks of transfusion for the same dose comparisons. Since each 95% CI included 1.0, none of the dose-pair comparisons showed a statistically significant difference in transfusion risk. Relative risks of transfusion at each darbepoetin dose also were not statistically significant when compared to epoetin controls for Glaspy and Tchekmedyian (2002) (Figure 6 of Key Question 1), and when compared to placebo controls for Hedenus, Hansen, Taylor, et al. (2002) and Kotasek, Steger, Faught, et al. (2003) (Figure 8).

The three trials for this comparison did not report other outcomes.

Figure 29

Darbepoetin Dose and Relative Risk of Transfusion

###### Summary

Two trials (combined N=226) suggest that weekly darbepoetin doses greater than recommended by FDA (2.25 mcg/kg) do not increase Hb responses or decrease transfusion rate. When patients are treated every third week, one trial (n=259) suggests Hb responses are more likely at 12–15 mcg/kg than at 4.5 mcg/kg, although transfusion risks did not differ.

##### B. Epoetin

###### Characteristics of Available Studies

Three studies randomized 324 patients to one of two epoetin doses adjusted by body weight or to untreated controls (Kunikane, Watanabe, Fukuoka et al., 2001; ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999). Table 41 summarizes doses compared, evaluable sample sizes, and differences in study and population characteristics between these trials. Each trial treated adult patients with solid tumors using platinum-based chemotherapy for most or all.

Table 41

Design and Populations of Studies Comparing Weight-Based Doses of Epoetin

Study | low dose^1^ | N eval.^1^ | high dose^1^ | N eval.^1^ | baseline Hb category | EPO Tx duration | iron use
Kunikane 2001 | 100 IU/kg thrice/wk | 16 | 200 IU/kg thrice/wk | 18 | ≥12 g/dL | 8 wks | not reported
ten Bokkel 1998 | 150 IU/kg thrice/wk | 45 | 300 IU/kg thrice/wk | 42 | >10-<12 g/dL | >24 wks | as needed
Thatcher 1999 | 150 IU/kg thrice/wk | 44 | 300 IU/kg thrice/wk | 42 | ≥12 g/dL | 26 wks | as needed

1 Each low dose arm corresponds to arm A, and each high dose arm to arm B, in comparisons of Figure 30

###### Results

None of the trials reported Hb response rates separately for the different epoetin dose arms. Figure 30 compares relative risk of transfusion of the high- versus low-dose arms, which significantly favored the high-dose arm in only one trial (Thatcher, De Campos, Bell, et al., 1999 The decrease in relative risk of transfusion was not statistically significant (RR=0.70; 95% CI: 0.40, 1.25; p=0.23) when data from trials that compared identical doses (ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998; Thatcher, De Campos, Bell, et al., 1999) were pooled for meta-analysis (not shown). Each arm is compared to controls in Figure 7 of Key Question 1.

Figure 30

Weight-Based Epoetin Dose and Relative Risk of Transfusion

Only the Thatcher, De Campos, Bell, et al. (1999) study evaluated quality of life outcomes, but the only measures utilized were LASA scale items and differences between dose arms were not statistically significant. Only the ten Bokkel Huinink, De Swart, Van Toorn, et al. (1998) study reported thromboembolic complications, which occurred in 9.5% of the high-dose arm and 4.4% of the low-dose arm (RR=2.14; 95% CI: 0.41, 11.10). Kunikane, Watanabe, Fukuoka et al., (2001) reported hypertension was more frequent in the low-dose arm (13.6% versus 9%) while ten Bokkel et al. (1998) reported effects in the opposite direction (2% in the low-dose arm versus 7% in the high-dose arm). However, neither difference was statistically significant.

###### Summary

Three trials (combined N=324) suggest that higher initial weight-based doses of epoetin are not more effective than a starting dose of 150 IU/kg three times weekly (the FDA-recommended weight-based initial dose).

#### KQ2 Comparison II. Different Fixed Doses

##### A. Darbepoetin

No studies compared different fixed doses of darbepoetin.

##### B. Epoetin

###### Characteristics of Available Studies

Five studies randomized 676 patients to one of multiple fixed epoetin doses (i.e., not based on body weight). Of these, only the Cazzola, Messinger, Battistel, et al. (1995) trial included (untreated) controls. Table 42 summarizes doses compared, evaluable sample sizes, and differences in study and population characteristics between these trials. Each trial studied adult patients and all but Sakai, Ohashi, Hirashima, et al. (2004) (reported in two meeting abstracts) were published as full papers. Patients enrolled in the Johansson, Wersall, Brandberg, et al. (2001) study were characterized as elderly.

Table 42

Design and Population Differences of Studies Comparing Fixed Epoetin Doses

Study | lower doses^1^ | N eval.^1^ | higher doses^1^ | N eval.^1^ | baseline Hb category | malignancy type | cancer therapy | EPO Tx duration | iron use
Cazzola 1995 | 1,000 IU/day 2,000 | A: 31 B: 29 | 5,000 IU/day 10,000 | C: 31 D: 26 | ≤10 g/dL | hematologic | unspecified chemotherapy | 8 wks | as needed
Glimelius 1998 | 2,000 IU 3X/wk | 41 | 10,000 IU 3X/wk | 43 | >10-<12 g/dL | solid tumors | unspecified chemotherapy | 18 wks | as needed
Johansson 2001 | 1,000 IU 3X/wk | 90 | 5,000 IU 3X/wk | 90 | ≤10 g/dL | solid | not reported | 12 wks | fixed
Olsson 2002 | 1,000 IU 3X/wk | 90 | 5,000 IU 3X/wk | 90 | ≤10 g/dL | solid | not reported | 24 wks | fixed
Sakai 2004 | 9,000 IU 1X/wk 18,000 | A: 28 B: 29 | 36,000 IU 1X/wk | C: 29 | ≤10 g/dL | mixed | unspecified chemotherapy | 12 wks | fixed

1 Letters denoting study arms in Table 42 correspond to letters denoting study arms compared in Figures 31 and 32.

###### Results

Figure 31 shows likelihood (relative risks) for a Hb response, comparing each pair of epoetin doses in the same multi-arm study. Meta-analysis was not done since doses varied substantially within and across trials. Cazzola, Messinger, Battistel, et al. (1995) studied daily dosing, and reported that raising doses from 1,000 to 5,000 IU daily increases the likelihood of Hb response. However, response likelihood did not change when daily dose increased to 10,000 IU. The two highest doses (arms C and D) are compared with controls in Figure 4 of Key Question 1.

Figure 31

Fixed Epoetin Dose and Relative Risk of Hematologic Response

Results of Johansson, Wersall, Brandberg, et al. (2001) and Olsson, Svensson, Sundstrom, et al. (2002) agreed with Cazzola, Messinger, Battistel, et al. (1995) that patients given 5,000 IU thrice weekly were more likely to achieve Hb responses than those given 1,000 IU thrice weekly. Glimelius, Linne, Hoffman, et al. (1998) reported responses are more likely after 10,000 IU thrice weekly than after 2,000 IU thrice weekly. Finally, Sakai, Ohashi, Hirashima, et al. (2004) reported inconsistent dose-response behavior for likelihood of Hb response after single weekly doses of 9,000, 18,000, and 36,000 IU

Figure 32 shows data from these trials on relative risks of transfusion at different fixed doses of epoetin. Arms C and D of Cazzola are compared with controls in Figure 7 of Key Question 1. Despite significantly greater likelihood (relative risk) to achieve Hb response, each paired comparison of doses for relative risk of transfusion was not statistically significant. This may be due to small sample sizes and inadequate statistical power in each comparison. Meta-analysis was possible only for the Johansson, Wersall, Brandberg, et al. (2001) and Olsson, Svensson, Sundstrom, et al. (2002) studies, which compared the same two thrice-weekly doses (not shown). Relative risk (5,000 versus 1,000 IU) was not statistically significant (RR=0.81; 95% CI: 0.64, 1.05; p=0.11).

Figure 32

Fixed Epoetin Dose and Relative Risk of Transfusion

Four of these trials assessed quality of life using the EORTC QLQ-C30 (Glimelius, Linne, Hoffman, et al., 1998; Johansson, Wersall, Brandberg, et al. 2001; Olsson, Svensson, Sundstrom, et al., 2002) or FACT-Fatigue (Sakai, Ohashi, Hirashima, et al., 2004) measures. None reported statistically significant increases in QOL scores at the higher epoetin doses.

Two trials reported more frequent thromboembolic events with larger fixed epoetin doses. Glimelius, Linne, Hoffman, et al. (1998) reported events in 14.6% of n=41 treated with 10,000 IU thrice weekly and in 7% of n=43 given 2,000 IU thrice weekly. Johansson, Wersall, Brandberg, et al. (2001) reported events in 12.2% of n=90 given 5,000 IU thrice weekly, and in 4.4% of n=90 given 1,000 IU thrice weekly. However, the relative risk for an event was not statistically significant in either trial (not shown). Both trials also measured effects of epoetin on hypertension at different doses, but reported hypertension was not observed in any patients.

###### Summary

Increasing fixed daily doses of epoetin from 1,000 to 5,000 IU, or thrice-weekly doses from 1,000–2,000 IU to 5,000–10,000 IU, increased the likelihood of hematologic response. However, the larger doses apparently did not significantly reduce relative risk of transfusion compared with the smaller doses. No trials compared these doses with the weekly fixed dose recommended by FDA (40,000 IU). Two trials reported more frequent thromboembolic complications at the higher doses, but the between-arm differences were not statistically significant.

#### KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens

##### A. Darbepoetin

###### Characteristics of available study

One trial 26 published as a full paper compared a weight-based versus a fixed-dose regimen of weekly darbepoetin (Hesketh, Arena, Patel, et al., 2004). This study randomized 242 adult patients with mean baseline Hb just above 10 g/dL (10.2±1), undergoing chemotherapy for one of various solid tumors or hematologic malignancies, to 4.5 mcg/kg (n=120) or 325 mcg (n=122) once weekly for 16 weeks. Patients were supplemented with iron at the treating physician’s discretion.

26 As this report was released, a new trial was published reporting similar outcomes with weekly weight-based (2.25 mcg/kg) versus every third week fixed-dose (500 mcg) darbepoetin (Canon, Vansteenkiste, Bodoky et al., 2006).

###### Results

Hesketh, Arena, Patel, et al. (2004) de fined Hb response to include those who achieved Hb concentrations ≥12 g/dL or a 2 g/dL rise, and reported similar response rates: 84% in the weight-based arm versus 86% in the fixed-dose arm by Kaplan-Meier analysis of time-to-response curves. Transfusion rates were also very similar in the two arms: 18.9% of 122 patients in the fixed-dose arm versus 15.8% of 120 in the weight-based arm (RR=1.19; 95% CI: 0.68, 2.07). Other outcomes were unavailable.

###### Summary

One RCT (n=242) suggests that outcomes are similar after weight-based (4.5 mcg/kg) or fixed-dose (325 mcg) regimens of once-weekly darbepoetin.

##### B. Epoetin

###### Characteristics of available study

One trial published as a full paper compared a weight-based versus a fixed-dose regimen for thrice-weekly treatment with epoetin (Granetto, Ricci, Martoni, et al., 2003). This study randomized 546 adult patients with mean baseline Hb <10g/dL, and with solid tumors undergoing platinum-based chemotherapy, to 150 IU/kg (n=264) or 10,000 IU (n=268) thrice weekly for 12 weeks. Patients were supplemented with iron as needed (transferrin saturation <20%).

###### Results

The likelihood for hematologic response was similar in both arms: 53% of 230 evaluable in the weight-based arm versus 50.5% of 218 evaluable in the fixed-dose arm (RR=0.95; 95% CI: 0.80, 1.14). Transfusion rates also were similar in the two arms: 12.6% of 238 in the weight-based arm versus 16.4% of 225 in the fixed-dose arm (RR=1.30; 95% CI: 0.84, 2.04). Subgroup analyses comparing the regimens in smaller-sized (45–63 kg) and larger-sized (70–100 kg) patients also found no significant differences in their effects on Hb responses or relative transfusion risks. Granetto, Ricci, Martoni, et al. (2003) also reported no significant differences between regimens in the rates of thromboembolic events or hypertension.

###### Summary

One RCT (n=546) suggests that outcomes are similar after weight-based (150 IU/kg) or fixed-dose (10,000 IU) regimens of thrice weekly epoetin treatment.

#### KQ2 Comparison IV. More- versus Less-Frequent Dosing

##### Characteristics of available studies

Two trials^27^ investigated fixed-dose epoetin regimens that gave the same total dose as a single bolus or as several fractions over time.

27 As this report was released, a new trial was published reporting similar outcomes with weekly weight-based (2.25 mcg/kg) versus every third week fixed (500 mcg) darbepoetin (Canon, Vansteenkiste, Bodoky et al., 2006).

- Cazzola, Beguin, Kloczko, et al. (2003) randomized patients to 30,000 IU/week given as either three (n=122) or one (n=119) injections per week. Treatment duration was 16 weeks.
- Steensma, Molina, Sloan, et al. (2005)^28^ randomized patients to 120,000 IU/3 weeks, injected either in three weekly fractions (n=183) or as a single bolus (n=182). Treatment duration was 21 weeks.
  28 As this report was released, a full-text version of this trial was published (Steensma, Molina, Sloan et al. 2006).

##### Results

Cazzola, Beguin, Kloczko, et al. (2003) reported similar proportions of patients in each arm achieved Hb responses: 85 of 118 (72%) in the arm given 30,000 IU once weekly and 89 of 119 (75%) in the arm given 10,000 IU thrice weekly (RR=0.96; 95% CI: 0.83, 1.12). Steensma, Molina, Sloan, et al. (2005) reported more frequent Hb responses in the arm given 40,000 IU once weekly (128 of 183, 70%) than in the arm given 120,000 once every three weeks (109 of 182, 60%), a statistically significant result (RR=0.86; 95% CI: 0.74, 1.00; p=0.04).

Differences between arms in transfusion rates were not statistically significant in either study, but neither trial was designed to test a non-inferiority hypothesis. Cazzola, Beguin, Kloczko, et al. (2003) reported transfusions in 10 of 115 patients (8.7%) given 30,000 IU once weekly and 16 of 114 (14%) patients given 10,000 IU thrice weekly (RR=0.62; 95% CI: 0.29, 1.31). In Steensma, Molina, Sloan, et al. (2005), 35 of 183 patients (19%) given 40,000 once weekly and 29 of 182 patients (16%) given 120,000 once every three weeks were transfused (RR=0.83; 95% CI: 0.53, 1.30).

Steensma, Molina, Sloan, et al. (2005) measured QoL and reported differences between groups at baseline that favored the every three weeks regimen, although QoL scores at end of study were equivalent in each arm. Thromboembolic complication rates were similar in both arms of Cazzola, Beguin, Kloczko, et al. (2003): 18 of 118 (15%) in the arm given 30,000 IU per week and 21 of 119 (17.7%) in the arm given 10,000 IU thrice weekly (RR=0.86; 95% CI: 0.49, 1.54).

##### Summary

Two RCTs suggest outcomes are similar with either more- or less-frequent dosing to achieve the same total amount of epoetin per week (N=237) or per three weeks (N=365). While one trial reported significantly more Hb responses with weekly than with every-three-weeks dosing, a second trial found no significant difference between thrice-weekly and once-weekly dosing. Neither trial reported a statistically significant difference in transfusion rates.

#### KQ2 Comparison V. Front-Loaded versus Reduced or Constant Dosing

##### Characteristics of available studies

Two studies investigated front-loaded regimens of darbepoetin.

- Glaspy, Jadeja, Justice, et al. (2003) randomized patients to 4.5 mcg/kg/week for four weeks, followed by eight more weeks at either 2.25 mcg/kg/week (n=32; arm B), 3 mcg/kg/2 weeks (n=32; arm C) or to 4.5 mcg/kg/week until Hb >12 g/dl, then 1.5 mcg/kg/week until week 12 (n=32; arm A; dose reduced). A control arm (N=31) received 40,000 IU epoetin once weekly.
- Kotasek, Canon, San Miguel, et al. (2004) randomized patients to four weeks of 4.5 mcg/kg/week, then every third week, weeks 5–16 (n=356), or to 2.25 mcg/kg/week (n=367) for 16 weeks.

##### Results

Glaspy, Jadeja, Justice, et al. (2003) reported no significant differences between arms in Hb response rates, but did not report transfusion rates. Kotasek, Canon, San Miguel, et al. (2004) reported no incremental benefit on Hb response rates from front-loading, and no significant difference between arms in transfusion rates. Both trials measured QoL using FACT scales but did not report clinically meaningful differences in QoL scores between different treatment schedules.

##### Summary

One trial (n=127) suggests outcomes of different front-loaded darbepoetin regimens are similar to each other; and another trial (n=723) shows outcomes of a front-loaded regimen are similar to outcomes of a constant dose regimen.

#### KQ2 Comparison VI. Titrated versus Constant Dosing

##### Characteristics of available study

Osterborg, Boogaerts, Cimino, et al. (1996) compared an initial dose of 2,000 IU/day for eight weeks, increasing to 5,000 IU/day for seven weeks if Hb <11 g/dl, and increasing again to 10,000 IU/day for seven weeks if Hb <11 g/dL at week 12 (n=48), versus a constant dose of 10,000 IU/day until Hb reached 11 g/dL (n=47). Treatment duration was up to 24 weeks.

##### Results

Differences in hematologic response rates between arms were not statistically significant: 23 of 38 evaluable (60.5%) in the titrated arm compared with 21 of 44 evaluable (47.7%) in the constant-dose arm (RR=1.27; 95% CI: 0.85, 1.90). Differences in transfusion rates also were not statistically significant: 31 of 48 (64.6%) in the titrated arm compared with 27 of 47 (57.5%) in the constant-dose arm (RR=1.12; 95% CI: 0.81, 1.55). Osterborg, Boogaerts, Cimino, et al. (1996) reported two pulmonary emboli and five cases of hypertension in the titrated group, and one pulmonary embolus and four cases of hypertension in the constant-dose group. These differences also were not statistically significant.

##### Summary

One trial (n=144) suggests outcomes are similar with either titrated or constant-dose regimens of epoetin.

#### KQ2 Comparison VII. Intravenous versus Subcutaneous Dosing

##### Characteristics of available study

Justice, Kessler, Jadeja, et al. (2005) compared 4.5 mcg/kg per week of darbepoetin administered subcutaneously versus intravenously (N=60 in each arm). After the first six weeks of treatment, dosing frequency decreased from weekly to every three weeks for the remaining 18 weeks.

##### Results

Justice et al. (2005) defined Hb response as achieving either a Hb concentration of 12 g/dL or a 2 g/dL increase. Responses were reported in 40 of 59 evaluable (67.8%) in the intravenous arm and 47 of 59 evaluable (79.7%) in the subcutaneous arm. Transfusion rates were similar in the two arms: 21 of 59 (35.6%) in the intravenous arm and 19 of 59 (32.2%) in the subcutaneous arm. Other outcomes were not reported quantitatively; however, the published study report states that adverse event rates were similar in both arms.

##### Summary

One trial (n=120) suggests outcomes are similar with either the intravenous or subcutaneous routes of darbepoetin administration.

### KQ2 Discussion and Conclusions

Of 19 studies included for this Key Question, only one darbepoetin trial, a pilot dose-finding study, included epoetin controls (Glaspy and Tchekmedyian, 2002B). It is uncertain whether the absence of statistically significant between-arm differences reflects small sample size per arm (N=31–33) or true similarity of outcomes. Thus, available evidence is insufficient to determine whether comparative efficacy or safety is altered by changes in dose, schedule, regimen, or route.

Aside from pilot dose-finding studies, the objective of trials that compare different doses, regimens, schedules or routes of administration is to determine whether the alternatives differ in efficacy or safety. For erythropoietic stimulants, comparing hematologic response rates tests whether the alternatives differ in their ability to elicit the predicted physiologic response. Comparing transfusion rates and changes in quality of life tests whether they differ in clinical benefits. Comparing adverse event rates tests whether they differ in safety. Absent differences in clinical benefit or safety, choice between alternatives may be driven by costs, convenience or a balance between these factors.

Except for low-dose arms in some early dose-finding studies, the evidence reviewed here showed no between-arm differences in transfusion rate for any comparisons of different doses, schedules, regimens, or routes of administration. None of the eight studies that reported changes in quality of life measures found a significant difference between the alternatives compared. Differences in thromboembolic event rates, and in rates of one or two other adverse events, also were not statistically significant. However, a minority of trials (six of 19) reported on adverse events. No trials reported costs, and none reported data on amounts of erythropoietic stimulant consumed per patient.^29^ Thus, it remains uncertain whether some of the dosing strategies compared in the studies reviewed here might be superior to an alternative with respect to safety or costs. It seems evident, though, that dosing strategies are optimally convenient when they minimize office visits (e.g., every third week in patients undergoing chemotherapy cycles of three weeks each).

29 A new trial, published as this report was being released, that compared weekly weight-based (2.25 mcg/kg) versus every third week fixed (500 mcg) darbepoetin, reported data on planned and delivered weekly average doses, weight-adjusted average weekly doses, and mean cumulative doses in each arm (Canon, Vansteenkiste, Bodoky et al., 2006).

The conclusions of this section are as follows:

- With either weight-based or fixed dosing of erythropoietic agents, incremental benefit from doses exceeding those recommended in FDA labeling (or commonly used by clinicians in the U.S.) appears limited. While some trials report modest increases in Hb response rates at higher doses, none report significantly larger reductions in transfusion risks or significantly larger improvements in quality of life.
- Comparisons of weight-based versus fixed-dose regimens; more- versus less-frequent injection schedules; and front-loaded or titrated versus constant-dose regimens showed similar transfusion rates in both arms, including the trials reporting statistically significant but modest differences in Hb response rates.
- Transfusion rates are similar with the subcutaneous or intravenous routes for darbepoetin, although Hb responses may be more frequent after subcutaneous administration.
- Reporting on adverse events is incomplete. Data on thromboembolic events are available for five comparisons, and on other adverse events for 4 comparisons. A minority (six of 19) of trials report on thromboembolic events and a similar minority (six of 19) on other adverse events. Although some trials reported higher rates of thromboembolic events at the highest doses tested, rate differences between arms were not statistically significant.

## Key Question 3: How do alternative thresholds for initiating treatment, or alternative criteria for discontinuing therapy or duration of therapy, affect the efficacy and safety of erythropoietic stimulants?

### Overview of Evidence and Findings for KQ3

Three unblinded trials, presented at meetings but not yet published, compared treatment with an erythropoietic stimulant at mean hemoglobin concentrations of ~11 g/dL (2 trials) and ~13 g/dL (1 trial) versus treatment only if hemoglobin fell below thresholds of 9 g/dL (1 trial) or 10 g/dL (2 trials) (Table 43). While all received erythropoietic stimulant in one arm of each trial, delayed arm patients were untreated if hemoglobin stayed above threshold. In all trials, delayed therapy was accompanied by higher transfusion rates without statistically significant between-arm differences. One trial reported statistically significant between-arm differences that favored immediate therapy in change from baseline to end of study of FACT quality of life measures; however significantly more thromboembolic events occurred with immediate therapy.

Table 43

Summary of Findings on Thresholds for Initiating Treatment

study | N randomized | | malignancy | drug and treatment duration | Hb when EPO/DARB initiated | | % patients given EPO/DARB | | % transfused | | between-arm differences in Δ (FACT measures) from baseline | thrombo-embolic events (%)
study | I^1^ | D^1^ | malignancy | drug and treatment duration | I^1^ | D^1^ | I^1^ | D^1^ | I^1^ | D^1^ | between-arm differences in Δ (FACT measures) from baseline | I^1^ | D^1^
Straus 2003 | 135 | 13 4 | hematologic | epoetin 16 weeks | 11.1 ± 0.7^3^ | <9 | 100 | 19.4 | 17.8 | 26.1 | FACT-An^*^, FACT-fatigue^*^ | 11 | 3^*^
Rearden 2004 | 102 | 10 2 | mixed solid or hematologic | darbepoetin 12 weeks^2^ | 11.1 ± 0.7^4^ | <10 | 100 | 62.7 | 17.2 | 26.5 | NS | 2 | 1
Crawford 2003 | 109 | 10 7 | non-small cell lung cancer | epoetin 16 weeks | 13.1 ± 1.0^3^ | <10 | 100 | 44 | 12.3 | 21.0 | NS | NR^5^ | NR^5^

1 I = erythropoietic stimulant therapy begun immediately after randomization; D = erythropoietic stimulant therapy delayed until Hb falls to threshold;

2 transfusion data include 22 weeks followup as patients received chemotherapy throughout;

3 mean ± standard deviation;

4 mean ± standard error;

5 “…no differences between groups in frequency or pattern of adverse events…”;

* statistically significant difference; NS=no significant difference; NR=not reported

Comparative data are unavailable to determine how the safety and benefits of darbepoetin or epoetin are affected by criteria for discontinuing therapy or duration of therapy (see Table 1, Introduction and Scope, for current recommendations in the FDA-approved package inserts).

### Detailed Analysis

#### A. Alternative Hb Thresholds for Initiating Treatment

This section evaluates outcomes of different thresholds for initiating treatment with an erythropoietic stimulant from RCTs comparing each threshold with treatment initiated immediately after randomization.

##### Characteristics of Available Studies

Three studies randomized patients to immediate treatment with epoetin or darbepoetin, versus treatment delayed until Hb fell below a threshold. Key aspects of study design and populations are summarized in Table 44.

Table 44

Characteristics of Studies on Thresholds for Initiating Treatment

study | N | | malignancy | erythropoietic stimulant | initial dose | treatment duration | baseline Hb | | Hb threshold
study | I^1^ | D^1^ | malignancy | erythropoietic stimulant | initial dose | treatment duration | I^1^ | D^1^ | Hb threshold
Straus 2003 | 135 | 134 | hematologic | epoetin | 40,000 IU weekly | 16 weeks | 11.1 ± 0.7^2^ | 11.2 ± 0.6^2^ | 9 g/dL
Rearden 2004 | 102 | 102 | mixed solid or hematologic | darbepoetin | 300 mcg every third week | 12 weeks | 11.1 ± 0.7^3^ | 11.2 ± 0.7^3^ | 10 g/dL
Crawford 2003 | 109 | 107 | non-small cell lung cancer | epoetin | 40,000 IU weekly | 16 weeks | 13.1 ± 1.0^2^ | 13.0 ± 1.2^2^ | 10 g/dL

1 I = erythropoietic stimulant therapy begun immediately after randomization; D = erythropoietic stimulant therapy delayed until Hb falls to threshold;

2 mean ± standard deviation;

3 mean ± standard error

- Straus, Testa, Riggs, et al. (2003) randomized adults with hematologic (lymphoid) malignancies to epoetin at mean baseline Hb=11.1 g/dL (n=135), or to epoetin delayed until Hb fell below 9 g/dL (n=134). Epoetin dosage was 40,000 IU weekly for 16 weeks.
- Rearden, Charu, Saidman, et al. (2004) randomized adults to darbepoetin at mean baseline Hb=11.1 g/dL (n=102) or to darbepoetin delayed until Hb fell below 10 g/dL (n=102). Patients were undergoing treatment for hematologic (lymphoid) malignancies or solid tumors (including breast, lung, gastrointestinal, genitourinary, gynecologic, or other cancers). Darbepoetin dosage was 300 mcg every third week for 12 weeks.
- Crawford, Robert, Perry, et al. (2003) randomized adults with non-small cell lung cancer to epoetin treatment at mean baseline Hb=13.1 g/dL (n=109) or to epoetin delayed until Hb fell below 10 g/dL (n=107). Epoetin dosage was 40,000 IU weekly for 16 weeks.

The Crawford, Robert, Perry, et al. (2003) trial enrolled patients with Hb concentrations from 11 to 15 g/dL. In contrast, the other trials enrolled patients with Hb concentrations from 10 (Straus, Testa, Riggs, et al., 2003) or 10.5 (Rearden, Charu, Saidman, et al., 2004) to 12 g/dL. No trial was blinded, placebo-controlled, or specified a transfusion trigger. Crawford, Robert, Perry, et al. (2003) supplemented patients with iron as needed, while the other trials did not report on iron use. Patients in each trial received concurrent chemotherapy, with some in the Rearden, Charu, Saidman, et al. (2004) study and most in the Crawford, Robert, Perry, et al. (2003) study given platinum-based regimens. Since these trials were presented at meetings and published only as abstracts, we could not determine whether randomization methods and allocation concealment were adequate. Each was judged a low-quality trial since they were unblinded and inadequately reported (Appendix Table C55).

Another trial, comparing epoetin initiated at Hb within the normal range versus delayed until Hb fell below 10 g/dL, was excluded since only interim results were reported (Richart, Petruska, Klebert, et al., 2002).

###### Results

Table 45 compares data from the three avai lable trials on Hb at start of treatment, proportion given an erythropoietic stimulant, and transfusion and thromboembolic event rates.

Table 45

Transfusion and Thromboembolic Event Rates from Trials on Thresholds for Initiating Therapy

study | N evalua-ted (for transfusion) | | drug and treatment duration | Hb when EPO/DARB initiated | | % patients given EPO/DARB | | % transfused | | relative risk of transfusion | 95% confidence interval | thrombo-embolic events (%)
study | I^1^ | D^1^ | drug and treatment duration | I^1^ | D^1^ | I^1^ | D^1^ | I^1^ | D^1^ | relative risk of transfusion | 95% confidence interval | I^1^ | D^1^
Straus 2003 | 135 | 134 | epoetin 16 weeks | 11.1 ± 0.7^3^ | <9 | 100 | 19.4 | 17.8 | 26.1 | 0.68 | 0.43, 1.08 | 11 | 3^*^
Rearden 2004 | 99 | 102 | darbepoetin 12 weeks^2^ | 11.1 ± 0.7^4^ | <10 | 100 | 62.7 | 17.2 | 26.5 | 0.65 | 0.38, 1.11 | 2 | 1
Crawford 2003 | 106 | 105 | epoetin 16 weeks | 13.1 ± 1.0^3^ | <10 | 100 | 44 | 12.3 | 21.0 | 0.59 | 0.31, 1.10 | NR^5^ | NR^5^

1 I = erythropoietic stimulant therapy begun immediately after randomization; D = erythropoietic stimulant therapy delayed until Hb falls to threshold;

2 transfusion data include 22 weeks followup as patients received chemotherapy throughout;

3 mean ± standard deviation;

4 mean ± standard error;

5 “…no differences between groups in frequency or pattern of adverse events…”;

* statistically significant difference; NR=not reported

We did not pool outcome data for meta-analysis because differences in Hb eligibility criteria and in Hb thresholds for treatment of patients in the delayed arms yielded a greater than two-fold range in the proportion untreated with an erythropoietic stimulant across these arms. Each trial compared a different pair of alternatives for initiating treatment.

All patients in the immediate arms were treated with an erythropoietic stimulant, but those in the delayed arms were not if Hb concentration remained above threshold throughout the study (Appendix Table C53). With mean baseline Hb at 11.2 g/dL and 9 g/dL as threshold, 80.6% of patients remained above and were not treated (Straus, Testa, Riggs, et al., 2003). With mean baseline Hb at 11.2 g/dL and 10 g/dL as threshold, fewer (37.3%) remained above and untreated, perhaps because followup and study duration was longer (22 versus 16 weeks) (Rearden, Charu, Saidman, et al., 2004). With mean baseline Hb at 13.0 g/dL and 10 g/dL as threshold, 56% remained above and untreated (Crawford, Robert, Perry, et al., 2003).

###### Hb responses

Only Rearden, Charu, Saidman, et al., (2004) reported Hb responses as defined for this review (Hb increase ≥2 g/dL; see Methods), but some randomized patients were not evaluated. They reported Hb responses in 19 of 94 patients (20.2%) in the arm treated at mean Hb of 11.1 g/dL and 16 of 86 (18.6%) in the arm delayed to a threshold of 10 g/dL (RR=1.09; 95%CI: 0.60, 1.97), a non-significant difference. Straus, Testa, Riggs, et al. (2003) included achieving Hb ≥12 in their definition of response, and reported responses in 95 of 135 (70.4%) of those in the arm treated at mean Hb of 11.1 g/dL and 34 of 134 (25.4%) of those in the arm delayed to a threshold of 9 g/dL (p<0.001). Crawford, Robert, Perry, et al. (2003) did not report Hb response rates, but Hb concentrations remained above 10 g/dL without transfusion for 82% of those in the arm treated at mean Hb of 13.1 g/dL versus 56% of those in the arm delayed to a threshold of 10 g/dL (p=0.0001).

###### Transfusion rate

Each trial reported fewer transfusions in the arm treated at randomization, although differences were not statistically significant in any trial. Rearden, Charu, Saidman, et al. (2004) reported transfusions in 17 of 99 (17.2%) patients treated with darbepoetin at mean Hb of 11.1 g/dL, and in 27 of 102 (26.5%) treated once Hb fell below 10 g/dL (RR=0.65; 95% CI: 0.38, 1.11). Straus, Testa, Riggs, et al. (2003) transfused 24 of 135 (17.8%) patients treated with epoetin at mean Hb of 11.1, and 35 of 134 (26.1%) patients treated once Hb fell below 9 g/dL (RR=0.68; 95% CI: 0.43, 1.08). Crawford, Robert, Perry, et al. (2003) reported transfusions in 13 of 106 (12.3%) patients treated with epoetin at mean Hb of 13.1, and in 22 of 105 (21.0%) treated after Hb fell below 10 g/dL (RR=0.59; 95% CI: 0.31, 1.10). Transfusion rates were 8% to 9% lower when treatment was initiated upon randomization. The trials were not pooled for meta-analysis for reasons discussed above.

###### Quality of Life

Each trial compared score changes on FACT scales and/or subscales following therapy with an erythropoietic stimulant at randomization or after Hb fell to a threshold. While the Crawford, Robert, Perry, et al. (2003) study did not show FACT scores, investigators reported “…scores were generally slightly higher throughout the study…” for the group treated at a mean Hb of 13.1 g/dL, versus the group delayed to Hb below 10 g/dL. However, they also noted that between-arm differences in scores and mean changes from baseline were not statistically significant.

The Straus, Testa, Riggs, et al. (2003) epoetin trial reported small positive changes in the physical and functional components of FACT-G, in the FACT-fatigue subscale, and in the FACT-An total score for patients treated at mean Hb of 11.1 g/dL (Appendix Table C60). In contrast, this study reported small negative changes for each measure in the arm delayed to Hb below 9 g/dL, with statistically significant between-arm differences for each change measure reported. However, absolute changes in either direction were very small compared to baseline score. Whether such small changes are clinically significant is unclear. In this study, baseline data were missing on 13% and 16% of patients randomized to immediate or delayed epoetin respectively. Although there were no losses to followup after the baseline assessment, it is not known how the lost patients affected the baseline comparison of study arm evaluable patient characteristics.

In contrast, Rearden, Charu, Saidman, et al. (2004) reported no statistically significant differences between arms at weeks 13 or 22 in FACT-fatigue change scores, comparing patients given darbepoetin at mean Hb of 11.1 g/dL versus those treated after Hb fell below 10 g/dL (Appendix Table C61). However, data were missing from 13% and 27% of immediate patients (weeks 13 and 22, respectively), and 29% and 49% of delayed patients. It is not known how many patients were missing from the initial FACT-fatigue assessment, and thus how many of these were lost to followup after the initial assessment. If losses to followup were substantial and not random (e.g., if patients with poorer quality of life were more likely to drop out), the results could be significantly biased.

Each trial was published in abstract form only; details of study design, missing data on FACT evaluation, losses to followup, and blinding to Hb concentration at the time of FACT instrument administration to patients were unavailable. Given somewhat inconsistent results between the trials and the lack of detailed information, conclusions are not possible with respect to changes in quality of life.

###### Thromboembolic events

Crawford, Robert, Perry, et al. (2003) did not report on thromboembolic events, but noted “…no differences between groups in frequency or pattern of adverse events.” Straus, Testa, Riggs, et al. (2003) reported 15 undefined thromboembolic events (11% of N=135) in the arm given epoetin at mean Hb of 11.1 g/dL, and only four events (3% of N=134) in the arm with treatment delayed until Hb fell below 9 g/dL (RR=3.72; 95% CI: 1.27, 10.92). Rearden, Charu, Saidman, et al. (2004) reported one case of atrial fibrillation and two cases of deep venous thrombosis, with two of these events in the arm given darbepoetin at mean Hb of 11.1 g/dL (2% of N=99) and one in the arm with treatment delayed until Hb fell below 10 g/dL (1% of N=102).

#### B. Alternative criteria for discontinuing therapy or duration of therapy

No randomized controlled trials were identified that fulfill the inclusion criteria of this review; thus, no results can be presented.

##### Duration of therapy: subgroup analyses for Question 1

Meta-analyses on studies of epoetin versus control included for Question 1 were conducted for treatment duration subgroups: 6–9 weeks; 12–16 weeks; and >20 weeks. Results for Hb response rates (Table 46) suggest a greater likelihood of response when treatment is limited to 6–9 weeks, but this result is based on a single study evaluating only 86 patients. The likelihood of response at 12–16 vs. >20 weeks is similar. No conclusions can be reached from these data.

Table 46

Question 1: Treatment Duration Subgroup Analysis for Hb Response

Outcome: Hb response Subgroup: treatment duration | Epo v Ctl: # Studies | # Total Patients | #Epo/#Ctl Patients | Point Estimate (RR for response) | 95% CI (p-value)
Epo tx 6–9 weeks | 1 | 86 | 57/29 | 8.91 | 2.30; 34.50
Epo tx 12–16 weeks | 11 | 2,560 | 1,376/1,184 | 3.31 | 2..91; 3.77
Epo tx >20 weeks | 4 | 647 | 411/236 | 3.65 | 2.62; 5.05
Epo tx ? Weeks
(Group difference^1^) | | | | | (0.1509)

Results for transfusion rates (Table 47) more strongly suggest a difference among treatment duration subgroups, with lower risk of transfusion at the shortest treatment duration. In the meta-regression analysis of transfusion outcomes, the final model included the covariate “duration of treatment.”

Table 47

Question 1: Treatment Duration Subgroup Analysis for Transfusion

Outcome: Transfusion Subgroup: treatment duration | Epo v Ctl: # Studies | #Total Patients | #Epo/#Ctl Patients | Meta-analysis Point Estimate (RR for transfusion) | 95% CI (p-value)
Epo tx 6–9 weeks | 5 | 320 | 182/138 | 0.43 | 0.28; 0.65
Epo tx 12–16 weeks | 18 | 3,189 | 1,689/1,500 | 0.64 | 0.59; 0.69
Epo tx >20 weeks | 10 | 1,329 | 802/527 | 0.67 | 0.60; 0.75
Epo tx ? Weeks | 1 | 372 | 186/186 | 0.4 | 0.23; 0.67
(Heterogeneity) | | | | | (0.0062)

However, these data cannot be used to reach firm conclusions about differences in treatment duration because the observation periods in these studies were generally the same as treatment duration, thus results from different observation time points are being compared. To answer this question, studies would require different durations of treatment and ideally evaluate outcomes at the same time points during and/or after treatment.

### KQ3 Discussion and Conclusions

Three trials compared treatment with erythropoietic stimulants upon randomization (at varying mean baseline Hb concentrations), versus therapy delayed until Hb fell below threshold, in patient populations undergoing chemotherapy for hematologic malignancies or solid tumors. There were no trials identified outlining criteria for discontinuing therapy or duration of therapy.

In the three trials evaluating thresholds to initiate therapy, mean baseline Hb was ~11 g/dL in two trials, and was ~13 g/dL in the third. Markedly fewer patients received erythropoietic stimulant when treatment was delayed to a threshold than when it began at randomization. All patients in immediate arms of each trial were treated with erythropoietic stimulant. When immediate treatment was initiated at 11.1 g/dL and threshold for delay was 9 g/dL, 19% of delayed patients were treated with erythropoietic stimulant (Straus, Testa, Riggs, et al., 2003); when immediate treatment was initiated at mean Hb of 13.1 g/dL and threshold for delay was 10 g/dL, 44% of delayed patients were treated; and when immediate therapy was at 11.1 g/dL and threshold for delay was 10 g/dL, 63% were treated (Rearden, Charu, Saidman, et al., 2004).

Fewer patients were transfused if treated with erythropoietic stimulant upon randomization than when treatment was delayed until Hb concentration declined below threshold, although between-arm differences were not statistically significant in any trial. The lack of blinding may have biased these results, and the absence of information on a transfusion trigger suggests another potential source of bias. Absolute rates of transfusion were 12%–18% of those randomized to immediate treatment and 21%–26% in delayed arms. Absolute between-arm differences in transfusion rates were 8%–9% in each trial. Thus, in the available trials, treating an additional 37% to 81% of patients with erythropoietic stimulant spared between 8% and 9% additional patients from transfusions.

Thromboembolic events were more frequent with treatment at randomization in two trials, with the difference statistically significant in one of these (delayed to Hb=9; Straus, Testa, Riggs, et al., 2003), while the third trial did not report on thromboembolic events. Note that eligibility for the trial reporting significantly more thromboembolic events in the immediate treatment arm (Straus, Testa, Riggs, et al., 2003) required baseline Hb ≤12 g/dL (consistent with current labeling) and mean baseline Hb was ~11 g/dL. In two trials (Rearden, Charu, Saidman, et al., 2004; Crawford, Robert, Perry, et al. 2003), between-arm differences in changes of FACT scores with time were not statistically significant; differences in change scores were statistically significant favoring the arm treated at randomization in a third trial (Straus, Testa, Riggs, et al., 2003).

Indirect comparison of the three available trials did not establish an optimal threshold for initiating therapy with an erythropoietic stimulant. Additionally, since the trials compared three different sets of paired alternatives, it also remained uncertain whether the balance of outcomes favors treatment early in a course of chemotherapy or only after Hb concentration falls to a threshold. We also sought to address these questions using another indirect approach, by comparing outcomes of trials on epoetin or darbepoetin versus control and grouping trials by mean baseline hemoglobin concentration (see Key Question 1). Univariate analysis suggested a larger difference between treated and control arms for trials with mean baseline Hb >10 and <12 g/dL than for trials with mean baseline Hb ≤10 g/dL (Figure 7; Table 15). However, multivariate regression analysis suggested this univariate result was confounded by other factors, and that mean baseline Hb was not an independent predictor for the effect of treatment on transfusion rates (Table 17). Additionally, univariate analyses on survival (Figures 9 and 15; Table 25) and thromboembolic events (Figure 18; Table 31) did not suggest significantly different effects of treatment between trials with mean baseline Hb >10 and <12 g/dL, compared with trials with mean baseline Hb ≤10 g/dL.

Further trials might determine whether the balance of outcomes from treatment delayed until hemoglobin falls to a threshold is more or less favorable than the balance of outcomes from immediate treatment, and if more favorable, what the optimal threshold might be. However, it is unlikely that baseline hemoglobin is the only factor affecting risks of either transfusion or adverse events from erythropoietic stimulant therapy. For example, each risk varies with tumor type and extent and type of anticancer therapy, while risk of thromboembolic events also depends on previous history of thrombosis, and presence of other factors such as surgery or immobilization (Levine, Lee, Kakkar 2005). Patient-level meta-analyses on trials included in this report, plus systematic reviews of literature unrelated to erythropoietic stimulant intervention may provide more complete understanding of risks for transfusion and thromboembolic events in cancer patients (see Future Research).

## Key Question 4. Are any patient characteristics at baseline or early hematologic changes useful to select patients or predict responses to treatment with erythropoietic stimulants?

### Overview of Findings for KQ4

This review included twenty-six cohort studies or randomized clinical trials (total N treated with epoetin or darbepoetin = 10,836) evaluating potential predictive factors measured at baseline (e.g., serum erythropoietin level or observed/predicted ratio (O/P ratio); serum ferritin) or early after starting treatment (e.g., Hb increase, serum ferritin, reticulocyte increase). In general, most of the studies/analyses included fewer than 120 patients; no study defined a refutable hypothesis; and no study was designed to test predictive factors as the primary objective nor used predictive factors prospectively to select treatment. Study quality and reporting was poor to moderate at best with regard to prediction outcomes.

Available evidence does not identify any one factor as clinically useful to select patients or guide treatment decisions; individual factors had mostly weak or no ability to discriminate between responders and non-responders to epoetin or darbepoetin treatment.

Algorithms combining multiple factors, potentially more useful to predict Hb response, are each presently supported only by one exploratory study. Larger studies do not report sufficient predictive ability for any algorithm to establish clinical utility for selecting treatment.

### Overview of Studies

Note that methods and materials for Key Question 4 are somewhat different than those for Key Questions 1–3 (see Methods). In particular:

- Randomized and nonrandomized controlled clinical trials; prospective cohort studies; as well as analyses based on data derived from such studies were all allowable. A key inclusion criterion was that the study be designed to prospectively test predictive factors for hematologic response (as defined for Key Question 1) as primary or secondary outcome measures. In addition, the study must have included and reported a direct comparison of patient characteristics at baseline or early hematologic changes in the first four weeks after therapy began for patients responding and not responding to therapy.
- Possible classification systems for predictive factor studies analogous to the different phases of clinical trials evaluating interventions (phase I–IV) have been developed but agreement on a standard system is lacking. Therefore, a 3-level classification system was developed for this review (see Methods). According to this system, studies are classified as level I–III in Appendix C Table C64. See also Table 48 for definitions.

Table 48

Characteristics of Included Studies for KQ4

| Number of studies | Number of patients treated^1^
Study Design
RCTs | 14 | 2,194
Prospective cohort studies | 10 | 4,802
Phase I/II | 1 | 21
Review of studies | 1 | 5,934^2^
Publication Source
Full Text | 22 | 6,684^2^
Full Text (Letter) | 1 | 143
Abstract | 3 | 6045^3^
Study classification
I - exploratory study i.e., no clear statement if possible predictive factors had been defined before the study and/or analysis started, no refutable hypotheses | 25 | 10,662^4^
II - prospective evaluation of potential predictive factors i.e., a restricted set of factors had been defined before the study started, refutable hypotheses | 1 | 174
III - fulfills standards defined by Simon & Altman (1994) or an RCT employing a predictive model in one arm and standard epoetin therapy in the other arm | 0 | 0
% of applicable quality criteria met
average of all studies | 32
range across studies | 16–50

1 Patients evaluated for primary outcomes; number evaluated for prediction not always reported.

2 2,289 patients reported in Demetri, Kris, Wade, et al. 1998 (cohort study) also included in McKenzie, Lefebvre, Rosberg, et al., 2004 review.

3 Includes 5,934 patients in McKenzie, Lefebvre, Rosberg, et al., 2004 review, 2,289 of which were originally reported in the Demetri 1998 publication.

4 Patients reported in Demetri, Kris, Wade, et al. 1998 and in McKenzie, Lefebvre, Rosberg, et al., 2004 counted only once.

In addition to study classification, for the purposes of this review, a list of 19 quality assessment criteria was developed based on several proposed quality assessment tools for predictive factor studies (see Methods). All studies were assessed for each criterion as met, not/partially met, or not applicable.

Of 145 potentially relevant studies reviewed in full text, 26 were included in this review for Key Question 4. All but one study (Hedenus, Hansen, Taylor, et al., 2002) treated patients with epoetin. Because some studies did not report the number of patients initially enrolled, the total number enrolled cannot be accurately calculated. Additionally, because the number of patients in the predictive factor analyses was often not available or unclear, numbers of study patients quoted in this key question refer to total who received treatment. McKenzie, Lefebvre, Rosberg, et al. (2004) reported a study in an abstract that used patient data from three prospective cohort studies (per personal communication with Dr. McKenzie): Demetri, Kris, Wade, et al. (1998); Gabrilove, Cleeland, Livingston et al. (2001); and Shasha, George, and Harrison (2003). Patient totals presented here count patients from Demetri, Kris, Wade, et al. 1998, also included in this analysis, only once.

The total number of treated patients in these studies is approximately 10,836 (many studies did not specify the number evaluable for predictive factors). This estimate also does not include patients that did not receive epoetin or darbepoetin treatment (i.e. controls; patients enrolled but not treated). The number of original study patients ranges from 10 (Garton, Gertz, Witzig, et al., 1995) to 2,289 (Demetri, Kris, Wade, et al., 1998); data from 5,934 patients in 3 different trials were analyzed in the McKenzie, Lefebvre, Rosberg, et al. (2004) review.

Hematologic response was the only outcome assessed in trials reporting on predictive factors. However, the definition of response varied widely between studies. Nine studies (Miller, Platanias, Mills, et al., 1992; Cascinu, Fedeli, Del Ferro, et al., 1994; Garton, Gertz, Witzig, et al., 1995; Glaspy, Bukowski, Steinberg, et al., 1997; Musto, Falcone, D’Arena, et al., 1997; Fjornes, Wiedemann, Sack, et al., 1998; Glimelius, Linne, Hoffman, et al., 1998; Gonzalez, Ordonez, Jua, et al., 1999; Chang, Couture, Young, et al., 2005) did not define Hb increase as >2 g/dL as required in the protocol for this review, but in view of the limited available evidence, these studies were included.

To evaluate study quality systematically, studies were categorized according to study design (primarily prospective cohort study vs. RCT), source, study classification (using the classification system described in Methods and in Table 48), and evaluated for 19 desirable study quality characteristics. Table 48 summarizes the overall results. Most studies were exploratory; only one study (Witzig, Silberstein, Loprinzi, et al., 2004) was classified as phase II, even though it did not report a refutable hypothesis, since it was a RCT with the secondary objective of evaluating a previously published prediction algorithm. Most studies met less than 50% of desirable quality criteria (however, we did not employ a summary score); in general, study quality is poor to moderate, at best.

A large number of potential predictive factors were explored in the included studies. The predictive factors and the number of studies and patients evaluated for each are summarized in Table 49. Few factors were evaluated in more than 5 publications. In addition, in some cases, (e.g., Ludwig, Fritz, Leitgeb, et al., 1994; Gonzalez-Baron, Ordonez, Franquesa, et al., 2002; Littlewood, Zagari, Pallister, et al., 2003) many factors were evaluated within a single study, making it likely that some would be statistically significant by chance alone. Because studies used various statistical methods to evaluate possible predictive factors (univariate, descriptive, multivariate, etc.) comparability of results was limited.

Table 49

Predictive Factors Measured, Numbers of Studies Reporting, and Numbers of Patients Treated

Predictive factor | Number of studies | Number of patients treated 1
Measured at baseline
Serum erythropoietin level | 22 | 6,547
Serum erythropoietin observed/predicted ratio (O/P ratio) as described in Beguin et al. 1992 | 7 | 1,125^2^
Serum ferritin | 10 | 1,457
Serum iron | 4 | 267
Serum transferrin | 4 | 324
Serum transferrin saturation | 4 | 872
Soluble transferrin receptor (sTFR) | 3 | 149
Leukocyte count | 3 | 662
Neutrophil count | 3 | 548
Platelet count | 6 | 697
Reticulocyte count | 6 | 822
Serum creatinine | 4 | 457
Creatinine clearance | 1 | 22
Various other factors^3^ | 4 | 228
Measured early after initiation of treatment (2, 3, or 4 weeks)
Hemoglobin/Hematocrit (absolute) | 1 | 117
Hemoglobin/Hematocrit increase | 10 | 9,379
Serum erythropoietin (absolute) | 2 | 197
Serum erythropoietin increase | 2 | 197
Serum ferritin (absolute) | 4 | 932
Serum ferritin increase | 2 | 197
Reticulocyte count (absolute) | 1 | 117
Reticulocyte count increase | 4 | 901
Various other factors^4^ | 5 | 1,031
Algorithms | 7 | 22–2030/algorithm

1 Actual number evaluated for each predictor could not be determined for all trials; patients evaluated in the McKenzie 2004 combined analysis of trials were not included if the original trial populations were already counted.

2 Some studies used their own controls to establish predicted epo levels (e.g. Musto 1997, Glimelius 1998).

3 C-reactive protein; interleukin-1 and -6; tumor necrosis factor alpha and beta; neopterin; alpha-1 antitrypsin; interferon gamma; stem cell factor; number of circulating erythropoietic blast-forming units (BFE-E); percent hypochromic erythrocytes; undefined “hemogram,” “chemistry,” “renal failure.”

4 Increase in: serum neopterin; serum C-reactive protein; serum sTFR; serum transferrin; transferrin saturation; serum iron; alpha-1 antitrypsin; interleukin-1 and -6; tumor necrosis factor; interferon-gamma; stem-cell factor; leukocytes; platelets; reticulocyte hemoglobin. Absolute levels of: serum iron; transferrin; transferrin saturation.

### Main Findings

For predicting Hb response, negative predictive value (NPV) is an important parameter; predictive factors should result in a very high NPV for the factor to be clinically useful to identify patients who will not receive treatment because they are so unlikely to respond. Positive predictive value (PPV) should also be high so that the majority of patients selected by the predictive factor for continued treatment with erythropoiesis-stimulating agents would be expected to respond. Where sensitivity and specificity were reported or could be calculated, PPV and NPV were calculated based on the assumption of an overall response rate of 60% (see Hematologic Outcomes in this review).

#### Predictive Factors Measured at Baseline

##### Measures of endogenous erythropoietin

Of twenty-two studies measuring baseline endogenous erythropoietin levels, thirteen comparing levels of serum erythropoietin in responders compared to non-responders reported no significant difference (Miller, Platanias, Mills, et al., 1992; Case, Bukowski, Carey, et al., 1993; Cascinu, Fedeli, Del Ferro, et al., 1994; Garton, Gertz, Witzig, et al., 1995; Glaspy, Bukowski, Steinberg, et al., 1997; Kasper, Terhaar, Fossa, et al., 1997; Demetri, Kris, Wade, et al. 1998; Glimelius, Linne, Hoffman, et al., 1998; Oberhoff, Neri, Amadori, et al., 1998; Gonzalez-Baron, Ordonez, Franquesa, et al., 2002; Hedenus, Hansen, Taylor, et al., 2002; Katodritou, Speletas, Kapetanos, et al., 2004; Witzig, Silberstein, Loprinzi, et al., 2004)., In contrast, 3 studies making the same comparison reported significant correlations (Ludwig, Fritz, Leitgeb, et al., 1994; Fjornes, Wiedemann, Sack, et al., 1998; Cazzola, Beguin, Kloczko, et al., 2003).

Seven studies tested the use of specific cutoff values of serum erythropoietin to discriminate responders from non-responders; results are shown in Table 50.

Table 50

Prediction of Hemoglobin Response to Erythropoietic Stimulants Based on Use of a Baseline Serum Erythropoietin Cutoff Value

Study (RCT unless otherwise indicated) | #Patients treated | Serum erythropoietin cutoff tested | Comparison of % patients responding below cutoff vs. above | Predictive value
Cazzola 1995 | 117 | <50 IU/L | <cutoff significantly more likely to respond
Boogaerts 2003 | 133 | <50 IU/L | <cutoff significantly more likely to respond
Glimelius 1998 | 99 | <50 IU/L | no significant difference
Osterborg 1996 | 77 | <50 IU/L vs. ≥ 400 IU/L | 76% vs. 9% response
Littlewood 2003 | 561 | <100 IU/L | p=0.004 | sensitivity = 75%, specificity = 43%, PPV= 66%, NPV = 53%
Ludwig 1994 (cohort) | 80 | <100 IU/L | no significant difference
Henry 1995 | 143 | <100 IU/L | | sensitivity = 62% specificity = 53% PPV = 66% NPV = 48%

Seven studies tested serum erythropoietin observed/predicted ratio (O/P ratio); results are shown in Table 51.

Table 51

Prediction of Hemoglobin Response to Erythropoietic Stimulants Based on Use of a Baseline Serum Erythropoietin Observed to Predicted Ratio (O/P) Cutoff Value

Study (RCT unless otherwise indicated) | #Patients treated | Serum erythropoietin O/P ratio cutoff tested | Comparison of % patients responding below cutoff vs. above
Musto 1997 (cohort) | 37 | 0.8 | p=0.001
Glimelius 1998 | 99 | 0.8 | no significant difference
Cazzola 1995 | 117 | 0.8 | Patients with O/P ratio <cutoff more likely to respond
Boogaerts 2003 | 133 | 0.9 | predictive only for patients with solid tumors: RR=1.9; 95% CI, 1.0–3.7; p<0.001
Littlewood 2003 | 561 | 0.9 | no significant difference
Osterborg 1996 | 77 | N/A | O/P ratio = only significant predictor in multivariate analysis: HR 0.84, p<0.01
Oberhoff 1998 | 101 | N/A | No significant correlation between O/P ratio and response

Results for both endogenous erythropoietin and serum O/P levels as predictors of Hb response are in some cases statistically significant. Overall, however, test sensitivities and specificities, where reported, do not result in high enough predictive power to be clinically useful. Many studies enrolled a small number of patients and were likely underpowered for prediction analysis; however, study size or design did not appear to be related to results.

##### Measures of iron metabolism

Study results testing measures of iron metabolism as predictors of Hb response are shown in Table 52. Studies were mostly small cohorts and were likely underpowered for predictive factor analysis. Only one larger evaluation of RCT results (Littlewood, Zagari, Pallister, et al., 2003) identified a significant predictor of response in ferritin ≤400 ng/mL but the resulting predictive power was low.

Table 52

Prediction of Hemoglobin Response to Erythropoietic Stimulants Based on Use of Various Measures of Iron Metabolism

Study (RCT unless otherwise indicated) | #Patients treated | Predictor of Hb response
Study (RCT unless otherwise indicated) | #Patients treated | Baseline ferritin | | | Baseline iron | Baseline serum transferrin | Transferrin saturation | Soluble transferrin receptor
Miller 1992 (cohort) | 21 | NS
Ludwig 1994 (cohort) | 80 | NS | | | NS | NS | | NS
Henry 1995 | 143 | Using ferritin cutoff values:
Henry 1995 | 143 | | [underlined: 400 ng/mL] | [underlined: 500 ng/mL]
Henry 1995 | 143 | Sensitivity | 60% | 68%
Henry 1995 | 143 | Specificity | 58% | 56%
Henry 1995 | 143 | PPV | 68% | 70%
Henry 1995 | 143 | NPV | 50% | 54%
Cazzola 1995 | | | | | | | NS using a cutoff of 40%
Osterborg 1996 | | | | | | | NS
Kasper 1997 (cohort) | 48 | NS | | | NS | NS
Musto 1997 | | | | | | | | O/P ratio cutoff of <0.8: Sensitivity = 92% Specificity = 13% PPV = 61% NPV = 52%
Fjornes 1998 (cohort) | 22 | NS | | | NS
Gonzalez 1999 (cohort) | 79 | NS | | | | NS
Gonzalez-Baron 2002 (cohort) | 117 | NS | | | NS | NS | NS
Littlewood 2003 | 561 | Using cutoff value of <400 ng/mL: Significant relationship with greater Hb response in a multivariate regression model (p=0.0002); | | | | | NS using cutoff values of ≤40% or >20%
Littlewood 2003 | 561 | Sensitivity = 61% | Specificity = 50% | | | | NS using cutoff values of ≤40% or >20%
Littlewood 2003 | 561 | PPV = 65% | NPV = 46% | | | | NS using cutoff values of ≤40% or >20%
Katodritou 2004 (cohort) | 32 | NS | | | | | | NS
Chang 2005 | 354 | NS

Abbreviations: NS, no significant correlation.

##### Cell Counts

Eleven studies evaluated various cell counts as factors possibly predicting Hb response; results are shown in Table 53. Two relatively small RCTs using 100,000/uL platelets as a cutoff found significantly more responders above the cutoff than below the cutoff. However, the differences between groups are relatively small and not likely to be of clinical use. No other studies identified significant cell count predictors of Hb response.

Table 53

Evaluation of Cell Counts as Predictors of Hb Response

Cell type | #Studies, Study type | #Patients treated | Cell count significantly corresponds with responder status? | Significant discrimination of responder status using cutoff value?
Leukocytes^1^ | 2-cohort 1-RCT | 21, 80 561 | cohort studies: no | RCT: ≤2000/uL vs. >2000/uL, p=0.2
Neutrophils^2^ | 3-RCT | 117, 77, 354 | no
Platelets^3^ | 3-cohort 3-RCT | 21, 80, 48 117, 77, 354 | cohort studies: no RCT (N=354): no | RCTs ≤100,000/uL vs. >100,000/uL: 1) 13% vs. 38% responders, p=0.04 2) 39% vs. 72% responders, p<0.01
Reticulocytes^4^ | 4-cohort 2-RCT | 80, 22, 117, 32 10, 561 | cohort studies: no RCT (N=10): no | RCT (N=561): >2.5% vs. ≤2.5%, p=0.6

1 Miller 1992; Ludwig 1994; Littlewood 2003

2 Cazzola 1995; Osterborg 1996; Chang 2004

3 Miller 1992; Cazzola 1995; Ludwig 1994; Osterborg 1996; Kasper 1997; Chang 2004

4 Ludwig 1994; Garton 1995; Fjornes 1998; Gonzalez-Baron 2002; Littlewood 2003; Katodritou 2004

##### Measures of renal function

Only one study (Fjornes, Wiedemann, Sack, et al., 1998; cohort study, n=22) reported on creatinine clearance, finding a significant difference in values between responders and non-responders. This study also reported a significant difference in serum creatinine between response groups. However, three RCTs (Cazzola, Messinger, Battistel, et al, 1995, n=117; Osterborg, Boogaerts, Cimino, et al., 1996; n=77; Cazzola, Beguin, Kloczko, et al., 2003; n=241) were unable to confirm serum creatinine as a significant predictor.

##### Other baseline measures

Of several other factors investigated in four studies (see Table 49, footnote 2), only three showed significant correlation with responder status in one cohort study of 37 patients (Musto, Falcone, D’Arena, et al., 1997): increased number of circulating erythropoietic burst-forming units (BFU-E; p<0.01); decreased levels of interleukin-1 (p<0.001) and tumor necrosis factor (p<0.001). Selected cutoff values for each parameter resulted in 2 groups with the following percentages of responders: 17% vs. 67%; 14% vs. 63%; and 11% vs. 61%, respectively. No additional data confirms the significance of these potential predictors.

#### Predictive Factors Measured Early After Initiation of Treatment

##### Hemoglobin/Hematocrit

Ten studies measured the early increase in Hb (and/or equivalent Hct) and determined the correlation with eventual full hematologic response; data were reported in various formats without sufficient information to transform them into a common format. Results are shown in Table 54. Several studies reported some degree of discrimination between eventual hematologic responders and non-responders using specified increases in Hb over 2–4 weeks after start of treatment. However, where sufficient information was available on performance characteristics, at best the results are PPVs of 80–89% and NPVs of 65–71%, which are not likely clinically useful to determine which patients should continue to receive erythropoiesis-stimulating agents and which should not.

Table 54

Prediction of Hemoglobin Response to Erythropoietic Stimulants Based on Use of Early Changes in Serum Components

| | Predictor of Hb response
Study (RCT unless otherwise indicated) | #Patients treated | Early increase in hemoglobin, cutoff = 0.5 g/dL | Early increase in hemoglobin, cutoff = 1 g/dL | Hemoglobin, other | Serum erythropoietin | Serum Ferritin | Reticulocyte count
Ludwig 1994 (cohort) | 80 | Hb increase ≥ vs. <cutoff at 2 wks: R^2^=0.39; p<0.001 | | | Increase at 2 wks: r=0.55, p<0.01 Absolute level at 2 wks: r=0.39, p<0.01 | <400 ng/mL after 2–4 wks: r=0.32, p<0.01 increase after 2 wks: r=−0.32, p<0.01 absolute level after 2 wks: r=0.37, p<0.02 | increase at 2 wks: r=0.28, p<0.05
Henry 1995 | 143 | Hb increase ≥cutoff at 2 wks: 64% responders | | | | | increase >40,000/mcL at 2 wks: 59% responders
Glaspy 1997 (cohort) | 2,030 | | Hb increase ≥ vs. <cutoff at 4 wks: 75% vs. 30% responders; Sensitivity = 75%, Specificity = 72%, PPV = 80%, NPV = 65%
Demetri 1998 (cohort) | 2,289 | | Hb increase ≥cutoff at 4 wks: 81% responders
Glimelius 1998 | 99 | Hb increase ≥ vs. <cutoff at 2–3 wks: 79% vs. 45% responders; PPV=76%, NPV=58%
Gonzalez- Baron 2002 (cohort) | 117 | Hb increase ≥ vs. <cutoff at 4 wks: PPV=89%, NPV=71% | | no discriminatory ability for absolute Hb or Hct levels measured early after the start of treatment | no discriminatory power for either absolute concentration of or increase in erythropoietin at 2 or 4 wks | no significant discrimination between responders and non-responders for absolute level or increase at 2 or 4 wks | no significant discrimination between responders and non-responders for absolute or count increase at 2 or 4 wks
Littlewood 2003 | 561 | Hb increase ≥ vs. <cutoff at 2 wks: 77% vs. 62% responders, p=0.001 | Hb increase ≥ vs. <cutoff at 4 wks: 88% vs. 52% responders, p<0.001; Sensitivity = 59%, Specificity = 82% | | | ≤400 vs. >400 ng/mL at 2 wks: 75% vs. 57% responders, p=0.04 | increase > vs. < 0.8% at 2 or 4 wks: 72–73% vs. 61–63%, p=0.016–0.21
Cazzola 2003 | 117 | | | Hb increase ≥0.1 g/dL at 3 wks, HR=1.05, p<0.05
Witzig 2004 | 174 | | Hb increase ≥ vs. <cutoff at 4 wks: 77% vs. 62% responders; Sensitivity 60%, Specificity 59% | | | <400 vs. ≥400 ng/mL at 2 wks: 77% vs. 39%, Sensitivity 76% Specificity 63%
McKenzie 2004 (review) | 5,934^1^ | | Hb increase ≥ vs. <cutoff at 4 wks: 79–84% vs. 44–49% responders, p<0.0001

1 Includes 2,289 from Demetri 1998.

##### Serum erythropoietin

Results of 2 small cohort studies (Table 54) evaluating absolute concentration or increase in serum erythropoietin at 2–4 weeks are either negative or, where positive, correlate only weakly with Hb response.

##### Serum ferritin

Various measures of early changes in serum ferritin have been tested as predictors of Hb response (Table 54). Two small cohort studies report weak or no correlation between absolute concentration of serum ferritin at 2–4 weeks after start of treatment with Hb response. Two RCTs found that absolute concentration of ferritin <400 ng/mL after 2 weeks predicted a significantly better response, but corresponding predictive values are unlikely to be clinically useful.

##### Reticulocyte counts

Based on the available evidence (Table 54), the ability of absolute or increased reticulocyte counts to discriminate between responders and non-responders is poor in four studies, and unlikely to be clinically useful for determining which patients should be administered erythropoiesis-stimulating agents.

##### Other factors

Several other factors, measured early after start of treatment, have been investigated in 5 studies (Ludwig, Fritz, Leitgeb, et al., 1994; Gonzalez-Baron, Ordonez, Franquesa, et al., 2002; Littlewood, Zagari, Pallister, et al., 2003; Cazzola, Beguin, Kloczko, et al., 2003; Katodritou, Speletas, Kapetanos, et al., 2004) for ability to effectively discriminate between Hb responders and non-responders (see Table 49, footnote 3). A small cohort study (Katodritou, Speletas, Kapetanos, et al., 2004; N=32) reported 100% sensitivity and 80% specificity for increase in reticulocyte Hb at 2 weeks after start of treatment; at 60% prevalence of response, PPV would be 88% and NPV 100%. These results might be considered clinically useful to select patients for treatment if confirmed among larger study populations and tested prospectively.

Cazzola, Beguin, Kloczko, et al. (2003; RCT, n=241) investigated various cutoff values for soluble transferrin receptor measured after 2–3 weeks with significant discrimination between eventual responders and non-responders, but modest hazard ratios of 1.6–1.7 and lower confidence limits close to 1. Other potential predictive factors showed either non-significant discriminatory capacity or differences between predictive groups were not sufficiently different to be clinically useful.

Of several other baseline factors investigated, only one (increase in reticulocyte hemoglobin at 2 weeks) showed potentially clinically useful predictive power; no additional data supports these results.

##### Predictive algorithms

Seven studies reported results for different algorithms attempting to predict which patients will have a hematologic response to erythropoiesis-stimulating agents; results are shown in Table 55 (Ludwig, Fritz, Leitgeb, et al., 1994; Cazzola, Messinger, Battistel, et al., 1995; Henry, Brooks, Case, et al., 1995; Glaspy, Bukowski, Steinberg, et al., 1997; Fjornes, Wiedemann, Sack, et al., 1998; Littlewood, Zagari, Pallister, et al., 2003; Witzig, Silberstein, Loprinzi, et al., 2004). NPVs for response in these studies ranged from 42–90%. PPVs for response ranged from 70–100%. The highest predictive values all came from small cohort studies whereas larger cohort studies and RCTs tended to result in lower predictive values, suggesting that some studies are likely underpowered for testing algorithms.

Table 55

Results of Algorithms Combining Various Parameters to Predict Hb Response

Study | Algorithm predicting response | Algorithm predicting non- response | %Responders meeting response/non-response criteria | Sensitivity/Specificity | PPV/NPV (assuming 60% prevalence of Hb response)
Ludwig 1994 cohort N=80 | Baseline erythropoietin level < 100 IU/l [underlined: and/or] Hb increase after [underlined: 2 weeks] ≥ 0.5 g/dl | Baseline erythropoietin level ≥100 IU/l [underlined: and] Hb increase after [underlined: 2 weeks] < 0.5 g/dl | 80%/6% | 76%/95% | 96%/72%
Ludwig 1994 cohort N=80 | Baseline erythropoietin level < 100 IU/l [underlined: and] Hb increase > 0.5 g/dl after [underlined: 4 weeks] | Baseline erythropoietin level ≥ 100 IU/l [underlined: and/or] Hb increase 0.5 g/dl after [underlined: 4 weeks] | 100%/38% | 39%/100% | 100%/52%
Cazzola 1995 RCT N=117 | Step 1: baseline erythropoietin level ≥ 50 IU/L or erythropoietin O/P ratio ≥ 0.9 Step 2: after 2 weeks increase of Hb ≥ 0.3 g/dl | Step 1: baseline erythropoietin level > 50 IU/L or erythropoietin O/P ratio > 0.9 Step 2: after 2 weeks increase of Hb < 0.3 g/dl | Step 1: 75%/12% Step 2: 88%/0% | Step 1: 97%/41% Step 2: 100%/60% | 71%/90%
Henry 1995 RCT N=143 | Hb increase ≥ 0.5 g/dl and reticulocytes increase ≥ 40000/μl after [underlined: 2 weeks] | Hb increase < 0.5 g/dl and reticulocytes increase < 40000/μl after [underlined: 2 weeks] | For response: 67%/53% For non- response: 52%/39% | For response: 19%/88% For non- response: 53%/57% | For response: 70%/42% For non-response: 45%/64%
Henry 1995 RCT N=143 | Hb increase ≥ 1 g/dl and reticulocytes increase ≥ 40000/μl after [underlined: 4 weeks] | Hb increase < 1 g/dl and reticulocytes increase < 40000/μl after [underlined: 4 weeks] | For response: 84%/46% For non- response: 64%/33% | For response: 38%/91% For non- response: 52%/77% | For response: 86%/49% For non-response: 60%/71%
Glaspy 1997 cohort N=2030 | Hb increase after 4 weeks ≥ 1 g/dl and no transfusion requirement during first 4 weeks | Hb increase < 1 g/dl and transfusion requirement during first 4 weeks | For response: 81%/34% For non- response: 78%/43% | For response: 62%/84% For non- response: 17%/96% | For response: 85%/60% For non-response: 74%/63%
Fjornes 1998 cohort N=22 | Baseline erythropoietin level < 75 IU/l and serum creatinine > upper limit of normal and creatinine clearance < 60 ml/min | Baseline erythropoietin level ≥ 75 IU/l and serum creatinine ≥ upper limit of normal and creatinine clearance ≥ 60 ml/min | 100%/14% | 80%/100% | 100%/77%
Littlewood 2003 RCT N=561 | 12 algorithms tested/reported incorporating two or three factors per algorithm | | | | (All algorithm results essentially no better than single factors)
Littlewood 2003 RCT N=561 | Example (modification of Ludwig 1994): Baseline erythropoietin ≤ 100 mU/mL and Hb increase at week 4 >1.0 g/dL | Baseline erythropoietin >100 mU/mL and Hb increase at week 4 ≤ 1.0 g/dL | 88%/44% | 74%/66% | 88%/44%
Witzig 2004 RCT N=174 (modification of Ludwig 1994 algorithm) | Erythropoietin level < 100 IU/l [underlined: and/or] Hb increase after 4 weeks ≥ 0.5 g/dl | Erythropoietin level ≥ 100 IU/l [underlined: and] Hb increase after 4 weeks < 0.5 g/dl; | 72%/50% | 19%/92% | 78%/43%
Witzig 2004 RCT N=174 (modification of Ludwig 1994 algorithm) | Erythropoietin level < 100 IU/l [underlined: and] Hb increase ≥ 0.5 g/dl after 4 weeks | Erythropoietin level ≥ 100 IU/l [underlined: and/or] Hb increase < 0.5 g/dl after 4 weeks | 84%/55% | 60%/75% | 78%/56%

All studies were exploratory and only one algorithm, originally tested in a small cohort study (Ludwig, Fritz, Leitgeb, et al., 1994) was re-tested in a larger RCT (Ludwig, Fritz, Leitgeb, et al., 1994) with resulting lower predictive power. Littlewood, Zagari, Pallister, et al. (2003) also tested a version of this algorithm, changing the cutoff value for Hb increase after 4 weeks from 0.5 g/dL to 1.0 g/dL, with similarly reduced predictive power. Thus, most algorithms are supported by only one, exploratory, and often small study and results do not indicate sufficient predictive power to be of clinical use in selecting treatment.

Based on the available evidence for individual predictive factors summarized above, it is not possible to identify any single factor as a clinically relevant predictive factor for Hb response. As noted, none of the algorithms tested appear to have sufficient predictive power to warrant further testing. Rather, a comprehensive multivariate analysis of pooled data for individual predictors may be needed to evaluate possible predictive factors for a complex algorithm that meets published quality standards (Simon and Altman, 1994; Concato, Feinstein, and Holford, 1993). Factors to be evaluated might include: baseline Hb, baseline erythropoietin, reticulocytes, platelets, and Hb increase after 2–4 weeks. In addition, other patient characteristics such as age and tumor type may need to be included.

Several different algorithms for predicting Hb response or non-response have been tested in exploratory studies, but none have been rigorously studied. Based on the available evidence, none have sufficient predictive power to be clinically useful in making treatment decisions.

### KQ 4 Discussion and Conclusions

Many individual potential predictive factors, measured at baseline (e.g., serum erythropoietin level; serum erythropoietin observed/predicted ratio (O/P ratio); serum ferritin) or early after the start of treatment (e.g., Hb increase, serum ferritin, reticulocyte increase), were evaluated in 26 studies with mostly weak or no statistical clinical significance and overall poor predictive power for Hb response. Few factors were evaluated by more than 5 studies, and for all studies there are quality limitations to the evidence. Most studies were exploratory and did not identify predictive factors or hypotheses in advance; many were small and likely underpowered. In addition, some studies evaluated a large number of factors within a single study, making it likely that some would be statistically significant by chance alone. Thus, based on the available evidence, it is not possible to identify any single factor as a clinically relevant predictive factor for Hb response that could be used to make treatment decisions.

Predictive algorithms combining multiple factors are potentially more useful for predicting Hb response. Presently, however, most algorithms are supported by only one, exploratory, and often underpowered study. Results from larger studies do not indicate sufficient positive or negative predictive power for any particular algorithm to be of clinical use in selecting treatment and thus do not warrant additional studies. Rather, a comprehensive multivariate analysis of pooled data for individual predictors may be needed to evaluate possible predictive factors for a complex algorithm that meets published quality standards. Factors to be evaluated might include: baseline Hb, baseline erythropoietin, reticulocytes, platelets, and Hb increase after 2–4 weeks. In addition, other patient characteristics such as age and tumor type may need to be included.