# Methods

## Technical Expert Panel

A technical expert panel (TEP) provided consultation for the systematic review (see Appendix E for a list of panel members). Specifically, they helped develop the final key questions, systematic review protocol, and commented on an early draft of the review.

## Literature Search

The following databases were searched electronically.

- MEDLINE (January 1999 to March 2005),
- EMBASE (January 1999 to March 2005), and
- Cochrane Central Register of Controlled Trials Register (CENTRAL, January 1999 to March 2005).

The full search strategy is displayed in Appendix A. Literature search databases included fields for errata and other trial-related publications such as letters and special reports; the contents of all documents and publications related to included trials were screened.

Data previously abstracted from studies reviewed for the first Cochrane Review (Erythropoietin for patients with malignant disease; Bohlius, Langensiepen, Schwarzer, et al., 2005) or AHRQ report (Seidenfeld, Aronson, Piper, et al., 2001) were updated if necessary and included in the present report.

We sought additional studies by searching reference lists of included studies, relevant review articles, and relevant clinical practice guidelines.^2^

2 Guidelines searched included those of the American Society of Hematology/American Society of Clinical Oncology (ASH/ASCO; Rizzo, Lichtin, Woolf, et al., 2002), Cancer Care Ontario Practice Guidelines (CCOPG; Quirt, Bramwell, Charette, et al., 2005), European Organization for Research and Treatment of Cancer (EORTC; Bokemeyer, Aapro, Courdi et al., 2004), Federation Nationale des Centres de Lutte Contre le Cancer (FNCLCC; Federation Nationale des Centres de Lutte Contre le Cancer, 2003), and the National Comprehensive Cancer Network (NCCN; National Comprehensive Cancer Network, 2004)

The following conference proceedings were searched electronically or by hand if they were unavailable in electronic format:

- American Society of Clinical Oncology (January 1999–May 2005),
- American Society of Hematology (January 1999–March 2005),
- European Society of Medical Oncology (January 1999–March 2005).

Abstracts selected from conference proceedings were traced for full-text publications.

Finally, from the Food and Drug Administration (FDA) web site, we identified one briefing document from a May 2004 meeting of the Oncologic Drugs Advisory Committee (ODAC) plus an additional Microsoft® PowerPoint® presentation prepared by medical reviewers of the FDA, and three documents, plus additional PowerPoint® presentations prepared by the companies Roche, Johnson & Johnson, and Amgen. All of these documents are publicly available through the FDA briefing document at http://www.fda.gov/ohrms/dockets/ac/04/slides/4037s2.htm (slides) and http://www.fda.gov/ohrms/dockets/ac/04/briefing/4037b2.htm (briefing documents).

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described in the “Introduction and Scope” section. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. Results published only in abstract form lack adequate information to assess the validity of the data. Nevertheless, in an effort to include the most recent data possible, we included abstracts from the conference proceedings listed if full-text articles were not published subsequently. The QUOROM diagrams (Figures 1 and 2) outline the selection of articles for inclusion in the review. Table 2 provides the included citations and table/figure designations for the Key Questions.

Table 2

Included Studies and Figure/Table Designations

A. Included Studies, Key Question 1
Study | Publication type(s) | Figure/table designation
Darbepoetin versus Epoetin
Glaspy and Tchekmedyian, 2002B | Full Text | Glaspy 2002 PB a Glaspy 2002 PB b Glaspy 2002 PB c Glaspy 2002 PB d
Glaspy, Jadeja, Justice, et al., 2003 | Full Text | Glaspy 2003a Glaspy 2003b Glaspy 2003c
Waltzman, Croot, Williams, 2005 1 | Abstract | Waltzman 2005
Schwartzberg, Yee, Senecal, et al., 2004 | Full Text | Schwartzberg 2004a Schwartzberg 2004b Schwartzberg 2004c
Alexopolous and Kotsori, 2004 | Abstract | Alexopolous 2004
Glaspy, Berg, Tomita, et al., 2005 | Abstract | Glaspy 2005
Glaspy, Jadeja, Justice, et al., 2002A | Full Text | Glaspy 2002 PA c Glaspy 2002 PA d Glaspy 2002 PA e
Epoetin versus Control
Aravantinos, Linardou, Makridaki, et al., 2003 | Full Text | Aravantinos 2003
Bamias, Aravantinos, Kalofonos, et al., 2003 | Full Text | Bamias 2003
Boogaerts, Coiffier, Kainz, 2003/Coiffier and Boogaerts, 2001 | Full Text, Abstract, Unpublished Data, FDA Documents | Boogaerts 2003 Coiffier 2001
Carabantes, Benavides, Trujillo, et al., 1999 | Abstract | Carabantes 1999
Cascinu, Fedeli, Del Ferro, et al., 1994 | Full Text, Unpublished Data | Cascinu 1994
Case, Bukowski, Carey, et al., 1993 | Full Text, Unpublished Data, FDA Documents | Case 1993
Cazzola, Messinger, Battistel, et al, 1995 | Full Text, Unpublished Data, FDA Documents | Cazzola 1995c Cazzola 1995d
Chang, Couture, Young, et al., 2005 | Full Text | Chang 2005
Dammacco, Castoldi, Rodjer, et al., 2001 | Full Text, Unpublished Data, FDA Documents | Dammacco 2001
Del Mastro, Venturini, Lionetto, et al., 1997 | Full Text, Unpublished Data | Del Mastro 1997
Dunphy, Harrison, Dunleavy, et al., 1999 | Full Text | Dunphy 1999
EPO-CAN-15 | FDA Documents | EPO-CAN-15
EPO-CAN-20 | FDA Documents | EPO-CAN-20
EPO-GBR-07 | FDA Documents | EPO-GBR-07
GOG-191 | FDA Documents | GOG-191
Henke, Laszig, Ruebe, et al., 2003 | Full Text, FDA Documents | Henke 2003
Henry, Brooks, Case, et al., 1995 | Full Text, Unpublished Data, FDA Documents | Henry 1995
Henze, Michon, Morland, et al., 2002 | Abstract | Henze 2002
Huddart, Welch, Chan, et al., 2002 | Abstract | Huddart 2002
Iconomou, Koutras, Rigopoulos, et al., 2003 | Full Text | Iconomou 2003
INT-1 | FDA Documents | INT-1
INT-3 | FDA Documents | INT-3
Janinis, Dafni, Aravantinos, et al., 2003 | Abstract | Janinis 2003
Kunikane, Watanabe, Fukuoka, et al., 2001 | Full Text | Kunikane 2001a Kunikane 2001b
Kurz, Marth, Windbichler, et al., 1997 | Full Text, Unpublished Data | Kurz 1997
Leyland-Jones, 2003 1 | Full Text, FDA Documents | Leyland-Jones, 2003
Littlewood, Bajetta, Nortier, et al., 2001 | Full Text, Unpublished Data, FDA Documents | Littlewood 2001
Machtay, Pajak, Suntharalingam, et al., 2004 | Abstract, FDA Documents | Machtay 2004
N93 004^2^ | FDA Documents | N93 004
Oberhoff, Neri, Amadori, et al., 1998 | Full Text, Unpublished Data, FDA Documents | Oberhoff 1998
O’Shaughnessy, Vukelja, Holmes, et al., 2005 | Full Text | O’Shaughnessy, 2005
Osterborg, Boogaerts, Cimino, et al., 1996 | Full Text, Unpublished Data, FDA Documents | Osterborg 1996a Osterborg 1996b
Osterborg, Brandberg, Molostova, et al., 2002/Osterborg, Brandberg, Hedenus, 2005 | Full Text, Unpublished Data, FDA Documents | Osterborg 2002 Osterborg 2005
P-174, 2004 | FDA Documents | P-174
Quirt, Micucci, Moran, et al., 1996 | Abstract | Quirt 1996
Razzouk, Hockenberry, Hinds, et al., 2004 | Abstract | Razzouk 2004
Rose, Rai, Revicki, et al., 1994 | Abstract, Unpublished Data, FDA Documents | Rose 1994
Rosenzweig, Bender, Lucke, et al., 2004 | Full Text, FDA Documents | Rosenzweig, 2004
Savonije, Van Groeningen, Van Bochove, et al., 2004 3 | Abstract | Savonije 2004
Silvestris, Romito, Fanelli, et al., 1995 | Full Text | Silvestris 1995
ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998 | Full Text, Unpublished Data, FDA Documents | ten Bokkel 1998a ten Bokkel 1998b
Thatcher, De Campos, Bell, et al., 1999 | Full Text, Unpublished Data, FDA Documents | Thatcher 1999a Thatcher 1999b
Thomas, McAdam, Thomas, et al., 2002 | Abstract | Thomas 2002
Throuvalas, Antonadou, Boufi, et al., 2000 | Abstract, Unpublished Data | Throuvalas 2000
Vadhan-Raj, Skibber, Crane, et al., 2004 | Abstract, FDA Documents | Vadhan-Raj 2004
Welch, James, Wilkinson, 1995 | Full Text | Welch 1995
Witzig, Silberstein, Loprinzi, et al., 2005 | Full Text, FDA Documents | Witzig 2005
Wurnig, Windhager, Schwameis, et al., 1996 | Full Text | Wurnig 1996
Darbepoetin versus Control
Hedenus, Hansen, Taylor, et al., 2002 | Full Text | Hedenus 2002a Hedenus 2002b Hedenus 2002c
Hedenus, Adriansson, San Miguel, et al., 2003 1 | Full Text | Hedenus 2003
Kotasek, Steger, Faught, et al., 2003 | Full Text | Kotasek 2003a Kotasek 2003b Kotasek 2003c Kotasek 2003d Kotasek 2003e Kotasek 2003f
Vansteenkiste, Pirker, Massuti, et al., 2002 | Full Text | Vansteenkiste 2002
B. Included Studies, Key Question 2
Study | Publication type(s) | Figure/table designation
Cazzola, Beguin, Kloczko, et al., 2003 | Full Text | Cazzola 2003
Cazzola, Messinger, Battistel, et al, 1995 | Full Text, Unpublished Data, FDA Documents | Cazzola 1995
Glaspy and Tchekmedyian, 2002B | Full Text | Glaspy 2002 part B
Glaspy, Jadeja, Justice, et al., 2003 | Full Text | Glaspy 2003
Glimelius, Linne, Hoffman, et al., 1998 | Full Text | Glimelius 1998
Granetto, Ricci, Martoni, et al., 2003 | Full Text | Granetto 2003
Hedenus, Hansen, Taylor et al. 2002 | Full Text | Hedenus 2002
Hesketh, Arena, Patel, et al., 2004 | Full Text | Hesketh 2004
Johansson, Wersall, Brandberg, et al., 2001 | Full Text | Johansson 2001
Justice, Kessler, Jadeja, et al., 2005 | Full Text | Justice 2005
Kotasek, Canon, San Miguel, et al., 2004 | Abstract | Kotasek 2004
Kotasek, Steger, Faught et al. 2003 | Full Text | Kotasek 2003
Kunikane, Watanabe, Fukuoka, et al., 2001 | Full Text | Kunikane 2001
Olsson, Svensson, Sundstrom, et al., 2002 | Full Text | Olsson 2002
Osterborg, Boogaerts, Cimino, et al., 1996 | Full Text, Unpublished Data, FDA Documents | Osterborg 1996
Sakai, Ohashi, Hirashima, et al., 2004 | Abstract | Sakai 2004
Steensma, Molina, Sloan, et al., 2005 1 | Abstract | Steensma 2005
ten Bokkel Huinink, De Swart, Van Toorn, et al., 1998 | Full Text | ten Bokkel 1998
Thatcher, De Campos, Bell, et al., 1999 | Full Text | Thatcher 1999
C. Included Studies, Key Question 3
Study | Publication type(s) | Figure/table designation
Rearden, Charu, Saidman, et al., 2004 | Abstract | Rearden 2004
Straus, Testa, Riggs, et al., 2003 | Abstract | Straus 2003
Crawford, Robert, Perry, et al., 2003 | Abstract | Crawford 2003
D. Included Studies, Key Question 4
Study | Publication type(s) | Figure/table designation
Boogaerts, Coiffier, Kainz, 2003 | Full Text | Boogaerts 2003
Cascinu, Fedeli, Del Ferro, et al., 1994 | Full Text | Cascinu 1994
Case, Bukowski, Carey, et al., 1993 | Full Text | Case 1993
Cazzola, Beguin, Kloczko, et al., 2003 | Full Text | Cazzola 2003
Cazzola, Messinger, Battistel, et al, 1995 | Full Text | Cazzola 1995
Chang, Couture, Young, et al., 2005 | Full Text | Chang 2005
Demetri, Kris, Wade, et al. 1998 | Full Text | Demetri 1998
Fjornes, Wiedemann, Sack, et al., 1998 | Full Text | Fjornes 1998
Garton, Gertz, Witzig, et al., 1995 | Full Text | Garton 1995
Glaspy, Bukowski, Steinberg, et al., 1997 | Full Text | Glaspy 1997
Glimelius, Linne, Hoffman, et al., 1998 | Full Text | Glimelius 1998
Gonzalez, Ordonez, Jua, et al., 1999 | Abstract | Gonzalez 1999
Gonzalez-Baron, Ordonez, Franquesa, et al., 2002 | Full Text | Gonzalez-Baron 2002
Hedenus, Hansen, Taylor, et al. 2002 | Full Text | Hedenus 2002
Henry, Abels, and Larholt | Letter | Henry 1995a
Kasper, Terhaar, Fossa, et al., 1997 | Full Text | Kasper 1997
Katodritou, Speletas, Kapetanos, et al., 2004 | Abstract | Katodritou 2004
Littlewood, Zagari, Pallister, et al., 2003 | Full Text | Littlewood 2003
Ludwig, Fritz, Leitgeb, et al., 1994 | Full Text | Ludwig 1994
Ludwig, Sundal, Pecherstorfer, et al. 1995 | Full Text | Ludwig 1995
McKenzie, Lefebvre, Rosberg, et al., 2004 | Abstract | McKenzie 2004
Miller, Platanias, Mills, et al., 1992 | Full Text | Miller 1992
Musto, Falcone, D’Arena, et al., 1997 | Full Text | Musto 1997
Oberhoff, Neri, Amadori, et al., 1998 | Full Text | Oberhoff 1998
Osterborg, Boogaerts, Cimino, et al., 1996 | Full Text | Osterborg 1996
Witzig, Silberstein, Loprinzi, et al., 2004 | Full Text | Witzig 2004

1 As this report went to press, a full-text version of this trial was published (Waltzman, Croot, Justice, et al., 2005).

1 As this report went to press, a full-text version of this trial was published (Leyland-Jones, Semiglazov, Pawlicki, et al., 2005).

2 As this report went to press, a full-text version of this trial was published (Grote, Yeilding, Castillo, et al., 2005).

3 As this report went to press, a full-text version of this trial was published (Savonije, van Groeningen, van Bochove, et al., 2005)

1 As this report went to press, an additional analysis of quality of life data from this trial was published (Littlewood, Kallich, San Miguel, et al., 2006)

1 As this report went to press, a full-text version of this trial was published (Steensma, Molina, Sloan et al., 2006).

Figure 1

QUOROM Diagram, Key Questions 1–3

Figure 2

QUOROM Diagram, Key Question 4

## Data Extraction

A standardized data extraction form was used (Appendix B). Data extraction from randomized, controlled trials (RCTs) on epoetin or darbepoetin versus control for Key Question 1 was independently performed by two reviewers. In addition, plots and tables were fact-checked by a third reviewer. For all other studies and questions, data were extracted by one reviewer then checked by a second reviewer. Disagreements arising at any stage were resolved by discussion and consensus.

### Handling of discrepant data

For studies published in multiple articles, reports or presentations, we extracted the most recent or most comprehensive data. The data of any study taken from different sources were compared. If data from different sources were discrepant, data were selected for analysis using the following rules:

- For survival, data with longest follow up or highest number of deaths were used for analysis.
- For other outcomes, the most complete data sets were used (i.e., those with the largest sample size), or with consistently defined outcomes across trials.
- If different results were available from the same study (e.g., adjusted and unadjusted) we used the unadjusted data for a base-case analysis, then explored the influence of alternative results in sensitivity analyses.

### Handling of incompletely reported numbers

If a study only reported the overall number of randomized patients but failed to report the number of patients per study arm we assigned 50 percent of the study patients to each of the study arms. In some cases, this reflected a reported 1:1 assignment; in other cases it was assumed as the most common trial design. This occurred in 10 out of 46 studies of epoetin vs. control, no studies of darbepoetin vs. control, and two studies of epoetin vs. darbepoetin.

If percentages but not absolute numbers were reported for any outcome, we calculated absolute numbers based on the reported percentage and sample size per arm.

Some studies reported Kaplan-Meier estimates but not absolute numbers. In these cases, we used the Kaplan-Meier estimates as percentages and recorded the Kaplan-Meier estimates in the relevant evidence tables.

### Allocation of treatment arms for Key Questions 2 and 3

To compare different active study arms, we allocated them to “intervention” and “control” arms as displayed in Table 3.

Table 3

Allocation of Study Arms

Type of Intervention | Arm Assigned to “Intervention” | Arm Assigned to “Control”
Dose escalation | Higher (single) dose | Lower (single) dose
Weight-based/fixed | Fixed dose | Weight-adjusted dose
Frequency of administration | Lower frequency | Higher frequency
Front-loading/titration schedules | Group with changing dose | Group with constant dose
Initiating treatment | Early or “immediate” therapy | Late or “delayed” therapy

## Quality Assessment

### Key Questions 1–3

Study quality characteristics were abstracted. Items abstracted included whether allocation was random, whether treatment allocation was concealed; blinding of participants and clinicians to treatment received; whether loss of patients was similar across study arms; whether analysis was intention-to-treat (ITT); whether participant characteristics were similar at baseline across study arms. These categories were used only for descriptive purposes.

For the subgroup analysis, studies that met all three criteria below were defined as higher-quality trials.

- The study was a randomized controlled trial.
- The study was double-blind.
- At least one of the following conditions was true:
  - less than 10 percent of subjects within each study arm were excluded from the analysis AND the percentage of subjects excluded from analysis in each arm was less than 2:1; OR
  - less than 5 percent of subjects were excluded in each study arm.

One reviewer performed the quality assessment, and a second reviewer checked the results. Discordance was resolved by consensus.

In the original Cochrane Review (including studies for Key Question 1 published before May 2002) all first authors or sponsoring pharmaceutical companies of the included trials were contacted to obtain information on the study design. This was not done with any other studies.

### Key Question 4

Included studies were first classified in a manner analogous to the different phases of clinical trials evaluating interventions (phase I–IV). Possible classification systems for predictive factor studies have been developed (Boracchi and Biganzoli, 2003; Infante-Rivard, Villeneuve, Esnaola, 1989; McGuire, 1991; Pepe, 2003; Schumacher, Hollander, Schwarzer, et al., 2001; Simon and Altman, 1994), but agreement on a standard system is lacking. Therefore, a 3-level classification system was developed for this review and is summarized in Table 4.

Table 4

Classification System for Predictive Factor Studies

Classification | Description | Utility
I | Exploratory study, i.e., no clear statement if possible predictive factors had been defined before the study and/or analysis started, no refutable hypotheses | Hypothesis-generating
II | Study prospectively evaluating/testing possible predictive factors, i.e., a restricted set of factors had been defined before the study started, refutable hypotheses | Hypothesis-testing
III | Study fulfilling the criteria as defined by Simon & Altman 2001 (e.g., prospective study, prespecified hypotheses, study specifically designed to evaluate predictive factors, prospective power calculation) or a randomized controlled trial employing a predictive factor/model in one arm and standard treatment in the other arm | Results may be used to guide clinical practice

In addition to study classification, studies included for Key Question 4 were assessed for specific quality criteria. Although specific assessment tools for predictive factor studies were not found, studies of predictive factors are related to diagnostic and prognostic factor studies. Several authors have formulated minimum criteria for these kinds of studies or statistical methods employed (Boracchi and Biganzoli, 2003; Infante-Rivard, Villeneuve, Esnaola, 1989; McGuire, 1991; Pepe, 2003; Hollander, Schwarzer, et al., 2001; Simon and Altman, 1994; Altman, 2001; Concato, Feinstein, Holford, 1993; Justice, Covinsky, Berlin, 1999; Altman and Royston, 2000; Hollander and Schumacher, 2001; Bossuyt, Reitsma, Bruns, et al., 2003). From these guidelines, a list of 19 quality assessment criteria was developed (Table 5).

Table 5

Quality Criteria Assessed for Studies Included in Key Question 4

Assessed for all studies:
1 | Study classification (see above)
2 | Refutable hypothesis reported (Authors should state minimum requirements of performance measures or other requirements that a predictive factor is satisfying.)
3 | Objective prospectively defined
4 | Inclusion criteria defined for predictive factors study (Yes if inclusion explicitly stated [e.g., all patients were included for which baseline erythropoietin levels and data for response status were available]); Unclear if inclusion criteria were not explicitly stated but reasonable to assume that all patients treated with Epo/evaluated for Hb response were included; No for all other studies)
5 | Sample size calculation and method used if applicable
6 | Number and characteristics of excluded patients reported (Yes/Partially if explicitly stated; Unclear if not explicitly stated but reasonable to assume that all patients treated/evaluated for Hb response were included; No for all other studies)
7 | Missing data handling reported, including losses to follow-up reported
8 | Internal validation of discovered predictive factors and method used if applicable (e.g., splitting sample in training and validation set)
9 | Follow-up of patients at least 4 weeks
10 | Selection process of possible predictive factors explained and adequate (e.g., based on previous studies, biological hypotheses)
11 | Cut-off values for continuous variables explained and adequate (Yes if based on statistical tests for example; Partially if method unsatisfactory [e.g., arbitrarily chosen or medians used]; No for all other studies)
12 | Performance measures reported (e.g., sensitivity, specificity)
13 | Method of statistical analysis (just descriptive no assessment of adequacy)
14 | Prognostic variables fully defined (This is mostly relevant for non-standard laboratory values but may also apply to factors not clearly described)
Assessed if multivariate methods were used:
15 | Statistical package used (just descriptive no assessment of adequacy)
16 | Coding of variables reported (relevant for a continuous variable coded as ranked variable)
17 | Problem with overfitting (A cut-off of 10 events per tested variable was chosen for the label “probable”)
18 | Conformity of linearity for ranked variables reported
19 | Tests of interaction performed

## Data Synthesis

Where data allowed, quantitative methods were used to summarize outcomes of epoetin or darbepoetin treatment. Known clinical heterogeneity, and discovered statistical heterogeneity in some cases warranted exploration of patient subgroups. For a discussion of heterogeneity, impact on meta-analysis, and methods of evaluation, see Appendix F.

### Procedure

Most analyses were performed using Review Manager (RevMan), 4.2.5; the statistical software package R (Ihaka and Gentleman, 1996) was used for additional analyses (e.g., meta-regression) that cannot be done with RevMan 4.2.5.

A fixed-effects model was initially assumed for all meta-analyses. For binary data, the relative risk was used as a measure of treatment effect and we used the Mantel-Haenszel method for pooling in RevMan. The p-value of the homogeneity test and the I^2^ statistic were used to describe the extent of heterogeneity inherent in a meta-analysis. When the value of I^2^ was greater than 25 percent, a random-effects analysis (RevMan) was also conducted. For primary outcome measures potential causes of heterogeneity were explored by performing sensitivity and subgroup analyses. The statistical significance of differences in effect among subgroups was calculated by the inverse variance method. The resulting p-value of subgroup differences is based on the partitioning of heterogeneity: Chi^2^(between groups) = Chi^2^(all) − Chi^2^(within groups).

The estimated overall relative risk and a range of plausible values for the baseline-risk were used to estimate numbers needed to treat (NNT) and numbers needed to harm (NNH) for selected outcomes. Where there was significant statistical heterogeneity across studies, a L’Abbe plot (L’Abbe, Detsky, O’Rourke, 1987) was utilized to assess the constancy of the pooled treatment effect prior to calculating NNT or NNH.

Time-to-event data, i.e., overall survival, were calculated as hazard ratios (HR) based on individual patient data (IPD). If IPD were not available the HR was calculated (i) from published reports, using methods described in Parmar, Torri, and Stewart (1998), or (ii) from binary mortality data. For the latter method, numbers of deaths and sample sizes were imputed in the corresponding section in RevMan and processed with “calculate.”

In addition to subgroup analyses, a fixed-effects meta-regression, i.e., method “1” in Thompson and Sharp (1999), was conducted for the outcome “proportion of participants transfused.” For this analysis, data from RCTs comparing epoetin or darbepoetin versus control were pooled together. All covariates showing a significant effect (p <0.05) in univariate analyses were included in the regression. For model selection, the data set was restricted to studies that provided information on all variables found statistically significant in univariate analyses. Next, a back-wise selection method was used; the covariate with the largest p-value was removed consecutively until the only remaining covariates were significant according to the Akaike Information Criterion (Akaike, 1969). For a more detailed description of the meta-regression see the subsection on “meta-regression” in the section on transfusion for Key Question 1.

Several studies compared different epoetin or darbepoetin dosages, routes, or schedules of administration versus one control group. For each of these studies, we artificially divided and randomly assigned control patients to the corresponding number of separate control groups for entry into RevMan (base model). As this might influence study weighting and thus pooled results, we merged the two (or more) active arms of any such study into one experimental arm and compared it to that study’s full control group. Results of these alternative analytic approaches were compared and described for each outcome.

### Sensitivity Analysis and Subgroup Analysis

#### Subgroup analysis

We extracted data on the following patient, trial, publication, and quality characteristics, which were used for subgroup analyses when appropriate (Figure 3). However, formal subgroup analyses were performed only for Key Question 1. For Key Questions 2, and 3, insufficient numbers of trials addressing the same question were available to permit formal subgroup analysis.

Figure 3

Patient, Study, and Reporting Variables Prespecified for Subgroup Analysis

- Patient baseline characteristics
  - Hemoglobin (Hb) at study entry (Hb ≤10 g/dL versus >10 but <12 g/dL versus ≥12 g/dL vs. unclear). Categorizations were based on the aggregated mean or median Hb at baseline. If hematocrit (Hct) was reported instead of Hb, we documented the Hct and converted it into Hb for categorization. If the baseline Hb or Hct was not reported, the study was categorized as “unclear.”
  - Solid tumors versus hematologic malignancies versus mixed (including both solid and hematological malignancies) vs. unclear. Studies including solid tumors only were categorized as “solid tumors.” Studies including hematological malignancies only were categorized as “hematological malignancies.” Studies including both hematological and solid tumors were categorized as “mixed.” Studies with imprecise information on the population evaluated, e.g., “cancer patients,” were categorized as “unclear.”
  - Age (elderly [aged >65 years] versus non-elderly adults versus children [≤18 years]). Studies were categorized as “adults” if the majority of the population were adults. If a study was restricted to children (≤18 years), the study was categorized as “children.” If the study was restricted to elderly patients (e.g., age >65 years), the study was categorized as “elderly patients” (however, no included studies met the latter criterion).
  - Ethnicity. Not applied, as data were not available.
  - Gender (female versus male patients). Not applied, as data were not available.
- Treatment protocols
  - Type of treatment given. All studies were assigned to the following five different study groups:
    - - Platinum-based chemotherapy: More than 70% of the study population received platinum-based chemotherapy.
    - - Some patients receiving platinum-based chemotherapy: Less than 70% of the patients received platinum-based chemotherapy.
    - - Chemotherapy without platinum: Studies with all patients receiving platinum-free chemotherapy
    - - Radiotherapy/chemoradiotherapy: Patients receiving an anticancer regimen mainly based on radiotherapy. Whether chemotherapy was concomitantly administered was not evaluated in this analysis.
    - - Unclear: Some studies failed to report the anticancer treatment given. If insufficient information on the therapy or the cancer entity was reported, the study was categorized as “unclear.”
  - Iron supplementation (fixed vs. as necessary vs. unclear). Studies using a fixed dose and schedule of iron supplementation for all patients were categorized as “fixed.” Studies supplementing patients with iron as necessary, i.e., if iron stores were measured and found deficient, were categorized as “as necessary.” Studies either not using iron or not reporting on iron usage were categorized as “unclear.”
  - Duration of epoetin or darbepoetin treatment. Duration of treatment with epoetin or darbepoetin was categorized into the following subgroups: 6 to 9 weeks, 12 to 16 weeks, more than 20 weeks and unclear if the reporting was insufficient.^3^ The following assumptions were made. If, for example, a study reported that epoetin was given for three chemotherapy cycles with a cycle length of three weeks, the duration of epoetin treatment was calculated to be 3 × 3 weeks = 9 weeks.
    3 Although discontinuous, these categories include all studies, i.e., no trials had treatment durations of 9–12 or 16–20 weeks.
  - For overall survival additionally: duration of follow up. The duration of followup was split into studies with follow up less than 1 year and studies with duration of followup greater than 1 year. If the duration of follow up was not reported or was not estimable from the available information the study was categorized as “unclear.”
- Reporting and quality
- Study quality (high- versus low-quality studies). Studies were grouped into “higher” and “lower” quality studies. Higher-quality studies were randomized controlled trials; were double-blinded; and either, a) less than 10% of subjects within each study arm were excluded from the analysis AND the percentage of subjects excluded from analysis in each arm was less than 2:1; OR b) less than 5% of subjects were excluded in each study arm.
  - Source of data (full-text publications versus abstract publications versus unreported data versus documents presented at FDA hearing). Data taken from full-text reports were categorized as “full-text publications.” Data taken from abstract publications were categorized as “abstract publications.” Unreported data of published studies that were submitted by the investigators for the first Cochrane Review were categorized as “unpublished data.” Data of either unpublished or published studies that were reported and taken from one of the FDA documents were categorized as “FDA documents.”

#### Sensitivity analysis

With sensitivity analysis we explored the influence of single large studies in a meta-analysis and the use of different data sets, e.g., adjusted vs. unadjusted data.

For Key Question 4 (“Factors Predicting Response”), to allow an assessment of the power of different predictive factors, performance measures, i.e., specificity, sensitivity, predictive values were calculated whenever possible. Specificity and sensitivity depend on the study definitions of a positive test and of Hb outcome. Predictive values depend on prevalence, which for purposes of comparison across studies was assumed to be a number similar to the pooled result for hematologic outcomes in Key Question 1 of this review.

## Peer Review

We requested peer review of the draft of this report from content or methodology experts and professional or patient advocacy organizations. The draft report was reviewed by external reviewers, including members of the technical expert panel, other invited technical experts, and stakeholders (see Appendix E). Revisions were made to the draft report based on reviewers’ comments.