# Introduction

This review compares the efficacy and adverse effects of specific erythropoietic stimulants (i.e., epoetin [alfa or beta], darbepoetin alfa) when used to manage anemia in patients undergoing cancer therapy (i.e., chemotherapy and/or radiation).^1^ This review also addresses questions relevant to optimizing the use of erythropoietic stimulants as a general class: the outcomes of using alternative thresholds to initiate or discontinue treatment and whether there are early predictors of response to treatment.

1 This review overlaps somewhat with a critical appraisal of the literature on outcomes of erythropoietin for anemia related to cancer treatment conducted for the National Institute for Health and Clinical Excellence (NICE) in the U.K. (Wilson, Yao, Rafferty, et al., 2005). The evidence base used in the appraisal was an update of the earlier Cochrane review (Bohlius, Langensiepen, Schwarzer, et al., 2005), and included a cost-effectiveness component (Wilson, Yao, Rafferty, et al., 2005). Note that pooled analyses for the appraisal included trials in patients with myelodysplastic syndrome, as well as trials of patients with cancer who were not receiving cancer therapy. These types of trials were excluded from the present analysis, which is limited to patients undergoing cancer treatment. In addition, the search date cutoff for the NICE appraisal was September 2004, whereas the search date cutoff for this analysis was March 2005.

Erythropoietin is an endogenous hormone, produced primarily in the kidney, which participates in regulating red blood cell production (erythropoiesis). Two forms of recombinant human erythropoietin—epoetin alfa and epoetin beta (the latter not commercially available in the United States)—have been extensively studied and used clinically for more than a decade to treat various anemias; they have similar clinical efficacy (Halstenson, Macres, Katz, et al., 1991; Storring, Tiplady, Gaines Das, et al., 1998). In a recent review of safety concerns associated with recombinant human erythropoietins, a U.S. Food and Drug Administration (FDA) briefing document noted that “…the biochemical differences between various erythropoietin products are not associated with marked differences in the pharmacodynamic properties of the different products when used at recommended doses, thus effects observed with these non-US-licensed products may also be associated with the U.S. licensed product.”

A novel long-acting recombinant erythropoietin--“novel erythropoiesis-stimulating protein” (NESP) or darbepoetin alfa--was developed more recently. Darbepoetin alfa, which produces a similar physiologic response when compared to recombinant human erythropoietin (Joy, 2002), has been tested in prospective clinical trials (Glaspy, Jadeja, Justice, et al., 2003; Hedenus, Hansen, Taylor, et al., 2003; Vansteenkiste, Pirker, Massuti, et al., 2002), and is commercially available in the United States. The epoetins have the same amino acid sequence as endogenous erythropoietin, while darbepoetin alfa has two additional oligosaccharide chains; however, the epoetins and darbepoetin all have pharmacologic actions identical to those of the endogenous hormone (McEvoy, 2005). They increase the number of red blood cells, and thus the blood concentration of hemoglobin, when given to individuals with functioning erythropoiesis.

Anemia, defined as a deficiency in the concentration of hemoglobin-containing red blood cells, is a widely prevalent complication among cancer patients. The National Cancer Institute and others have agreed to use the following classification for anemia based on hemoglobin (Hb) values (National Cancer Institute Cancer Therapy Evaluation Program, 1999):

- Grade 0, within normal limits, hemoglobin values are 12 to 16 g/dL for women and 14 to 18 g/dL for men
- Grade 1, mild (Hb 10.0 g/dL to less than lower limit of normal)
- Grade 2, moderate (Hb 8 to <10.0 g/dL)
- Grade 3, serious/severe (Hb 6.5 to <8.0 g/dL)
- Grade 4, life threatening (Hb <6.5 g/dL).

Historically, red blood cell transfusion has been the conventional treatment of choice for severe anemia in cancer patients. The literature reports a critical degree of anemia as Hb less than 8 g/dL, while mild-to-moderate anemia (Hb level 8–10 g/dL) usually has been left untreated (Koeller, 1998; Blajchman and Hebert, 2001). Although blood transfusion is the fastest method to alleviate symptoms, short- and long-term risks exist (Engert, 2000). Potential complications associated with blood transfusion include transmitting infectious diseases, transfusion reactions, alloimmunization, and over-transfusion (Goodnough, 2005). However, the risks are quite small. Adverse events due to error in transfusion are estimated to be 1 in 14,000 units in the United States. The risk of transfusion-related acute lung injury is about 1 in 5,000 transfusions. The risk of severe infections is estimated to be to 1 in 220,000 per unit of blood transfused for hepatitis B, 1 in 1,600,000 per unit for hepatitis C, and 1 in 1,800,000 for human immunodeficiency virus (HIV) (Busch, Kleinman, and Nemo, 2003). Emerging bloodborne infections such as the West Nile virus outbreak in 2002 are of concern; screening for West Nile virus was implemented in the U.S. in July 2003 (Pealer, Marfin, Petersen, 2003); that summer, 4,137 cases of West Nile virus infection were reported to the Centers for Disease Control and Prevention (CDC), only 2 of which were known to be transmitted by blood (Goodnough, 2005).

Among cancer patients, the prevalence of anemia varies according to the type of neoplasia (Knight, Wade, and Balducci, 2004). Defining anemia as an Hb range of 9–11 g/dL, one systematic review reported that the prevalence of anemia in solid tumor types (e.g., breast, brain, prostate) varies from 13–78 percent (Knight, Wade, and Balducci, 2004), depending on tumor type. Among patients with solid tumors, the highest frequency of anemia requiring transfusion has been reported for lung, gynecologic (e.g., ovarian), and genitourinary tumors, in part attributable to the use of platinum-based therapies (Groopman and Itri, 1999). Patients with hematologic malignancies frequently experience anemia. At the time of diagnosis, 30 to 40 percent of patients with Hodgkin’s or non-Hodgkin’s lymphoma and up to 70 percent of patients with multiple myeloma are anemic; the figures are even higher in patients with myelodysplastic syndromes (Garton, Gertz, Witzig, et al., 1995). The type and amount of chemotherapy also influences the extent of anemia. For patients with lymphoma, anemia is present in around 40 percent of patients at diagnosis; however, after 3 to 4 cycles of chemotherapy, up to 70 percent of patients will be anemic (Samol and Littlewood, 2003). Patients with cancer-related anemia not undergoing cancer treatment are a different patient group, with distinct causes of their anemia; they should be analyzed separately from those undergoing treatment for their malignancy, and thus are outside the scope of this report.

## Scope and Key Questions

Several evidence-based guidelines have addressed whether recombinant erythropoietin’s ability to increase hemoglobin levels reduces the risk for blood transfusions in patients with malignant disease. The most comprehensive guideline is from the American Society of Clinical Oncology (ASCO) and the American Society of Hematology (ASH) (Rizzo, Lichtin, Woolf, et al., 2002). The basis of this guideline is a systematic review commissioned by the Agency for Healthcare Research and Quality (AHRQ) and conducted by the Blue Cross and Blue Shield Association’s Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC) (Aronson, Seidenfeld, Piper, et al., 2001; Seidenfeld, Piper, Flamm, et al., 2001). That AHRQ report summarizes and analyzes evidence published through 1999 on the use of epoetin to manage anemia in oncology patients.

In collaboration with authors of the AHRQ report, the Cochrane Haematological Malignancies Group conducted a Cochrane Review on the effects of recombinant erythropoietin in patients with malignant disease (Bohlius, Langensiepen, Schwarzer, et al., 2004). The Cochrane Review included 3,287 patients from 27 studies, published between 1993 and May 2002. Both reviews found that treatment with epoetin statistically significantly reduced the need for red blood cell transfusions. Epoetin-treated patients were more likely to have a hematologic response and less likely to undergo transfusion than untreated patients. The evidence on quality-of-life changes from treatment with epoetin was inconclusive.

A post-hoc analysis amended to the study protocol of Littlewood, Bajetta, Nortier, et al. (2001) generated interest in the effects of epoetin on survival. Some investigators hypothesized that epoetin might improve survival, either by improving tumor oxygenation and thus enhancing cytocidal effects of chemotherapy and/or radiation therapy (Glaspy, 2002), or by some other consequence of reversing anemia shown to predict poor prognosis in patients with malignancy (Caro, Salas, Ward, et al., 2001; Bokemeyer, Oechsle, Hartmann, et al., 2002). Others cautioned that these hypotheses must be tested in randomized controlled trials (Watine and Bouarioua, 2002; Steensma and Loprinzi, 2005), especially given evidence that some malignant cells carry erythropoietin receptors that are able to promote tumor cell proliferation when stimulated (e.g., Westenfelder and Baranowski, 2000; Acs, Zhang, Rebbeck, et al., 2002). Data collected and analyzed for the Cochrane Review also suggested that overall survival of anemic oncology patients receiving epoetin may be greater than among patients receiving only red blood cell transfusion as needed (Bohlius, Langensiepen, Schwarzer, et al., 2004). However, the evidence was only used to generate hypotheses, as the study by Littlewood and co-workers (2001) and other studies included in the Cochrane analysis were not designed to test the effect of epoetin on survival.

To test the effect of erythropoietic stimulants on survival, a trial should have a homogeneous primary tumor type and treatment regimen. Duration of follow-up and number of participants should be sufficient to detect a clinically meaningful difference in overall survival or surrogate outcomes such as tumor response or progression-free survival (Food and Drug Administration Oncologic Drugs Advisory Committee, 2004). Survival data available for the 2004 Cochrane Review were largely from trials designed to test effects of epoetin on hemoglobin response and risk of transfusion. Almost all trials included mixed populations with respect to tumor types and treatment regimens. Data on survival were collected subsequent to these trials’ prespecified endpoints, and so do not represent results of the original randomized controlled trial design.

Subsequently, several studies designed to assess overall or progression-free survival have been conducted and published. The evidence thus generated needs to be assessed: two studies demonstrated significantly worse overall survival for patients receiving epoetin (Henke, Laszig, Ruebe, et al., 2003; Leyland-Jones, 2003; Leyland-Jones, Semiglazov, Pawlicki, et al., 2005). Further, other important clinical questions have not yet been resolved, including optimal hemoglobin thresholds to initiate and stop treatment with erythropoietic stimulants, and which patients are most likely to benefit from such treatment. Because both epoetin and darbepoetin alfa are expensive, a systematic review comparing their costs and effectiveness as treatment alternatives also would be useful. In addition, the evidence on darbepoetin alfa has not yet been systematically reviewed.

For further background details on the pathophysiology of cancer-related anemia and a more detailed description of epoetin, readers are referred to the AHRQ evidence report, “Uses of Erythropoietin for Anemia in Oncology” (Aronson, Seidenfeld, Piper, et al., 2001).

Although several types of erythropoiesis-stimulating products currently are approved for use or undergoing active research in other countries --(e.g., other epoetin alfa products [Eprex®, Janssen-Cilag]; epoetin beta [NeoRecormon® and Recormon®, Roche; Epogin®, Chugai]; epoetin omega [Epomax®, Elanex]; epoetin delta [Dynepo®, TKT]; synthetic peptide-based erythropoiesis-stimulating agent [Hematide™, Affymax, Inc., currently in Phase II trials]; continuous erythropoiesis-receptor activator [CERA]) (Deicher and Horl, 2004)-- there are three products commercially available in the U.S. These are Epogen® and Procrit® (both epoetin alfa), and Aranesp® (darbepoetin alfa). Table 1 describes the FDA-labeled indications and dosages for these products. Note, however, that this review includes evidence from trials of epoetin beta (not licensed in the United States) as well as from trials of epoetin alfa and darbepoetin alfa.

Table 1

Erythropoietic Stimulants Available Commercially in the United States

Drug | Trade name(s) | Half-life | Labeled indications | Initial dose recommendations for anemia of cancer chemotherapy | Recommended dosage adjustments for anemia of cancer chemotherapy
epoetin alfa^*^ | Epogen® (Amgen, Inc., 2005) and Procrit® (Ortho-Biotech, 2005)^*^ | 40 hours with a range of 16 to 67 hours | anemia of chronic renal failure anemia in zidovudine-treated HIV-infected patients anemia in cancer patients receiving chemotherapy reduction of allogeneic blood transfusion in surgery patients | 150 units/kg SC 3 times weekly or 40,000 units SC weekly (adults) | Reduce dose by 25% when hemoglobin approaches 12 g/dL or hemoglobin increases >1 g/dL in any 2-week period Withhold dose if the hemoglobin exceeds 13 g/dL until the hemoglobin falls to 12 g/dL, then restart dose at 25% below the previous dose Increase dose to 300 units 3 times weekly if response is not satisfactory (i.e., no reduction in transfusion requirements or rise in hemoglobin) after 8 weeks For patients receiving once-weekly therapy, if after 4 weeks of therapy the hemoglobin has not increased by >1 g/dL, in the absence of RBC transfusion, the epoetin alfa dose should be increased to 60,000 units weekly Recommended target hemoglobin: 10 g/dL to 12 g/dL
darbepoetin alfa | Aranesp® (Amgen, Inc., 2006) | observed half-life after SC administration in chronic renal failure patients: 49 hours (range: 27 to 89 hours) after IV administration, there is a distribution half-life of ~1.4 hours and a mean terminal half-life of 21 hours after IV administration, the terminal half-life of darbepoetin alfa is approximately 3-fold longer than epoetin alfa | anemia of chronic renal failure anemia in cancer patients receiving chemotherapy | 2.25 mcg/kg SC weekly or 500 mcg SC every 3 weeks | If the hemoglobin exceeds 13 g/dL, doses should be temporarily withheld until the hemoglobin falls to 12 g/dL. At this point, therapy should be reinitiated at a dose approximately 25% below the previous dose If hemoglobin increases by more than 1.0 g/dL in a 2-week period or if the hemoglobin exceeds 12 g/dL, the dose should be reduced by approximately 25% If there is less than a 1.0 g/dL increase in hemoglobin after 6 weeks of therapy, the dose should be increased up to 4.5 mcg/kg Target hemoglobin should not exceed 12 g/dL in men or women

Abbreviations: IV, intravenously; SC, subcutaneously

* Epoetin alfa preparations are derived from the same source and are identical in composition (McEvoy, 2005)

The National Comprehensive Cancer Network (NCCN) in its oncology practice guideline on cancer- and treatment-related anemia provides dosing schedules for treatment according to the FDA-approved package inserts (Table 1), as well as “commonly used” regimens for darbepoetin. The first regimen recommends darbepoetin at a dosage of 3 mcg/kg subcutaneously every 2 weeks; in patients without response, the guideline recommends increasing dosage to 5 mcg/kg every 2 weeks. The second common regimen is a fixed-dose regimen of 200 mcg every 2 weeks, with titration to up to 300 mcg every 2 weeks in patients with no or inadequate response (NCCN, 2006).

In 2004, the FDA revised the labeling of erythropoietic stimulants licensed in the Untied States. Studies presented at a May 4, 2004, meeting of the Food and Drug Administration (FDA) Center for Drug Evaluation and Research (CDER) Oncologic Drugs Advisory Committee (ODAC) (Food and Drug Administration Oncologic Drugs Advisory Committee, 2004) showed the potential for increased thromboembolic complications, and possibly worse survival, in patients whose target hemoglobin was higher than 12 g/dL. A subsequent healthcare provider communication highlighted the results of the ODAC meeting and revised the product labeling to include information on thromboembolic complications in the “Warnings” and “Precautions” sections. The revised labeling for all three commercially available products recommends that the target hemoglobin in patients with cancer not exceed 12 g/dL in both men and women.

The following four key questions are addressed in the current review.

1. What are the comparative efficacy and safety of epoetin (alfa or beta) and darbepoetin? Outcomes of interest include hematologic responses, transfusions, tumor response to therapy, overall survival, quality of life, thromboembolic complications, and other adverse events.
2. How do alternative dosing strategies affect the comparative efficacy and safety of epoetin and darbepoetin?
3. How do alternative thresholds for initiating treatment or alternative criteria for discontinuing therapy or duration of therapy affect the efficacy and safety of erythropoietic stimulants?
4. Are any patient characteristics at baseline or early hematologic changes useful to select patients or predict responses to treatment with erythropoietic stimulants? The outcome of interest is limited to hematologic response.

Key Questions 1–3 address questions of therapeutic outcome, for which we required evidence from randomized controlled trials. Key Question 4 addresses predicting responses to erythropoietic stimulants, to which we applied an approach used to evaluate diagnostic tests.

Two reviewers screened all article titles and abstracts identified by the search strategy (see Search Strategy; Appendix A). If eligibility could not be assessed satisfactorily from the title and abstract, we retrieved the article in full text.

### Types of participants

- All trials included patients diagnosed with malignant disease and undergoing treatment with chemotherapy or radiotherapy. Other reasons for anemia, such as hemolysis, iron deficiency, and occult bleeding, should have been ruled out.
- Trials were excluded if (a) patients were not undergoing treatment for cancer, or (b) treatment was high-dose myeloablative therapy with stem-cell transplant, or (c) patients had myelodysplastic syndrome.
- Also excluded were trials using epoetin for short-term preoperative treatment to correct anemia or to support collection of autologous blood prior to cancer surgery.

### Types of interventions

- Trials were included for Key Question 1 if they directly compared epoetin and darbepoetin in patients undergoing cancer treatment. Also included were studies comparing epoetin or darbepoetin versus observation (alone or with placebo) until red blood cell transfusions were necessary.
- If epoetin (alfa or beta) was not administered subcutaneously or intravenously at doses of at least 300 U/kg body weight per week for at least four weeks, trials or study arms were excluded for Key Question 1 (e.g., arms a and b from Cazzola, Messinger, Battistel, et al., 1995). Data were abstracted on all darbepoetin doses for which outcomes were reported separately by study arm/dose level.
- For Key Questions 2 and 3, trials were included if they directly compared two different methods for using epoetin or darbepoetin to manage anemia in patients undergoing cancer treatment:
  - Alternative dosages or treatment schedules are relevant interventions for Key Question 2.
  - Alternative thresholds to initiate therapy; criteria to discontinue therapy; or durations of therapy are relevant interventions for Key Question 3.
- No minimal epoetin (alfa or beta) or darbepoetin dose was required for trials comparing alternative dosing schemes or treatment schedules (Key Question 2).
- Interventions relevant to Key Question 4 were laboratory measures for hematologic parameters at baseline or in the first 4 weeks of treatment that might be used to predict responses to epoetin or darbepoetin.
- Adjusting epoetin or darbepoetin dose based on hematologic response was allowed for all Key Questions.
- Concomitant supportive treatments, e.g., granulocyte colony-stimulating factors (G-CSF) or iron supplementation, and cancer therapies had to be given equally in all study arms.

### Types of outcome measures

- Hematologic response. Proportion of patients with an increase in hemoglobin level of 2 g/dL or more by end of study or an increase in hematocrit of 6 points or more by end of study, independent of blood transfusions. Of studies that reported hematologic responses, 2 g/dL or more was the most consistently used definition. It was also a robust response, not easily achieved in those receiving placebo or no treatment. Data from studies using other definitions were abstracted and summarized in the report, but were not pooled for meta-analysis with data conforming to this definition. Note that study lengths were 6–16 weeks in duration. Thus, this aggregate outcome measure does not conflict with the FDA labeling, which states that dosage should be reduced if Hb increases more than 1 g/dL in any 2-week period, as in any study, individual patients may experience Hb increases that require dose reduction or temporary discontinuation.
- Transfusion. Proportion of patients receiving red blood cell transfusions.
- Quality of life (QoL). Preferred measures were validated instruments, such as SF-36; EORTC Quality of life Questionnaire (QLQ-C30); Functional Assessment of Cancer Therapy (FACT, including G-General; F-Fatigue; An-Anemia). Visual analog scales (VAS) (including versions named linear analog self-assessment [LASA] and cancer linear analog scale [CLAS]), although initially excluded, were also abstracted. Sample size and amount of missing data for QoL measures were extracted.
- Tumor response. Tumor response was only evaluated from studies prospectively designed to assess tumor response. These were trials with a homogeneous patient population undergoing a predefined cancer therapy.
- Overall survival. For some studies that did not report survival, unpublished survival data were obtained from investigators by the Cochrane Hematologic Malignancies Review Group, who made the data available for this review.
- Adverse effects. Included thromboembolic events, hypertension, thrombocytopenia and/or hemorrhage, rash and similar symptoms, and seizures. Additionally, we abstracted data on development of antibodies to epoetin or darbepoetin, since such antibodies might also bind to and neutralize endogenous erythropoietin, thus impairing normal erythropoiesis.

Key Questions 1–3 assessed all outcomes cited here except for tumor response, which was assessed in Key Question 1 only. For Key Question 4, hematologic response was the only outcome assessed.

### Types of studies

- All studies included for Key Questions 1–3 were randomized controlled trials, with at least 10 participants per study arm, published in any language. Ongoing studies and interim analyses were excluded.
- For Key Question 1, trials compared (a) epoetin to darbepoetin, or (b) epoetin to no epoetin, or (c) darbepoetin to no darbepoetin.
- For Key Question 2, trials directly compared at least two alternative dosing schemes or treatment schedules.
- For Key Question 3, included studies directly compared (a) at least two different thresholds to initiate treatment, or (b) at least two alternative criteria to discontinue treatment, or (c) at least two durations of treatment.
- For Key Question 4, non-randomized controlled clinical trials and prospective cohort studies were included in addition to randomized controlled clinical trials.

Studies included in Key Question 4 were designed to prospectively test predictive factors for hematologic response in patients responding and not responding to treatment with erythropoietic stimulants. Predictive factors were patient characteristics at baseline or early hematologic changes in the first four weeks after initiating treatment.