# Community Studies

## Community Studies of Epoetin and Darbepoetin

Four community studies of epoetin enrolled 8,501 patients from over 1,700 community oncology practices, of whom, 7,725 were evaluable at baseline, which was one month prior to epoetin treatment (Glaspy, Bukowski, Steinberg, et al., 1997; Demitri, Kris, Wade, et al., 1998; Gabrilove, Cleeland, Livingston, et al., 2001; Shasha, George, and Harrison, 2003). Patients in community studies are similar to those in randomized controlled trials as selection criteria for enrollment were largely the same as those used in most RCTs: undergoing chemotherapy and/or radiotherapy, Hb ≤11, life expectancy of at least six months. Study duration, 16 weeks, was the same as in the majority of RCTs. All community studies reported pre-post comparisons; none had a control group.

The study objective of Glaspy, Bukowski, Steinberg, et al. (1997) was to evaluate effectiveness of epoetin in a community oncology practice setting. Demetri, Kris, Wade, et al. (1998) correlated changes in quality of life measures with hemoglobin response and assessed these independent of tumor response. Gabrilove, Cleeland, Livingston, et al. (2001) and Shasha, George, and Harrison (2003) evaluated once-weekly epoetin dosing, used as an alternative to the standard three-times-weekly dosing,

These studies report that benefits of epoetin can be achieved in community oncology settings. Frequency of transfusion decreased from baseline and quality of life improved, as measured by FACT-An or linear analog scale assessment (LASA). Magnitude of effect is difficult to judge in these uncontrolled studies or to compare with that observed in RCTs. Transfusion results were reported in community studies as persons transfused per month and cannot be directly compared to the result reported in RCTs, percent of all patients transfused over the study duration.

Loss to follow-up was very high in the community studies. Pooling the four studies, the number of evaluable patients at study endpoint (four months) was 58 percent of those enrolled and 64 percent of those evaluable at baseline. In general, the most common reasons reported for loss to follow-up were death, disease progression, and failure to respond to epoetin. In contrast, few RCTs had more than 10 percent of patients not evaluable for transfusion, though loss to follow up for quality of life measures was 19 percent across studies and as high as 59 percent in one trial.

The community studies do not add to knowledge of adverse effects of epoetin. The studies generally reported adverse effects to be those expected with chemotherapy.

One community study of darbepoetin (Vadhan-Raj, Mirtsching, Charu, et al., 2003) enrolled 1,173 patients from 194 oncology practices, with 69% of patients completing the study. Patient population and study duration were similar to those in the community studies of epoetin and RCTs of darbepoetin. Study objective was to assess ability darbepoetin to correct anemia of chemotherapy and to examine the relationship between improvements in hemoglobin and changes in fatigue and functional capacity. Improvements in fatigue and function were reported to parallel rise in hemoglobin. Each treatment-related adverse event (e.g., deep vein thrombosis, myalgia, edema) reportedly occurred in fewer than 1% of subjects, except for injection site pain in 2%.