# Clinical Trials

## Clinical Trials of Erythropoietic Stimulants in Cancer (as per www.clinicaltrials.gov, searched March 2006)

Epoetin versus Darbepoetin Alfa Trials

Trial ID/Study Design | Study Title/Objective
NCT00264108 Prospective Observational | “…to evaluate the cost-effectiveness of epoetin alfa compared with darbepoetin alfa in the treatment of anemia in adults receiving chemotherapy for cancer.”

Epoetin Trials

Trial ID/Study Design | Study Title/Objective
NCT00046969 Randomized Phase IV epoetin beta | “…to determine the effectiveness of epoetin beta in treating anemia in patients who are receiving cisplatin and radiation therapy for stage IIB, stage III, or stage IVA cervical cancer.”
NCT00060398 Randomized Phase III epoetin alfa | “…[to study] epoetin alfa and dexamethasone to see how well they work compared to epoetin alfa alone in treating anemia-related fatigue in patients with prostate cancer that is refractory to treatment with hormone therapy.”
NCT00049348^*^ Randomized Phase II epoetin alfa | Study of more- versus less-intensive regimens for pancreatic cancer epoetin alfa is administered as support for the more-intensive regimen
NCT00267007^**^ Randomized Phase II epoetin alfa | “…to evaluate the neuroprotective effect of PROCRIT® (epoetin alfa, a glycoprotein that stimulates red blood cell production) versus placebo in patients with advanced ovarian cancer who develop chemotherapy-induced peripheral neuropathy due to paclitaxel and carboplatin treatment.”
NCT00258440 “Partially Randomized” Pilot Study epoetin alfa | “Determine the efficacy, in terms of maintenance of target hemoglobin andhematocrit levels, of interval dosing with epoetin alfa in treating patients with anemia undergoing chemotherapy for nonmyeloid cancer”
NCT00255749 Randomized Phase II epoetin alfa | Study in patients undergoing treatment for nonmyeloid cancer immediate administration of epoetin alfa versus when patient’s Hb falls to 10.5 or below

* No longer recruiting patients

** Not yet recruiting patients

Darbepoetin Alfa Trials

Trial ID/Study Design | Study Title/Objective
NCT00119613 Randomized Phase III | “…to evaluate whether increasing or maintaining hemoglobin concentrations with darbepoetin alfa, when administered with platinum-containing chemotherapy in subjects with previously untreated extensive-stage small cell lung cancer (SCLC), increases survival.
NCT00058422 Phase II | “Study of Rituximab, Cyclophosphamide, Doxorubicin, Vincristine, and Prednisone Combined With Yttrium Y 90 Ibritumomab Tiuxetan in Patients Age 60 and Over With Previously Untreated Diffuse Large B-Cell Lymphoma”--- Two of the study objectives are to determine the effect of darbepoetin alfa on 1) transfusion and hematologic response and 2) quality of life.
NCT00144755 Randomized Phase III | “ [to evaluate] the efficacy and safety of R-CHOP given every 14 days compared to R-CHOP given every 21 days and in association or not with darbepoetin alfa in order to maintain hemoglobin above 13 g/dl, compared to classical symptomatic treatment of anemia in patients aged from 66 to 80 years with diffuse large B-cell lymphoma.”
NCT00239239 Phase II | “… to characterize the pharmacokinetics/pharmacodynamics (PK/PD) of darbepoetin alfa administered at a subcutaneous (SC) dose of 0.45 mcg/kg three times weekly (TIW) in anemic patients with non-myeloid malignancies receiving multicycle chemotherapy.”
NCT00098696 Randomized Phase III | Primary objective “…to compare the efficacy of darbepoetin alfa vs placebo in reducing the occurrence of red blood cell transfusions for treatment of anemia in patients with non-myeloid cancer who are not receiving chemotherapy.
NCT00091858 Randomized Phase III | “… to evaluate the efficacy of darbepoetin alfa versus placebo in reducing the occurrences of red blood cell transfusions in subjects with anemia of cancer who are not receiving chemotherapy.”
NCT00153868 Web-based Pilot Study | “…to evaluate the association between the treatment of anemia with darbepoetin alfa (aranesp) and the clinical benefits in symptom palliation, improved functional status and quality of life in patients with cancer. The feasibility of web-based assessments and data capture will be evaluated.”
NCT00135317 Randomized Phase III | “…to assess if the addition of intravenous (IV) iron to 500 mcg every 3 week (Q3W) darbepoetin alfa treatment enhances response as compared to the standard practice (oral iron or no iron administration).”
NCT00261313 Phase II | “An Open Label Phase 2 Study of Doxorubicin and Cyclophosphamide Followed by Paclitaxel Delivered Every 14 Days With Pegfilgrastim and Darbepoetin Alfa Support for the Adjuvant Treatment of Women With Breast Cancer”
NCT00204633 Randomized Phase II | “…to determine the frequency of RBC transfusion in patients with metastatic “poor prognosis” germ cell tumor during high-dose chemotherapy (HD-VIP, level 6) with or without Darbepoetin alfa.”
NCT00077311 Randomized Phase II | “Phase II Randomized Study of Docetaxel and Cisplatin With or Without Dimesna in Patients With Stage IIIB or IV Non-Small Cell Lung Cancer” In both arms, darbepoetin alfa is administered SC on day 1 of each course for hemoglobin 11 g/dL.
NCT00281892 Phase III | “…[to study] fludarabine to see how well it works when given together with or without darbepoetin alfa in treating older patients with chronic lymphocytic leukemia.”
NCT00095277 Randomized Phase II | “…to demonstrate benefit with respect to hematopoietic response in subjects with anemia of cancer randomized to Darbepoetin Alfa once every 4 weeks.”
NCT00058422 Phase II | “…to study the effectiveness of combining rituximab and combination chemotherapy with yttrium Y 90 ibritumomab tiuxetan in treating older patients who have B-cell lymphoma that has not been previously treated.” darbepoetin alfa given as support therapy
NCT00144131 Randomized Phase II | “… [to] compare the efficacy (non-inferiority) of darbepoetin alfa extended dose schedule administration (EDS) versus darbepoetin alfa administered once per week (QW) in the treatment of anemia in subjects with non-myeloid malignancies receiving multi-cycle chemotherapy.”