# Technical Expert Panel (TEP) and Peer Reviewers

## Technical Expert Panel (TEP)

- Andreas Engert, M.D.
- Professor for Internal Medicine
- Hematology & Oncology
- University Hospital of Cologne
- Department of Internal Medicine
- Cologne

- Michael S. Gordon, M.D.
- Arizona Cancer Center - Greater Phoenix Area
- New Therapeutics Program
- Scottsdale, AZ

- Mark Helfand, M.D., M.P.H.
- Professor of Medicine
- Division of General Internal Medicine
- Portland Veterans Affairs Medical Center and
- Director, Evidence-Based Practice Center
- Oregon Health Sciences University
- Portland, OR

- Alan Lichtin, M.D.
- Department of Hematology & Medical Oncology
- The Cleveland Clinic Foundation
- Cleveland, OH

- J. Douglas Rizzo, M.D.
- Associate Professor of Medicine
- Medical College of Wisconsin
- Milwaukee, WI

## Peer Reviewers

- James O. Armitage, M.D.
- Professor, Internal Medicine
- Section of Hematology & Oncology
- University of Nebraska Medical Center
- Omaha, NE

- David Atkins, M.D., M.P.H.
- Coordinator for Clinical Preventive Services
- Agency for Healthcare Research and Quality
- Rockville, MD

- Ann M. Berger, Ph.D., R.N., A.O.C.N.
- Associate Professor and Advanced Practice Nurse
- University of Nebraska
- College of Nursing
- Oncology Nursing Society Nominee

- David Cella, Ph.D.
- Director, Center on Outcomes, Research, and Education (CORE)
- Evanston Northwestern Healthcare
- Evanston, IL

- Mona Chitre, Pharm.D.
- Director of Clinical Services
- FLRx Pharmacy Management
- Rochester, NY

- Janet E. Dancey, M.D., F.R.C.P.C.
- Senior Investigator
- Investigational Drug Branch
- Cancer Therapy Evaluation Program
- National Cancer Institute
- Rockville, MD

- Anne-Marie Duliege, M.D., M.S.
- Vice President, Clinical, Medical, and Regulatory Affairs
- Affymax, Inc.
- 4001 Miranda Avenue
- Palo Alto, CA

- Alan M. Garber, M.D., Ph.D.
- Staff Physician, U.S. Department of Veterans Affairs
- Henry J. Kaiser, Jr., Professor
- Professor of Medicine, Economics, and Health Research and Policy
- Stanford University
- Stanford, CA

- Deneen Hesser, R.N., B.S., O.C.N.
- Director of Patient Services
- American Brain Tumor Association
- Des Plaines, IL

- American Brain Tumor Association Representative
- James Khatcheressian, M.D.
- Virginia Commonwealth University-Medical College of Virginia
- Division of Hematology-Oncology
- Richmond, VA

- Barnett Kramer, M.D., M.P.H.
- Director
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, MD

- Kathleen N. Lohr, Ph.D.
- Director, Health Services and Policy Research
- RTI International
- Research Triangle Park, NC

- R. Scott McKenzie, M.D.
- Regional Director
- Ortho Biotech Clinical Affairs LLC
- Bridgewater, NJ

- Parthiv J. Mahadevia, M.D., M.P.H.
- Associate Director, Payment and Coverage Group
- Amgen, Inc.
- Thousand Oaks, CA

- Karin Noss, M.P.A., M.S.A.
- President
- Virginia Breast Cancer Foundation
- Richmond, VA
- National Breast Cancer Coalition Nominee

- Joshua J. Ofman, M.D., M.H.S.
- Vice President, Global Coverage and Reimbursement Policy
- Amgen, Inc.
- Washington, D.C.

- Jane Perlmutter, Ph.D., M.B.A.
- Board and Executive Committee Member and
- Chair, Technology Committee
- Y-ME National Breast Cancer Organization
- Naperville, IL
- Y-ME National Breast Cancer Organization Nominee

- Thomas J. Smith, M.D.
- Chair
- Division of Hematology/Oncology
- Virginia Commonwealth University-Medical College of Virginia
- Richmond, VA
- American Cancer Society Nominee

- Ralph Vogler, M.D.
- Scientific Program Director, Research Department
- American Cancer Society, Inc.
- Atlanta, GA
- American Cancer Society Representative